# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Alan Baer, M.D.
  Good Samaritan Hospital
  Director, Johns Hopkins University Clinical Practice
  Johns Hopkins University School of Medicine
  Baltimore, MD
- Jasvinder Singh, M.D., M.P.H.
  Professor of Medicine and Staff Rheumatologist
  University of Alabama at Birmingham and VA Medical Center
  Birmingham, AL
- William Taylor, M.B.Ch.B, Ph.D.
  Department of Medicine
  University of Otago
  Wellington, New Zealand
- Penny Whiting, Ph.D.
  Senior Research Fellow
  School of Social and Community Medicine
  University of Bristol
  Bristol, United Kingdom