# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Hyon K. Choi, M.D., Ph.D.^*^
  * Technical Expert Panel members who were also Peer Reviewers
  Professor of Medicine, Harvard Medical School
  Director, Gout and Crystal Arthropathy Center
  Director, Clinical Epidemiology and Health Outcomes
  Division of Rheumatology, Allergy, and Immunology
  Department of Medicine
  Massachusetts General Hospital
  Boston, MA
- Nicola Dalbeth, M.D.^*^
  Bone and Joint Research Group
  Department of Medicine
  Faculty of Medical and Health Sciences
  University of Auckland
  Aucland, New Zealand
- Russell Harris, M.D., M.P.H.
  Sheps Center for Health Services Research
  University of North Carolina
  Professor, Division of General Medicine
  University of North Carolina–Chapel Hill
  Chapel Hill, NC
- Gerald D. Levy, M.D.^*^
  Rheumatologist
  Kaiser Permanente
  Bellflower, CA
- Shari Ling, M.D.
  Deputy Chief Medical Officer
  Office of Clinical Standards and Quality
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Ted Mikuls, M.D.
  Associate Professor, Department of Internal Medicine
  Division of Rheumatology
  University of Nebraska Medical Center
  Omaha, NE
- Esther Myers, Ph.D, R.D.
  Director, Scientific Affairs and Research
  Academy of Nutrition and Dietetics
  Trenton, IL
- Tuhina Neogi, M.D.^*^
  Associate Professor of Medicine, Epidemiology
  Boston University School of Medicine
  Boston, MA
- Savvas Nicolaou, M.D.^*^
  Vice-Chair, Undergraduate Education and Continuing Professional Development
  University of British Columbia and Vancouver General Hospital
  Vancouver, British Columbia, Canada
- H. Ralph Schumacher, Jr., M.D.^*^
  Professor of Medicine
  University of Pennsylvania
  Philadelphia, PA
- Ralf G. Thiele, M.D.^*^
  Associate Professor
  Department of Medicine, Allergy/Immunology and Rheumatology
  School of Medicine and Dentistry
  University of Rochester Medical Center
  Rochester, NY
- Richard Treger, M.D.
  Board-Certified Nephrologist
  Greater Los Angeles VA Health Care System
  Los Angeles, CA
- Peter Tugwell, M.D.
  Institute of Population Health
  University of Ottawa
  Director, Centre for Global Health
  Ottawa, Ontario, Canada
- Daniel Waxman, M.D., Ph.D.^*^
  Natural Scientist and Visiting Associate Professor of Emergency Medicine
  RAND and University of California, Los Angeles
  Los Angeles, CA
- Neil Wenger, M.D.
  General Internal Medicine Physician and Senior Researcher
  RAND and University of California, Los Angeles
  Los Angeles, CA