# Acknowledgments

We wish to acknowledge the help of the Key Informants; Technical Expert Panel members; Peer Reviewers; our AHRQ Task Order Officer, Aysegul Gozu; and the Associate Editor, Kathy Lohr, in conducting this review and completing the report. We also wish to thank Patty Smith for her assistance with administrative tasks.