# Data Abstraction Tools

Gout Data Abstraction Tool

QUADAS-2: Tool for the Quality Assessment of Diagnostic Accuracy Studies

AMSTAR Assessment of Reporting Quality for Systematic Reviews