# Evidence Table

Table C-1 Evidence table