# List of Excluded Studies

## Not Human – N=2

1 Sundaram PV, Igloi MP, Wassermann R, et al. Immobilized-enzyme nylon-tube reactor for routine determination of uric acid in serum. Clin Chem. Oct. 1978;24(10):1813-7. [pmid: 699291].
2 Takanabe A, Tanaka M, Taniguchi A, et al. Quantitative analysis with advanced compensated polarized light microscopy on wavelength dependence of linear birefringence of single crystals causing arthritis. Journal of Physics D-Applied Physics. Jul. 2014;47(28). PMID: WOS:000338721900011.

## Diagnostic Method Beyond Scope of Review- N=44

1 Backhaus M, Schmidt WA, Mellerowicz H, et al. Technical aspects and value of arthrosonography in rheumatologic diagnosis. 4: Ultrasound of the elbow. Z Rheumatol. Aug. 2002;61(4):415-25. [pmid: 12426847].
2 Barber C, Thompson K, Hanly JG. Impact of a rheumatology consultation service on the diagnostic accuracy and management of gout in hospitalized patients. J Rheumatol. Aug. 2009;36(8):1699-704. [pmid: 19567626].
3 Chauhan N, Pundir CS. An amperometric uric acid biosensor based on multiwalled carbon nanotube-gold nanoparticle composite. Anal Biochem. Jun. 15. 2011;413(2):97-103. [pmid: 21315682].
4 Cheng X, Haggins DG, York RH, et al. Analysis of crystals leading to joint arthropathies by Raman spectroscopy: comparison with compensated polarized imaging. Appl Spectrosc. Apr. 2009;63(4):381-6. [pmid: 19366502].
5 Chu QC, Lin M, Geng CH, et al. Determination of uric acid in human saliva and urine using miniaturized capillary electrophoresis with amperometric detection. Chromatographia. Feb. 2007;65(3-4):179-84. PMID: WOS:000244670700007.
6 Dodd LG, Major NM. Fine-needle aspiration cytology of articular and periarticular lesions. Cancer. Jun. 25. 2002;96(3):157-65. [pmid: 12115304].
7 Friedman RJ, Hawthorne KB, Genez BM. The use of computerized tomography in the measurement of glenoid version. J Bone Joint Surg Am. Aug. 1992;74(7):1032-7. [pmid: 1522089].
8 Galvez J, Saiz E, Linares LF, et al. Delayed examination of synovial fluid by ordinary and polarised light microscopy to detect and identify crystals. Ann Rheum Dis. May. 2002;61(5):444-7. [pmid: 11959769].
9 Goldenberg DL, Cohen AS. Synovial membrane histopathology in the differential diagnosis of rheumatoid arthritis, gout, pseudogout, systemic lupus erythematosus, infectious arthritis and degenerative joint disease. Medicine (Baltimore). May. 1978;57(3):239-52. [pmid: 642792].
10 Heidelmann G, Thiele P, Crasselt C, et al. Uncharacteristic symptoms of the motor apparatus in gout. Z Rheumatol. Nov-Dec. 1975;34(11-12):381-90. [pmid: 1210793].
11 Hujazi I, Ambler G, Arora A, et al. Role of Newman's classification in predicting outcomes in patients with crystal arthritis. International Orthopaedics. Jun. 2012;36(6):1287-90. PMID: WOS:000304160000027. [pmid: 22218914].
12 Ivorra J, Rosas J, Pascual E. Most calcium pyrophosphate crystals appear as non-birefringent. Ann Rheum Dis. Sep. 1999;58(9):582-4. [pmid: 10460193].
13 Johnson JS, Freemont AJ. A 10 year retrospective comparison of the diagnostic usefulness of synovial fluid and synovial biopsy examination. Journal of Clinical Pathology. 2001;54(8):605-7. [pmid: 11477114].
14 Kaneko K, Maru M. Determination of urate crystal formation using flow cytometry and microarea X-ray diffractometry. Anal Biochem. May. 15. 2000;281(1):9-14. [pmid: 10847604].
15 Klaus R, Fischer W, Hauck HE. Qualitative and Quantitative-Analysis of Uric-Acid, Creatine and Creatinine Together with Carbohydrates in Biological-Material by Hptlc. Chromatographia. Oct. 1991;32(7-8):307-16. PMID: WOS:A1991GP25100001.
16 Koski JM, Hermunen HS, Kilponen VM, et al. Verification of palpation-guided intra-articular injections using glucocorticoid-air-saline mixture and ultrasound imaging (GAS-graphy). Clinical and Experimental Rheumatology. 2006;24(3):247-52. [pmid: 16870090].
17 Kratky G, Hefel P. Differential diagnosis of knee joint fluid. Enzymatic analysis (author's transl). Arch Orthop Trauma Surg. Dec. 12. 1978;93(1):65-73. [pmid: 727932].
18 Lenz W, Klein W, Huth F. Needle biopsy in gout and pseudogout (author's transl). Beitr Pathol. Apr. 1976;157(2):161-82. [pmid: 179523].
19 Li X, Wang X, Yu Y, et al. Value of dual energy spectral CT for detecting uric acid deposition in tophaceous gout with base material mapping. Chinese Journal of Radiology. (China). 2014;48(4):303-7.
20 Lichtenstein MJ, Pincus T. How useful are combinations of blood tests in “rheumatic panels” in diagnosis of rheumatic diseases?. J Gen Intern Med. Sep-Oct. 1988;3(5):435-42. [pmid: 3262732].
21 Lin J, Zhao GQ, Che CY, et al. Characteristics of ocular abnormalities in gout patients. Int J Ophthalmol. 2013;6(3):307-11. [pmid: 23826523].
22 Lin X, Wang YF, Sun JY, et al. Determination of uric acid in human plasma and urine by microemulsion electrokinetic chromatography. Analytical Methods. 2013;5(19):5201-7. PMID: WOS:000324489100035.
23 Liu Y, Yu P, Sun X, et al. Metabolite target analysis of human urine combined with pattern recognition techniques for the study of symptomatic gout. Mol Biosyst. Nov. 2012;8(11):2956-63. [pmid: 22932763].
24 Matsubara C, Yokoi Y, Nakamichi N, et al. Spectrophotometric determination of uric acid in serum using a titanium (IV)-porphyrin complex. Yakugaku Zasshi. Jan. 1994;114(1):48-53. [pmid: 8133459].
25 McGill NW, McGill VG. Quality assurance for synovial fluid examination for crystals: an improved method. Ann Rheum Dis. Aug. 1997;56(8):504-6. [pmid: 9306876].
26 Medellin MV, Erickson AR, Enzenauer RJ. Variability of treatment for gouty arthritis between rheumatologists and primary care physicians. J Clin Rheumatol. Feb. 1997;3(1):24-7. [pmid: 19078113].
27 Menghini S, Della Corte E. Evaluation of hyperuricemia caused by fructose in a status of altered uric acid metabolism. Quad Sclavo Diagn. Dec. 1987;23(4):441-6. [pmid: 3509875].
28 Nasonova VA, Zakharova MM, Barskova VG, et al. Detection of sodium monourate crystals in biopsies of gastric mucosa in patients with gout. Ter Arkh. 2004;76(6):47-51. [pmid: 15332576].
29 Papanicolas LE, Hakendorf P, Gordon DL. Concomitant Septic Arthritis in Crystal Monoarthritis. Journal of Rheumatology. Jan. 2012;39(1):157-60. PMID: WOS:000299400500028. [pmid: 22133623].
30 Pascual E, Tovar J, Ruiz MT. The ordinary light microscope: An appropriate tool for provisional detection and identification of crystals in synovial fluid. Annals of the Rheumatic Diseases. 1989;48(12):983-5. [pmid: 2559666].
31 Piliaev VG, Petrov VP, Pikhlak EG, et al. The importance of arthroscopy and guided biopsy of the knee joint in gout. Revmatologiia (Mosk). Oct-Dec. 1989;(4):15-8. [pmid: 2637459].
32 Pobirci O, Bogdan F, Pobirci DD, et al. The study of synovities with articular inflammatory liquid, through clinical-statistical, histological and immunohistochemical methods. Rom J Morphol Embryol. 2011;52(1 Suppl):333-8. [pmid: 21424072].
33 Schlesinger N. Response to application of ice may help differentiate between gouty arthritis and other inflammatory arthritides. J Clin Rheumatol. Dec. 2006;12(6):275-6. [pmid: 17149056].
34 Shidham V, Chivukula M, Basir Z, et al. Evaluation of crystals in formalin-fixed, paraffin-embedded tissue sections for the differential diagnosis of pseudogout, gout, and tumoral calcinosis. Mod Pathol. Aug. 2001;14(8):806-10. [pmid: 11504841].
35 Sivera F, Aragon R, Pascual E. First metatarsophalangeal joint aspiration using a 29-gauge needle. Ann Rheum Dis. Feb. 2008;67(2):273-5. [pmid: 17557892].
36 Song JS, Choi ST, Park EH. The usefulness of procalcitonin for differentiating acute gout arthritis from infectious disease. Annals of the Rheumatic Diseases. 2014;73.
37 Strobel G, Schwarz R, Heppt P, et al. Use of an improved transmission ultrasound camera for diagnosis of rheumatic joint diseases. Z Rheumatol. Mar-Apr. 1993;52(2):114-20. [pmid: 8517073].
38 Vasil'ev A, Obramenko IE. Magnetic resonance imaging differential diagnosis of psoriatic polyarthropathy with gouty polyarthropathy and rheumatoid polyarthritis. Vestn Rentgenol Radiol. Jan-Feb. 2013;(1):29-33. [pmid: 23700923].
39 Yamakita J, Yamamoto T, Moriwaki Y, et al. Effect of urine storage on urinary uric acid concentrations. Ann Clin Biochem. May. 2000;37(Pt 3):355-9. [pmid: 10817251].
40 Yin L, Zhu J, Xue Q, et al. Micropure imaging for the evaluation of microcalcifications in gouty arthritis involving the first metatarsophalangeal joint: A Preliminary Study. PLoS ONE. 2014;9(5).
41 Yu MX, He ZG, Zhang NZ. Analysis of knee arthroscopic findings in rheumatic diseases. Zhonghua Nei Ke Za Zhi. Dec. 1990;29(12):713-6. 64. [pmid: 2092955].
42 Zamani B, Jamali R, Ehteram H. Synovial fluid adenosine deaminase and high-sensitivity C-reactive protein activity in differentiating monoarthritis. Rheumatol Int. Jan. 2012;32(1):183-8. [pmid: 20721560].
43 Zborovskii AB, Stazharov M, Martem'ianov VF. Purine metabolism enzymes in diagnosis and differential diagnosis of osteoarthritis and gout arthritis. Ter Arkh. 2000;72(4):21-4. [pmid: 10833792].
44 Zsernaviczky J, Dressler D. Gout, pseudo-gout or hyperlipoproteinemia? (author's transl). Z Orthop Ihre Grenzgeb. Apr. 1976;114(2):243-7. [pmid: 1274401].

## Not Gout Diagnosis or Management or Does Not Address Key Question - N=69

1 Antommattei O, Schumacher HR, Reginato AJ, et al. Prospective study of morphology and phagocytosis of synovial fluid monosodium urate crystals in gouty arthritis. J Rheumatol. Dec. 1984;11(6):741-4. [pmid: 6520827].
2 Artmann A, Ratzenbock M, Noszian I, et al. Dual energy CT--a new perspective in the diagnosis of gout. Rofo. Mar. 2010;182(3):261-6. [pmid: 19862652].
3 Bardin T. Epidemiology of gout. Épidémiologie de la goutte. 2007;74(2):147-9.
4 Blaauw AAM, Schuwirth LWT, Vandervleuten CPM, et al. Assessing Clinical Competence - Recognition of Case Descriptions of Rheumatic Diseases by General-Practitioners. British Journal of Rheumatology. Apr. 1995;34(4):375-9. PMID: WOS:A1995RC64700016. [pmid: 7788155].
5 Choi HK, Burns LC, Shojania K, et al. Dual energy CT in gout: a prospective validation study. Ann Rheum Dis. Sep. 2012;71(9):1466-71. [pmid: 22387729].
6 Craig MH, Poole GV, Hauser CJ. Postsurgical gout. Am Surg. Jan. 1995;61(1):56-9. [pmid: 7832383].
7 Dalbeth N, Clark B, Gregory K, et al. Computed tomography measurement of tophus volume: comparison with physical measurement. Arthritis Rheum. Apr. 15. 2007;57(3):461-5. [pmid: 17394233].
8 de Avila Fernandes E, Kubota ES, Sandim GB, et al. Ultrasound features of tophi in chronic tophaceous gout. Skeletal Radiol. Mar. 2011;40(3):309-15. [pmid: 20676636].
9 Dihlmann W, Dihlmann A. Osteoclastic finger arthrosis--a subtype of hand polyarthrosis. Rofo. Feb. 1998;168(2):128-32. [pmid: 9519043].
10 Dixit AK, Dey RK, Panda AK, et al. Biochemical and serological profiling of sandhi shoola (Arthralgia) patients of ayurveda hospital. International Journal of Research in Ayurveda and Pharmacy. March/April. 2013;4(2):141-4. FULL TEXT LINK http://dx.doi.org/10.7897/2277-4343.04210.
11 Eid AS, Burrows V, Murray JRM, et al. Are we managing acute knee effusion well?. British Journal of Medical Practitioners. 2012;5(1).
12 Fernandes EA, Lopes MG, Mitraud SA, et al. Ultrasound characteristics of gouty tophi in the olecranon bursa and evaluation of their reproducibility. Eur J Radiol. Feb. 2012;81(2):317-23. [pmid: 21237599].
13 Feydy A, Liote F, Carlier R, et al. Cervical spine and crystal-associated diseases: imaging findings. Eur Radiol. Feb. 2006;16(2):459-68. [pmid: 15856241].
14 Fiechtner JJ, Simkin PA. Urate spherulites in gouty synovia. JAMA. Apr. 17. 1981;245(15):1533-6. [pmid: 7206161].
15 Filippucci E, Delle Sedie A, Riente L, et al. Ultrasound imaging for the rheumatologist. XLVII. Ultrasound of the shoulder in patients with gout and calcium pyrophosphate deposition disease. Clin Exp Rheumatol. Sep-Oct. 2013;31(5):659-64. [pmid: 24050142].
16 Filippucci E, Scire CA, Delle Sedie A, et al. Ultrasound imaging for the rheumatologist. XXV. Sonographic assessment of the knee in patients with gout and calcium pyrophosphate deposition disease. Clin Exp Rheumatol. Jan-Feb. 2010;28(1):2-5. [pmid: 20346230].
17 Gaber W, Ezzat Y, Abd El Rahman SF. Role of diagnostic ultrasonography in detecting gouty arthritis. Egyptian Rheumatologist. April. 2013;35(2):71-5. FULL TEXT LINK http://dx.doi.org/10.1016/j.ejr.2012.12.003.
18 Gamez-Nava JI, Gonzalez-Lopez L, Davis P, et al. Referral and diagnosis of common rheumatic diseases by primary care physicians. British Journal of Rheumatology. 1998;37(11):1215-9. [pmid: 9851272].
19 Gancheva RN, Kundurdjiev A, Ivanova M, et al. Ultrasonographic examination of target organs in gout. Annals of the Rheumatic Diseases. 2014;73.
20 Gordon TP, Bertouch JV, Walsh BR, et al. Monosodium urate crystals in asymptomatic knee joints. J Rheumatol. Nov-Dec. 1982;9(6):967-9. [pmid: 7161792].
21 Grassi W, Filippucci E, Farina A, et al. Sonographic imaging of the distal phalanx. Semin Arthritis Rheum. Jun. 2000;29(6):379-84. [pmid: 10924024].
22 Gruber M, Bodner G, Rath E, et al. Dual-energy computed tomography compared with ultrasound in the diagnosis of gout. Rheumatology (Oxford). Jan. 2014;53(1):173-9. [pmid: 24136065].
23 Guggi V, Calame L, Gerster JC. Contribution of digit joint aspiration to the diagnosis of rheumatic diseases. Joint Bone Spine. 2002;69(1):58-61. [pmid: 11858358].
24 Gutiérrez M, Di Geso L, Rovisco J, et al. Ultrasound learning curve in gout: A disease-oriented training program. Arthritis Care and Research. 2013;65(8):1265-74. [pmid: 23509029].
25 Hollingworth P, Williams PL, Scott JT. Frequency of chondrocalcinosis of the knees in asymptomatic hyperuricaemia and rheumatoid arthritis: a controlled study. Ann Rheum Dis. Aug. 1982;41(4):344-6. [pmid: 7114915].
26 Howard RG, Pillinger MH, Gyftopoulos S, et al. Reproducibility of musculoskeletal ultrasound for determining monosodium urate deposition: concordance between readers. Arthritis Care Res (Hoboken). Oct. 2011;63(10):1456-62. [pmid: 21702086].
27 Jozsa L, Reffy A, Kannus P, et al. Pathological alterations in human tendons. Arch Orthop Trauma Surg. 1990;110(1):15-21. [pmid: 2288799].
28 Kayamori Y, Katayama Y. A Sensitive Determination of Uric-Acid in Serum Using Uricase/Catalase/Formaldehyde Dehydrogenase Coupled with Formate Dehydrogenase. Clinical Biochemistry. Apr. 1994;27(2):93-7. PMID: WOS:A1994NF30600004. [pmid: 8070073].
29 Konatalapalli RM, Demarco PJ, Jelinek JS, et al. Gout in the axial skeleton. J Rheumatol. Mar. 2009;36(3):609-13. [pmid: 19208604].
30 Kotz R, Skalova M, Friza B, et al. Vasoconstrictor phenomenon (P factor) in the synovial fluid of chronic inflammatory joint diseases. Wien Med Wochenschr. Apr. 18. 1970;120(16):288-9. [pmid: 4110747].
31 Lawry GV 2nd, Fan PT, Bluestone R. Polyarticular versus monoarticular gout: a prospective, comparative analysis of clinical features. Medicine (Baltimore). Sep. 1988;67(5):335-43. [pmid: 3412175].
32 Lequesne M, Bensasson M, Kahn MF, et al. Gout, hyperuricemia and femur head osteonecrosis (FHON). Rev Rhum Mal Osteoartic. Mar. 1975;42(3):177-83. [pmid: 1179124].
33 Levin RW, Park J, Ostrov B, et al. Clinical assessment of the 1987 American College of Rheumatology criteria for rheumatoid arthritis. Scand J Rheumatol. 1996;25(5):277-81. [pmid: 8921919].
34 Link TM, Gaubitz M, Lenzen H, et al. Clinical use of magnification radiography in rheumatologic differential diagnosis. Z Rheumatol. May-Jun. 1993;52(3):161-6. [pmid: 8368021].
35 Liote F, Lancrenon S, Lanz S, et al. GOSPEL: prospective survey of gout in France. Part I: design and patient characteristics (n = 1003). Joint Bone Spine. Oct. 2012;79(5):464-70. [pmid: 22281230].
36 Liu W, Xue HD, Zeng XJ, et al. Application of dual-energy computed tomography for detecting uric acid deposition in patients with gout. Zhongguo Yi Xue Ke Xue Yuan Xue Bao. Dec. 2010;32(6):645-8. [pmid: 21219793].
37 Mallinson PI, Reagan AC, Coupal T, et al. The distribution of urate deposition within the extremities in gout: a review of 148 dual-energy CT cases. Skeletal Radiol. Mar. 2014;43(3):277-81. [pmid: 24337414].
38 Mohanaruban K, Joglekar M, Swift CG, et al. Significance of single serum urate estimations in acutely hospitalized elderly patients. Age Ageing. Jul. 1987;16(4):221-4. [pmid: 3630844].
39 Narasaki K. Clinical studies of gout. Problems in the areas outside the cities. Geka Chiryo. Mar. 1970;22(3):296-300. [pmid: 5467647].
40 Naredo E, Uson J, Jimenez-Palop M, et al. Ultrasound-detected musculoskeletal urate crystal deposition: which joints and what findings should be assessed for diagnosing gout?. Ann Rheum Dis. 2013. May. 24. [pmid: 23709244].
41 Oliviero F, Scanu A, Galozzi P, et al. Prevalence of calcium pyrophosphate and monosodium urate crystals in synovial fluid of patients with previously diagnosed joint diseases. Joint Bone Spine. May. 2013;80(3):287-90. [pmid: 23021157].
42 Park J, Schumacher HR Jr. The clinical significance of cytoplasmic inclusions(CPI) in synovial fluid examination. J Korean Med Sci. Aug. 1996;11(4):326-31. [pmid: 8878801].
43 Pascual E, Batlle-Gualda E, Martinez A, et al. Synovial fluid analysis for diagnosis of intercritical gout. Annals of Internal Medicine. 1999;131(10):756-9. [pmid: 10577299].
44 Paul H, Reginato AJ, Schumacher HR. Alizarin red S staining as a screening test to detect calcium compounds in synovial fluid. Arthritis Rheum. Feb. 1983;26(2):191-200. [pmid: 6186260].
45 Peiteado D, De Miguel E, Villalba A, et al. Value of a short four-joint ultrasound test for gout diagnosis: a pilot study. Clin Exp Rheumatol. Nov-Dec. 2012;30(6):830-7. [pmid: 23020889].
46 Pelaez-Ballestas I, Cuevas CH, Burgos-Vargas R, et al. Diagnosis of Chronic Gout: Evaluating the American College of Rheumatology Proposal, European League Against Rheumatism Recommendations, and Clinical Judgment. Journal of Rheumatology. Aug. 2010;37(8):1743-8. PMID: WOS:000280860600028. [pmid: 20551101].
47 Pérez Ruiz F, Ruiz López J, Herrero Beites AM. Influence of the natural history of disease on a previous diagnosis in patients with gout. Influencia de la historia natural de la enfermedad en el diagnóstico previo en pacientes con gota. 2009;5(6):248-51.
48 Poor G. Crystal arthritis. Baillieres Clin Rheumatol. May. 1995;9(2):397-406. [pmid: 7656347].
49 Popp JD, Bidgood WD Jr., Edwards NL. Magnetic resonance imaging of tophaceous gout in the hands and wrists. Semin Arthritis Rheum. Feb. 1996;25(4):282-9. [pmid: 8834016].
50 Prowse RL, Dalbeth N, Kavanaugh A, et al. A Delphi exercise to identify characteristic features of gout - Opinions from patients and physicians, the first stage in developing new classification criteria. Journal of Rheumatology. 2013;40(4):498-505. [pmid: 23418379].
51 Puig JG, de Miguel E, Castillo MC, et al. Asymptomatic hyperuricemia: impact of ultrasonography. Nucleosides Nucleotides Nucleic Acids. Jun. 2008;27(6):592-5. [pmid: 18600510].
52 Punzi L, Cimmino MA, Frizziero L, et al. Italian Society of Rheumatology (SIR) recommendations for performing arthrocentesis. Raccomandazioni della Società Italiana di Reumatologia per l'esecuzione dell'artrocentesis. 2007;59(3):227-34.
53 Raddatz DA, Mahowald ML, Bilka PJ. Acute polyarticular gout. Ann Rheum Dis. Apr. 1983;42(2):117-22. [pmid: 6847258].
54 Roddy E, Menon A, Hall A, et al. Polyarticular sonographic assessment of gout: a hospital-based cross-sectional study. Joint Bone Spine. May. 2013;80(3):295-300. [pmid: 23142256].
55 Santos-Moreno P, Bello JM, Cubides M, et al. Rheumathoid arthritis misdiagnosis and osteoarthritis as the most frequent cause for diagnosis mistake. Annals of the Rheumatic Disease. 2013;71(3):2012-06.
56 Stamp LK, Zhu X, Dalbeth N, et al. Serum urate as a soluble biomarker in chronic gout-evidence that serum urate fulfills the OMERACT validation criteria for soluble biomarkers. Semin Arthritis Rheum. Jun. 2011;40(6):483-500. [pmid: 21056459].
57 Stiehl P, Hantzschel H. Importance of cytologic synovial findings for the early diagnosis, differential diagnosis and activity assessment of joint diseases. Z Gesamte Inn Med. Sep. 15. 1971;26(18):573-81. [pmid: 5127648].
58 Stockman A, Darlington LG, Scott JT. Frequency of chondrocalcinosis of the knees and avascular necrosis of the femoral heads in gout: a controlled study. Ann Rheum Dis. Feb. 1980;39(1):7-11. [pmid: 7377863].
59 Sun Y, Ma L, Zhou Y, et al. Features of urate deposition in patients with gouty arthritis of the foot using dual-energy computed tomography. Int J Rheum Dis. 2013. Nov. 15. [pmid: 24238356].
60 Suteanu S, Ciobanu V, Gheorghiu M, et al. Clinical and humoral studies of sero-negative rheumatoid arthritis. II. Med Interna (Bucur). Nov. 1969;21(11):1377-84. [pmid: 5379704].
61 Tausche AK, Gehrisch S, Panzner I, et al. A 3-Day Delay in Synovial Fluid Crystal Identification Did Not Hinder the Reliable Detection of Monosodium Urate and Calcium Pyrophosphate Crystals. Jcr-Journal of Clinical Rheumatology. Aug. 2013;19(5):241-5. PMID: WOS:000330461400003. [pmid: 23872540].
62 Thiele RG, Schlesinger N. Diagnosis of gout by ultrasound. Rheumatology (Oxford). Jul. 2007;46(7):1116-21. [pmid: 17468505].
63 Toyoda K, Miyamoto Y, Ida M, et al. Hyperechoic medulla of the kidneys. Radiology. Nov. 1989;173(2):431-4. [pmid: 2678257].
64 Weinberger A, Schoenberg O, David M, et al. Synovial fluid examination in hyperuricemic psoriatic patients. Biomed Pharmacother. Jan. 1982;36(1):47-8. [pmid: 7126772].
65 Weinfeld SB, Schon LC. Hallux metatarsophalangeal arthritis. Clin Orthop Relat Res. Apr. 1998;(349):9-19. [pmid: 9584362].
66 Wild JH, Zvaifler NJ. An office technique for identifying crystal in synovial fluid. Am Fam Physician. Jul. 1975;12(1):72-81. [pmid: 168759].
67 Wu H, Xue J, Ye L, et al. The application of dual-energy computed tomography in the diagnosis of acute gouty arthritis. Clin Rheumatol. 2014. Apr. 18. [pmid: 24744154].
68 Zayat AS, Conaghan P, Freeston J, et al. Ultrasound detected bone erosions: Are they specific for rheumatoid arthritis?. Rheumatology. May. SUPPL. 3. 2012;51(2012):iii69.
69 Zillessen E, Baldauf G. The distribution of destructive polyarthritic changes in the hand skeleton. Z Rheumatol. Jul-Aug. 1978;37(7-8):225-32. [pmid: 695997].

## No Original Data - N=29

1 Borner H, Ewald HO. “Calcium gout”. Dtsch Z Verdau Stoffwechselkr. Dec. 1967;27(5):197-204. [pmid: 5595740].
2 Bousson V, Hamze B, Wybier M, et al. Soft tissue tumors and pseudotumors of the foot and ankle. J Radiol. Jan. 2008;89(1 Pt 1):21-34. [pmid: 18288023].
3 Brower AC. Appendicular arthropathy. Orthop Clin North Am. Jul. 1990;21(3):405-22. [pmid: 2367097].
4 Chaturvedi V. A decade experience of a bedside MSK Ultrasound by a clinician - Was it worth it?. International Journal of Rheumatic Diseases. 2013;16:14. [pmid: 23441767].
5 de Miguel E. Role of ultrasound in microcrystalline arthritis. Reumatol Clin. Oct. Suppl 2. 2008;4:50-4. [pmid: 21794565].
6 Dihlmann W. Principles of roentgen diagnosis in inflammatory rheumatic joint diseases of the extremities. Internist (Berl). Aug. 1973;14(8):350-61. [pmid: 4586535].
7 Dimov D. Actual aspects of gout diagnostics. Revmatologiia. 2009;17(1):22-7.
8 Grobner W, Zollner N. Gout. Z Rheumatol. Feb. 2004;63(1):2-9. [pmid: 14991273].
9 Gutierrez M, Filippucci E, Salaffi F, et al. The current role of ultrasound in the assessment of crystal-related arthropathies. Reumatismo. Jul-Sep. 2009;61(3):216-21. [pmid: 19888507].
10 Jansen TL. Rheumatology meets radiology in the hot soup of Gutta. Arthritis Res Ther. Dec. 19. 2012;14(6):126. [pmid: 23256732].
11 Jiang GY, Yang XL. Diagnostic evaluation and clinical characteristics of gout. Chinese Journal of Clinical Rehabilitation. 25. 2006;10(28):150-5.
12 Krajnc I, Pahor A. Identification of crystals in synovial fluid. Reumatizam. 1990;37(1-6):25-30. [pmid: 1966921].
13 Leclercq P, Malaise MG. Gout. Rev Med Liege. May. 2004;59(5):274-80. [pmid: 15264576].
14 Lioté F. Diagnosis of crystal-induced arthritis. Diagnostic d'une arthropathie microcristalline. 2011;40(9):869-76.
15 Lioté F, Bardin T. Treatment of gout. Traitement de la goutte. 2007;74(2):160-7.
16 Muller-Fassbender H, Bach GL. Radiologic findings in gout. Wien Med Wochenschr. 1997;147(16):377-81. [pmid: 9446416].
17 Nieradko-Iwanicka B. Colchicine in treatment of acute gout attacks - Is it really necessary?. Kolchicyna w leczeniu ostrego napadu dny moczanowej - Czy jest rzeczywiście potrzebna?. 2008;10(1):55-8.
18 Oliviero F, Pascual E, Punzi L. Detection and identification of crystals in synovial fluid. Reumatismo. Jul-Sep. 2005;57(3):208-11. [pmid: 16258607].
19 Paparo F, Sconfienza LM, Muda A, et al. Multimodality imaging of chronic tophaceous gout. Reumatismo. Oct-Dec. 2010;62(4):286-91. [pmid: 21253623].
20 Raab W. Dermal gout: Pathogenesis, clinic and therapy. Hautgicht - Pathogenese, klinik und therapie. Haut. June. 2009;20(3):97-100.
21 Romhild N, Treutler H. Roentgen examinations of joints in patients with gouty arthritis. Z Gesamte Inn Med. Jul. 1. 1982;37(13):421-3. [pmid: 7136083].
22 Schlesinger N. Can ultrasonography make identification of asymptomatic hyperuricemic individuals at risk for developing gouty arthritis more crystal clear?. Arthritis Research and Therapy. 2010;13(2).
23 Sebesta I, Krijt J, Schneiderka P. The importance of uric acid examination. Sb Lek. 1994;95(4):383-9. [pmid: 8867710].
24 Sieper J. New aspects in diagnosis of inflammatory rheumatic diseases. NEUE ASPEKTE IN DER DIAGNOSTIK ENTZUNDLICH-RHEUMATISCHER ERKRANKUNGEN. Klinikarzt. 1998. 1998;27(2):23-7.
25 Tausche AK, Aringer M. Hyperuricemia and gout. Diagnostic and therapeutic approach. Hyperurikämie und gicht. Welche abklärung, welche therapie?. 2009;49(4):743-54.
26 Villiger PM. Gout and its differential diagnosis. Ther Umsch. Sep. 2004;61(9):563-6. [pmid: 15493116].
27 Vock P, Bonel H. Uric acid, a neglected molecule--the value of imaging. Ther Umsch. Sep. 2004;61(9):557-62. [pmid: 15493115].
28 Winzer M, Gräßler J, Aringer M. Crystal-induced arthritis - Old but important. Kristallarthropathien - Alt, aber wichtig. 2007;66(4):317-25.
29 Zimmermann-Górska I. Diagnosis and therapy of crystal-induced diseases. Postȩpowanie diagnostyczno-terapeutyczne w chorobach wywoływanych przez kryształy. 2012;50(2):177-80.

## Conference Proceedings/Presentations/Abstracts - N=38

1 Bhamra K, Seymour M, Swales C, et al. Utility of ultrasound in the nuffield orthopaedic centre emergency rheumatology clinic: Survey of clinical effectiveness. Annals of the Rheumatic Diseases. 2014;73.
2 Bhamra KK, Seymour MW, Swales CE, et al. Utility of ultrasound in the nuffield orthopaedic centre emergency rheumatology clinic: Survey of clinical effectiveness. Rheumatology (United Kingdom). 2014;53:i109.
3 Breuer GS, Bogot N, Nesher G. Dual-energy computed tomography as a diagnostic tool for gout during intercritical periods. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S67.
4 Choi ST, Song JS. Serum procalcitonin could be a useful serologic marker for the differential diagnosis between acute gouty attack and bacterial infection. Arthritis and Rheumatism. 2011;63(10):2011-11.
5 Chowalloor P. Prevalence and distribution of subclinical synovitis in gout. Internal Medicine Journal. May. SUPPL. 2. 2013;43:22.
6 Chowalloor P, Keen H. Subclinical synovial inflammation in gout. Internal Medicine Journal. May. SUPPL. 1. 2012;42:30. [pmid: 23035679].
7 Dalbeth N, Kalluru R, Aati O, et al. Tendon and ligament involvement in gout: A dual energy computed tomography study. Arthritis and Rheumatism. October. SUPPL. 10. 2012;64:S1095.
8 Das S, Ghosh P, Lahiri D, et al. Ultrasonographic features of gout and their relation with serum uric acid level. Indian Journal of Rheumatology. November. SUPPL. 1. 2012;7:S4.
9 Fabreguet I, So A, Dumusc A, et al. Utility of joint ultrasonography in the diagnosis of suspected acute crystal arthritis-results of a prospective controlled study of 90 patients. Annals of the Rheumatic Diseases. 2014;73.
10 Fiene M, Karnebeck V, Rosenberg C, et al. Tendon involvement in chronic tophaceous gout detected by dual-anergy-computertomography. Annals of the Rheumatic Diseases. 2014;73.
11 Gelber AC, Lanzkron S, Maynard J, et al. Population-based association of sickle ceil disease with gout. American Journal of Hematology. August. 2010;85(8):E9-E10.
12 Gruber M, Krestan C, Schueller-Weidekamm C, et al. Dual energy CT compared to sonography in the detection of acute and chronic gout. Skeletal Radiology. June. 2011;40(6):805-6.
13 Guillen Astete CA, Medina Quinones C, Ahijon Lana M, et al. Use of procalcitonin measurement to distinguish an infectious and a microcrystalline arthritis in an urgency enviroment. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
14 Holbrook M, Hermansen P, Palmer M, et al. Additional clinical effectiveness from a full synovial cytology service. Acta Cytologica. May. SUPPL. 1. 2013;57:41.
15 Iagnocco A. Ultrasound assessment of the cartilage. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
16 Kang T. Standard scans, sonographic anatomy, and basic sonographic pathology. International Journal of Rheumatic Diseases. 2013;16:2.
17 Kienhorst L, Eijgelaar R, Janssen M. A comparison of three different types of synovial fluid preservation to study the stability of monosodium urate and calcium pyrophosphate dihydrate crystals. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
18 Kienhorst L, Janssens H, Fransen J, et al. The performance of a diagnostic rule for acute gouty arthritis without joint fluid analysis: A validation study. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S500.
19 Kienhorst L, Janssens H, Van De Lisdonk E, et al. No exclusivity for gout in arthritis of the first metatarsophalangeal joint. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
20 Kudaeva F, Vladimirov S, Bozhieva L, et al. Usefulness of imaging techniques in mixed crystal deposition (pilot study). Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
21 Kuzmanova S, Solakov P, Sapoundjiev L. Establishment of msum crystals in synovial fluid by polarized light microscopy: Detection by four different methods. Revmatologiia. 2006;14(4):37-9.
22 Lamers-Karnebeek FB, Van Lieshout AW, Van Riel PL, et al. Ultrasonographic signals have additive value for gout in patients presenting with mono-/oligoarthritis. Annals of the Rheumatic Disease. 2013;71(3):2012-06.
23 Lee K, Choi ST, Kang EJ, et al. The performance of a novel scoring system in the differential diagnosis between acute gout and septic arthritis. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
24 Mustak M, Boltuch-Sherif J, Kasper M, et al. Seronegative arthropathies: Value of dual-energy CT for differential diagnosis. Journal fur Mineralstoffwechsel. 2012. 2012;19(4):175.
25 Mustak M, Boltuch-Sherif J, Kasper M, et al. Seronegative arthropathies: Value of dual-energy CT for differential diagnosis. Annals of the Rheumatic Disease. 2013;71(3):2012-06.
26 Ngoc LNT, Hoai TP. Ultrasound findings of ankle joint in gout disease. International Journal of Rheumatic Diseases. September. SUPPL. 1. 2012;15:102-3. [pmid: 22324953].
27 Perez-Ruiz F, Castillo E, Chinchilla SP, et al. Coexistence of gout and pyrophosphate arthritis in two large cohorts: Hyperuricemia as a factor for clinical misdiagnosis. Annals of the Rheumatic Diseases. 2014;73.
28 Petrova M, Mazurov V, Shemerovskaya T, et al. Asymptomatic hyperuricemia and markers of inflammation. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
29 Petsch C, Araujo E, Englbrecht M, et al. Gout and RA: Not such a rare coexistence after all. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S175.
30 Reuss-Borst M, Pape C, Tausche AK. Clinical and ultrasound findings in manual workers at high risk of occupational disability and hyperuricemia. Annals of the Rheumatic Diseases. 2014;73.
31 Schmidt WA, Huppertz A. Systematic staging for uric acid deposits with dual-energy computed tomography and ultrasound in suspected gout. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S88.
32 Sivera F, Pascual E. First metatarsophalangeal joint aspiration. Seminarios de la Fundacion Espanola de Reumatologia. 2007;8(3):127-9.
33 Slot O, Terslev L. Ultrasonographically guided dry-needle synovial tissue aspiration is a useful method to obtain material for diagnostic microscopy in patients with clinically and ultrasonographically suspected gout without synovial fluid effusion or clinical tophi. Annals of the Rheumatic Diseases. 2013;72(3):2013-06.
34 Slot O, Terslev L. The double contour sign is a consistent finding in MTP joints in gout patients. Results from an ultrasound pilot study in daily clinical practice. Annals of the Rheumatic Disease. 2013;71(3):2012-06.
35 Solakov PT, Kuzmanova SI, Andreev SA. Establishment of MSUM crystals in synovial fluid by polarized light microscopy: Detection by four different methods. Revmatologiia. 2005;13(4):48-50.
36 Song JS, Choi ST, Kang EJ, et al. Serum procalcitonin could be a useful serologic marker for the differential diagnosis between acute gouty attack and bacterial infection. International Journal of Rheumatic Diseases. September. SUPPL. 1. 2012;15:101.
37 Song JS, Lee KH, Choi ST, et al. The performance of a novel scoring system in the differential diagnosis between acute gout and septic arthritis. Arthritis and Rheumatism. October. SUPPL. 10. 2013;65:S507-S8.
38 Wang H, Glazebrook KN, Kavros SJ, et al. Gouty enthesopathy: An important pattern of uric acid deposition in difficult to diagnose gout. Arthritis and Rheumatism. 2011;63(10):2011-11.

## Could Not Obtain Article - N=15

1 Chernin MM, Pitt MJ. Radiographic disease patterns at the carpus. Clin Orthop Relat Res. Jul-Aug. 1984;(187):72-80. [pmid: 6744739].
2 de Reus HD. Chondrocalcinosis (“pseudogout”). Dtsch Med Wochenschr. Feb. 1974;99(8):363-5. [pmid: 4822440].
3 Dimov D. Gout in women. II. Clinical laboratory and therapeutical features. Revmatologiia. 2008;16(3-4):3-7.
4 Hu HJ, Liao MY, Tian ZX, et al. The value of using dual-energy CT in the detection of monosodium urate crystals in patients with gout. Chinese Journal of Radiology. December. (2012). 2012;46(12):1101-4. FULL TEXT LINK http://dx.doi.org/10.3760/cma.j.issn.1005-1201.2012.12.011.
5 Liote F. Diagnosis of crystal-induced arthritis. Presse Med. Sep. 2011;40(9 Pt 1):869-76. [pmid: 21816563].
6 Lioté F, Nguyen C. Gout: Diagnostic criteria, classification and the quality of life. Goutte: critères de diagnostic, de classification et de qualité de vie. 2010;77(2):144-7.
7 Ostovic KT, Kaic G, Ostovic I, et al. The importance of urgent cytological examination of synovial fluids in differentiation inflammatory and non-inflammatory joint diseases. Coll Antropol. Mar. 2010;34(1):145-52. [pmid: 20432743].
8 Ottaviani S, Richette P, Allard A, et al. Ultrasonography in gout: a case-control study. Clin Exp Rheumatol. Jul-Aug. 2012;30(4):499-504. [pmid: 22512867].
9 Potocki K, Babic-Naglic D, Prutki M, et al. Radiologic imaging of crystalline arthritides. Reumatizam. 2012;59(2):97-104. [pmid: 23745465].
10 Savina LV, Pavlishchuk SA, Samsygin V, et al. Polarization microscopy in diagnosis of metabolic disorders. Klin Lab Diagn. Mar. 2003;(3):11-4. [pmid: 12715390].
11 Schlapbach P, Pfluger D, Gerber NJ. Crystal Identification in Synovial-Fluid - Joint Specific Identification and Correlation with Preliminary Diagnosis. Schweizerische Medizinische Wochenschrift. Jun. 1992;122(25):969-74. PMID: WOS:A1992JA02500002. [pmid: 1621079].
12 Švec V. Validated diagnostic criteria for selected rheumatic disease. Validované diagnostické kritériá vybraných reumatických chorôb. 2013;27(2):95-105.
13 Vezikova NN, Ignat'ev VK. Radionuclide diagnosis of local inflammation in patients with rheumatoid arthritis. Ter Arkh. 1995;67(12):43-6. [pmid: 8820057].
14 Wang L, Qiu L, Zhang LY. High-frequency ultrasonographic findings of gouty arthritis. Chinese Journal of Medical Imaging Technology. February. 2011;27(2):376-9.
15 Zhang Y, Zhang H, Guo JH, et al. The diagnostic value of musculoskeletal ultrasound in gouty arthritis. Zhonghua Nei Ke Za Zhi. Apr. 2012;51(4):304-7. [pmid: 22781952].

## Gout Management Only - N=13

1 Carter JD, Kedar RP, Anderson SR, et al. An analysis of MRI and ultrasound imaging in patients with gout who have normal plain radiographs. Rheumatology (Oxford). Nov. 2009;48(11):1442-6. [pmid: 19745028].
2 Choi HK, Al-Arfaj AM, Eftekhari A, et al. Dual energy computed tomography in tophaceous gout. Ann Rheum Dis. Oct. 2009;68(10):1609-12. [pmid: 19066180].
3 Dalbeth N, Aati O, Gao A, et al. Assessment of tophus size: a comparison between physical measurement methods and dual-energy computed tomography scanning. J Clin Rheumatol. Jan. 2012;18(1):23-7. [pmid: 22157268].
4 Dalbeth N, Ames R, Gamble GD, et al. Effects of skim milk powder enriched with glycomacropeptide and G600 milk fat extract on frequency of gout flares: a proof-of-concept randomised controlled trial. Ann Rheum Dis. Jun. 2012;71(6):929-34. [pmid: 22275296].
5 Kang MH, Moon KW, Jeon YH, et al. Sonography of the first metatarsophalangeal joint and sonographically guided intraarticular injection of corticosteroid in acute gout attack. J Clin Ultrasound. 2014. Jul. 9. [pmid: 25041810].
6 Maldonado BP, So A. The etiology and management of gout. Zeitschrift Fur Rheumatologie. Feb. 2012;71(2):127-36. PMID: WOS:000300854300007. [pmid: 22370804].
7 Ottaviani S, Allard A, Bardin T, et al. An exploratory ultrasound study of early gout. Clin Exp Rheumatol. Sep-Oct. 2011;29(5):816-21. [pmid: 22011529].
8 Ottaviani S, Gill G, Aubrun A, et al. Ultrasound in gout: A useful tool for follow-up with urate-lowering therapy. Annals of the Rheumatic Diseases. 2014;73.
9 Pérez Ruiz F. Treatment of Gout: Reflections From the GEMA Study. Tratamiento de la gota: reflexiones desde el estudio GEMA. 2008;4(SUPPL. 2):41-4.
10 Perez-Ruiz F, Carmona L, Yebenes MJG, et al. An Audit of the Variability of Diagnosis and Management of Gout in the Rheumatology Setting The Gout Evaluation and Management Study. Jcr-Journal of Clinical Rheumatology. Oct. 2011;17(7):349-55. PMID: WOS:000295320000001. [pmid: 21946457].
11 Perez-Ruiz F, Martin I, Canteli B. Ultrasonographic measurement of tophi as an outcome measure for chronic gout. J Rheumatol. Sep. 2007;34(9):1888-93. [pmid: 17659752].
12 Schueller-Weidekamm C, Schueller G, Aringer M, et al. Impact of sonography in gouty arthritis: comparison with conventional radiography, clinical examination, and laboratory findings. Eur J Radiol. Jun. 2007;62(3):437-43. [pmid: 17234377].
13 Shi D, Xu JX, Wu HX, et al. Methods of assessment of tophus and bone erosions in gout using dual-energy CT: reproducibility analysis. Clinical Rheumatology. 2014.

## No Reference Standard or Not All Patients Received Reference Standard - N=7

1 Choi HK, Burns LC, Shojania K, et al. Dual energy CT in gout: a prospective validation study. Ann Rheum Dis. Sep. 2012;71(9):1466-71. [pmid: 22387729].
2 Filippucci E, Meenagh G, Delle Sedie A, et al. Ultrasound imaging for the rheumatologist XXXVI. Sonographic assessment of the foot in gout patients. Clin Exp Rheumatol. Nov-Dec. 2011;29(6):901-5. [pmid: 22206648].
3 Filippucci E, Riveros MG, Georgescu D, et al. Hyaline cartilage involvement in patients with gout and calcium pyrophosphate deposition disease. An ultrasound study. Osteoarthritis Cartilage. Feb. 2009;17(2):178-81. [pmid: 18657999].
4 Lenski M, Scherer MA. Analysis of synovial inflammatory markers to differ infectious from gouty arthritis. Clin Biochem. Jan. 2014;47(1-2):49-55. [pmid: 24177196].
5 Naredo E, Uson J, Jimenez-Palop M, et al. Ultrasound-detected musculoskeletal urate crystal deposition: which joints and what findings should be assessed for diagnosing gout?. Ann Rheum Dis. 2013. May. 24. [pmid: 23709244].
6 Wang C, Zhong D, Liao Q, et al. Procalcitonin levels in fresh serum and fresh synovial fluid for the differential diagnosis of knee septic arthritis from rheumatoid arthritis, osteoarthritis and gouty arthritis. Exp Ther Med. Oct. 2014;8(4):1075-80. [pmid: 25187799].
7 Wu H, Xue J, Ye L, et al. The application of dual-energy computed tomography in the diagnosis of acute gouty arthritis. Clin Rheumatol. 2014. Apr. 18. [pmid: 24744154].