# Search Strategy

## PubMed

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed - ∼1946 - 11/7/2014

SEARCH STRATEGY:

gout OR gouty

AND

X-ray* OR radiograph* OR erosion OR diagnostic imaging[mh] OR radiography [Subheading] OR Computed tomography OR Computer tomography OR dual energy CT OR DECT OR Radiography, Dual-Energy Scanned Projection[mh] OR Ultrasound OR Ultrasonography[mh] OR Ultrasonography[sh] OR double contour OR radionuclide imaging [Subheading] OR (polariz* AND microscop*) OR Joint aspiration OR Serum urate OR Uric acid OR Crystal* OR Tophi OR tophus OR tophaceous OR Synovial fluid OR Urate OR kidney stones OR Kidney Calculi[mh] OR urate stones OR gouty nephropathy OR Hyperuricemia OR clinical symptom*

AND

Accura* OR Sensitivity and specificity[mh] OR Sensitivity[tiab] OR Specificity[tiab] OR False positive reactions[mh] OR false positive* OR False negative reactions[mh] OR False negative* OR Predictive value OR predictive value of tests[mh] OR Distinguish* OR Differential* OR Identif* OR Detect* OR valid* OR reliab* OR reproducibility of results

## Web of Science SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH

DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science SCI-EXPANDED, SSCI, A&HCI, CPCI-S, CPCI-SSH – 1/1/1980 - 11/7/2014

SEARCH STRATEGY:

ts=(gout OR gouty)

AND

ts=(x-ray* or radiograph* or erosion or diagnostic imaging or Computed tomography or Computer tomography or dual energy CT or DECT or Ultrasound or Ultrasonograph* or double contour or radionuclide or (polariz* and microscop*) or Joint aspiration or Serum urate or Uric acid or Crystal* or Tophi or tophus or tophaceous or Synovial fluid or Urate or kidney stones or Kidney Calculi or urate stones or gouty nephropathy or Hyperuricemia or clinical symptom*)

AND

ts=(Accura* or Sensitivity or Specificity or false positive* or False negative* or Predictive value or Distinguish* or Differential* or Identif* or Detect* or valid* or reliab* or reproducibility of results)

## Cochrane

DATABASE SEARCHED & TIME PERIOD COVERED:

Cochrane – Earliest - 11/7/2014

SEARCH STRATEGY:

gout or gouty

AND

x-ray* or radiograph* or erosion or diagnostic imaging or Computed tomography or Computer tomography or dual energy CT or DECT or Ultrasound or Ultrasonograph* or double contour or radionuclide or (polariz* and microscop*) or Joint aspiration or Serum urate or Uric acid or Crystal* or Tophi or tophus or tophaceous or Synovial fluid or Urate or kidney stones or Kidney Calculi or urate stones or gouty nephropathy or Hyperuricemia or clinical symptom* IN TITLE, ABSTRACT, KEYWORD

AND

Accura* or Sensitivity or Specificity or false positive* or False negative* or Predictive value or Distinguish* or Differential* or Identif* or Detect* or valid* or reliab* or reproducibility of results

## Embase

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase 1/1/1972-11/7/14

LIMITERS:

Humans

SEARCH STRATEGY:

‘gout’ OR ‘gout’/exp OR gout OR gouty

AND

‘x ray’/exp OR ‘x ray’ OR ‘x rays’/exp OR ‘x rays’ OR ‘x-ray’/exp OR ‘x-ray’ OR ‘x-rays’/exp OR ‘x-rays’ OR radiograph* OR ‘erosion’/exp OR erosion OR ‘diagnostic imaging’/exp OR ‘diagnostic imaging’ OR ‘computed tomography’/exp OR ‘computed tomography’ OR ‘computer tomography’/exp OR ‘computer tomography’ OR ‘dual energy ct’ OR dect OR ‘ultrasound’/exp OR ultrasound OR ultrasonograph* OR ‘double contour’ OR ‘radionuclide’/exp OR radionuclide OR microscop* OR ‘joint aspiration’/exp OR ‘joint aspiration’ OR ‘serum urate’/exp OR ‘serum urate’ OR ‘uric acid’/exp OR ‘uric acid’ OR crystal* OR tophi OR tophus OR tophaceous OR ‘synovial fluid’/exp OR ‘synovial fluid’ OR ‘urate’/exp OR urate OR (‘kidney’/exp OR kidney AND stones) OR (‘kidney’/exp OR kidney AND (‘calculi’/exp OR calculi)) OR ‘urate stones’/exp OR ‘urate stones’ OR ‘gouty nephropathy’ OR ‘hyperuricemia’/exp OR hyperuricemia OR ‘hyperuricaemia’/exp OR hyperuricaemia OR ‘clinical symptom’ OR ‘clinical symptoms’

AND

accura* OR sensitivity OR specificity OR ‘false positive’ OR ‘false positives’ OR ‘false negative’ OR ‘false negatives’ OR ‘predictive value’/exp OR ‘predictive value’ OR distinguish* OR differential* OR identif* OR detect* OR valid* OR reliab* OR ‘reproducibility of results’/exp OR ‘reproducibility of results’

## Web of Science

DATABASE SEARCHED & TIME PERIOD COVERED:

Web of Science – 1/1/2006-11/7/2014

SEARCH STRATEGY:

Forward search on the following article:

EULAR evidence based recommendations for gout. Part I: Diagnosis. Report of a task force of the standing committee for international clinical studies including therapeutics (ESCISIT)

W Zhang, M Doherty, E Pascual, T Bardin, V Barskova, P Conaghan, J Gerster, J Jacobs, B Leeb, F Liote´, G McCarthy, P Netter, G Nuki, F Perez-Ruiz, A Pignone, J Pimenta˜o, L Punzi, E Roddy, T Uhlig, I Zimmermann-Go` rska Ann Rheum Dis 2006;65:1301–1311. doi: 10.1136/ard.2006.055251

## SCOPUS

DATABASE SEARCHED & TIME PERIOD COVERED:

SCOPUS – 1/1/2006-11/7/2014

SEARCH STRATEGY:

Forward search on the following article:

EULAR evidence based recommendations for gout. Part I: Diagnosis. Report of a task force of the standing committee for international clinical studies including therapeutics (ESCISIT)

W Zhang, M Doherty, E Pascual, T Bardin, V Barskova, P Conaghan, J Gerster, J Jacobs, B Leeb, F Liote´, G McCarthy, P Netter, G Nuki, F Perez-Ruiz, A Pignone, J Pimenta˜o, L Punzi, E Roddy, T Uhlig, I Zimmermann-Go` rska Ann Rheum Dis 2006;65:1301–1311. doi: 10.1136/ard.2006.055251

## Grey Literature Report

DATABASE SEARCHED & TIME PERIOD COVERED:

Grey Literature Report – no date limitation

SEARCH STRATEGY:

Gout OR gouty

NUMBER OF RESULTS: 0

## Embase (Rerun)

DATABASE SEARCHED & TIME PERIOD COVERED:

Embase (rerun of 4/22/2014 search) – 1/1/1972-11/7/2014

LIMITERS:

Humans

SEARCH STRATEGY:

‘gout’ OR ‘gout’/exp OR gout OR gouty

AND

‘x ray’/exp OR ‘x ray’ OR ‘x rays’/exp OR ‘x rays’ OR ‘x-ray’/exp OR ‘x-ray’ OR ‘x-rays’/exp OR ‘x-rays’ OR radiograph* OR ‘erosion’/exp OR erosion OR ‘diagnostic imaging’/exp OR ‘diagnostic imaging’ OR ‘computed tomography’/exp OR ‘computed tomography’ OR ‘computer tomography’/exp OR ‘computer tomography’ OR ‘dual energy ct’ OR dect OR ‘ultrasound’/exp OR ultrasound OR ultrasonograph* OR ‘double contour’ OR ‘radionuclide’/exp OR radionuclide OR microscop* OR ‘joint aspiration’/exp OR ‘joint aspiration’ OR ‘serum urate’/exp OR ‘serum urate’ OR ‘uric acid’/exp OR ‘uric acid’ OR crystal* OR tophi OR tophus OR tophaceous OR ‘synovial fluid’/exp OR ‘synovial fluid’ OR ‘urate’/exp OR urate OR (‘kidney’/exp OR kidney AND stones) OR (‘kidney’/exp OR kidney AND (‘calculi’/exp OR calculi)) OR ‘urate stones’/exp OR ‘urate stones’ OR ‘gouty nephropathy’ OR ‘hyperuricemia’/exp OR hyperuricemia OR ‘hyperuricaemia’/exp OR hyperuricaemia OR ‘clinical symptom’ OR ‘clinical symptoms’

AND

accura* OR sensitivity OR specificity OR ‘false positive’ OR ‘false positives’ OR ‘false negative’ OR ‘false negatives’ OR ‘predictive value’/exp OR ‘predictive value’ OR distinguish* OR differential* OR identif* OR detect* OR valid* OR reliab* OR ‘reproducibility of results’/exp OR ‘reproducibility of results’

## CliicalTrials.gov

CLINICALTRIALS.GOV

CONDITION = “Gout”

RECEIVED FROM: Earliest in database to 11/7//2014