# Abbreviations/Acronyms

3e: Evidence, Expertise, Exchange
3ei: Evidence, Expertise, Exchange initiative
ACA: American College of Rheumatology
ACP: American College of Physicians
AHRQ: Agency for Healthcare Research and Quality
ARA: American Rheumatism Association (formerly American College of Rheumatology)
AUC: Area under the curve
BSF: Bright stippled foci
CART: Classification and regression tree
CGD: Clinical Gout Disease
CI: Confidence interval
CPPD: Calcium Pyrophosphate Deposition Disease (formerly pseudogout)
CT (Scan): Computed tomography
CVD: Cardiovascular disease
DCS: Double-Contour Sign
DECT: Dual-energy computed tomography
EPC: California Evidence-based Practice Center
FN: False negative
FP: False positive
HTN: Hypertension
KQ: Key Question
LDH: Lactate dehydrogenase
LR: Likelihood ratio
LRN: Negative likelihood ratio
LRP: Positive likelihood ratio
MRI: Magnetic resonance imaging
MSU: Monosodium urate
MTP: Metatarsophalangeal
NHANES: National Health and Nutrition Examination Survey
NLR: Nonlikelihood ratio
NPV: Negative predictive value
NSAIDS: Nonsteroidal anti-inflammatory drugs
NY: New York
OA: Osteoarthritis
PCPs: Primary care physicians
PICOTS: Populations, Interventions, Comparators, Outcomes, and Timing
PLM: Polarized light microscopy
PLR: Positive likelihood ratio
PPV: Positive predictive value
RA: Rheumatoid arthritis
ROC: Receiver-operating characteristics
SA: Septic arthritis
SCEPC: Southern California Evidence-based Practice Center
SFWBC: Synovial Fluid White Blood Cell Count
SpA: Spondyloarthritis
SRs: Systematic Reviews
sUA: Serum uric acid
TEP: Technical Expert Panel
US: Ultrasound
US DHHS: U.S. Department of Health and Human Services
VA: Veterans Administration