# Results

Our searches for systematic reviews retrieved 699 citations. After review of abstracts, 58 of these citations were deemed potentially relevant and the corresponding full-length articles were obtained and examined in full text. After full-text review, 30 systematic reviews were considered eligible, and provided information on 297 potentially relevant primary studies on the diagnosis of acute appendicitis. Our literature searches for primary studies retrieved 28,203 citations. Based on abstract review, 5187 of these citations were considered potentially relevant and were retrieved in full text. Our search strategies for all databases are presented in Appendix A; the complete lists of included and excluded studies (organized by reason for exclusion) are presented in Appendix B. After full-text review, 925 primary studies were considered eligible (630 of which had not been included in previous reviews – mainly because they had been published after last search date of the reviews). Figure 2 presents the literature flow.

Figure 2 Flow chart of included studies

CCRCT = Cochrane Central Register of Controlled Trials; KQ = Key Question

This figure illustrates the flow of studies in the report. We retrieved 28203 publications from our initial searches. To these, we added 297 studies identified through other systematic reviews. Of these 5187 were reviewed in full text, with 926 included in the final report, of which 903 address KQ1, 76 KQ2, and 83 KQ3. Reasons for exclusion included: abstract only (364 studies), appendicitis specific test results not reported (166 studies), case report or case series (188 studies), case-control study design (78 studies), data not extractable (92 studies), duplicate publication (38 studies), index test confounded by antibiotics (1 study), index test results not reported (190 studies), less than sample size cut-off (48 studies), no human subjects (4 studies), no primary data (922 studies), no reference standard or reference standard not approved (20), non-English (1067 studies), not outcome of interest (36 studies), not population of interest (88 studies), not retrieved (17 studies), not test of interest (527 studies), selected on basis of index test results (38 studies), selected on the basis of outcomes (380 studies)

## Key Question 1 What is the performance of alternative diagnostic tests, alone or in combination, for patients with right lower quadrant (RLQ) pain and suspected acute appendicitis?

### Included Studies With Information on Test Performance

In total, 903 studies, published between 1956 and 2014, met the inclusion criteria for Key Question 1. We organized studies into five categories based on the tests they evaluated: clinical symptoms and signs (137 studies), laboratory tests (217 studies), imaging tests (519 studies), multivariable diagnostic scores (127 studies), and diagnostic laparoscopy (55 studies). Appendix C contains a list of all included studies for this Key Question, with information on the tests examined in each study, test performance data, a summary of study characteristics, and details of our risk of bias assessment. In this section we summarize information on tests that were examined most often in the studies we reviewed and those that, based on our reading of the literature, and discussions with Key Informants and Technical Experts, were thought to be more clinically relevant.

Results for each test category (and each test) are presented separately for adults, children, women of reproductive age, pregnant women (some studies reported results for more than one of these subgroups), and mixed populations (typically including male and female patients of all ages). When five or more independent studies had evaluated the same test in the same population subgroup, we conducted meta-analyses of test performance using a binomial-bivariate normal random effects model. Results from these analyses are presented as summary sensitivity and specificity estimates, and corresponding positive and likelihood ratios (with 95% central CrIs).^a^

a To aid in the interpretation of likelihood ratios we remind readers that these statistics can be used to convert pre-test probabilities to post-test probabilities. For example, before testing, assume that a patient has probability of disease pre-test p = 0.1 and p r e - t e s t o d d s = (p r e - t e s t p)/(1 - p r e - t e s t p) = (0.1)/(0.9) = 0.11 . If the diagnostic test has a positive likelihood ratio (LR^+^) of 15 then the post-test odds are post-test odds = pre-test odds × LR^+^ = 0.11×15 = 1.67. This corresponds to a post-test probability of p o s t - t e s t p = (p o s t - t e s t o d d s)/(p o s t - t e s t o d d s + 1) = (1.67)/(1.67 + 1) = 0.625 (i.e. the post-test probability is approximately 6 times greater than the pre-test value). If the test results had been negative and the test had a negative likelihood ratio (LR^−^) of 0.1, the post-tests odds would be post-test odds = pre-test odds × LR^−^ = 0.11 × 0.1 = 0.011, which corresponds to p o s t - t e s t p = (0.011)/(0.011 + 1) = 0.011 (i.e., the post-test probability is approximately 10 times lower than the pre-test value). As a rule of thumb, LR^+^ > 10 and LR^−^ < 0.1 are generally considered clinically meaningful.

### Test Performance of Clinical Symptoms and Signs (in Isolation)

One hundred and thirty seven studies, published between 1976 and 2014, provided information on the performance of clinical symptoms and signs for the diagnosis of acute appendicitis. Commonly examined symptoms included right lower quadrant abdominal pain, anorexia, nausea and vomiting, and fever. Commonly examined signs included guarding, tenderness (including rebound tenderness), rigidity, and other signs indicative of peritoneal inflammation. Table 1 presents a summary of the descriptive characteristics of the studies. Table 2 presents a summary of items related to study risk of bias. Studies were at moderate to high risk of bias. Blinding of index test and reference standard assessors were either not used or relevant information was not reported; the definition of a positive index test was often not provided; and most studies had differential verification. Table 3 presents a summary of the test performance results for clinical symptoms and signs. In general, their performance was limited. Almost all tests had positive likelihood ratios lower than 3 (no test had a positive likelihood ratio higher than 6) and most tests had negative likelihood ratios higher than 0.2. Figure 3 (parts 1 through 3) presents study results and summary ROC curves for selected clinical symptoms and signs. There was substantial heterogeneity in sensitivity and specificity for most tests; however, in most cases summary ROC lines appeared to fit the data relatively well (indicating that some of the heterogeneity may be due to threshold effects). Figure 4 shows the positive and negative predictive value for selected clinical symptoms and signs, over appendicitis prevalence.

Table 1 Descriptive characteristics for studies evaluating clinical symptoms and signs for the diagnosis of acute appendicitis

Patient Population | N Studies (Median N Patients/Affected/Unaffected) | Median % of Women | Median of Average Age (Yrs) | Community Setting | Ambulatory Setting | Surgical Cohort | Clinical Presentation Consistent With Appendicitis | Median % of Patients With Perforation
Adults | 21 (232/115/50) | 52.5% | 33.5 | 14.3% | 38.1% | 33.3% | 85.7% | 11.2%
Children | 40 (156/69/69) | 46.2% | 10.9 | 2.5% | 45.0% | 12.5% | 85.0% | 12.5%
Children <5yrs | 2 (136.5/98/38.5) | 43.8% | 3.8 | 0.0% | 0.0% | 100.0% | 100.0% | 35.4%
Elderly | 0 | NA | NA | NA | NA | NA | NA | NA
Women of reproductive age | 5 (105/26/45) | 100.0% | 29.7 | 20.0% | 60.0% | 20.0% | 100.0% | 26.2%
Pregnant women | 11 (37/29/14) | 100.0% | 25.0 | 18.2% | 9.1% | 81.8% | 100.0% | 13.2%
Mixed | 66 (214.5/104.5/80) | 53.3% | 26.5 | 9.1% | 33.3% | 27.3% | 80.3% | 9.7%

N = number; NA = not applicable; yrs = years

Table 2 Assessment of risk of bias for studies evaluating clinical symptoms and signs for the diagnosis of acute appendicitis

Patient Population | Consecutive or Random Sample of Patients | Study Avoided Inappropriate Exclusions | Index Test Results Interpreted Without Knowledge of Ref. Std. | Were the Positivity Criteria Prespecified? | Ref. Std. Results Interpreted Without Knowledge of Index Test | All Patients Received a Ref. Std. | All Patients Received the Same Ref. Std. | All Patients Received Pathology for a Ref. Std. | All Patients Included in the Analysis
Adults | 42.9% | 0.0 | 38.1% | 23.8% | 14.3% | 95.2% | 47.6% | 47.6% | 76.2%
Children | 50.0% | 100.0 | 57.5% | 27.5% | 7.5% | 85.0% | 25.0% | 20.0% | 85.0%
Children <5yrs | 100.0% | 50.0 | 50.0% | 0.0% | 0.0% | 100.0% | 100.0% | 100.0% | 100.0%
Women of reproductive age | 40.0% | 100.0 | 80.0% | 40.0% | 0.0% | 100.0% | 40.0% | 40.0% | 100.0%
Pregnant women | 81.8% | 100.0 | 27.3% | 9.1% | 0.0% | 100.0% | 90.9% | 90.9% | 90.9%
Mixed | 51.5% | 100.0 | 57.6% | 28.8% | 16.7% | 97.0% | 37.9% | 31.8% | 75.8%

N = number; ref. std. = reference standard; yrs = years

Table 3 Summary estimates of test performance of clinical symptoms and signs for the diagnosis of acute appendicitis

Test | Population | N Studies [Affected/Unaffected] | Sensitivity | Specificity | LR+ | LR−
Anorexia | Adults | 12 [1655/1553] | 0.62 (0.50 to 0.73) | 0.51 (0.34 to 0.67) | 1.26 (0.94 to 1.78) | 0.75 (0.53 to 1.10)
Anorexia | Children | 15 [2171/3891] | 0.72 (0.58 to 0.83) | 0.51 (0.40 to 0.62) | 1.47 (1.15 to 1.88) | 0.54 (0.34 to 0.82)
Anorexia | Children <5yrs | 1 [155/28] | 0.68 | 0.50 | 1.35 | 0.65
Anorexia | Women of reproductive age | 1 [17/27] | 0.71 | 0.48 | 1.36 | 0.61
Anorexia | Pregnant women | 6 [181/117] | 0.50 (0.20 to 0.80) | 0.67 (0.41 to 0.87) | 1.50 (0.63 to 3.39) | 0.75 (0.34 to 1.28)
Anorexia | Mixed | 23 [4266/4936] | 0.70 (0.59 to 0.79) | 0.54 (0.40 to 0.67) | 1.49 (1.22 to 1.93) | 0.57 (0.44 to 0.72)
Constipation | Adults | 2 [295/461] | 0.14 (0.11 to 0.18) | 0.90 (0.89 to 0.91) | 1.41 (1.22 to 1.59) | 0.95 (0.93 to 0.98)
Constipation | Children | 2 [165/57] | 0.11 (0.02 to 0.19) | 0.54 (0.23 to 0.84) | 0.62 (0.03 to 1.21) | 2.60 (0.96 to 4.23)
Constipation | Pregnant women | 2 [83/37] | 0.04 (0.03 to 0.04) | 0.95 (0.90 to 1.00) | 0.37 (0.37 to 0.37) | 1.02 (0.97 to 1.07)
Constipation | Mixed | 6 [2229/3155] | 0.12 (0.04 to 0.32) | 0.85 (0.63 to 0.96) | 0.83 (0.34 to 2.59) | 1.03 (0.86 to 1.25)
Diarrhea | Adults | 5 [570/969] | 0.07 (0.01 to 0.32) | 0.82 (0.55 to 0.94) | 0.41 (0.07 to 1.55) | 1.12 (0.90 to 1.56)
Diarrhea | Children | 10 [1963/1558] | 0.22 (0.11 to 0.41) | 0.77 (0.51 to 0.92) | 0.97 (0.42 to 2.43) | 1.01 (0.79 to 1.44)
Diarrhea | Children <5yrs | 2 [196/77] | 0.13 (0.10 to 0.15) | 0.88 (0.86 to 0.90) | 1.02 (0.96 to 1.08) | 1.00 (0.99 to 1.00)
Diarrhea | Pregnant women | 5 [153/79] | 0.11 (0.02 to 0.35) | 0.93 (0.77 to 0.99) | 1.67 (0.28 to 13.34) | 0.95 (0.74 to 1.14)
Diarrhea | Mixed | 10 [3070/4119] | 0.16 (0.06 to 0.37) | 0.85 (0.65 to 0.95) | 1.07 (0.70 to 1.76) | 0.99 (0.88 to 1.08)
Fever | Adults | 15 [2082/1796] | 0.46 (0.29 to 0.64) | 0.63 (0.47 to 0.77) | 1.26 (0.83 to 1.93) | 0.85 (0.61 to 1.14)
Fever | Children | 22 [3952/3845] | 0.51 (0.41 to 0.61) | 0.72 (0.66 to 0.77) | 1.82 (1.37 to 2.37) | 0.68 (0.54 to 0.83)
Fever | Children <5yrs | 2 [196/77] | 0.88 (0.83 to 0.93) | 0.34 (0.29 to 0.39) | 1.35 (1.16 to 1.53) | 0.39 (0.18 to 0.60)
Fever | Women of reproductive age | 2 [37/36] | 0.36 (0.20 to 0.53) | 0.94 (0.89 to 1.00) | 4.76 (4.76 to 4.76) | 0.66 (0.53 to 0.80)
Fever | Pregnant women | 10 [309/166] | 0.33 (0.14 to 0.59) | 0.65 (0.37 to 0.86) | 0.96 (0.46 to 1.86) | 1.02 (0.73 to 1.58)
Fever | Mixed | 33 [8766/5386] | 0.50 (0.39 to 0.61) | 0.72 (0.62 to 0.80) | 1.76 (1.45 to 2.22) | 0.70 (0.59 to 0.80)
Guarding | Adults | 5 [771/1158] | 0.67 (0.36 to 0.89) | 0.69 (0.43 to 0.87) | 2.14 (1.10 to 4.49) | 0.48 (0.18 to 0.93)
Guarding | Children | 8 [870/1554] | 0.64 (0.49 to 0.77) | 0.69 (0.54 to 0.81) | 2.07 (1.46 to 3.14) | 0.52 (0.36 to 0.70)
Guarding | Women of reproductive age | 1 [17/27] | 0.76 | 0.85 | 5.16 | 0.28
Guarding | Pregnant women | 4 [144/103] | 0.63 (0.14 to 0.76) | 0.55 (0.43 to 0.74) | 1.34 (0.32 to 2.44) | 0.63 (0.50 to 1.53)
Guarding | Mixed | 18 [3151/4231] | 0.63 (0.47 to 0.78) | 0.69 (0.53 to 0.81) | 2.03 (1.50 to 2.89) | 0.53 (0.37 to 0.71)
Nausea | Adults | 5 [406/790] | 0.57 (0.32 to 0.77) | 0.62 (0.47 to 0.75) | 1.46 (0.81 to 2.39) | 0.71 (0.37 to 1.15)
Nausea | Children | 7 [652/1783] | 0.70 (0.49 to 0.84) | 0.43 (0.22 to 0.68) | 1.23 (0.85 to 2.05) | 0.70 (0.37 to 1.38)
Nausea | Children <5yrs | 1 [155/28] | 0.75 | 0.61 | 1.90 | 0.41
Nausea | Pregnant women | 8 [281/190] | 0.83 (0.69 to 0.93) | 0.33 (0.20 to 0.46) | 1.23 (1.00 to 1.51) | 0.52 (0.24 to 0.99)
Nausea | Mixed | 14 [3076/4603] | 0.69 (0.53 to 0.82) | 0.50 (0.32 to 0.69) | 1.37 (1.01 to 2.07) | 0.63 (0.38 to 0.98)
Nausea or vomiting | Adults | 4 [415/115] | 0.48 (0.35 to 0.79) | 0.38 (0.00 to 0.73) | 1.07 (0.48 to 1.33) | 0.88 (0.87 to 1.24)
Nausea or vomiting | Children | 10 [1641/2252] | 0.76 (0.66 to 0.84) | 0.50 (0.33 to 0.67) | 1.51 (1.11 to 2.31) | 0.48 (0.31 to 0.81)
Nausea or vomiting | Pregnant women | 1 [21/1] | 0.52 | 1.00 | . | 0.48
Nausea or vomiting | Mixed | 9 [1545/745] | 0.66 (0.46 to 0.81) | 0.38 (0.22 to 0.56) | 1.07 (0.65 to 1.68) | 0.89 (0.40 to 2.10)
Obturator sign | Children | 3 [458/786] | 0.29 (0.17 to 0.34) | 0.90 (0.87 to 0.94) | 2.84 (2.19 to 3.52) | 0.82 (0.73 to 0.89)
Obturator sign | Pregnant women | 1 [54/30] | 0.13 | 0.73 | 0.49 | 1.19
Obturator sign | Mixed | 6 [2035/999] | 0.13 (0.04 to 0.36) | 0.84 (0.37 to 0.98) | 0.82 (0.19 to 5.21) | 1.03 (0.81 to 2.14)
Pain | Adults | 1 [54/363] | 0.87 | 0.20 | 1.09 | 0.64
Pain | Children <5yrs | 1 [155/28] | 1.00 | 0.00 | 1.00 | .
Pain | Mixed | 9 [2172/1286] | 0.93 (0.67 to 0.99) | 0.24 (0.04 to 0.67) | 1.20 (0.96 to 2.42) | 0.32 (0.06 to 1.35)
Pain cough | Children | 1 [87/13] | 0.00 | 0.15 | 0.00 | 6.50
Pain cough | Women of reproductive age | 1 [17/27] | 0.82 | 0.59 | 2.02 | 0.30
Pain cough | Mixed | 6 [1117/3621] | 0.67 (0.36 to 0.88) | 0.66 (0.35 to 0.87) | 1.93 (1.28 to 3.21) | 0.51 (0.30 to 0.77)
Pain duration | Adults | 3 [145/519] | 0.80 (0.74 to 0.93) | 0.32 (0.22 to 0.37) | 1.18 (1.17 to 1.19) | 0.61 (0.34 to 0.70)
Pain duration | Children | 5 [1312/1126] | 0.73 (0.44 to 0.90) | 0.35 (0.16 to 0.58) | 1.11 (0.72 to 1.61) | 0.79 (0.33 to 1.77)
Pain duration | Mixed | 8 [1651/3789] | 0.71 (0.49 to 0.86) | 0.44 (0.25 to 0.65) | 1.27 (0.94 to 1.81) | 0.66 (0.36 to 1.11)
Pain migration | Adults | 11 [1831/864] | 0.56 (0.45 to 0.67) | 0.65 (0.50 to 0.78) | 1.62 (1.22 to 2.27) | 0.67 (0.56 to 0.81)
Pain migration | Children | 15 [2049/3535] | 0.57 (0.39 to 0.73) | 0.74 (0.66 to 0.81) | 2.19 (1.56 to 2.94) | 0.58 (0.38 to 0.80)
Pain migration | Women of reproductive age | 1 [17/27] | 0.53 | 0.67 | 1.59 | 0.71
Pain migration | Pregnant women | 1 [42/14] | 0.57 | 0.86 | 4.00 | 0.50
Pain migration | Mixed | 23 [4475/6156] | 0.61 (0.49 to 0.71) | 0.67 (0.56 to 0.76) | 1.81 (1.37 to 2.44) | 0.59 (0.45 to 0.76)
Pain progression | Adults | 3 [451/568] | 0.70 (0.60 to 0.95) | 0.38 (0.22 to 0.88) | 1.21 (0.96 to 5.81) | 0.34 (0.24 to 1.06)
Pain progression | Children | 1 [68/371] | 0.66 | 0.65 | 1.89 | 0.52
Pain progression | Mixed | 6 [2253/4232] | 0.43 (0.14 to 0.79) | 0.72 (0.44 to 0.89) | 1.49 (0.89 to 2.32) | 0.80 (0.43 to 1.03)
Pain RLQ | Adults | 7 [551/747] | 0.87 (0.68 to 0.97) | 0.23 (0.05 to 0.62) | 1.13 (0.88 to 2.11) | 0.55 (0.15 to 2.38)
Pain RLQ | Children | 6 [1834/1123] | 0.79 (0.43 to 0.95) | 0.41 (0.15 to 0.73) | 1.30 (0.89 to 2.28) | 0.53 (0.19 to 1.23)
Pain RLQ | Pregnant women | 7 [278/156] | 0.64 (0.33 to 0.86) | 0.39 (0.14 to 0.73) | 1.05 (0.61 to 2.06) | 0.92 (0.40 to 2.30)
Pain RLQ | Mixed | 9 [1640/1649] | 0.92 (0.73 to 0.98) | 0.58 (0.20 to 0.89) | 2.18 (1.07 to 8.36) | 0.14 (0.02 to 0.77)
Pain RUQ | Adults | 1 [26/33] | 0.12 | 0.85 | 0.76 | 1.04
Pain RUQ | Pregnant women | 8 [297/165] | 0.12 (0.06 to 0.20) | 0.88 (0.70 to 0.97) | 0.99 (0.38 to 4.43) | 1.00 (0.88 to 1.23)
Pain RUQ | Mixed | 1 [234/614] | 0.06 | 0.89 | 0.51 | 1.06
PSOAS Sign | Children | 4 [501/873] | 0.31 (0.22 to 0.38) | 0.87 (0.86 to 0.92) | 2.63 (1.95 to 3.15) | 0.80 (0.70 to 0.86)
PSOAS Sign | Pregnant women | 3 [101/42] | 0.17 (0.15 to 0.62) | 0.67 (0.29 to 1.00) | 0.66 (0.44 to 0.87) | 1.28 (0.83 to 1.33)
PSOAS Sign | Mixed | 11 [2671/1893] | 0.24 (0.12 to 0.41) | 0.88 (0.61 to 0.97) | 1.94 (0.71 to 6.57) | 0.88 (0.72 to 1.15)
Rigidity | Adults | 6 [513/1217] | 0.28 (0.06 to 0.67) | 0.89 (0.58 to 0.98) | 2.38 (0.73 to 8.70) | 0.83 (0.45 to 1.08)
Rigidity | Children | 1 [68/371] | 0.04 | 0.99 | 4.09 | 0.97
Rigidity | Pregnant women | 1 [19/9] | 0.32 | 0.89 | 2.84 | 0.77
Rigidity | Mixed | 5 [1397/3677] | 0.19 (0.04 to 0.54) | 0.97 (0.88 to 1.00) | 6.70 (0.96 to 51.94) | 0.84 (0.49 to 1.00)
Rovsing sign | Children | 3 [614/1018] | 0.32 (0.30 to 0.34) | 0.84 (0.84 to 0.91) | 2.01 (1.91 to 3.94) | 0.81 (0.72 to 0.83)
Rovsing sign | Pregnant women | 4 [133/101] | 0.34 (0.31 to 0.67) | 0.74 (0.00 to 0.91) | 1.22 (0.67 to 3.70) | 0.91 (0.72 to 0.93)
Rovsing sign | Mixed | 10 [2564/2198] | 0.38 (0.21 to 0.59) | 0.84 (0.59 to 0.95) | 2.42 (1.13 to 6.51) | 0.74 (0.56 to 0.94)
Symptom duration | Adults | 3 [389/353] | 0.86 (0.84 to 1.00) | 0.35 (0.04 to 0.52) | 1.30 (1.04 to 1.79) | 0.27 (0.00 to 0.46)
Symptom duration | Children | 3 [206/321] | 0.77 (0.72 to 0.86) | 0.55 (0.41 to 0.82) | 1.58 (1.31 to 4.89) | 0.52 (0.17 to 0.56)
Symptom duration | Pregnant women | 1 [21/1] | 0.71 | 1.00 | . | 0.29
Symptom duration | Mixed | 7 [1145/1607] | 0.68 (0.42 to 0.85) | 0.43 (0.17 to 0.74) | 1.16 (0.86 to 2.05) | 0.77 (0.45 to 1.37)
Tenderness | Children | 2 [206/474] | 0.63 (0.26 to 1.00) | 0.57 (0.46 to 0.68) | 1.33 (0.80 to 1.86) | 0.55 (0.00 to 1.09)
Tenderness | Children <5yrs | 1 [155/28] | 0.98 | 0.25 | 1.31 | 0.08
Tenderness | Women of reproductive age | 1 [17/27] | 1.00 | 0.04 | 1.04 | 0.00
Tenderness | Mixed | 10 [1450/1510] | 0.99 (0.95 to 1.00) | 0.30 (0.08 to 0.67) | 1.41 (1.08 to 2.94) | 0.03 (0.00 to 0.21)
Tenderness rebound | Adults | 11 [1423/1540] | 0.67 (0.50 to 0.81) | 0.70 (0.51 to 0.83) | 2.19 (1.38 to 3.76) | 0.48 (0.29 to 0.72)
Tenderness rebound | Children | 11 [1013/1895] | 0.60 (0.43 to 0.77) | 0.73 (0.57 to 0.84) | 2.22 (1.39 to 3.44) | 0.55 (0.34 to 0.78)
Tenderness rebound | Children <5yrs | 1 [155/28] | 0.85 | 0.86 | 5.92 | 0.18
Tenderness rebound | Women of reproductive age | 1 [26/79] | 0.42 | 0.65 | 1.19 | 0.89
Tenderness rebound | Pregnant women | 5 [160/111] | 0.71 (0.36 to 0.92) | 0.58 (0.21 to 0.88) | 1.63 (0.80 to 5.50) | 0.52 (0.14 to 1.41)
Tenderness rebound | Mixed | 30 [5859/6738] | 0.74 (0.65 to 0.82) | 0.60 (0.48 to 0.72) | 1.87 (1.47 to 2.51) | 0.43 (0.31 to 0.57)
Tenderness rectal | Adults | 6 [896/1694] | 0.36 (0.10 to 0.73) | 0.83 (0.58 to 0.95) | 2.10 (0.53 to 7.55) | 0.78 (0.34 to 1.20)
Tenderness rectal | Children | 7 [443/837] | 0.42 (0.25 to 0.60) | 0.90 (0.82 to 0.95) | 4.09 (2.18 to 9.03) | 0.65 (0.45 to 0.83)
Tenderness rectal | Women of reproductive age | 1 [155/45] | 0.45 | 0.42 | 0.78 | 1.30
Tenderness rectal | Pregnant women | 2 [58/30] | 0.33 (0.21 to 0.45) | 0.48 (0.14 to 0.83) | 0.86 (0.52 to 1.19) | 2.41 (0.96 to 3.86)
Tenderness rectal | Mixed | 15 [3753/4690] | 0.33 (0.21 to 0.48) | 0.61 (0.37 to 0.81) | 0.86 (0.49 to 1.67) | 1.09 (0.80 to 1.75)
Tenderness RLQ | Adults | 7 [1077/1040] | 0.92 (0.77 to 0.98) | 0.38 (0.10 to 0.76) | 1.47 (1.02 to 3.63) | 0.21 (0.05 to 0.88)
Tenderness RLQ | Children | 14 [3506/2627] | 0.92 (0.80 to 0.97) | 0.50 (0.20 to 0.79) | 1.81 (1.15 to 4.32) | 0.17 (0.06 to 0.49)
Tenderness RLQ | Children <5yrs | 1 [41/49] | 0.93 | 0.18 | 1.14 | 0.40
Tenderness RLQ | Pregnant women | 4 [133/101] | 0.83 (0.50 to 0.97) | 0.23 (0.05 to 0.33) | 1.07 (0.63 to 1.25) | 0.67 (0.50 to 2.50)
Tenderness RLQ | Mixed | 12 [3081/2969] | 0.93 (0.80 to 0.98) | 0.16 (0.07 to 0.30) | 1.10 (1.00 to 1.24) | 0.45 (0.19 to 1.02)
Vomiting | Adults | 10 [1395/1667] | 0.46 (0.35 to 0.57) | 0.72 (0.58 to 0.83) | 1.65 (1.24 to 2.36) | 0.75 (0.65 to 0.86)
Vomiting | Children | 13 [2043/1994] | 0.66 (0.63 to 0.70) | 0.59 (0.47 to 0.70) | 1.60 (1.25 to 2.21) | 0.58 (0.47 to 0.72)
Vomiting | Children <5yrs | 2 [196/77] | 0.75 (0.63 to 0.86) | 0.54 (0.39 to 0.69) | 1.74 (1.41 to 2.07) | 0.44 (0.36 to 0.53)
Vomiting | Women of reproductive age | 1 [17/27] | 0.35 | 0.81 | 1.91 | 0.79
Vomiting | Pregnant women | 7 [223/131] | 0.68 (0.41 to 0.87) | 0.56 (0.43 to 0.68) | 1.53 (0.90 to 2.23) | 0.57 (0.23 to 1.09)
Vomiting | Mixed | 19 [4264/6045] | 0.46 (0.33 to 0.60) | 0.72 (0.64 to 0.80) | 1.67 (1.23 to 2.26) | 0.74 (0.57 to 0.90)

LR = likelihood ratio; N = number; RLQ = right lower quadrant; RUQ = right upper quadrant; yrs = years.

Sensitivity, specificity, and LR values are medians and 95% central credible intervals when 5 or more studies were available; medians and minimum to maximum values are reported when <5 studies were available; when a single study was available we report the estimate from that study.

Figure 3 Scatterplot of results in the receiver operating characteristic space and summary receiver operating characteristic curves of clinical symptoms and signs for the diagnosis of acute appendicitis

Figure 3 Scatterplot of results in the receiver operating characteristic space and summary receiver operating characteristic curves of clinical symptoms and signs for the diagnosis of acute appendicitis (part 1)

Sens. = sensitivity, spec.=specificity

This figure includes fourteen scatterplot graphs showing 1-specificity (x axis, range 0.0 to 1.0) versus sensitivity (y axis, range 0.0 to 1.0) for different clinical signs and symptoms in different populations with overlaid summary ROC curves. In general, test performance of diagnostic tests is limited (average sensitivity and specificity were relatively low).

Figure 3 Scatterplot of results in the receiver operating characteristic space and summary receiver operating characteristic curves of clinical symptoms and signs for the diagnosis of acute appendicitis (part 2)

sens.=sensitivity; spec.=specificity

This figure includes fifteen scatterplot graphs showing 1-specificity (x axis, range 0.0 to 1.0) versus sensitivity (y axis, range 0.0 to 1.0) for different clinical signs and symptoms in different populations with overlaid summary ROC curves. In general, test performance of diagnostic tests is limited (average sensitivity and specificity were relatively low).

Figure 3 Scatterplot of results in the receiver operating characteristic space and summary receiver operating characteristic curves of clinical symptoms and signs for the diagnosis of acute appendicitis (part 3)

Sens.=sensitivity; spec.=specificity; RLQ=right lower quadrant; RUQ=right upper quadrant

This figure includes twelve scatterplot graphs showing 1-specificity (x axis, range 0.0 to 1.0) versus sensitivity (y axis, range 0.0 to 1.0) for different clinical signs and symptoms in different populations with overlaid summary ROC curves. In general, test performance of diagnostic tests is limited (average sensitivity and specificity were relatively low).

Figure 4 Positive and negative predictive value curves of clinical symptoms and signs for the diagnosis of acute appendicitis

Figure 4 Positive and negative predictive value curves of clinical symptoms and signs for the diagnosis of acute appendicitis (part 1)

This figure includes fourteen scatterplots showing prevalence (x axis, range 0.0 to 1.0) versus predicted value (y axis, range 0.0 to 1.0) for different clinical signs and symptoms in different populations with overlaid summary curves. In general, these figures also show that performance was limited across symptoms and signs.

Figure 4 Positive and negative predictive value curves of clinical symptoms and signs for the diagnosis of acute appendicitis (part 2)

RLQ = right lower quadrant

This figure includes fifteen scatterplots showing prevalence (x axis, range 0.0 to 1.0) versus predicted value (y axis, range 0.0 to 1.0) for different clinical signs and symptoms in different populations with overlaid summary curves. In general, these figures also show that performance was limited across symptoms and signs.

Figure 4 Positive and negative predictive value curves of clinical symptoms and signs for the diagnosis of acute appendicitis (part 3)

RLQ = right lower quadrant; RUQ=right upper quadrant

This figure includes twelve scatterplots showing prevalence (x axis, range 0.0 to 1.0) versus predicted value (y axis, range 0.0 to 1.0) for different clinical signs and symptoms in different populations with overlaid summary curves. In general, these figures also show that performance was limited across symptoms and signs.

#### Factors That Affect the Test Performance of Clinical Symptoms and Signs

The vast majority of studies did not report adequate data to assess factors that may affect test performance (i.e., based on within study comparisons); for this reason we relied on comparisons across studies (via meta-regression analyses) to identify factors that may affect test performance. Table 4 summarizes the results of meta-regression analyses for various factors that may affect the performance of clinical signs for the diagnosis of acute appendicitis. Overall, no distinct pattern emerged to establish a particular factor as a modifier of test performance. Recent studies tended to produce lower estimates of summary sensitivity (published from 2005 onwards), often but not always associated with higher estimates of specificity. Yet, for all factors examined but CrIs were wide, indicating substantial uncertainty regarding the relative test performance of tests over levels of the modifiers we examined.

Table 4 Meta-regression results for factors that affect the performance of clinical signs and symptoms for the diagnosis of acute appendicitis

Test | Population | Subgroup | | N Studies | Sensitivity | Relative Sensitivity | Specificity | Relative Specificity
Anorexia | Adults | Study year | <2005 | 5 | 0.76 (0.66 to 0.85) | 1.24 (0.63 to 2.42) | 0.46 (0.22 to 0.69) | 1.42 (0.43 to 5.29)
Anorexia | Adults | Study year | >=2005 | 7 | 0.51 (0.40 to 0.62) | | 0.55 (0.34 to 0.74)
Anorexia | Adults | Ambulatory setting | no | 7 | 0.59 (0.43 to 0.75) | 1.82 (1.01 to 3.21) | 0.50 (0.26 to 0.72) | 1.01 (0.25 to 4.58)
Anorexia | Adults | Ambulatory setting | yes | 5 | 0.66 (0.46 to 0.82) | | 0.51 (0.26 to 0.76)
Anorexia | Adults | Surgical cohorts | no | 7 | 0.60 (0.43 to 0.76) | 1.57 (0.85 to 2.92) | 0.52 (0.30 to 0.73) | 0.89 (0.19 to 3.55)
Anorexia | Adults | Surgical cohorts | yes | 5 | 0.64 (0.45 to 0.81) | | 0.49 (0.22 to 0.74)
Anorexia | Children | Ambulatory setting | no | 6 | 0.70 (0.45 to 0.87) | 1.49 (0.59 to 3.82) | 0.46 (0.31 to 0.63) | 1.40 (0.57 to 2.96)
Anorexia | Children | Ambulatory setting | yes | 9 | 0.74 (0.55 to 0.87) | | 0.54 (0.40 to 0.66)
Anorexia | Mixed | Study year | <2005 | 14 | 0.73 (0.62 to 0.82) | 1.60 (0.86 to 2.91) | 0.45 (0.29 to 0.62) | 1.82 (0.59 to 5.77)
Anorexia | Mixed | Study year | >=2005 | 8 | 0.70 (0.56 to 0.82) | | 0.60 (0.38 to 0.79)
Anorexia | Mixed | Ambulatory setting | no | 11 | 0.75 (0.64 to 0.84) | 0.64 (0.36 to 1.15) | 0.53 (0.36 to 0.72) | 0.84 (0.25 to 2.09)
Anorexia | Mixed | Ambulatory setting | yes | 11 | 0.68 (0.56 to 0.79) | | 0.48 (0.29 to 0.65)
Anorexia | Mixed | Surgical cohorts | no | 17 | 0.70 (0.60 to 0.79) | 1.11 (0.46 to 2.65) | 0.55 (0.41 to 0.69) | 0.43 (0.12 to 1.26)
Anorexia | Mixed | Surgical cohorts | yes | 5 | 0.79 (0.64 to 0.89) | | 0.35 (0.16 to 0.58)
Anorexia | Mixed | Appendicitis presentation | atypical/other/unclear | 7 | 0.71 (0.55 to 0.85) | 1.57 (0.66 to 3.47) | 0.52 (0.26 to 0.74) | 0.90 (0.28 to 3.64)
Anorexia | Mixed | Appendicitis presentation | typical | 15 | 0.73 (0.61 to 0.81) | | 0.50 (0.34 to 0.66)
Fever | Adults | Study year | <2005 | 7 | 0.58 (0.35 to 0.78) | 1.67 (0.62 to 4.53) | 0.53 (0.30 to 0.76) | 2.24 (0.55 to 7.95)
Fever | Adults | Study year | >=2005 | 8 | 0.36 (0.18 to 0.58) | | 0.72 (0.50 to 0.86)
Fever | Adults | Ambulatory setting | no | 10 | 0.45 (0.24 to 0.66) | 3.22 (1.11 to 10.10) | 0.58 (0.35 to 0.77) | 1.82 (0.35 to 10.55)
Fever | Adults | Ambulatory setting | yes | 5 | 0.49 (0.21 to 0.78) | | 0.72 (0.42 to 0.91)
Fever | Adults | Surgical cohorts | no | 8 | 0.43 (0.22 to 0.67) | 2.11 (0.74 to 6.49) | 0.68 (0.46 to 0.84) | 0.60 (0.15 to 2.35)
Fever | Adults | Surgical cohorts | yes | 7 | 0.50 (0.26 to 0.74) | | 0.57 (0.32 to 0.79)
Fever | Children | Study year | <2005 | 7 | 0.65 (0.51 to 0.78) | 3.53 (1.10 to 12.07) | 0.74 (0.63 to 0.82) | 0.86 (0.47 to 1.54)
Fever | Children | Study year | >=2005 | 15 | 0.44 (0.34 to 0.55) | | 0.71 (0.63 to 0.77)
Fever | Children | Ambulatory setting | no | 10 | 0.48 (0.34 to 0.63) | 3.13 (1.16 to 9.34) | 0.68 (0.60 to 0.76) | 1.37 (0.81 to 2.21)
Fever | Children | Ambulatory setting | yes | 12 | 0.54 (0.40 to 0.67) | | 0.75 (0.67 to 0.80)
Fever | Mixed | Study year | <2005 | 24 | 0.54 (0.41 to 0.68) | 0.75 (0.26 to 2.19) | 0.66 (0.53 to 0.77) | 2.92 (1.03 to 9.42)
Fever | Mixed | Study year | >=2005 | 8 | 0.40 (0.20 to 0.64) | | 0.85 (0.70 to 0.94)
Fever | Mixed | Ambulatory setting | no | 22 | 0.47 (0.34 to 0.60) | 0.15 (0.01 to 2.91) | 0.72 (0.60 to 0.83) | 0.85 (0.29 to 2.21)
Fever | Mixed | Ambulatory setting | yes | 10 | 0.59 (0.39 to 0.76) | | 0.69 (0.48 to 0.84)
Fever | Mixed | Surgical cohorts | no | 24 | 0.56 (0.43 to 0.69) | 0.18 (0.01 to 3.78) | 0.70 (0.56 to 0.81) | 1.44 (0.42 to 4.19)
Fever | Mixed | Surgical cohorts | yes | 8 | 0.35 (0.19 to 0.58) | | 0.77 (0.54 to 0.90)
Guarding | Mixed | Ambulatory setting | no | 12 | 0.66 (0.45 to 0.82) | 0.24 (0.01 to 4.82) | 0.66 (0.47 to 0.82) | 1.57 (0.34 to 4.91)
Guarding | Mixed | Ambulatory setting | yes | 6 | 0.58 (0.30 to 0.83) | | 0.75 (0.46 to 0.89)
Guarding | Mixed | Surgical cohort | no | 13 | 0.65 (0.44 to 0.81) | 3.21 (0.13 to 73.13) | 0.70 (0.51 to 0.84) | 0.86 (0.16 to 3.75)
Guarding | Mixed | Surgical cohort | yes | 5 | 0.61 (0.30 to 0.86) | | 0.66 (0.33 to 0.87)
Nausea | Mixed | Study year | <2005 | 5 | 0.70 (0.41 to 0.89) | 1.12 (0.68 to 1.90) | 0.40 (0.16 to 0.67) | 1.89 (0.56 to 9.28)
Nausea | Mixed | Study year | >=2005 | 9 | 0.68 (0.47 to 0.84) | | 0.56 (0.35 to 0.77)
Nausea | Mixed | Appendicitis presentation | atypical/other/unclear | 5 | 0.74 (0.48 to 0.90) | 1.23 (0.67 to 2.25) | 0.38 (0.14 to 0.67) | 2.17 (0.50 to 14.78)
Nausea | Mixed | Appendicitis presentation | typical | 9 | 0.66 (0.45 to 0.83) | | 0.57 (0.35 to 0.79)
Nausea or vomiting | Children | Ambulatory setting | no | 5 | 0.74 (0.57 to 0.86) | 1.49 (0.89 to 2.59) | 0.46 (0.22 to 0.73) | 1.39 (0.25 to 6.35)
Nausea or vomiting | Children | Ambulatory setting | yes | 5 | 0.78 (0.63 to 0.88) | | 0.54 (0.27 to 0.77)
Pain migration | Children | Ambulatory setting | no | 6 | 0.53 (0.38 to 0.69) | 0.68 (0.31 to 1.49) | 0.67 (0.44 to 0.83) | 0.90 (0.24 to 3.44)
Pain migration | Children | Ambulatory setting | yes | 5 | 0.60 (0.43 to 0.74) | | 0.64 (0.39 to 0.83)
Pain migration | Mixed | Study year | no | 6 | 0.42 (0.19 to 0.69) | 0.99 (0.51 to 1.91) | 0.78 (0.67 to 0.87) | 0.70 (0.31 to 1.41)
Pain migration | Mixed | Study year | yes | 9 | 0.66 (0.45 to 0.83) | | 0.71 (0.61 to 0.80)
Pain migration | Mixed | Ambulatory setting | <2005 | 15 | 0.62 (0.48 to 0.74) | 1.42 (0.81 to 2.59) | 0.71 (0.60 to 0.80) | 0.44 (0.19 to 0.92)
Pain migration | Mixed | Ambulatory setting | >=2005 | 7 | 0.61 (0.40 to 0.79) | | 0.52 (0.34 to 0.67)
Psoas sign | Mixed | Study year | no | 9 | 0.67 (0.50 to 0.80) | 1.41 (0.80 to 2.47) | 0.57 (0.41 to 0.72) | 1.84 (0.72 to 4.17)
Psoas sign | Mixed | Study year | yes | 13 | 0.58 (0.43 to 0.72) | | 0.70 (0.57 to 0.80)
Psoas sign | Mixed | Ambulatory setting | <2005 | 6 | 0.22 (0.09 to 0.47) | 0.99 (0.54 to 1.85) | 0.90 (0.55 to 0.99) | 0.59 (0.03 to 9.40)
Psoas sign | Mixed | Ambulatory setting | >=2005 | 5 | 0.25 (0.10 to 0.52) | | 0.84 (0.37 to 0.98)
Tenderness rebound | Adults | Study year | no | 6 | 0.19 (0.07 to 0.41) | 1.18 (0.64 to 2.19) | 0.93 (0.66 to 0.99) | 0.28 (0.02 to 3.36)
Tenderness rebound | Adults | Study year | yes | 5 | 0.30 (0.11 to 0.60) | | 0.78 (0.30 to 0.97)
Tenderness rebound | Adults | Ambulatory setting | <2005 | 5 | 0.72 (0.47 to 0.88) | 0.83 (0.31 to 2.13) | 0.73 (0.48 to 0.89) | 0.70 (0.18 to 2.79)
Tenderness rebound | Adults | Ambulatory setting | >=2005 | 6 | 0.62 (0.39 to 0.82) | | 0.66 (0.41 to 0.85)
Tenderness rebound | Children | Ambulatory setting | no | 6 | 0.63 (0.40 to 0.82) | 0.38 (0.17 to 0.88) | 0.65 (0.39 to 0.84) | 1.54 (0.37 to 7.00)
Tenderness rebound | Children | Ambulatory setting | yes | 5 | 0.72 (0.46 to 0.88) | | 0.74 (0.48 to 0.90)
Tenderness rebound | Mixed | Study year | no | 6 | 0.52 (0.32 to 0.74) | 0.99 (0.38 to 2.77) | 0.70 (0.48 to 0.85) | 1.29 (0.36 to 4.66)
Tenderness rebound | Mixed | Study year | yes | 5 | 0.68 (0.45 to 0.85) | | 0.75 (0.51 to 0.89)
Tenderness rebound | Mixed | Ambulatory setting | <2005 | 21 | 0.74 (0.62 to 0.83) | 1.93 (0.78 to 5.59) | 0.61 (0.46 to 0.74) | 0.86 (0.33 to 2.87)
Tenderness rebound | Mixed | Ambulatory setting | >=2005 | 9 | 0.75 (0.57 to 0.88) | | 0.58 (0.37 to 0.79)
Tenderness rebound | Mixed | Surgical cohorts | no | 18 | 0.73 (0.59 to 0.83) | 1.13 (0.62 to 2.20) | 0.59 (0.42 to 0.73) | 1.21 (0.43 to 3.36)
Tenderness rebound | Mixed | Surgical cohorts | yes | 12 | 0.77 (0.62 to 0.88) | | 0.63 (0.43 to 0.79)
Tenderness rebound | Mixed | Appendicitis presentation | no | 20 | 0.77 (0.66 to 0.85) | 1.11 (0.59 to 2.09) | 0.64 (0.50 to 0.76) | 0.59 (0.23 to 1.48)
Tenderness rebound | Mixed | Appendicitis presentation | yes | 10 | 0.69 (0.52 to 0.82) | | 0.51 (0.32 to 0.70)
Tenderness rectal | Mixed | Surgical cohorts | atypical/other/unclear | 7 | 0.64 (0.43 to 0.83) | 1.02 (0.44 to 2.50) | 0.71 (0.46 to 0.86) | 0.53 (0.18 to 1.84)
Tenderness rectal | Mixed | Surgical cohorts | typical | 23 | 0.77 (0.67 to 0.85) | | 0.57 (0.43 to 0.70)
Tenderness RLQ | Children | Ambulatory setting | no | 10 | 0.29 (0.17 to 0.46) | 0.33 (0.14 to 0.87) | 0.65 (0.34 to 0.86) | 0.63 (0.09 to 4.96)
Tenderness RLQ | Children | Ambulatory setting | yes | 5 | 0.42 (0.21 to 0.64) | | 0.53 (0.17 to 0.86)
Tenderness RLQ | Mixed | Ambulatory setting | no | 7 | 0.85 (0.59 to 0.96) | 1.19 (0.68 to 1.97) | 0.40 (0.11 to 0.82) | 2.32 (0.15 to 18.40)
Tenderness RLQ | Mixed | Ambulatory setting | yes | 7 | 0.96 (0.85 to 0.99) | | 0.59 (0.17 to 0.90)

N = number; RLQ = right lower quadrant; RUQ = right upper quadrant

Sensitivity, relative sensitivity, specificity, and relative specificity values are medians and 95% central credible intervals when 5 or more studies were available; medians and minimum to maximum values are reported when <5 studies were available; when a single study was available we report the estimate from that study.

#### Impact of Risk of Bias Items on Estimated Test Performance of Clinical Symptoms and Signs

Table 5 summarizes the results of meta-regression analyses for various factors that may affect the performance of clinical symptoms and signs tests for the diagnosis of acute appendicitis. In some cases items related to study risk of bias appeared to be associated with worse test performance of various clinical symptoms and signs. Specifically, nondifferential verification was associated with lower sensitivity in studies of fever in mixed populations; blinding of reference standard assessors was associated with lower specificity in studies of pain migration in mixed populations; complete verification was associated with lower sensitivity in studies of rebound tenderness in mixed populations; and blinding of index test assessors was associated with lower sensitivity in studies of rebound tenderness in mixed populations.

Table 5 Meta-regression results for the impact of risk of bias items on the estimated test performance of clinical signs and symptoms for the diagnosis of acute appendicitis

Test | Population | Subgroup | | N Studies | Sensitivity | Relative Sensitivity | Specificity | Relative Specificity
Anorexia | Adults | All pts. received same ref. std. | no | 6 | 0.60 (0.40 to 0.76) | 1.14 (0.40 to 3.59) | 0.52 (0.30 to 0.76) | 0.91 (0.16 to 3.14)
Anorexia | Adults | All pts. received same ref. std. | yes | 6 | 0.64 (0.46 to 0.80) | | 0.49 (0.22 to 0.72)
Anorexia | Adults | Pathology (100%) | no | 6 | 0.60 (0.40 to 0.76) | 1.14 (0.40 to 3.59) | 0.52 (0.30 to 0.76) | 0.91 (0.16 to 3.14)
Anorexia | Adults | Pathology (100%) | yes | 6 | 0.64 (0.46 to 0.80) | | 0.49 (0.22 to 0.72)
Anorexia | Adults | Consecutive/random sample | no | 5 | 0.55 (0.36 to 0.74) | 1.66 (0.55 to 4.64) | 0.56 (0.29 to 0.79) | 0.69 (0.17 to 3.04)
Anorexia | Adults | Consecutive/random sample | yes | 7 | 0.67 (0.51 to 0.80) | | 0.47 (0.24 to 0.70)
Anorexia | Adults | Blinding index tests | no | 6 | 0.69 (0.53 to 0.82) | 0.55 (0.20 to 1.44) | 0.45 (0.22 to 0.70) | 1.63 (0.33 to 6.06)
Anorexia | Adults | Blinding index tests | yes | 6 | 0.54 (0.37 to 0.71) | | 0.56 (0.30 to 0.77)
Anorexia | Children | Consecutive/random sample | no | 9 | 0.72 (0.53 to 0.86) | 1.03 (0.27 to 3.90) | 0.49 (0.35 to 0.63) | 1.31 (0.47 to 3.36)
Anorexia | Children | Consecutive/random sample | yes | 6 | 0.73 (0.49 to 0.88) | | 0.55 (0.36 to 0.72)
Anorexia | Children | Blinding index tests | no | 6 | 0.63 (0.38 to 0.81) | 2.00 (0.64 to 8.29) | 0.61 (0.46 to 0.75) | 0.52 (0.20 to 1.12)
Anorexia | Children | Blinding index tests | yes | 9 | 0.77 (0.61 to 0.89) | | 0.45 (0.32 to 0.57)
Anorexia | Mixed | All pts. received same ref. std. | no | 17 | 0.71 (0.60 to 0.80) | 1.34 (0.53 to 3.48) | 0.53 (0.38 to 0.67) | 0.67 (0.19 to 2.16)
Anorexia | Mixed | All pts. received same ref. std. | yes | 5 | 0.76 (0.59 to 0.88) | | 0.43 (0.20 to 0.69)
Anorexia | Mixed | Pathology (100%) | no | 17 | 0.71 (0.60 to 0.80) | 1.34 (0.53 to 3.48) | 0.53 (0.38 to 0.67) | 0.67 (0.19 to 2.16)
Anorexia | Mixed | Pathology (100%) | yes | 5 | 0.76 (0.59 to 0.88) | | 0.43 (0.20 to 0.69)
Anorexia | Mixed | Consecutive/random sample | no | 11 | 0.69 (0.56 to 0.80) | 1.36 (0.61 to 3.26) | 0.49 (0.31 to 0.67) | 1.17 (0.37 to 3.19)
Anorexia | Mixed | Consecutive/random sample | yes | 11 | 0.75 (0.63 to 0.85) | | 0.53 (0.33 to 0.70)
Anorexia | Mixed | Blinding index tests | no | 7 | 0.78 (0.64 to 0.88) | 0.62 (0.26 to 1.37) | 0.49 (0.27 to 0.70) | 1.09 (0.40 to 3.39)
Anorexia | Mixed | Blinding index tests | yes | 15 | 0.69 (0.58 to 0.78) | | 0.51 (0.36 to 0.67)
Fever | Adults | All pts. received same ref. std. | no | 6 | 0.43 (0.19 to 0.71) | 1.23 (0.28 to 5.13) | 0.71 (0.47 to 0.87) | 0.54 (0.14 to 2.03)
Fever | Adults | All pts. received same ref. std. | yes | 9 | 0.48 (0.26 to 0.70) | | 0.57 (0.35 to 0.76)
Fever | Adults | Pathology (100%) | no | 6 | 0.43 (0.19 to 0.71) | 1.23 (0.28 to 5.13) | 0.71 (0.47 to 0.87) | 0.54 (0.14 to 2.03)
Fever | Adults | Pathology (100%) | yes | 9 | 0.48 (0.26 to 0.70) | | 0.57 (0.35 to 0.76)
Fever | Adults | Consecutive/random sample | no | 7 | 0.44 (0.21 to 0.68) | 1.21 (0.31 to 5.09) | 0.69 (0.47 to 0.85) | 0.61 (0.17 to 1.99)
Fever | Adults | Consecutive/random sample | yes | 8 | 0.48 (0.26 to 0.72) | | 0.58 (0.36 to 0.77)
Fever | Adults | Blinding index tests | no | 9 | 0.43 (0.23 to 0.66) | 1.32 (0.31 to 5.82) | 0.65 (0.43 to 0.82) | 0.86 (0.23 to 3.15)
Fever | Adults | Blinding index tests | yes | 6 | 0.50 (0.24 to 0.77) | | 0.61 (0.35 to 0.82)
Fever | Children | Pre-specified positivity criteria | no | 15 | 0.49 (0.37 to 0.61) | 1.25 (0.53 to 3.05) | 0.74 (0.67 to 0.79) | 0.71 (0.41 to 1.25)
Fever | Children | Pre-specified positivity criteria | yes | 7 | 0.55 (0.38 to 0.71) | | 0.67 (0.56 to 0.76)
Fever | Children | All pts. received same ref. std. | no | 16 | 0.49 (0.38 to 0.61) | 1.26 (0.57 to 2.87) | 0.73 (0.66 to 0.78) | 0.87 (0.47 to 1.67)
Fever | Children | All pts. received same ref. std. | yes | 6 | 0.55 (0.38 to 0.72) | | 0.70 (0.58 to 0.80)
Fever | Children | Pathology (100%) | no | 17 | 0.51 (0.40 to 0.63) | 1.00 (0.30 to 2.51) | 0.73 (0.66 to 0.79) | 0.77 (0.40 to 1.54)
Fever | Children | Pathology (100%) | yes | 5 | 0.51 (0.28 to 0.70) | | 0.68 (0.53 to 0.79)
Fever | Children | Consecutive/random sample | no | 14 | 0.44 (0.34 to 0.56) | 2.08 (1.00 to 4.35) | 0.71 (0.63 to 0.77) | 1.20 (0.68 to 2.06)
Fever | Children | Consecutive/random sample | yes | 8 | 0.62 (0.48 to 0.75) | | 0.74 (0.64 to 0.82)
Fever | Children | Blinding index tests | no | 8 | 0.57 (0.42 to 0.72) | 0.66 (0.29 to 1.43) | 0.72 (0.62 to 0.80) | 1.02 (0.55 to 1.79)
Fever | Children | Blinding index tests | yes | 14 | 0.47 (0.35 to 0.59) | | 0.72 (0.64 to 0.78)
Fever | Mixed | Pre-specified positivity criteria | no | 24 | 0.52 (0.38 to 0.65) | 0.83 (0.30 to 2.31) | 0.68 (0.55 to 0.79) | 2.12 (0.71 to 6.33)
Fever | Mixed | Pre-specified positivity criteria | yes | 8 | 0.47 (0.27 to 0.69) | | 0.82 (0.64 to 0.92)
Fever | Mixed | Blinding ref. std. to index test results | no | 27 | 0.49 (0.36 to 0.62) | 1.62 (0.48 to 5.67) | 0.73 (0.62 to 0.82) | 0.54 (0.16 to 1.98)
Fever | Mixed | Blinding ref. std. to index test results | yes | 5 | 0.61 (0.34 to 0.83) | | 0.60 (0.33 to 0.83)
Fever | Mixed | All pts. received same ref. std. | no | 23 | 0.55 (0.42 to 0.68) | 0.53 (0.21 to 1.45) | 0.68 (0.55 to 0.79) | 1.72 (0.60 to 5.31)
Fever | Mixed | All pts. received same ref. std. | yes | 9 | 0.39 (0.22 to 0.61) | | 0.79 (0.60 to 0.91)
Fever | Mixed | All pts. included in the analysis | no | 5 | 0.58 (0.31 to 0.80) | 0.69 (0.23 to 2.30) | 0.70 (0.43 to 0.89) | 1.09 (0.29 to 3.69)
Fever | Mixed | All pts. included in the analysis | yes | 27 | 0.49 (0.37 to 0.62) | | 0.72 (0.60 to 0.81)
Fever | Mixed | Pathology (100%) | no | 24 | 0.58 (0.45 to 0.69) | 0.32 (0.12 to 0.86) | 0.68 (0.55 to 0.78) | 1.95 (0.72 to 5.51)
Fever | Mixed | Pathology (100%) | yes | 8 | 0.31 (0.16 to 0.51) | | 0.80 (0.63 to 0.91)
Fever | Mixed | Consecutive/random sample | no | 13 | 0.55 (0.37 to 0.73) | 0.73 (0.27 to 1.83) | 0.71 (0.51 to 0.84) | 1.06 (0.41 to 3.25)
Fever | Mixed | Consecutive/random sample | yes | 19 | 0.48 (0.33 to 0.62) | | 0.72 (0.58 to 0.83)
Fever | Mixed | Blinding index tests | no | 13 | 0.55 (0.38 to 0.74) | 0.74 (0.24 to 1.80) | 0.68 (0.50 to 0.82) | 1.27 (0.49 to 3.65)
Fever | Mixed | Blinding index tests | yes | 19 | 0.47 (0.32 to 0.63) | | 0.73 (0.59 to 0.84)
Guarding | Mixed | Pre-specified positivity criteria | no | 13 | 0.59 (0.40 to 0.76) | 2.01 (0.47 to 8.32) | 0.73 (0.55 to 0.85) | 0.50 (0.13 to 2.10)
Guarding | Mixed | Pre-specified positivity criteria | yes | 5 | 0.74 (0.45 to 0.91) | | 0.58 (0.30 to 0.82)
Guarding | Mixed | All pts. received same ref. std. | no | 13 | 0.59 (0.38 to 0.76) | 1.99 (0.44 to 10.39) | 0.71 (0.52 to 0.84) | 0.76 (0.16 to 3.37)
Guarding | Mixed | All pts. received same ref. std. | yes | 5 | 0.74 (0.44 to 0.92) | | 0.65 (0.33 to 0.87)
Guarding | Mixed | Consecutive/random sample | no | 9 | 0.64 (0.39 to 0.84) | 0.95 (0.18 to 3.86) | 0.72 (0.49 to 0.87) | 0.69 (0.18 to 3.05)
Guarding | Mixed | Consecutive/random sample | yes | 9 | 0.63 (0.37 to 0.83) | | 0.65 (0.40 to 0.83)
Guarding | Mixed | Blinding index tests | no | 7 | 0.68 (0.43 to 0.88) | 0.72 (0.16 to 2.43) | 0.65 (0.39 to 0.84) | 1.42 (0.37 to 5.19)
Guarding | Mixed | Blinding index tests | yes | 11 | 0.60 (0.38 to 0.79) | | 0.72 (0.51 to 0.86)
Nausea | Mixed | Consecutive/random sample | no | 6 | 0.74 (0.51 to 0.89) | 0.63 (0.15 to 2.42) | 0.36 (0.18 to 0.60) | 2.71 (0.83 to 9.40)
Nausea | Mixed | Consecutive/random sample | yes | 8 | 0.65 (0.42 to 0.82) | | 0.61 (0.40 to 0.79)
Nausea or vomiting | Children | Blinding index tests | no | 5 | 0.76 (0.62 to 0.87) | 0.95 (0.36 to 2.49) | 0.57 (0.34 to 0.77) | 0.56 (0.18 to 1.96)
Nausea or vomiting | Children | Blinding index tests | yes | 5 | 0.76 (0.60 to 0.86) | | 0.43 (0.23 to 0.66)
Pain migration | Adults | All pts. received same ref. std. | no | 5 | 0.56 (0.39 to 0.72) | 0.98 (0.38 to 2.36) | 0.65 (0.41 to 0.83) | 1.04 (0.29 to 4.17)
Pain migration | Adults | All pts. received same ref. std. | yes | 6 | 0.56 (0.40 to 0.70) | | 0.66 (0.43 to 0.83)
Pain migration | Adults | Pathology (100%) | no | 5 | 0.56 (0.39 to 0.72) | 0.98 (0.38 to 2.36) | 0.65 (0.41 to 0.83) | 1.04 (0.29 to 4.17)
Pain migration | Adults | Pathology (100%) | yes | 6 | 0.56 (0.40 to 0.70) | | 0.66 (0.43 to 0.83)
Pain migration | Adults | Consecutive/random sample | no | 6 | 0.60 (0.46 to 0.74) | 0.70 (0.29 to 1.69) | 0.62 (0.40 to 0.79) | 1.40 (0.44 to 4.71)
Pain migration | Adults | Consecutive/random sample | yes | 5 | 0.52 (0.36 to 0.67) | | 0.70 (0.47 to 0.85)
Pain migration | Adults | Blinding index tests | no | 6 | 0.58 (0.42 to 0.72) | 0.88 (0.34 to 2.10) | 0.60 (0.38 to 0.78) | 1.76 (0.52 to 6.37)
Pain migration | Adults | Blinding index tests | yes | 5 | 0.54 (0.38 to 0.70) | | 0.72 (0.50 to 0.87)
Pain migration | Children | Consecutive/random sample | no | 10 | 0.51 (0.30 to 0.72) | 2.13 (0.44 to 9.46) | 0.75 (0.65 to 0.83) | 0.87 (0.38 to 1.93)
Pain migration | Children | Consecutive/random sample | yes | 5 | 0.69 (0.38 to 0.88) | | 0.72 (0.57 to 0.84)
Pain migration | Children | Blinding index tests | no | 6 | 0.63 (0.35 to 0.85) | 0.67 (0.14 to 3.02) | 0.74 (0.60 to 0.85) | 1.01 (0.43 to 2.37)
Pain migration | Children | Blinding index tests | yes | 9 | 0.54 (0.30 to 0.75) | | 0.74 (0.63 to 0.83)
Pain migration | Mixed | Blinding ref. std. to index test results | no | 17 | 0.59 (0.46 to 0.72) | 1.53 (0.52 to 4.51) | 0.70 (0.59 to 0.79) | 0.39 (0.15 to 1.02)
Pain migration | Mixed | Blinding ref. std. to index test results | yes | 5 | 0.69 (0.46 to 0.85) | | 0.47 (0.29 to 0.68)
Pain migration | Mixed | Consecutive/random sample | no | 15 | 0.62 (0.48 to 0.75) | 0.95 (0.34 to 2.58) | 0.61 (0.48 to 0.73) | 1.67 (0.67 to 4.21)
Pain migration | Mixed | Consecutive/random sample | yes | 7 | 0.61 (0.40 to 0.78) | | 0.73 (0.55 to 0.85)
Pain migration | Mixed | Blinding index tests | no | 7 | 0.70 (0.51 to 0.83) | 0.59 (0.23 to 1.55) | 0.72 (0.53 to 0.85) | 0.61 (0.23 to 1.69)
Pain migration | Mixed | Blinding index tests | yes | 15 | 0.58 (0.44 to 0.71) | | 0.61 (0.48 to 0.73)
Psoas sign | Mixed | Consecutive/random sample | no | 6 | 0.27 (0.11 to 0.52) | 0.65 (0.14 to 2.80) | 0.72 (0.29 to 0.94) | 12.23 (0.93 to 163.99)
Psoas sign | Mixed | Consecutive/random sample | yes | 5 | 0.19 (0.07 to 0.45) | | 0.97 (0.79 to 1.00)
Psoas sign | Mixed | Blinding index tests | no | 5 | 0.25 (0.09 to 0.54) | 0.85 (0.17 to 5.01) | 0.74 (0.26 to 0.96) | 5.77 (0.26 to 77.32)
Psoas sign | Mixed | Blinding index tests | yes | 6 | 0.22 (0.09 to 0.48) | | 0.94 (0.67 to 0.99)
Tenderness rebound | Adults | All pts. received same ref. std. | no | 6 | 0.71 (0.47 to 0.86) | 0.71 (0.20 to 2.72) | 0.71 (0.46 to 0.88) | 0.80 (0.19 to 3.73)
Tenderness rebound | Adults | All pts. received same ref. std. | yes | 5 | 0.63 (0.38 to 0.83) | | 0.67 (0.38 to 0.87)
Tenderness rebound | Adults | Pathology (100%) | no | 6 | 0.71 (0.47 to 0.86) | 0.71 (0.20 to 2.72) | 0.71 (0.46 to 0.88) | 0.80 (0.19 to 3.73)
Tenderness rebound | Adults | Pathology (100%) | yes | 5 | 0.63 (0.38 to 0.83) | | 0.67 (0.38 to 0.87)
Tenderness rebound | Adults | Consecutive/random sample | no | 6 | 0.75 (0.55 to 0.89) | 0.42 (0.11 to 1.44) | 0.49 (0.37 to 0.63) | 6.02 (2.70 to 13.04)
Tenderness rebound | Adults | Consecutive/random sample | yes | 5 | 0.56 (0.32 to 0.77) | | 0.85 (0.77 to 0.91)
Tenderness rebound | Adults | Blinding index tests | no | 6 | 0.75 (0.55 to 0.89) | 0.42 (0.11 to 1.44) | 0.49 (0.37 to 0.63) | 6.02 (2.70 to 13.04)
Tenderness rebound | Adults | Blinding index tests | yes | 5 | 0.56 (0.32 to 0.77) | | 0.85 (0.77 to 0.91)
Tenderness rebound | Mixed | Pre-specified positivity criteria | no | 23 | 0.74 (0.63 to 0.83) | 1.10 (0.36 to 3.34) | 0.55 (0.42 to 0.68) | 2.50 (0.82 to 7.58)
Tenderness rebound | Mixed | Pre-specified positivity criteria | yes | 7 | 0.76 (0.54 to 0.90) | | 0.76 (0.53 to 0.89)
Tenderness rebound | Mixed | All pts. received same ref. std. | no | 18 | 0.72 (0.59 to 0.83) | 1.33 (0.48 to 3.35) | 0.64 (0.48 to 0.77) | 0.68 (0.29 to 1.98)
Tenderness rebound | Mixed | All pts. received same ref. std. | yes | 12 | 0.77 (0.62 to 0.88) | | 0.55 (0.37 to 0.73)
Tenderness rebound | Mixed | Pathology (100%) | no | 19 | 0.75 (0.63 to 0.84) | 0.98 (0.42 to 2.27) | 0.64 (0.49 to 0.76) | 0.65 (0.26 to 1.67)
Tenderness rebound | Mixed | Pathology (100%) | yes | 11 | 0.74 (0.59 to 0.85) | | 0.54 (0.35 to 0.72)
Tenderness rebound | Mixed | Consecutive/random sample | no | 15 | 0.70 (0.56 to 0.82) | 1.50 (0.63 to 3.61) | 0.67 (0.50 to 0.80) | 0.53 (0.20 to 1.57)
Tenderness rebound | Mixed | Consecutive/random sample | yes | 15 | 0.78 (0.65 to 0.87) | | 0.52 (0.35 to 0.70)
Tenderness rebound | Mixed | Blinding index tests | no | 14 | 0.80 (0.67 to 0.89) | 0.58 (0.24 to 1.29) | 0.58 (0.40 to 0.73) | 1.22 (0.51 to 3.28)
Tenderness rebound | Mixed | Blinding index tests | yes | 16 | 0.69 (0.55 to 0.80) | | 0.63 (0.46 to 0.77)
Tenderness rectal | Mixed | All pts. received same ref. std. | no | 10 | 0.27 (0.15 to 0.43) | 2.40 (0.71 to 8.85) | 0.64 (0.36 to 0.85) | 0.66 (0.09 to 3.83)
Tenderness rectal | Mixed | All pts. received same ref. std. | yes | 5 | 0.47 (0.24 to 0.71) | | 0.54 (0.18 to 0.85)
Tenderness rectal | Mixed | Pathology (100%) | no | 10 | 0.27 (0.15 to 0.43) | 2.40 (0.71 to 8.85) | 0.64 (0.36 to 0.85) | 0.66 (0.09 to 3.83)
Tenderness rectal | Mixed | Pathology (100%) | yes | 5 | 0.47 (0.24 to 0.71) | | 0.54 (0.18 to 0.85)
Tenderness rectal | Mixed | Consecutive/random sample | no | 9 | 0.35 (0.19 to 0.53) | 0.87 (0.27 to 3.16) | 0.56 (0.24 to 0.81) | 1.60 (0.28 to 14.89)
Tenderness rectal | Mixed | Consecutive/random sample | yes | 6 | 0.32 (0.15 to 0.55) | | 0.68 (0.32 to 0.92)
Tenderness rectal | Mixed | Blinding index tests | no | 6 | 0.34 (0.14 to 0.58) | 0.95 (0.26 to 4.10) | 0.47 (0.18 to 0.78) | 2.52 (0.44 to 13.59)
Tenderness rectal | Mixed | Blinding index tests | yes | 9 | 0.33 (0.18 to 0.55) | | 0.69 (0.40 to 0.88)
Tenderness RLQ | Children | Consecutive/random sample | no | 6 | 0.96 (0.85 to 0.99) | 0.29 (0.03 to 1.41) | 0.26 (0.05 to 0.71) | 6.25 (0.52 to 71.67)
Tenderness RLQ | Children | Consecutive/random sample | yes | 8 | 0.87 (0.64 to 0.96) | | 0.69 (0.29 to 0.92)
Tenderness RLQ | Children | Blinding index tests | no | 5 | 0.81 (0.50 to 0.95) | 4.62 (0.65 to 26.22) | 0.67 (0.20 to 0.94) | 0.33 (0.03 to 3.96)
Tenderness RLQ | Children | Blinding index tests | yes | 9 | 0.95 (0.86 to 0.99) | | 0.40 (0.12 to 0.77)
Tenderness RLQ | Mixed | Blinding index tests | no | 5 | 0.93 (0.66 to 0.99) | 0.79 (0.07 to 9.17) | 0.14 (0.03 to 0.37) | 1.13 (0.24 to 11.50)
Tenderness RLQ | Mixed | Blinding index tests | yes | 6 | 0.91 (0.66 to 0.98) | | 0.16 (0.05 to 0.42)

N = number; pts. = patients; ref. std. = reference standard; RLQ = right lower quadrant; RUQ = right upper quadrant

Sensitivity, relative sensitivity, specificity, and relative specificity values are medians and 95% central credible intervals when 5 or more studies were available; medians and minimum to maximum values are reported when <5 studies were available; when a single study was available we report the estimate from that study.

These results that study conduct may have affected estimates of test performance in meta-analyses of clinical symptoms and signs. However, our analyses relied on information that was often poorly reported in the primary studies and meta-regression results were often imprecise, indicating substantial uncertainty. The aforementioned differences were the only cases when CrIs did not include the null value among the large number of comparisons summarized in Table 5. Because each risk of bias item was examined individually, and because different items may be correlated between them and with other study characteristics that may affect performance estimates, we do not believe that definitive conclusions about specific items can be reached.

### Test Performance of Laboratory Tests

Two hundred and seventeen studies, published between 1956 and 2014, provided information on the test performance of laboratory tests for the diagnosis of acute appendicitis. Commonly evaluated tests included the white blood cell count, measures based on the blood count and differential, and serum C-reactive protein concentration. Table 6 presents a summary of the descriptive characteristics of the studies reporting information on laboratory tests. Table 7 presents a summary of key items related to study risk of bias. Studies were at moderate to high risk of bias. Blinding of the reference standard assessors was either not used or relevant information was not reported; a large proportion of studies had differential verification. Table 8 presents a summary of the test performance results for clinical symptoms and signs. In general, the performance of individual laboratory tests was rather poor; however, it was better than that of clinical symptoms and signs. Almost all laboratory tests had positive likelihood ratios lower than 3 (no test had a summary positive likelihood ratio higher than 5) and most tests had negative likelihood ratios higher than 0.2. Figure 5 presents study results and summary ROC curves for selected laboratory tests. There was substantial heterogeneity in sensitivity and specificity for most tests; however, in most cases summary ROC lines appeared to fit the data relatively well. Figure 6 shows the positive and negative predictive value for selected laboratory tests, over appendicitis prevalence.

Table 6 Descriptive characteristics for studies evaluating laboratory tests for the diagnosis of acute appendicitis

Patient Population | N studies (Median N Patients/Affected/Unaffected) | Median % of Women | Median of Average Age (Yrs) | Community Setting | Ambulatory Setting | Surgical Cohorts | Clinical Presentation Consistent With Appendicitis | Median % of Patients With Perforation
Adults | 38 (134/73/29) | 44.2% | 29.4 | 10.5% | 21.1% | 52.6% | 92.1% | 11.9%
Children | 55 (169/90.5/52.5) | 44.4% | 10.4 | 7.3% | 25.5% | 23.6% | 94.5% | 14.2%
Children <5yrs | 1 (90/41/49) | 41.1% | 3.8 | 0.0% | 0.0% | 100.0% | 100.0% | 17.8%
Elderly | 3 (85/77/10) | 27.2% | 55.1 | 0.0% | 0.0% | 100.0% | 100.0% | 38.9%
Women of reproductive age | 4 (72/45.5/18.5) | 100.0% | 24.0 | 25.0% | 0.0% | 50.0% | 100.0% | NR
Pregnant women | 7 (39/29/9) | 100.0% | 24.5 | 14.3% | 0.0% | 85.7% | 100.0% | 12.0%
Mixed | 123 (168/95/58.5) | 50.6% | 27.0 | 7.3% | 17.9% | 42.3% | 93.5% | 10.0%

N = number; NA = not applicable; NR = not reported; yrs = years

Table 7 Assessment of risk of bias for studies evaluating laboratory tests for the diagnosis of acute appendicitis

Patient Population | Consecutive or Random Sample of Patients | Study Avoided Inappropriate Exclusions | Index Test Results Interpreted Without Knowledge of Ref. Std. | Were the Positivity Criteria Prespecified? | Ref. Std. Results Interpreted Without Knowledge of Index Test | All Patients Received a Ref. Std. | All Patients Received the Same Ref. Std. | All Patients Received Pathology for Ref. Std. | All Patients Included in the Analysis
Adults | 63.2% | 100.0 | 42.1% | 34.2% | 7.9% | 94.7% | 68.4% | 68.4% | 73.7%
Children | 50.9% | 100.0 | 47.3% | 45.5% | 9.1% | 90.9% | 40.0% | 41.8% | 81.8%
Children <5yrs | 100.0% | 100.0 | 0.0% | 0.0% | 0.0% | 100.0% | 100.0% | 100.0% | 100.0%
Elderly | 100.0% | 100.0 | 66.7% | 66.7% | 0.0% | 100.0% | 100.0% | 100.0% | 33.3%
Women of reproductive age | 75.0% | 100.0 | 0.0% | 25.0% | 25.0% | 100.0% | 75.0% | 75.0% | 100.0%
Pregnant women | 71.4% | 100.0 | 42.9% | 14.3% | 0.0% | 100.0% | 100.0% | 100.0% | 100.0%
Mixed | 56.9% | 100.0 | 44.7% | 41.5% | 12.2% | 93.5% | 49.6% | 48.0% | 70.7%

ref. std. = reference standard; yrs = years

Table 8 Summary estimates of test performance of laboratory tests for the diagnosis of acute appendicitis

Test | Population | N Studies [Affected/Unaffected] | Sensitivity | Specificity | LR+ | LR−
CRP | Adults | 15 [1541/983] | 0.84 (0.73 to 0.92) | 0.67 (0.50 to 0.81) | 2.53 (1.59 to 4.62) | 0.23 (0.11 to 0.46)
CRP | Children | 22 [2226/1635] | 0.73 (0.66 to 0.80) | 0.72 (0.61 to 0.81) | 2.62 (1.91 to 3.81) | 0.37 (0.28 to 0.48)
CRP | Elderly | 2 [213/72] | 0.91 (0.91 to 0.92) | 0.21 (0.17 to 0.25) | 1.16 (1.11 to 1.21) | 0.42 (0.36 to 0.47)
CRP | Women of reproductive age | 3 [169/133] | 0.79 (0.44 to 0.97) | 0.70 (0.33 to 0.93) | 1.44 (1.19 to 13.64) | 0.62 (0.03 to 0.81)
CRP | Pregnant women | 1 [31/8] | 0.68 | 0.50 | 1.35 | 0.65
CRP | Mixed | 52 [8742/5903] | 0.79 (0.74 to 0.83) | 0.65 (0.57 to 0.72) | 2.23 (1.78 to 2.86) | 0.33 (0.25 to 0.42)
ESR | Children | 2 [121/88] | 0.40 (0.39 to 0.41) | 0.87 (0.85 to 0.90) | 3.27 (2.72 to 3.82) | 0.69 (0.68 to 0.70)
ESR | Mixed | 5 [565/466] | 0.30 (0.20 to 0.43) | 0.79 (0.60 to 0.90) | 1.41 (0.73 to 2.89) | 0.89 (0.73 to 1.15)
IL-6 | Adults | 2 [113/66] | 0.59 (0.33 to 0.84) | 0.65 (0.46 to 0.83) | 1.74 (1.57 to 1.92) | 0.57 (0.34 to 0.81)
IL-6 | Children | 6 [319/467] | 0.90 (0.63 to 0.98) | 0.85 (0.54 to 0.98) | 5.99 (1.89 to 34.09) | 0.12 (0.02 to 0.46)
IL-6 | Mixed | 4 [306/87] | 0.73 (0.46 to 0.84) | 0.63 (0.31 to 1.00) | 1.58 (0.96 to 3.58) | 0.48 (0.21 to 1.10)
Left shift | Adults | 1 [243/15] | 0.76 | 0.13 | 0.87 | 1.82
Left shift | Children | 4 [270/420] | 0.75 (0.60 to 0.88) | 0.65 (0.22 to 0.90) | 2.21 (1.13 to 5.92) | 0.49 (0.26 to 0.53)
Left shift | Mixed | 5 [1105/496] | 0.77 (0.37 to 0.95) | 0.64 (0.29 to 0.87) | 2.05 (1.02 to 4.73) | 0.38 (0.10 to 0.98)
Neutrophil% | Adults | 5 [831/328] | 0.79 (0.60 to 0.90) | 0.59 (0.40 to 0.76) | 1.90 (1.21 to 3.26) | 0.36 (0.17 to 0.76)
Neutrophil% | Children | 6 [833/584] | 0.78 (0.47 to 0.93) | 0.70 (0.55 to 0.81) | 2.52 (1.34 to 4.24) | 0.32 (0.10 to 0.80)
Neutrophil% | Elderly | 1 [77/8] | 0.88 | 0.25 | 1.18 | 0.47
Neutrophil% | Mixed | 15 [3328/1558] | 0.80 (0.71 to 0.87) | 0.61 (0.50 to 0.72) | 2.06 (1.59 to 2.83) | 0.33 (0.22 to 0.48)
PMNC count | Children | 3 [863/697] | 0.83 (0.81 to 0.96) | 0.64 (0.56 to 0.72) | 2.33 (2.20 to 2.90) | 0.26 (0.06 to 0.26)
PMNC count | Mixed | 6 [1429/634] | 0.85 (0.69 to 0.95) | 0.71 (0.60 to 0.79) | 2.91 (2.11 to 3.85) | 0.21 (0.07 to 0.43)
WBC | Adults | 26 [4070/2452] | 0.81 (0.74 to 0.87) | 0.54 (0.42 to 0.64) | 1.74 (1.40 to 2.27) | 0.35 (0.24 to 0.51)
WBC | Children | 41 [6595/4473] | 0.80 (0.73 to 0.85) | 0.65 (0.56 to 0.73) | 2.29 (1.87 to 2.90) | 0.31 (0.23 to 0.40)
WBC | Elderly | 3 [287/82] | 0.71 (0.69 to 0.77) | 0.50 (0.38 to 0.70) | 1.54 (1.14 to 2.30) | 0.46 (0.44 to 0.76)
WBC | Women of reproductive age | 2 [49/18] | 0.64 (0.60 to 0.69) | 0.67 (0.67 to 0.67) | 1.93 (1.80 to 2.07) | 0.53 (0.47 to 0.60)
WBC | Pregnant women | 6 [197/82] | 0.63 (0.21 to 0.92) | 0.75 (0.38 to 0.95) | 2.41 (0.64 to 12.27) | 0.51 (0.11 to 1.34)
WBC | Mixed | 84 [19074/10883] | 0.78 (0.75 to 0.82) | 0.62 (0.58 to 0.66) | 2.07 (1.88 to 2.30) | 0.35 (0.30 to 0.41)
WBC + CRP | Adults | 2 [194/68] | 0.93 (0.86 to 1.00) | 0.62 (0.37 to 0.86) | 4.35 (1.37 to 7.33) | 0.18 (0.00 to 0.37)
WBC + CRP | Children | 5 [566/132] | 0.81 (0.42 to 0.96) | 0.73 (0.54 to 0.85) | 2.88 (1.35 to 5.51) | 0.27 (0.05 to 0.82)
WBC + CRP | Elderly | 1 [77/8] | 0.96 | 0.13 | 1.10 | 0.31
WBC + CRP | Women of reproductive age | 1 [29/9] | 0.93 | 0.44 | 1.68 | 0.16
WBC + CRP | Mixed | 15 [4145/1734] | 0.72 (0.42 to 0.91) | 0.73 (0.54 to 0.88) | 2.62 (1.48 to 5.49) | 0.38 (0.14 to 0.77)
WBC + Neutrophil% | Adults | 1 [438/102] | 0.68 | 0.75 | 2.78 | 0.42
WBC + Neutrophil% | Children | 1 [212/48] | 0.71 | 0.71 | 2.44 | 0.41
WBC + Neutrophil% | Elderly | 1 [77/8] | 0.92 | 0.25 | 1.23 | 0.31
WBC + Neutrophil% | Mixed | 5 [1572/437] | 0.90 (0.65 to 0.98) | 0.65 (0.23 to 0.92) | 2.54 (1.14 to 10.88) | 0.16 (0.04 to 0.65)

CRP = c-reactive protein; ESR = erythrocyte sedimentation rate; IL-6 = interleukin 6; LR = likelihood ratio; N = number; PMNC = polymorphonuclear count; WBC = white blood cell count

Sensitivity, specificity, and LR values are medians and 95% central credible intervals when 5 or more studies were available; medians and minimum to maximum values are reported when <5 studies were available; when a single study was available we report the estimate from that study.

Figure 5 Scatterplot of results in the receiver operating characteristic space and summary receiver operating characteristic curves of laboratory tests for the diagnosis of acute appendicitis

CRP = c-reactive protein; IL-6 = interleukin 6; PMNC = polymorphonuclear count; WBC = white blood cell count; sens.=sensitivity; spec.=specificity

This figure includes fifteen scatterplot graphs showing 1-specificity (x axis, range 0.0 to 1.0) versus sensitivity (y axis, range 0.0 to 1.0) for different laboratory values in different populations with ROC lines fit where possible. In general test performance of diagnostic tests is limited but better than for signs and symptoms.

Figure 6 Positive predictive value and negative predictive value curves of laboratory tests for the diagnosis of acute appendicitis

CRP = c-reactive protein; IL-6 = interleukin 6; PMNC = polymorphonuclear count; WBC = white blood cell count

This figure includes fifteen scatterplots showing prevalence (x axis, range 0.0 to 1.0) versus predicted value (y axis, range 0.0 to 1.0) for different laboratory values in different populations with overlaid summary curves. In general, these figures also show slightly better performance than for signs and symptoms, but still limited.

#### Factors That Affect the Test Performance of Laboratory Tests

Table 9 summarizes the results of meta-regression analyses for various factors that may affect the performance of laboratory tests for the diagnosis of acute appendicitis. The vast majority of studies did not report adequate data to assess factors that may affect test performance (i.e., based on within study comparisons); for this reason we relied on comparisons across studies (via meta-regression analyses) to identify factors that may affect test performance. Overall, no distinct pattern emerged to establish a particular factor as a modifier of test performance. For all factors examined but CrIs were wide, indicating substantial uncertainty regarding the relative test performance of tests over levels of the modifiers we examined.

Table 9 Meta-regression results for factors that affect the performance of laboratory tests for the diagnosis of acute appendicitis

Test | Population | Subgroup | | N Studies | Sensitivity | Relative Sensitivity | Specificity | Relative Specificity
CRP | Adults | Study year | <2005 | 6 | 0.82 (0.60 to 0.94) | 1.37 (0.31 to 6.02) | 0.65 (0.37 to 0.86) | 1.14 (0.23 to 5.11)
CRP | Adults | Study year | >=2005 | 9 | 0.86 (0.71 to 0.95) | | 0.68 (0.45 to 0.86)
CRP | Adults | Ambulatory setting | no | 10 | 0.85 (0.70 to 0.94) | 0.84 (0.18 to 4.74) | 0.64 (0.42 to 0.82) | 1.43 (0.34 to 7.16)
CRP | Adults | Ambulatory setting | yes | 5 | 0.83 (0.58 to 0.96) | | 0.72 (0.44 to 0.91)
CRP | Adults | Surgical cohorts | no | 9 | 0.86 (0.70 to 0.95) | 0.82 (0.16 to 3.77) | 0.63 (0.41 to 0.82) | 1.58 (0.32 to 6.60)
CRP | Adults | Surgical cohorts | yes | 6 | 0.83 (0.61 to 0.94) | | 0.72 (0.44 to 0.90)
CRP | Children | Study year | <2005 | 7 | 0.70 (0.54 to 0.81) | 1.32 (0.61 to 3.10) | 0.71 (0.51 to 0.86) | 1.11 (0.34 to 3.01)
CRP | Children | Study year | >=2005 | 15 | 0.75 (0.66 to 0.83) | | 0.73 (0.58 to 0.83)
CRP | Children | Surgical cohorts | no | 13 | 0.76 (0.67 to 0.84) | 0.69 (0.30 to 1.45) | 0.77 (0.64 to 0.86) | 0.52 (0.20 to 1.43)
CRP | Children | Surgical cohorts | yes | 9 | 0.69 (0.55 to 0.80) | | 0.63 (0.44 to 0.79)
CRP | Mixed | Study year | <2005 | 27 | 0.80 (0.74 to 0.85) | 0.88 (0.51 to 1.43) | 0.62 (0.51 to 0.72) | 1.25 (0.65 to 2.53)
CRP | Mixed | Study year | >=2005 | 25 | 0.78 (0.71 to 0.83) | | 0.67 (0.56 to 0.77)
CRP | Mixed | Ambulatory setting | no | 45 | 0.78 (0.73 to 0.83) | 1.20 (0.55 to 2.57) | 0.61 (0.53 to 0.69) | 2.90 (1.17 to 6.91)
CRP | Mixed | Ambulatory setting | yes | 7 | 0.81 (0.68 to 0.90) | | 0.82 (0.66 to 0.91)
CRP | Mixed | Surgical cohorts | no | 27 | 0.78 (0.71 to 0.84) | 1.13 (0.65 to 1.96) | 0.66 (0.54 to 0.75) | 0.91 (0.45 to 1.83)
CRP | Mixed | Surgical cohorts | yes | 25 | 0.80 (0.73 to 0.85) | | 0.64 (0.51 to 0.75)
Neutrophil % | Mixed | Study year | <2005 | 9 | 0.83 (0.74 to 0.90) | 0.76 (0.30 to 1.85) | 0.63 (0.47 to 0.77) | 0.79 (0.28 to 2.30)
Neutrophil % | Mixed | Study year | >=2005 | 5 | 0.79 (0.64 to 0.89) | | 0.57 (0.37 to 0.77)
Neutrophil % | Mixed | Surgical cohorts | no | 6 | 0.84 (0.73 to 0.92) | 0.74 (0.28 to 1.79) | 0.70 (0.55 to 0.82) | 0.47 (0.19 to 1.11)
Neutrophil % | Mixed | Surgical cohorts | yes | 8 | 0.80 (0.68 to 0.88) | | 0.52 (0.38 to 0.67)
WBC | Adults | Study year | <2005 | 15 | 0.85 (0.76 to 0.91) | 0.56 (0.23 to 1.32) | 0.47 (0.34 to 0.62) | 1.78 (0.73 to 4.16)
WBC | Adults | Study year | >=2005 | 11 | 0.76 (0.62 to 0.86) | | 0.62 (0.45 to 0.76)
WBC | Adults | Ambulatory setting | no | 19 | 0.82 (0.74 to 0.88) | 0.81 (0.31 to 2.30) | 0.54 (0.41 to 0.66) | 0.96 (0.36 to 2.53)
WBC | Adults | Ambulatory setting | yes | 7 | 0.79 (0.62 to 0.90) | | 0.53 (0.33 to 0.72)
WBC | Adults | Surgical cohorts | no | 14 | 0.81 (0.70 to 0.89) | 1.02 (0.40 to 2.55) | 0.56 (0.42 to 0.70) | 0.77 (0.31 to 1.81)
WBC | Adults | Surgical cohorts | yes | 12 | 0.81 (0.70 to 0.89) | | 0.50 (0.34 to 0.66)
WBC | Children | Study year | <2005 | 15 | 0.73 (0.60 to 0.82) | 1.88 (1.01 to 3.77) | 0.75 (0.63 to 0.85) | 0.46 (0.22 to 0.95)
WBC | Children | Study year | >=2005 | 26 | 0.84 (0.77 to 0.89) | | 0.58 (0.47 to 0.69)
WBC | Children | Ambulatory setting | no | 31 | 0.80 (0.72 to 0.86) | 0.94 (0.38 to 2.24) | 0.65 (0.54 to 0.75) | 1.01 (0.41 to 2.67)
WBC | Children | Ambulatory setting | yes | 10 | 0.79 (0.64 to 0.89) | | 0.65 (0.47 to 0.81)
WBC | Children | Surgical cohorts | no | 31 | 0.82 (0.74 to 0.87) | 0.68 (0.29 to 1.64) | 0.67 (0.56 to 0.75) | 0.73 (0.30 to 1.82)
WBC | Children | Surgical cohorts | yes | 10 | 0.75 (0.59 to 0.86) | | 0.59 (0.40 to 0.76)
WBC | Mixed | Study year | <2005 | 49 | 0.80 (0.75 to 0.84) | 0.80 (0.53 to 1.18) | 0.60 (0.54 to 0.65) | 1.31 (0.94 to 1.84)
WBC | Mixed | Study year | >=2005 | 35 | 0.76 (0.70 to 0.81) | | 0.66 (0.60 to 0.72)
WBC | Mixed | Community setting | no | 78 | 0.78 (0.74 to 0.82) | 0.93 (0.42 to 2.10) | 0.62 (0.58 to 0.67) | 0.89 (0.45 to 1.76)
WBC | Mixed | Community setting | Yes | 6 | 0.77 (0.61 to 0.88) | | 0.60 (0.43 to 0.74)
WBC | Mixed | Ambulatory setting | No | 66 | 0.78 (0.74 to 0.82) | 1.11 (0.67 to 1.85) | 0.63 (0.58 to 0.67) | 0.89 (0.58 to 1.36)
WBC | Mixed | Ambulatory setting | yes | 18 | 0.80 (0.71 to 0.86) | | 0.60 (0.51 to 0.69)
WBC | Mixed | Surgical cohorts | No | 50 | 0.80 (0.75 to 0.84) | 0.79 (0.53 to 1.22) | 0.62 (0.57 to 0.67) | 1.04 (0.73 to 1.46)
WBC | Mixed | Surgical cohorts | yes | 34 | 0.76 (0.70 to 0.81) | | 0.63 (0.56 to 0.69)
WBC | Mixed | Appendicitis presentation | atypical/other/unclear | 7 | 0.83 (0.69 to 0.90) | 0.72 (0.38 to 1.65) | 0.55 (0.41 to 0.70) | 1.36 (0.72 to 2.52)
WBC | Mixed | Appendicitis presentation | typical | 77 | 0.78 (0.74 to 0.81) | | 0.63 (0.59 to 0.67)

CRP = c-reactive protein; N = number; WBC = white blood cell count

Sensitivity, relative sensitivity, specificity, and relative specificity values are medians and 95% central credible intervals when 5 or more studies were available; medians and minimum to maximum values are reported when <5 studies were available; when a single study was available we report the estimate from that study.

#### Impact of Study Risk of Bias Items on Estimated Test Performance

Table 10 summarizes the results of meta-regression analyses for various factors that may affect the performance of laboratory tests for the diagnosis of acute appendicitis. We only observed a single case where the 95% CrIs for a risk of bias item did not include the null value: studies of white blood cell count that had complete verification of index test results had lower specificity than studies with incomplete verification; these results were rather imprecise (i.e., CrIs were wide). More generally, these results should not be taken to mean that there is no potential for bias in studies of laboratory tests. Our analyses relied on information that was often poorly reported in the primary studies and meta-regression results were often imprecise, indicating substantial uncertainty. Because each risk of bias item was examined individually, and because different items may be correlated between them and with other study characteristics that may affect performance estimates, we do not believe that definitive conclusions about specific items can be reached.

Table 10 Meta-regression results for the impact of risk of bias items on the estimated test performance of laboratory tests for the diagnosis of acute appendicitis

Test | Population | Subgroup | | N Studies | Sensitivity | Relative Sensitivity | Specificity | Relative Specificity
CRP | Adults | Pre-specified positivity criteria | no | 10 | 0.83 (0.68 to 0.93) | 1.41 (0.28 to 5.80) | 0.74 (0.56 to 0.87) | 0.39 (0.10 to 1.39)
CRP | Adults | Pre-specified positivity criteria | yes | 5 | 0.87 (0.66 to 0.96) | | 0.52 (0.26 to 0.77)
CRP | Adults | All pts. received same ref. std. | no | 6 | 0.87 (0.67 to 0.96) | 0.75 (0.18 to 3.36) | 0.75 (0.51 to 0.91) | 0.52 (0.12 to 1.96)
CRP | Adults | All pts. received same ref. std. | yes | 9 | 0.83 (0.66 to 0.93) | | 0.61 (0.39 to 0.80)
CRP | Adults | Pathology (100%) | no | 6 | 0.87 (0.67 to 0.96) | 0.75 (0.18 to 3.36) | 0.75 (0.51 to 0.91) | 0.52 (0.12 to 1.96)
CRP | Adults | Pathology (100%) | yes | 9 | 0.83 (0.66 to 0.93) | | 0.61 (0.39 to 0.80)
CRP | Adults | Blinding index tests | no | 10 | 0.86 (0.72 to 0.94) | 0.75 (0.16 to 3.02) | 0.74 (0.58 to 0.87) | 0.28 (0.07 to 1.01)
CRP | Adults | Blinding index tests | yes | 5 | 0.82 (0.57 to 0.94) | | 0.45 (0.22 to 0.72)
CRP | Children | Pre-specified positivity criteria | no | 9 | 0.78 (0.67 to 0.87) | 0.65 (0.31 to 1.37) | 0.66 (0.47 to 0.80) | 1.64 (0.65 to 4.13)
CRP | Children | Pre-specified positivity criteria | yes | 13 | 0.70 (0.59 to 0.79) | | 0.76 (0.63 to 0.85)
CRP | Children | All pts. received same ref. std. | no | 8 | 0.75 (0.60 to 0.85) | 0.89 (0.42 to 2.27) | 0.82 (0.68 to 0.92) | 0.41 (0.13 to 1.03)
CRP | Children | All pts. received same ref. std. | yes | 14 | 0.73 (0.63 to 0.82) | | 0.65 (0.50 to 0.77)
CRP | Children | All pts. included in the analysis | no | 6 | 0.78 (0.62 to 0.88) | 0.71 (0.30 to 1.90) | 0.66 (0.42 to 0.83) | 1.47 (0.54 to 4.59)
CRP | Children | All pts. included in the analysis | yes | 16 | 0.72 (0.62 to 0.80) | | 0.74 (0.62 to 0.84)
CRP | Children | Pathology (100%) | no | 8 | 0.75 (0.60 to 0.85) | 0.89 (0.42 to 2.27) | 0.82 (0.68 to 0.92) | 0.41 (0.13 to 1.03)
CRP | Children | Pathology (100%) | yes | 14 | 0.73 (0.63 to 0.82) | | 0.65 (0.50 to 0.77)
CRP | Children | Consecutive/random sample | no | 7 | 0.75 (0.59 to 0.86) | 0.89 (0.39 to 2.22) | 0.77 (0.57 to 0.90) | 0.68 (0.22 to 2.13)
CRP | Children | Consecutive/random sample | yes | 15 | 0.73 (0.63 to 0.82) | | 0.70 (0.56 to 0.81)
CRP | Children | Blinding index tests | no | 14 | 0.77 (0.67 to 0.84) | 0.63 (0.30 to 1.40) | 0.71 (0.57 to 0.82) | 1.10 (0.40 to 3.14)
CRP | Children | Blinding index tests | yes | 8 | 0.67 (0.54 to 0.79) | | 0.73 (0.55 to 0.87)
CRP | Mixed | Pre-specified positivity criteria | no | 30 | 0.80 (0.75 to 0.85) | 0.80 (0.47 to 1.31) | 0.65 (0.55 to 0.75) | 0.95 (0.48 to 1.89)
CRP | Mixed | Pre-specified positivity criteria | yes | 22 | 0.76 (0.69 to 0.83) | | 0.64 (0.51 to 0.75)
CRP | Mixed | Blinding ref. std. to index test results | no | 46 | 0.77 (0.72 to 0.81) | 2.75 (1.28 to 6.28) | 0.64 (0.55 to 0.72) | 1.48 (0.52 to 3.97)
CRP | Mixed | Blinding ref. std. to index test results | yes | 6 | 0.90 (0.82 to 0.95) | | 0.72 (0.49 to 0.87)
CRP | Mixed | All pts. received same ref. std. | no | 24 | 0.79 (0.72 to 0.85) | 0.96 (0.57 to 1.60) | 0.65 (0.53 to 0.75) | 0.99 (0.51 to 2.11)
CRP | Mixed | All pts. received same ref. std. | yes | 28 | 0.78 (0.72 to 0.84) | | 0.65 (0.53 to 0.75)
CRP | Mixed | All pts. included in the analysis | no | 18 | 0.78 (0.70 to 0.85) | 1.05 (0.60 to 1.75) | 0.61 (0.48 to 0.74) | 1.31 (0.60 to 2.46)
CRP | Mixed | All pts. included in the analysis | yes | 34 | 0.79 (0.73 to 0.84) | | 0.67 (0.57 to 0.75)
CRP | Mixed | Pathology (100%) | no | 24 | 0.79 (0.72 to 0.85) | 0.96 (0.57 to 1.60) | 0.65 (0.53 to 0.75) | 0.99 (0.51 to 2.11)
CRP | Mixed | Pathology (100%) | yes | 28 | 0.78 (0.72 to 0.84) | | 0.65 (0.53 to 0.75)
CRP | Mixed | Consecutive/random sample | no | 21 | 0.83 (0.77 to 0.88) | 0.63 (0.38 to 1.02) | 0.71 (0.60 to 0.81) | 0.59 (0.31 to 1.11)
CRP | Mixed | Consecutive/random sample | yes | 31 | 0.75 (0.69 to 0.81) | | 0.60 (0.49 to 0.69)
CRP | Mixed | Blinding index tests | no | 31 | 0.75 (0.69 to 0.81) | 1.71 (1.03 to 2.78) | 0.61 (0.50 to 0.70) | 1.55 (0.76 to 3.10)
CRP | Mixed | Blinding index tests | yes | 21 | 0.84 (0.78 to 0.88) | | 0.70 (0.58 to 0.80)
Neutrophil % | Mixed | All pts. received same ref. std. | no | 5 | 0.82 (0.69 to 0.91) | 0.95 (0.33 to 2.30) | 0.68 (0.49 to 0.83) | 0.59 (0.21 to 1.63)
Neutrophil % | Mixed | All pts. received same ref. std. | yes | 9 | 0.81 (0.70 to 0.89) | | 0.56 (0.41 to 0.71)
Neutrophil % | Mixed | All pts. included in the analysis | no | 6 | 0.79 (0.65 to 0.88) | 1.34 (0.53 to 3.27) | 0.60 (0.39 to 0.78) | 1.11 (0.36 to 3.23)
Neutrophil % | Mixed | All pts. included in the analysis | yes | 8 | 0.83 (0.73 to 0.90) | | 0.62 (0.44 to 0.78)
Neutrophil % | Mixed | Pathology (100%) | no | 5 | 0.82 (0.69 to 0.91) | 0.95 (0.33 to 2.30) | 0.68 (0.49 to 0.83) | 0.59 (0.21 to 1.63)
Neutrophil % | Mixed | Pathology (100%) | yes | 9 | 0.81 (0.70 to 0.89) | | 0.56 (0.41 to 0.71)
Neutrophil % | Mixed | Consecutive/random sample | no | 6 | 0.81 (0.68 to 0.89) | 1.07 (0.43 to 2.76) | 0.49 (0.33 to 0.66) | 2.31 (0.93 to 5.86)
Neutrophil % | Mixed | Consecutive/random sample | yes | 8 | 0.82 (0.71 to 0.90) | | 0.69 (0.55 to 0.81)
Neutrophil % | Mixed | Blinding index tests | no | 8 | 0.83 (0.72 to 0.90) | 0.86 (0.33 to 2.09) | 0.60 (0.44 to 0.76) | 1.07 (0.35 to 2.97)
Neutrophil % | Mixed | Blinding index tests | yes | 6 | 0.80 (0.66 to 0.89) | | 0.62 (0.42 to 0.79)
WBC | Adults | Pre-specified positivity criteria | no | 16 | 0.79 (0.69 to 0.87) | 1.37 (0.58 to 3.18) | 0.46 (0.33 to 0.59) | 2.22 (1.01 to 5.08)
WBC | Adults | Pre-specified positivity criteria | yes | 10 | 0.84 (0.73 to 0.91) | | 0.65 (0.49 to 0.78)
WBC | Adults | All pts. received same ref. std. | no | 10 | 0.82 (0.70 to 0.91) | 0.99 (0.36 to 2.11) | 0.58 (0.41 to 0.75) | 0.71 (0.26 to 1.75)
WBC | Adults | All pts. received same ref. std. | yes | 16 | 0.81 (0.71 to 0.88) | | 0.50 (0.35 to 0.64)
WBC | Adults | All pts. included in the analysis | no | 7 | 0.85 (0.71 to 0.93) | 0.73 (0.27 to 1.96) | 0.67 (0.49 to 0.82) | 0.45 (0.18 to 1.09)
WBC | Adults | All pts. included in the analysis | yes | 19 | 0.80 (0.71 to 0.87) | | 0.48 (0.36 to 0.60)
WBC | Adults | Pathology (100%) | no | 10 | 0.82 (0.70 to 0.91) | 0.99 (0.36 to 2.11) | 0.58 (0.41 to 0.75) | 0.71 (0.26 to 1.75)
WBC | Adults | Pathology (100%) | yes | 16 | 0.81 (0.71 to 0.88) | | 0.50 (0.35 to 0.64)
WBC | Adults | Consecutive/random sample | no | 10 | 0.75 (0.58 to 0.85) | 1.90 (0.80 to 5.04) | 0.56 (0.39 to 0.72) | 0.85 (0.34 to 2.01)
WBC | Adults | Consecutive/random sample | yes | 16 | 0.85 (0.77 to 0.91) | | 0.52 (0.38 to 0.65)
WBC | Adults | Blinding index tests | no | 15 | 0.80 (0.70 to 0.88) | 1.25 (0.53 to 2.94) | 0.55 (0.40 to 0.69) | 0.88 (0.35 to 2.15)
WBC | Adults | Blinding index tests | yes | 11 | 0.83 (0.72 to 0.91) | | 0.52 (0.34 to 0.68)
WBC | Children | Pre-specified positivity criteria | no | 21 | 0.85 (0.78 to 0.90) | 0.47 (0.23 to 0.95) | 0.56 (0.43 to 0.67) | 2.32 (1.15 to 4.80)
WBC | Children | Pre-specified positivity criteria | yes | 20 | 0.73 (0.62 to 0.82) | | 0.74 (0.63 to 0.83)
WBC | Children | All pts. received same ref. std. | no | 25 | 0.81 (0.72 to 0.88) | 0.82 (0.34 to 1.89) | 0.69 (0.58 to 0.78) | 0.60 (0.27 to 1.36)
WBC | Children | All pts. received same ref. std. | yes | 16 | 0.78 (0.65 to 0.87) | | 0.57 (0.42 to 0.72)
WBC | Children | All pts. included in the analysis | no | 8 | 0.76 (0.58 to 0.87) | 1.34 (0.58 to 3.39) | 0.67 (0.47 to 0.83) | 0.90 (0.33 to 2.19)
WBC | Children | All pts. included in the analysis | yes | 33 | 0.81 (0.74 to 0.87) | | 0.65 (0.54 to 0.74)
WBC | Children | Pathology (100%) | no | 25 | 0.81 (0.72 to 0.88) | 0.82 (0.34 to 1.89) | 0.69 (0.58 to 0.78) | 0.60 (0.27 to 1.36)
WBC | Children | Pathology (100%) | yes | 16 | 0.78 (0.65 to 0.87) | | 0.57 (0.42 to 0.72)
WBC | Children | Consecutive/random sample | no | 20 | 0.83 (0.74 to 0.89) | 0.67 (0.33 to 1.48) | 0.61 (0.48 to 0.73) | 1.38 (0.66 to 2.86)
WBC | Children | Consecutive/random sample | yes | 21 | 0.77 (0.66 to 0.85) | | 0.69 (0.56 to 0.79)
WBC | Children | Blinding index tests | no | 22 | 0.79 (0.69 to 0.86) | 1.17 (0.52 to 2.55) | 0.66 (0.53 to 0.77) | 0.97 (0.43 to 2.16)
WBC | Children | Blinding index tests | yes | 19 | 0.81 (0.71 to 0.89) | | 0.65 (0.51 to 0.77)
WBC | Mixed | Pre-specified positivity criteria | no | 48 | 0.77 (0.71 to 0.81) | 1.25 (0.83 to 1.88) | 0.60 (0.55 to 0.66) | 1.22 (0.84 to 1.70)
WBC | Mixed | Pre-specified positivity criteria | yes | 36 | 0.80 (0.75 to 0.85) | | 0.65 (0.58 to 0.71)
WBC | Mixed | Blinding ref. std. to index test results | no | 75 | 0.78 (0.75 to 0.82) | 0.90 (0.45 to 1.76) | 0.62 (0.57 to 0.66) | 1.28 (0.75 to 2.23)
WBC | Mixed | Blinding ref. std. to index test results | yes | 9 | 0.77 (0.63 to 0.86) | | 0.67 (0.55 to 0.77)
WBC | Mixed | All pts. received same ref. std. | no | 46 | 0.79 (0.74 to 0.83) | 0.94 (0.62 to 1.36) | 0.64 (0.59 to 0.69) | 0.84 (0.61 to 1.20)
WBC | Mixed | All pts. received same ref. std. | yes | 38 | 0.78 (0.72 to 0.82) | | 0.60 (0.53 to 0.66)
WBC | Mixed | All pts. included in the analysis | no | 24 | 0.80 (0.74 to 0.86) | 0.84 (0.51 to 1.30) | 0.65 (0.57 to 0.72) | 0.87 (0.59 to 1.25)
WBC | Mixed | All pts. included in the analysis | yes | 60 | 0.77 (0.73 to 0.81) | | 0.61 (0.56 to 0.66)
WBC | Mixed | Pathology (100%) | no | 46 | 0.79 (0.74 to 0.83) | 0.94 (0.62 to 1.36) | 0.64 (0.59 to 0.69) | 0.84 (0.61 to 1.20)
WBC | Mixed | Pathology (100%) | yes | 38 | 0.78 (0.72 to 0.82) | | 0.60 (0.53 to 0.66)
WBC | Mixed | Consecutive/random sample | no | 37 | 0.77 (0.71 to 0.82) | 1.18 (0.77 to 1.77) | 0.62 (0.56 to 0.68) | 1.00 (0.72 to 1.42)
WBC | Mixed | Consecutive/random sample | yes | 47 | 0.79 (0.74 to 0.84) | | 0.62 (0.57 to 0.68)
WBC | Mixed | Blinding index tests | no | 44 | 0.78 (0.72 to 0.82) | 1.10 (0.72 to 1.64) | 0.62 (0.56 to 0.68) | 1.00 (0.67 to 1.39)
WBC | Mixed | Blinding index tests | yes | 40 | 0.79 (0.74 to 0.84) | | 0.62 (0.56 to 0.68)

CRP = c-reactive protein; N = number; pts. = patients; ref. std. = reference standard; WBC = white blood cell count

Sensitivity, relative sensitivity, specificity, and relative specificity values are medians and 95% central credible intervals when 5 or more studies were available; medians and minimum to maximum values are reported when <5 studies were available; when a single study was available we report the estimate from that study.

### Test Performance of Multivariable Diagnostic Scores

One hundred and twenty seven studies reported information on one or more multivariable diagnostic scores. The authors usually proposed two types of cut points for these scores: a low value, below which patients might be safely discharged or observed (we refer to this cut point as the “low-risk cutoff”), and a high value, above which patients could proceed to surgery without additional investigation (we refer to this cutoff as the “high-risk cutoff”). When studies reported results at multiple cut point, analyses were performed at a “low risk” and “high risk” cut points suggested by the original score developers or recommended in subsequent studies. For scores developed specifically for binary classification, we used a single cut point. The majority of multivariable diagnostic scores had been developed prior to the widespread use of diagnostic imaging with CT and US. However, more recently developed scores have been developed with the intention of identifying a low risk group in whom imaging can be omitted.

Fifty-six of the studies enrolled mixed populations; 36 enrolled exclusively adults and 31 enrolled exclusively children; two studies were conducted in women of reproductive age; no studies were conducted in pregnant women or the elderly. Table 11 summarizes the descriptive characteristics of studies assessing the test performance of multivariable diagnostic scores and Table 12 summarizes key elements related to study risk of bias.

Table 11 Descriptive characteristics for studies evaluating score tests for the diagnosis of acute appendicitis

Patient Population | N Studies (Median N Patients/Affected/Unaffected) | Median % of Women | Median of Average Age (Yrs) | Community Setting | Ambulatory Setting | Surgical Cohort | Clinical Presentation Consistent With Appendicitis | Median % of Patients With Perforation
Adults | 55 (201/87/67) | 47.8% | 30.1 | 0.0% | 38.2% | 32.7% | 98.2% | 11.6%
Children | 43 (196/70/89) | 46.6% | 10.8 | 2.3% | 65.1% | 4.7% | 97.7% | 9.1%
Children <5yrs | 1 (27/17/10) | NA | NA | 0.0% | 100.0% | 0.0% | 100.0% | NA
Elderly | 1 (17/7/10) | NA | NA | 0.0% | 0.0% | 100.0% | 100.0% | 94.1%
Women of reproductive age | 15 (70/48/19) | 100.0% | 34.1 | 0.0% | 13.3% | 60.0% | 100.0% | 13.5%
Mixed | 72 (211/113/72) | 52.1% | 26.5 | 2.8% | 36.1% | 23.6% | 94.4% | 6.9%

N = number; NA = not applicable; yrs = years

Table 12 Assessment of risk of bias for studies evaluating score tests for the diagnosis of acute appendicitis

Patient Population | Consecutive or Random Sample of Patients | Study Avoided Inappropriate Exclusions | Index Test Results Interpreted Without Knowledge of Ref. Std. | Were the Positivity Criteria Prespecified? | Ref. Std. Results Interpreted Without Knowledge of Index Test | All Patients Received a Ref. Std. | All Patients Received the Same Ref. Std. | All Patients Received Pathology for Ref. Std. | All Patients Included in the Analysis
Adults | 67.3% | 100.0 | 65.5% | 49.1% | 3.6% | 92.7% | 34.5% | 30.9% | 72.7%
Children | 53.5% | 100.0 | 58.1% | 46.5% | 16.3% | 95.3% | 11.6% | 9.3% | 65.1%
Children <5yrs | 0.0% | 100.0 | 100.0% | 0.0% | 0.0% | 100.0% | 0.0% | 0.0% | 0.0%
Elderly | 100.0% | 0.0 | 100.0% | 0.0% | 100.0% | 100.0% | 100.0% | 100.0% | 100.0%
Women of reproductive age | 20.0% | 0.0 | 60.0% | 40.0% | 6.7% | 93.3% | 66.7% | 66.7% | 40.0%
Mixed | 67.3% | 100.0 | 65.5% | 49.1% | 3.6% | 92.7% | 34.5% | 30.9% | 72.7%

ref. std. = reference standard; yrs = year

Table 13 summarizes the variables and scoring systems used in five or more of the included studies. The most commonly used score was the Alvarado score (n=77), developed from a cohort of patients who all underwent appendectomy, and includes three items created by dichotomizing continuous predictors, white blood cell count (10 or more), neutrophil percentage (75% or more) and increased temperature (≥ 37.3 Celsius). Studies often (n=11) assessed variants of the Alvarado score neutrophil percentage is not reported (or reported in a delayed fashion) by some laboratories. Thus, subsequent papers have frequently modified the original Alvarado score by omitting this element.

Table 13 Components and scoring methods for appendicitis scores evaluated in at least five studies

Score | Components | Scoring Rule and Item Weights | Interpretation of Results
Alvarado score | Migration of pain | +1 | The score is obtained by summing the components using the weights. Higher values indicate higher probability of appendicitis. Maximum total score is 10. The modified Alvarado score omits Shift to the Left resulting in a total score of 9. For both scores, a low risk cutpoint of ≥ 5 and a high risk cutpont ≥7 were evaluated.
Alvarado score | Anorexia/Acetone | +1
Alvarado score | Nausea/Vomiting | +1
Alvarado score | Tenderness in RLQ | +2
Alvarado score | Rebound pain | +1
Alvarado score | Elevated temperature | +1
Alvarado score | Leukocytosis | +2
Alvarado score | Shift to left | +1
PAS | Pain with cough/percussion/hopping | +2 | This score was developed for use in children. A low risk cutpoint of ≥ 6 and a high risk cutpont ≥8 were evaluated.
PAS | Anorexia | +1 | This score was developed for use in children. A low risk cutpoint of ≥ 6 and a high risk cutpont ≥8 were evaluated.
PAS | Elevated temperature | +1 | This score was developed for use in children. A low risk cutpoint of ≥ 6 and a high risk cutpont ≥8 were evaluated.
PAS | Nausea/Vomiting | +1 | This score was developed for use in children. A low risk cutpoint of ≥ 6 and a high risk cutpont ≥8 were evaluated.
PAS | Tenderness over right iliac fossa | +2 | This score was developed for use in children. A low risk cutpoint of ≥ 6 and a high risk cutpont ≥8 were evaluated.
PAS | Leukocytosis | +1 | This score was developed for use in children. A low risk cutpoint of ≥ 6 and a high risk cutpont ≥8 were evaluated.
PAS | Shift to left | +1 | This score was developed for use in children. A low risk cutpoint of ≥ 6 and a high risk cutpont ≥8 were evaluated.
PAS | Migration of pain | +1 | This score was developed for use in children. A low risk cutpoint of ≥ 6 and a high risk cutpont ≥8 were evaluated.

PAS = Pediatric Appendicitis Score

Tables 14 and 15 summarize information on the test performance of various multivariable diagnostic scores. In general, their test performance appeared to be better than that of their component clinical symptoms and signs, but still lower than that of imaging tests. Figure 7 presents study results and summary ROC curves for selected multivariable diagnostic scores. Figure 8 shows the positive and negative predictive value for selected multivariable diagnostic scores, over appendicitis prevalence.

Table 14 Summary estimates of test performance of diagnostic score tests (low-risk cutoff) for the diagnosis of acute appendicitis

Test^*^ | Population | N Studies [Affected/Unaffected] | Sensitivity | Specificity | LR+ | LR−
AIR | Adults | 1 [392/437] | 0.83 | 0.63 | 2.26 | 0.27
AIR | Mixed | 2 [422/748] | 0.94 (0.93 to 0.96) | 0.79 (0.73 to 0.85) | 4.96 (3.58 to 6.34) | 0.07 (0.05 to 0.08)
Alvarado | Adults | 3 [407/264] | 0.91 (0.89 to 0.93) | 0.31 (0.24 to 0.78) | 1.35 (1.17 to 4.15) | 0.23 (0.11 to 0.45)
Alvarado | Children | 6 [674/898] | 0.99 (0.92 to 1.00) | 0.48 (0.24 to 0.74) | 1.88 (1.28 to 3.74) | 0.03 (0.00 to 0.20)
Alvarado | Mixed | 20 [3986/4073] | 0.96 (0.92 to 0.98) | 0.46 (0.34 to 0.58) | 1.77 (1.42 to 2.30) | 0.09 (0.04 to 0.21)
Alvarado | Women of reproductive age | 2 [89/50] | 0.99 (0.98 to 1.00) | 0.24 (0.22 to 0.25) | 1.30 (1.26 to 1.33) | 0.05 (0.00 to 0.09)
Alvarado | Children <5yrs | 1 [17/10] | 1.00 | 0.20 | 1.25 | 0.00
Alvarado modified | Adults | 1 [53/208] | 0.55 | 0.76 | 2.28 | 0.60
Alvarado modified | Children | 1 [38/80] | 0.87 | 0.49 | 1.69 | 0.27
Alvarado modified | Women of reproductive age | 1 [108/18] | 0.58 | 0.67 | 1.75 | 0.63
Alvarado modified + tenesmus | Adults | 1 [126/32] | 0.83 | 0.66 | 2.42 | 0.25
Alvarado modified + tenesmus | Women of reproductive age | 1 [45/18] | 0.84 | 0.67 | 2.53 | 0.23
Arnbjornsson | Adults | 1 [84/26] | 1.00 | 0.27 | 1.37 | 0.00
Arnbjornsson | Mixed | 1 [84/26] | 1.00 | 0.27 | 1.37 | 0.00
Bengezi | Mixed | 2 [132/96] | 0.99 (0.99 to 1.00) | 0.74 (0.54 to 0.94) | 8.99 (2.18 to 15.80) | 0.01 (0.00 to 0.01)
Eskelinen | Adults | 1 [87/114] | 0.83 | 0.92 | 10.48 | 0.19
High-risk criteria | Children | 1 [65/113] | 0.75 | 0.75 | 3.04 | 0.33
Jearwattanakanok | Women of reproductive age | 1 [197/105] | 0.92 | 0.79 | 4.39 | 0.10
Kharbanda | Children | 1 [929/1461] | 0.95 | 0.36 | 1.50 | 0.12
Kharbanda refined | Children | 1 [1018/1607] | 0.98 | 0.24 | 1.29 | 0.08
Leeuwenburgh | Adults | 2 [75/244] | 0.77 (0.71 to 0.83) | 0.73 (0.71 to 0.75) | 2.84 (2.82 to 2.86) | 0.31 (0.24 to 0.39)
Low-risk criteria | Children | 1 [65/113] | 0.97 | 0.41 | 1.63 | 0.08
Ohmann | Women of reproductive age | 1 [108/18] | 0.98 | 0.00 | 0.98 | NA
Teicher | Adults | 1 [87/114] | 0.89 | 0.83 | 5.31 | 0.14
de Dombal | Adults | 1 [87/114] | 0.80 | 0.73 | 2.96 | 0.27

AIR = appendicitis inflammatory response score; LR = likelihood ratio; N = number; PAS = pediatric appendicitis score; yrs = years

* First author name used as test name when not otherwise specified.

Sensitivity, specificity, and LR values are medians and 95% central credible intervals when 5 or more studies were available; medians and minimum to maximum values are reported when <5 studies were available; when a single study was available we report the estimate from that study.

Table 15 Factors that affect the performance of multivariable diagnostic scores

Test | Population | Cutoff Type | Subgroup | | N Studies | Sensitivity | Relative Sensitivity | Specificity | Relative Specificity
Alvarado | Adults | HR | Surgical cohorts | no | 8 | 0.67 (0.43 to 0.86) | 2.31 (0.52 to 9.83) | 0.86 (0.71 to 0.94) | 0.24 (0.07 to 0.86)
Alvarado | Adults | HR | Surgical cohorts | yes | 8 | 0.82 (0.61 to 0.94) | | 0.60 (0.37 to 0.78)
Alvarado | Mixed | HR | Study year | <2005 | 9 | 0.86 (0.76 to 0.93) | 0.41 (0.17 to 0.90) | 0.75 (0.61 to 0.84) | 1.46 (0.72 to 3.10)
Alvarado | Mixed | HR | Study year | >=2005 | 21 | 0.72 (0.62 to 0.80) | | 0.81 (0.74 to 0.87)
Alvarado | Mixed | LR | Study year | <2005 | 6 | 0.97 (0.91 to 0.99) | 0.53 (0.12 to 2.23) | 0.57 (0.37 to 0.75) | 0.55 (0.21 to 1.25)
Alvarado | Mixed | LR | Study year | >=2005 | 14 | 0.95 (0.89 to 0.98) | | 0.42 (0.29 to 0.55)
Alvarado | Mixed | HR | Ambulatory setting | no | 20 | 0.76 (0.65 to 0.84) | 1.32 (0.54 to 3.19) | 0.77 (0.69 to 0.83) | 1.61 (0.84 to 3.13)
Alvarado | Mixed | HR | Ambulatory setting | yes | 10 | 0.80 (0.66 to 0.90) | | 0.84 (0.75 to 0.90)
Alvarado | Mixed | LR | Ambulatory setting | no | 11 | 0.95 (0.87 to 0.98) | 1.64 (0.42 to 8.56) | 0.42 (0.26 to 0.58) | 1.43 (0.57 to 3.92)
Alvarado | Mixed | LR | Ambulatory setting | yes | 9 | 0.97 (0.91 to 0.99) | | 0.51 (0.34 to 0.68)
Alvarado | Mixed | HR | Surgical cohorts | no | 25 | 0.77 (0.67 to 0.84) | 1.14 (0.35 to 3.46) | 0.82 (0.77 to 0.86) | 0.31 (0.14 to 0.69)
Alvarado | Mixed | HR | Surgical cohorts | yes | 5 | 0.79 (0.57 to 0.91) | | 0.59 (0.41 to 0.75)

HR = high risk; N = number; LR = low risk

Sensitivity, relative sensitivity, specificity, and relative specificity values are medians and 95% central credible intervals when 5 or more studies were available; medians and minimum to maximum values are reported when <5 studies were available; when a single study was available we report the estimate from that study.

Figure 7 Scatterplot of study results in the receiver operating characteristic space and summary receiver operating characteristic curves for appendicitis diagnostic scores for the diagnosis of acute appendicitis

HR = high-risk cutoff; mod. = modified; LR = low-risk cutoff; PAS = pediatric appendicitis score

This figure includes seven scatterplot graphs showing 1-specificity (x axis, range 0.0 to 1.0) versus sensitivity (y axis, range 0.0 to 1.0) for Alvarado, modified Alvarado, and the Pediatric Appendicitis Scores in different populations with overlaid summary ROC curves. Test performance for scores is modest but better than for the individual components.

Figure 8 Positive predictive value and negative predictive value for appendicitis diagnostic scores for the diagnosis of acute appendicitis

HR = high-risk cutoff; mod. = modified; LR = low-risk cutoff; PAS = pediatric appendicitis score

This figure includes fifteen scatterplots showing prevalence (x axis, range 0.0 to 1.0) versus predicted value (y axis, range 0.0 to 1.0) for Alvarado, modified Alvarado, and the Pediatric Appendicitis Scores in different populations with overlaid summary curves. Test performance for scores is better than for the individual components (signs and symptoms and laboratory tests).

Table 16 summarizes the results of meta-regression analyses. There was some indication that the sensitivity of the Alvarado score has been lower in more recent studies (published from 2005 onwards).

Table 16 Summary estimates of test performance of diagnostic score tests (high-risk cutoff) for the diagnosis of acute appendicitis

Test^*^ | Population | N Studies [Affected/Unaffected] | Sensitivity | Specificity | LR+ | LR−
AIR | Adults | 1 [392/437] | 0.15 | 0.97 | 4.89 | 0.88
AIR | Mixed | 2 [422/748] | 0.24 (0.10 to 0.37) | 1.00 (0.99 to 1.00) | 56.37 (56.37 to 56.37) | 0.77 (0.64 to 0.90)
Alvarado | Adults | 16 [2354/1212] | 0.75 (0.59 to 0.87) | 0.75 (0.57 to 0.87) | 2.96 (1.85 to 5.09) | 0.34 (0.19 to 0.52)
Alvarado | Children | 9 [855/1163] | 0.85 (0.75 to 0.93) | 0.84 (0.61 to 0.96) | 5.44 (2.04 to 20.95) | 0.18 (0.08 to 0.36)
Alvarado | Mixed | 30 [4475/4337] | 0.77 (0.69 to 0.84) | 0.79 (0.74 to 0.84) | 3.71 (2.91 to 4.84) | 0.29 (0.21 to 0.39)
Alvarado | Women of reproductive age | 5 [202/177] | 0.70 (0.35 to 0.92) | 0.91 (0.65 to 0.99) | 7.22 (1.77 to 67.68) | 0.33 (0.10 to 0.76)
Alvarado | Children <5yrs | 1 [17/10] | 0.76 | 0.60 | 1.91 | 0.39
Alvarado modified | Adults | 4 [254/126] | 0.68 (0.54 to 0.89) | 0.60 (0.14 to 0.89) | 1.96 (1.04 to 5.91) | 0.61 (0.42 to 0.78)
Alvarado modified | Children | 5 [109/110] | 0.89 (0.71 to 0.98) | 0.80 (0.37 to 0.97) | 4.49 (1.40 to 29.49) | 0.15 (0.03 to 0.44)
Alvarado modified | Elderly | 1 [7/10] | 0.86 | 0.80 | 4.29 | 0.18
Alvarado modified | Mixed | 6 [412/139] | 0.82 (0.63 to 0.93) | 0.62 (0.24 to 0.89) | 2.13 (1.01 to 7.66) | 0.30 (0.11 to 0.96)
Alvarado modified | Women of reproductive age | 4 [186/69] | 0.60 (0.17 to 0.91) | 0.50 (0.17 to 1.00) | 1.15 (1.09 to 1.28) | 0.79 (0.55 to 0.83)
Alvarado modified + tenesmus | Adults | 1 [126/32] | 0.83 | 0.66 | 2.42 | 0.25
Alvarado modified + tenesmus | Women of reproductive age | 1 [45/18] | 0.84 | 0.67 | 2.53 | 0.23
Arnbjornsson | Adults | 1 [84/26] | 0.24 | 0.96 | 6.19 | 0.79
Arnbjornsson | Mixed | 1 [84/26] | 0.24 | 0.96 | 6.19 | 0.79
Bengezi | Mixed | 2 [132/96] | 0.50 (0.20 to 0.81) | 0.96 (0.92 to 1.00) | 9.69 (9.69 to 9.69) | 0.50 (0.21 to 0.80)
Garcia Pena | Children | 1 [588/370] | 0.97 | 0.35 | 1.49 | 0.07
High risk criteria | Children | 1 [65/113] | 0.75 | 0.75 | 3.04 | 0.33
Jearwattanakanok | Women of reproductive age | 1 [197/105] | 0.92 | 0.79 | 4.39 | 0.10
Kharbanda | Children | 1 [929/1461] | 0.95 | 0.36 | 1.50 | 0.12
Leeuwenburgh | Adults | 2 [75/244] | 0.77 (0.71 to 0.83) | 0.73 (0.71 to 0.75) | 2.84 (2.82 to 2.86) | 0.31 (0.24 to 0.39)
Ohmann | Mixed | 1 [65/113] | 0.97 | 0.41 | 1.63 | 0.08
Ohmann | Women of reproductive age | 1 [15/88] | 1.00 | 0.06 | 1.06 | 0.00
PAS | Children | 1 [108/18] | 0.95 | 0.11 | 1.07 | 0.42
de Dombal | Adults | 5 [600/1469] | 0.03 (0.00 to 0.13) | 1.00 (0.99 to 1.00) | 22.85 (1.75 to 376.20) | 0.97 (0.87 to 1.00)

AIR = appendicitis inflammatory response score; LR = likelihood ratio; N = number; PAS = pediatric appendicitis score; yrs = years

* First author name used as test name when not otherwise specified.

Sensitivity, specificity, and LR values are medians and 95% central credible intervals when 5 or more studies were available; medians and minimum to maximum values are reported when <5 studies were available; when a single study was available we report the estimate from that study.

### Test Performance of Imaging Tests

Five hundred and nineteen studies, published between 1965 and 2014, provided information on the test performance of imaging tests for the diagnosis of acute appendicitis. By far the most commonly evaluated tests included CT, US, and MRI.

Table 17 presents a summary of the descriptive characteristics of the studies. Table 18 presents a summary of key items related to study risk of bias. Studies of CT and MRI were at moderate risk of bias; studies of US and other imaging tests were at moderate to high risk of bias. In general, blinding of index test and reference standard assessors were either not used or relevant information was not reported; and most studies had differential verification.

Table 17 Descriptive characteristics for studies evaluating imaging tests for the diagnosis of acute appendicitis

Patient Population | N Studies (Median N Patients/Affected/Unaffected) | Median % of Women | Median of Average Age (Yrs) | Community Setting | Ambulatory Setting | Surgical Cohort | Clinical Presentation Consistent With Appendicitis | Median % of Patients With Perforation
Adults | 113 | 52.6% | 37.0 | 3.5% | 42.5% | 19.5% | 83.2% | 9.0%
Children | 137 | 49.3% | 10.6 | 2.2% | 35.0% | 13.1% | 86.9% | 12.3%
Children <5yrs | 0 | NA | NA | NA | NA | NA | NA | NA
Elderly | 4 (119/18.5/79) | 78.4% | 70.0 | 0.0% | 25.0% | 25.0% | 100.0% | 25.0%
Women of reproductive age | 26 (64/27/27) | 100.0% | 28.5 | 3.8% | 50.0% | 19.2% | 84.6% | 25.0%
Pregnant women | 26 (23/4/15) | 100.0% | 26.9 | 7.7% | 30.8% | 15.4% | 84.6% | 2.0%
Mixed | 241 | 54.5% | 30.6 | 6.6% | 32.0% | 19.1% | 87.6% | 6.9%

N = number; NA = not applicable; yrs = years

Table 18 Assessment of risk of bias for studies evaluating imaging tests for the diagnosis of acute appendicitis

Patient Population | Consecutive or Random Sample of Patients | Study Aavoided Inappropriate Exclusions | Index Test Results Interpreted Without Knowledge of Ref. Std. | Were the Positivity Criteria Prespecified? | Ref. Std. Results Interpreted Without Knowledge of Index Test | All Patients Received a Ref. Std. | All Patients Received the Same Ref. Std. | All Patients Received Pathology for Ref. Std. | All Patients Included in the Analysis
Adults | 68.1% | 100.0 | 62.8% | 34.5% | 20.4% | 97.3% | 26.5% | 24.8% | 79.6%
Children | 52.6% | 100.0 | 62.0% | 42.3% | 10.2% | 92.0% | 18.2% | 19.0% | 77.4%
Elderly | 100.0% | 100.0 | 75.0% | 25.0% | 25.0% | 100.0% | 25.0% | 25.0% | 75.0%
Women of reproductive age | 65.4% | 100.0 | 57.7% | 26.9% | 11.5% | 96.2% | 34.6% | 34.6% | 92.3%
Pregnant women | 76.9% | 100.0 | 73.1% | 26.9% | 15.4% | 100.0% | 23.1% | 23.1% | 84.6%
Mixed | 55.6% | 100.0 | 60.6% | 41.1% | 9.1% | 91.7% | 25.7% | 23.2% | 76.8%

ref. std. = reference standard

Table 19 presents a summary of key test performance results for imaging tests. CT and MRI had high sensitivity and specificity in all populations for which data were available; US had lower sensitivity and comparable specificity. Positive and negative likelihood ratios were generally higher for CT and MRI, as compared to US, but all three tests had likelihood ratios that are clinically relevant. US also had substantially higher rates of non-diagnostic exams (the median percentage of non-diagnostic scans for CT was lower than 6% for all populations examined; the median proportion was substantially higher for US). However, the reporting of information on non-diagnostic scans was inconsistent across studies, raising concerns reporting bias. Computed tomography (CT) had high sensitivity (summary estimates ranging from 0.95 to 1) and specificity (ranging from 0.91 to 0.99) in all populations of interest to this report. MRI had high sensitivity (ranging from 0.91 to 1) but appeared to have variable specificity (ranging from 0.86 to 1), mainly due to the smaller number of available studies, which focused on its use for pregnant women. In adult populations, US had lower sensitivity (0.83) and specificity (0.89) than CT (0.96, both for sensitivity and specificity) and MRI, and produced more non-diagnostic scans. In children, the specificity of US was similar to that of CT (0.92 vs.0.91), but CT had greater sensitivity (0.89 vs. 0.96); these results were based on a large number of studies (72 for US and 32 for US). In the same patient population, MRI had a specificity of 0.99 and sensitivity of 1, but data were derived from only 3 studies. Among pregnant women, CT, MRI, and US had similar specificity (0.98, 0.98, and 0.95, respectively), but CT and MRI had higher sensitivity than US (0.95, 0.98, and 0.73, respectively).

Table 19 Summary estimates of test performance of imaging tests for the diagnosis of acute appendicitis

Test | Population | N Studies [Affected/Unaffected] | Sensitivity | Specificity | LR+ | LR− | Median % Nondiagnostic (Range)
Abdominal X x-ray | Adults | 3 [29/1007] | 0.38 (0.00 to 0.86) | 1.00 (1.00 to 1.00) | NA | 0.63 (0.14 to 1.00) | NA
Abdominal X x-ray | Children | 6 [925/784] | 0.68 (0.24 to 0.94) | 0.83 (0.42 to 0.97) | 3.79 (0.92 to 22.86) | 0.41 (0.08 to 1.06) | 31.3 (0.00 to 62.54)
Abdominal X x-ray | Mixed | 9 [1096/994] | 0.36 (0.10 to 0.75) | 0.94 (0.82 to 0.98) | 5.86 (1.47 to 23.17) | 0.68 (0.28 to 0.96) | 0.0 (0.00 to 0.00)
Barium enema | Children | 5 [88/53] | 0.91 (0.66 to 0.99) | 0.77 (0.57 to 0.91) | 3.87 (1.92 to 10.07) | 0.12 (0.01 to 0.46) | 20.5 (1.69 to 39.39)
Barium enema | Mixed | 5 [185/206] | 0.97 (0.90 to 1.00) | 0.87 (0.53 to 0.98) | 7.70 (2.08 to 42.82) | 0.03 (0.01 to 0.12) | 11.2 (7.57 to 14.85)
CT | Adults | 72 [7833/14469] | 0.96 (0.95 to 0.97) | 0.96 (0.93 to 0.97) | 21.83 (14.77 to 33.46) | 0.04 (0.03 to 0.05) | 4.0 (0.00 to 43.95)
CT | Children | 34 [3581/3122] | 0.96 (0.94 to 0.98) | 0.92 (0.85 to 0.96) | 12.13 (6.57 to 24.47) | 0.04 (0.02 to 0.06) | 5.7 (0.00 to 43.62)
CT | Elderly | 4 [144/582] | 1.00 (0.94 to 1.00) | 1.00 (0.43 to 1.00) | 55.32 (1.64 to 109.00) | 0.00 (0.00 to 0.15) | 0.0 (0.00 to 0.00)
CT | Women of reproductive age | 11 [596/652] | 0.99 (0.96 to 1.00) | 0.91 (0.75 to 0.97) | 10.65 (3.95 to 34.31) | 0.01 (0.00 to 0.05) | 2.0 (0.00 to 17.53)
CT | Pregnant women | 5 [26/84] | 0.99 (0.96 to 1.00) | 0.91 (0.75 to 0.97) | 10.65 (3.95 to 34.31) | 0.01 (0.00 to 0.05) | 0.0 (0.00 to 9.09)
CT | Mixed | 93 [9341/10357] | 0.96 (0.95 to 0.97) | 0.94 (0.91 to 0.95) | 15.00 (11.02 to 20.75) | 0.04 (0.03 to 0.05) | 3.3 (0.00 to 28.28)
MRI | Adults | 7 [512/467] | 0.95 (0.88 to 0.98) | 0.92 (0.87 to 0.95) | 11.56 (7.08 to 19.98) | 0.06 (0.02 to 0.14) | 5.4 (0.00 to 5.83)
MRI | Children | 7 [359/665] | 0.97 (0.87 to 1.00) | 0.96 (0.84 to 0.99) | 26.62 (5.94 to 123.70) | 0.03 (0.00 to 0.13) | 0.0 (0.00 to 0.48)
MRI | Women of reproductive age | 1 [50/88] | 1.00 | 0.86 | 7.33 | 0.00 | NA
MRI | Pregnant women | 11 [76/570] | 0.98 (0.92 to 1.00) | 0.98 (0.96 to 1.00) | 52.55 (26.44 to 263.00) | 0.02 (0.00 to 0.08) | 3.5 (0.00 to 48.48)
MRI | Mixed | 5 [243/141] | 0.94 (0.83 to 0.99) | 1.00 (0.97 to 1.00) | 311.70 (32.07 to 16750.00) | 0.06 (0.01 to 0.17) | 8.7 (0.00 to 41.79)
TC99M Nuclear | Adults | 5 [110/113] | 0.88 (0.76 to 0.96) | 0.97 (0.88 to 1.00) | 26.80 (7.46 to 228.90) | 0.12 (0.04 to 0.25) | 0.0 (0.00 to 0.00)
TC99M Nuclear | Children | 7 [141/185] | 0.93 (0.78 to 0.99) | 0.83 (0.63 to 0.94) | 5.55 (2.31 to 15.80) | 0.08 (0.02 to 0.29) | 12.1 (0.00 to 24.24)
TC99M Nuclear | Women of reproductive age | 4 [57/73] | 0.91 (0.75 to 0.93) | 0.89 (0.86 to 1.00) | 6.50 (6.00 to 9.33) | 0.10 (0.07 to 0.29) | 10.0 (0.00 to 20.00)
TC99M Nuclear | Pregnant women | 1 [2/11] | 0.50 | 0.73 | 1.83 | 0.69 | NA
TC99M Nuclear | Mixed | 11 [271/395] | 0.92 (0.84 to 0.97) | 0.89 (0.79 to 0.97) | 8.72 (4.16 to 26.93) | 0.09 (0.03 to 0.19) | 0.0 (0.00 to 47.71)
US | Adults | 38 [3560/3656] | 0.85 (0.79 to 0.90) | 0.90 (0.83 to 0.95) | 8.49 (5.00 to 15.67) | 0.17 (0.11 to 0.24) | 29.6 (4.07 to 63.08)
US | Children | 85 [8539/15167] | 0.89 (0.86 to 0.92) | 0.91 (0.89 to 0.94) | 10.35 (7.80 to 13.95) | 0.12 (0.09 to 0.16) | 9.8 (0.00 to 79.23)
US | Women of reproductive age | 11 [516/539] | 0.72 (0.51 to 0.88) | 0.92 (0.75 to 0.98) | 8.67 (2.97 to 35.50) | 0.31 (0.14 to 0.53) | 0.0 (0.00 to 0.00)
US | Pregnant women | 13 [188/198] | 0.72 (0.45 to 0.92) | 0.95 (0.84 to 0.99) | 13.10 (4.43 to 63.18) | 0.30 (0.09 to 0.58) | 77.3 (0.00 to 96.97)
US | Mixed | 125 [11902/14314] | 0.86 (0.83 to 0.89) | 0.90 (0.87 to 0.92) | 8.24 (6.43 to 10.69) | 0.15 (0.12 to 0.19) | 8.9 (0.00 to 75.76)

CT = computed tomography; LR = likelihood ratio; MRI = magnetic resonance imaging; N = number; NA = not applicable; TC99M = technetium-99m ; US = ultrasound

Sensitivity, specificity, and LR values are medians and 95% central credible intervals when 5 or more studies were available; medians and minimum to maximum values are reported when <5 studies were available; when a single study was available we report the estimate from that study.

Figure 9 presents study results and summary ROC curves for selected imaging tests. Studies of CT exhibited low heterogeneity in sensitivity and moderate heterogeneity in specificity; studies of US exhibited more heterogeneity, both for sensitivity and specificity. Studies of MRI had relatively homogeneous sensitivity and specificity, but the number of available studies was too limited to draw conclusions about consistency. Studies of other tests showed moderate heterogeneity. For all imaging tests, in most cases, summary ROC lines appeared to fit the data relatively well. Figure 10 shows the positive and negative predictive value for selected imaging tests, over appendicitis prevalence.

Figure 9 Scatterplot of results in the receiver operating characteristic space and summary receiver operating characteristic curves for selected imaging tests for the diagnosis of acute appendicitis

CT = computed tomography; US = ultrasound; MRI = magnetic resonance imaging; rep. = reproductive; sens. = sensitivity; spec. = specificity

This figure includes thirteen scatterplot graphs showing 1-specificity (x axis, range 0.0 to 1.0) versus sensitivity (y axis, range 0.0 to 1.0) for different imaging tests in different populations with overlaid summary ROC curves. For CT and MRI, most markers are clustered toward the top left corner, indicating high sensitivity and specificity. Ultrasound is somewhat less sensitive and spsecific, but better than signs and symptoms and laboratory values.

Figure 10 Positive predictive value and negative predictive value curves for selected imaging tests for the diagnosis of acute appendicitis

CT = computed tomography; US = ultrasound; MRI = magnetic resonance imaging; rep. = reproductive

This figure includes fifteen scatterplots showing prevalence (x axis, range 0.0 to 1.0) versus predicted value (y axis, range 0.0 to 1.0) for different imaging tests in different populations with overlaid summary curves. For CT and MRI, the curves indicate high PPV and NPV. Ultrasound is somewhat less accurate, but better than signs and symptoms and laboratory values.

Sensitivity analyses using test readings from worse performing raters (see methods section for a description of details of these analyses) produced results that were similar to our main analyses (which used test readings from the rater with the highest sum of sensitivity and specificity). Sensitivity analyses for the impact of indeterminate test results produced test performance estimates that were lower than the main analyses; the deterioration of performance was more pronounced for US (as compared to CT and MRI), reflecting the higher rate of indeterminate results. The complete sensitivity analyses are presented in Appendix D.

#### Factors That Affect the Test Performance of Imaging Tests

Table 20 summarizes the results of meta-regression analyses for various factors that may affect the performance of imaging tests for the diagnosis of acute appendicitis.

Table 20 Meta-regression results for factors that affect the performance of imaging tests for the diagnosis of acute appendicitis

Test | Population | Subgroup | | N Studies | Sensitivity | Relative Sensitivity | Specificity | Relative Specificity
CT | Adults | Study year | <2005 | 25 | 0.96 (0.93 to 0.98) | 1.24 (0.63 to 2.42) | 0.94 (0.90 to 0.97) | 1.44 (0.58 to 3.37)
CT | Adults | Study year | >=2005 | 47 | 0.97 (0.95 to 0.98) | | 0.96 (0.94 to 0.98)
CT | Adults | Oral contrast | no | 39 | 0.95 (0.93 to 0.97) | 1.82 (1.01 to 3.21) | 0.96 (0.93 to 0.98) | 0.93 (0.40 to 2.11)
CT | Adults | Oral contrast | yes | 33 | 0.97 (0.96 to 0.98) | | 0.95 (0.92 to 0.98)
CT | Adults | IV contrast | no | 28 | 0.95 (0.93 to 0.97) | 1.57 (0.85 to 2.92) | 0.94 (0.89 to 0.97) | 1.64 (0.71 to 4.00)
CT | Adults | IV contrast | yes | 44 | 0.97 (0.96 to 0.98) | | 0.96 (0.94 to 0.98)
CT | Adults | Rectal contrast | no | 63 | 0.96 (0.95 to 0.97) | 1.49 (0.59 to 3.82) | 0.96 (0.94 to 0.98) | 0.29 (0.08 to 1.01)
CT | Adults | Rectal contrast | yes | 9 | 0.97 (0.94 to 0.99) | | 0.88 (0.69 to 0.96)
CT | Adults | Multiple contrast (NOS) | no | 42 | 0.96 (0.94 to 0.97) | 1.60 (0.86 to 2.91) | 0.96 (0.94 to 0.98) | 0.62 (0.27 to 1.45)
CT | Adults | Multiple contrast (NOS) | yes | 30 | 0.97 (0.96 to 0.98) | | 0.94 (0.90 to 0.97)
CT | Adults | Ambulatory setting | no | 36 | 0.97 (0.96 to 0.98) | 0.64 (0.36 to 1.15) | 0.94 (0.89 to 0.96) | 2.12 (0.91 to 4.74)
CT | Adults | Ambulatory setting | yes | 36 | 0.96 (0.93 to 0.97) | | 0.97 (0.95 to 0.98)
CT | Adults | Surgical cohorts | no | 62 | 0.96 (0.95 to 0.97) | 1.11 (0.46 to 2.65) | 0.96 (0.95 to 0.98) | 0.16 (0.05 to 0.45)
CT | Adults | Surgical cohorts | yes | 10 | 0.97 (0.93 to 0.99) | | 0.80 (0.61 to 0.92)
CT | Adults | Appendicitis presentation | atypical/other/unclear | 12 | 0.95 (0.90 to 0.98) | 1.57 (0.66 to 3.47) | 0.96 (0.92 to 0.99) | 0.79 (0.25 to 2.05)
CT | Adults | Appendicitis presentation | typical | 60 | 0.97 (0.95 to 0.98) | | 0.95 (0.93 to 0.97)
CT | Children | Study year | <2005 | 14 | 0.95 (0.91 to 0.98) | 1.67 (0.62 to 4.53) | 0.92 (0.79 to 0.97) | 1.05 (0.27 to 4.75)
CT | Children | Study year | >=2005 | 20 | 0.97 (0.95 to 0.99) | | 0.92 (0.83 to 0.97)
CT | Children | Oral contrast | no | 24 | 0.95 (0.92 to 0.97) | 3.22 (1.11 to 10.10) | 0.93 (0.85 to 0.97) | 0.70 (0.17 to 3.21)
CT | Children | Oral contrast | yes | 10 | 0.98 (0.96 to 0.99) | | 0.90 (0.73 to 0.97)
CT | Children | IV contrast | no | 22 | 0.95 (0.92 to 0.98) | 2.11 (0.74 to 6.49) | 0.93 (0.85 to 0.97) | 0.68 (0.16 to 2.85)
CT | Children | IV contrast | yes | 12 | 0.98 (0.95 to 0.99) | | 0.90 (0.74 to 0.97)
CT | Children | Rectal contrast | no | 27 | 0.95 (0.93 to 0.97) | 3.53 (1.10 to 12.07) | 0.93 (0.86 to 0.97) | 0.46 (0.09 to 2.37)
CT | Children | Rectal contrast | yes | 7 | 0.99 (0.96 to 1.00) | | 0.86 (0.59 to 0.97)
CT | Children | Multiple contrast (NOS) | no | 23 | 0.95 (0.92 to 0.97) | 3.13 (1.16 to 9.34) | 0.93 (0.84 to 0.97) | 0.81 (0.19 to 3.25)
CT | Children | Multiple contrast (NOS) | yes | 11 | 0.98 (0.96 to 0.99) | | 0.91 (0.75 to 0.97)
CT | Children | Ambulatory setting | no | 23 | 0.97 (0.94 to 0.98) | 0.75 (0.26 to 2.19) | 0.90 (0.79 to 0.95) | 2.38 (0.58 to 9.79)
CT | Children | Ambulatory setting | yes | 11 | 0.96 (0.91 to 0.98) | | 0.95 (0.87 to 0.99)
CT | Women of reproductive age | Study year | <2005 | 5 | 1.00 (0.97 to 1.00) | 0.15 (0.01 to 2.91) | 0.85 (0.53 to 0.97) | 2.61 (0.26 to 20.83)
CT | Women of reproductive age | Study year | >=2005 | 6 | 0.98 (0.89 to 1.00) | | 0.93 (0.76 to 0.98)
CT | Women of reproductive age | IV contrast | no | 5 | 1.00 (0.97 to 1.00) | 0.18 (0.01 to 3.78) | 0.90 (0.63 to 0.98) | 1.13 (0.10 to 10.81)
CT | Women of reproductive age | IV contrast | yes | 6 | 0.98 (0.89 to 1.00) | | 0.91 (0.67 to 0.98)
CT | Women of reproductive age | Multiple contrast (NOS) | no | 5 | 1.00 (0.96 to 1.00) | 0.24 (0.01 to 4.82) | 0.91 (0.63 to 0.98) | 1.06 (0.10 to 10.92)
CT | Women of reproductive age | Multiple contrast (NOS) | yes | 6 | 0.98 (0.90 to 1.00) | | 0.91 (0.66 to 0.98)
CT | Women of reproductive age | Ambulatory setting | no | 6 | 0.99 (0.91 to 1.00) | 3.21 (0.13 to 73.13) | 0.86 (0.59 to 0.97) | 2.57 (0.26 to 18.29)
CT | Women of reproductive age | Ambulatory setting | yes | 5 | 1.00 (0.95 to 1.00) | | 0.94 (0.76 to 0.99)
CT | Mixed | Study year | <2005 | 40 | 0.96 (0.94 to 0.97) | 1.12 (0.68 to 1.90) | 0.94 (0.90 to 0.96) | 0.94 (0.48 to 1.80)
CT | Mixed | Study year | >=2005 | 53 | 0.96 (0.95 to 0.97) | | 0.93 (0.90 to 0.96)
CT | Mixed | Oral contrast | no | 70 | 0.96 (0.95 to 0.97) | 1.23 (0.67 to 2.25) | 0.93 (0.91 to 0.95) | 1.16 (0.55 to 2.45)
CT | Mixed | Oral contrast | yes | 23 | 0.97 (0.94 to 0.98) | | 0.94 (0.89 to 0.97)
CT | Mixed | IV contrast | no | 57 | 0.95 (0.94 to 0.97) | 1.49 (0.89 to 2.59) | 0.93 (0.89 to 0.95) | 1.46 (0.73 to 2.84)
CT | Mixed | IV contrast | yes | 36 | 0.97 (0.95 to 0.98) | | 0.95 (0.92 to 0.97)
CT | Mixed | Community setting | no | 85 | 0.96 (0.95 to 0.97) | 0.68 (0.31 to 1.49) | 0.94 (0.91 to 0.96) | 0.85 (0.28 to 2.80)
CT | Mixed | Community setting | >=2005 | 8 | 0.94 (0.89 to 0.97) | | 0.93 (0.81 to 0.98)
CT | Mixed | Rectal contrast | no | 76 | 0.96 (0.95 to 0.97) | 0.99 (0.51 to 1.91) | 0.94 (0.91 to 0.96) | 1.00 (0.43 to 2.41)
CT | Mixed | Rectal contrast | yes | 17 | 0.96 (0.93 to 0.98) | | 0.94 (0.87 to 0.97)
CT | Mixed | Multiple contrast (NOS) | no | 67 | 0.96 (0.94 to 0.97) | 1.42 (0.81 to 2.59) | 0.93 (0.90 to 0.95) | 1.17 (0.53 to 2.50)
CT | Mixed | Multiple contrast (NOS) | yes | 26 | 0.97 (0.95 to 0.98) | | 0.94 (0.90 to 0.97)
CT | Mixed | Ambulatory setting | no | 67 | 0.96 (0.94 to 0.97) | 1.41 (0.80 to 2.47) | 0.90 (0.87 to 0.93) | 4.16 (2.05 to 8.32)
CT | Mixed | Ambulatory setting | yes | 26 | 0.97 (0.95 to 0.98) | | 0.98 (0.96 to 0.99)
CT | Mixed | Surgical cohorts | no | 73 | 0.96 (0.95 to 0.97) | 0.99 (0.54 to 1.85) | 0.95 (0.93 to 0.97) | 0.20 (0.09 to 0.45)
CT | Mixed | Surgical cohorts | yes | 20 | 0.96 (0.93 to 0.98) | | 0.80 (0.67 to 0.89)
CT | Mixed | Appendicitis presentation | atypical/other/unclear | 15 | 0.95 (0.92 to 0.97) | 1.18 (0.64 to 2.19) | 0.97 (0.93 to 0.98) | 0.45 (0.20 to 1.11)
CT | Mixed | Appendicitis presentation | typical | 78 | 0.96 (0.95 to 0.97) | | 0.93 (0.90 to 0.95)
US | Adults | Study year | <2005 | 13 | 0.87 (0.75 to 0.93) | 0.83 (0.31 to 2.13) | 0.88 (0.70 to 0.96) | 1.48 (0.39 to 6.05)
US | Adults | Study year | >=2005 | 25 | 0.84 (0.76 to 0.90) | | 0.91 (0.83 to 0.96)
US | Adults | Ambulatory setting | no | 24 | 0.89 (0.83 to 0.93) | 0.38 (0.17 to 0.88) | 0.89 (0.79 to 0.95) | 1.31 (0.32 to 4.73)
US | Adults | Ambulatory setting | yes | 14 | 0.75 (0.61 to 0.86) | | 0.91 (0.79 to 0.97)
US | Adults | Surgical cohorts | no | 27 | 0.85 (0.77 to 0.91) | 0.99 (0.38 to 2.77) | 0.92 (0.86 to 0.96) | 0.35 (0.10 to 1.26)
US | Adults | Surgical cohorts | yes | 11 | 0.85 (0.72 to 0.93) | | 0.81 (0.58 to 0.93)
US | Adults | Appendicitis presentation | atypical/other/unclear | 8 | 0.77 (0.56 to 0.89) | 1.93 (0.78 to 5.59) | 0.94 (0.83 to 0.98) | 0.53 (0.10 to 1.78)
US | Adults | Appendicitis presentation | typical | 30 | 0.87 (0.80 to 0.92) | | 0.89 (0.80 to 0.94)
US | Children | Study year | <2005 | 39 | 0.88 (0.82 to 0.92) | 1.13 (0.62 to 2.20) | 0.94 (0.90 to 0.96) | 0.56 (0.32 to 1.11)
US | Children | Study year | >=2005 | 46 | 0.89 (0.85 to 0.93) | | 0.89 (0.85 to 0.93)
US | Children | Ambulatory setting | no | 57 | 0.88 (0.84 to 0.92) | 1.11 (0.59 to 2.09) | 0.90 (0.86 to 0.93) | 1.85 (0.99 to 3.55)
US | Children | Ambulatory setting | yes | 28 | 0.90 (0.84 to 0.94) | | 0.94 (0.91 to 0.96)
US | Children | Surgical cohorts | no | 74 | 0.89 (0.85 to 0.92) | 1.02 (0.44 to 2.50) | 0.92 (0.90 to 0.94) | 0.28 (0.12 to 0.76)
US | Children | Surgical cohorts | yes | 11 | 0.89 (0.79 to 0.95) | | 0.78 (0.60 to 0.90)
US | Children | Appendicitis presentation | atypical/other/unclear | 10 | 0.96 (0.90 to 0.98) | 0.33 (0.14 to 0.87) | 0.90 (0.79 to 0.96) | 1.16 (0.46 to 3.22)
US | Children | Appendicitis presentation | typical | 75 | 0.88 (0.84 to 0.91) | | 0.92 (0.89 to 0.94)
US | Mixed | Study year | <2005 | 67 | 0.85 (0.80 to 0.89) | 1.19 (0.68 to 1.97) | 0.90 (0.86 to 0.93) | 0.90 (0.51 to 1.58)
US | Mixed | Study year | >=2005 | 58 | 0.87 (0.82 to 0.91) | | 0.89 (0.84 to 0.92)
US | Mixed | Community setting | no | 118 | 0.87 (0.83 to 0.90) | 0.56 (0.18 to 1.77) | 0.89 (0.86 to 0.92) | 1.82 (0.59 to 5.58)
US | Mixed | Community setting | >=2005 | 7 | 0.78 (0.55 to 0.92) | | 0.94 (0.83 to 0.98)
US | Mixed | Ambulatory setting | no | 87 | 0.83 (0.79 to 0.87) | 2.12 (1.20 to 3.82) | 0.88 (0.84 to 0.91) | 1.68 (0.94 to 3.05)
US | Mixed | Ambulatory setting | yes | 38 | 0.91 (0.87 to 0.95) | | 0.92 (0.88 to 0.95)
US | Mixed | Surgical cohorts | no | 104 | 0.88 (0.84 to 0.91) | 0.47 (0.24 to 0.95) | 0.91 (0.88 to 0.93) | 0.49 (0.23 to 1.01)
US | Mixed | Surgical cohorts | yes | 21 | 0.77 (0.64 to 0.86) | | 0.82 (0.70 to 0.90)
US | Mixed | Appendicitis presentation | atypical/other/unclear | 13 | 0.93 (0.83 to 0.97) | 0.46 (0.18 to 1.27) | 0.95 (0.88 to 0.98) | 0.46 (0.16 to 1.12)
US | Mixed | Appendicitis presentation | typical | 112 | 0.85 (0.82 to 0.89) | | 0.89 (0.86 to 0.91)

CT = computed tomography; IV = intravenous; N = number; NOS = not otherwise specified; US = ultrasound

Sensitivity, relative sensitivity, specificity, and relative specificity values are medians and 95% central credible intervals when 5 or more studies were available; medians and minimum to maximum values are reported when <5 studies were available; when a single study was available we report the estimate from that study.

The vast majority of studies did not report adequate data to assess factors that may affect test performance (i.e., based on within study comparisons); for this reason we relied on comparisons across studies (via meta-regression analyses) to identify factors that may affect test performance. Overall, no distinct pattern emerged to establish a particular factor as a modifier of test performance. For all factors examined but CrIs were wide, indicating substantial uncertainty regarding the relative test performance of tests over levels of the modifiers we examined.

#### Impact of Study Risk of Bias Items on Estimated Test Performance

Table 21 summarizes the results of meta-regression analyses for various factors that may affect the performance of imaging tests for the diagnosis of acute appendicitis. In some cases items related to study risk of bias appeared to be associated with worse test performance of various clinical symptoms and signs. Specifically, for CT in adult populations, differential verification and blinding of index test assessors were associated with higher specificity. For CT in children, incomplete verification was associated with higher sensitivity. For CT in mixed populations differential verification was associated with higher specificity and partial verification was associated with lower sensitivity. For US in adults, the use of prespecified positivity criteria were associated with higher sensitivity. For US in children complete verification was associated with higher sensitivity. For US in mixed populations differential verification was associated with higher sensitivity and specificity, partial verification was associated with lower sensitivity, and using a consecutive or random sample of patients was associated with higher sensitivity.

Table 21 Meta-regression results for the impact of risk of bias items on the estimated test performance of imaging tests for the diagnosis of acute appendicitis

Test | Population | Subgroup | | N Studies | Sensitivity | Relative Sensitivity | Specificity | Relative Specificity
CT | Adults | Pre-specified positivity criteria | no | 48 | 0.96 (0.94 to 0.97) | 1.55 (0.81 to 3.08) | 0.95 (0.92 to 0.97) | 1.25 (0.51 to 3.03)
CT | Adults | Pre-specified positivity criteria | yes | 24 | 0.97 (0.96 to 0.99) | | 0.96 (0.92 to 0.98)
CT | Adults | Blinding ref. std. to index test results | no | 59 | 0.97 (0.95 to 0.98) | 0.74 (0.35 to 1.60) | 0.96 (0.94 to 0.97) | 0.79 (0.25 to 2.34)
CT | Adults | Blinding ref. std. to index test results | yes | 13 | 0.96 (0.92 to 0.98) | | 0.95 (0.87 to 0.98)
CT | Adults | All pts. received same ref. std. | no | 56 | 0.96 (0.95 to 0.97) | 1.23 (0.59 to 2.71) | 0.97 (0.96 to 0.98) | 0.13 (0.06 to 0.30)
CT | Adults | All pts. received same ref. std. | yes | 16 | 0.97 (0.94 to 0.99) | | 0.80 (0.66 to 0.89)
CT | Adults | All pts. included in the analysis | no | 13 | 0.94 (0.89 to 0.97) | 1.86 (0.80 to 4.03) | 0.96 (0.90 to 0.98) | 0.89 (0.31 to 2.52)
CT | Adults | All pts. included in the analysis | yes | 59 | 0.97 (0.96 to 0.98) | | 0.96 (0.93 to 0.97)
CT | Adults | Pathology (100%) | no | 56 | 0.96 (0.95 to 0.98) | 1.14 (0.57 to 2.37) | 0.97 (0.95 to 0.98) | 0.16 (0.07 to 0.38)
CT | Adults | Pathology (100%) | yes | 16 | 0.97 (0.94 to 0.98) | | 0.83 (0.71 to 0.92)
CT | Adults | Consecutive/random sample | no | 19 | 0.98 (0.95 to 0.99) | 0.62 (0.32 to 1.32) | 0.95 (0.89 to 0.98) | 1.12 (0.43 to 3.05)
CT | Adults | Consecutive/random sample | yes | 53 | 0.96 (0.95 to 0.97) | | 0.96 (0.93 to 0.97)
CT | Adults | Blinding index tests | no | 31 | 0.96 (0.94 to 0.97) | 1.32 (0.71 to 2.46) | 0.93 (0.88 to 0.96) | 2.66 (1.17 to 5.89)
CT | Adults | Blinding index tests | yes | 41 | 0.97 (0.95 to 0.98) | | 0.97 (0.95 to 0.98)
CT | Children | Pre-specified positivity criteria | no | 23 | 0.96 (0.94 to 0.98) | 0.93 (0.32 to 2.86) | 0.89 (0.79 to 0.95) | 2.64 (0.59 to 11.55)
CT | Children | Pre-specified positivity criteria | yes | 11 | 0.96 (0.92 to 0.99) | | 0.96 (0.87 to 0.99)
CT | Children | All pts. received same ref. std. | no | 28 | 0.96 (0.94 to 0.98) | 0.85 (0.26 to 2.95) | 0.94 (0.89 to 0.97) | 0.12 (0.03 to 0.56)
CT | Children | All pts. received same ref. std. | yes | 6 | 0.96 (0.89 to 0.99) | | 0.67 (0.33 to 0.90)
CT | Children | All pts. included in the analysis | no | 7 | 0.98 (0.96 to 0.99) | 0.36 (0.11 to 1.14) | 0.92 (0.75 to 0.98) | 0.94 (0.21 to 4.78)
CT | Children | All pts. included in the analysis | yes | 27 | 0.95 (0.92 to 0.97) | | 0.92 (0.84 to 0.96)
CT | Children | Pathology (100%) | no | 28 | 0.96 (0.94 to 0.98) | 1.03 (0.29 to 3.67) | 0.95 (0.91 to 0.97) | 0.07 (0.02 to 0.30)
CT | Children | Pathology (100%) | yes | 6 | 0.96 (0.90 to 0.99) | | 0.56 (0.27 to 0.82)
CT | Children | Consecutive/random sample | no | 15 | 0.97 (0.95 to 0.99) | 0.58 (0.19 to 1.58) | 0.90 (0.76 to 0.96) | 1.78 (0.40 to 6.63)
CT | Children | Consecutive/random sample | yes | 19 | 0.96 (0.92 to 0.98) | | 0.94 (0.85 to 0.98)
CT | Children | Blinding index tests | no | 15 | 0.97 (0.95 to 0.99) | 0.61 (0.18 to 1.59) | 0.93 (0.82 to 0.97) | 0.81 (0.21 to 3.54)
CT | Children | Blinding index tests | yes | 19 | 0.96 (0.92 to 0.98) | | 0.91 (0.81 to 0.97)
CT | Women of reproductive age | All pts. received same ref. std. | no | 6 | 0.99 (0.93 to 1.00) | 1.15 (0.05 to 22.91) | 0.96 (0.87 to 0.99) | 0.15 (0.03 to 0.92)
CT | Women of reproductive age | All pts. received same ref. std. | yes | 5 | 0.99 (0.93 to 1.00) | | 0.77 (0.49 to 0.93)
CT | Women of reproductive age | Pathology (100%) | no | 6 | 0.99 (0.93 to 1.00) | 1.15 (0.05 to 22.91) | 0.96 (0.87 to 0.99) | 0.15 (0.03 to 0.92)
CT | Women of reproductive age | Pathology (100%) | yes | 5 | 0.99 (0.93 to 1.00) | | 0.77 (0.49 to 0.93)
CT | Mixed | Pre-specified positivity criteria | no | 49 | 0.96 (0.95 to 0.98) | 0.78 (0.47 to 1.28) | 0.93 (0.89 to 0.95) | 1.29 (0.65 to 2.47)
CT | Mixed | Pre-specified positivity criteria | yes | 44 | 0.95 (0.94 to 0.97) | | 0.94 (0.91 to 0.96)
CT | Mixed | Blinding ref. std. to index test results | no | 83 | 0.96 (0.95 to 0.97) | 0.96 (0.43 to 2.10) | 0.93 (0.91 to 0.95) | 1.71 (0.60 to 4.74)
CT | Mixed | Blinding ref. std. to index test results | yes | 10 | 0.96 (0.92 to 0.98) | | 0.96 (0.90 to 0.98)
CT | Mixed | All pts. received a ref. std. | no | 6 | 0.95 (0.89 to 0.98) | 1.23 (0.50 to 3.10) | 0.92 (0.78 to 0.97) | 1.32 (0.37 to 4.43)
CT | Mixed | All pts. received a ref. std. | yes | 87 | 0.96 (0.95 to 0.97) | | 0.94 (0.91 to 0.95)
CT | Mixed | All pts. received same ref. std. | no | 65 | 0.96 (0.95 to 0.97) | 0.74 (0.43 to 1.26) | 0.96 (0.95 to 0.97) | 0.15 (0.08 to 0.27)
CT | Mixed | All pts. received same ref. std. | yes | 28 | 0.95 (0.93 to 0.97) | | 0.78 (0.68 to 0.85)
CT | Mixed | All pts. included in the analysis | no | 26 | 0.94 (0.91 to 0.96) | 1.84 (1.06 to 3.15) | 0.92 (0.86 to 0.96) | 1.28 (0.57 to 2.78)
CT | Mixed | All pts. included in the analysis | yes | 67 | 0.97 (0.96 to 0.97) | | 0.94 (0.91 to 0.96)
CT | Mixed | Pathology (100%) | no | 67 | 0.96 (0.95 to 0.97) | 0.92 (0.53 to 1.57) | 0.96 (0.95 to 0.97) | 0.14 (0.07 to 0.25)
CT | Mixed | Pathology (100%) | yes | 26 | 0.96 (0.94 to 0.97) | | 0.76 (0.66 to 0.85)
CT | Mixed | Consecutive/random sample | no | 35 | 0.96 (0.94 to 0.97) | 0.96 (0.57 to 1.60) | 0.92 (0.88 to 0.95) | 1.33 (0.67 to 2.58)
CT | Mixed | Consecutive/random sample | yes | 58 | 0.96 (0.95 to 0.97) | | 0.94 (0.91 to 0.96)
CT | Mixed | Blinding index tests | no | 39 | 0.96 (0.95 to 0.98) | 0.82 (0.49 to 1.37) | 0.92 (0.87 to 0.95) | 1.52 (0.74 to 2.98)
CT | Mixed | Blinding index tests | yes | 54 | 0.96 (0.94 to 0.97) | | 0.95 (0.92 to 0.96)
US | Adults | Pre-specified positivity criteria | no | 26 | 0.80 (0.71 to 0.87) | 2.99 (1.21 to 6.81) | 0.89 (0.79 to 0.95) | 1.59 (0.44 to 5.13)
US | Adults | Pre-specified positivity criteria | yes | 12 | 0.92 (0.85 to 0.96) | | 0.92 (0.81 to 0.97)
US | Adults | All pts. received same ref. std. | no | 23 | 0.85 (0.76 to 0.91) | 0.93 (0.37 to 2.39) | 0.93 (0.87 to 0.97) | 0.31 (0.09 to 1.03)
US | Adults | All pts. received same ref. std. | yes | 15 | 0.84 (0.73 to 0.92) | | 0.81 (0.63 to 0.92)
US | Adults | All pts. included in the analysis | no | 7 | 0.90 (0.76 to 0.96) | 0.59 (0.18 to 1.83) | 0.80 (0.47 to 0.95) | 2.66 (0.49 to 16.28)
US | Adults | All pts. included in the analysis | yes | 31 | 0.84 (0.76 to 0.90) | | 0.92 (0.85 to 0.96)
US | Adults | Pathology (100%) | no | 24 | 0.87 (0.79 to 0.92) | 0.72 (0.30 to 1.83) | 0.93 (0.87 to 0.97) | 0.31 (0.09 to 1.04)
US | Adults | Pathology (100%) | yes | 14 | 0.82 (0.69 to 0.91) | | 0.80 (0.61 to 0.92)
US | Adults | Consecutive/random sample | no | 13 | 0.85 (0.73 to 0.92) | 0.96 (0.42 to 2.49) | 0.81 (0.63 to 0.92) | 3.04 (0.91 to 10.30)
US | Adults | Consecutive/random sample | yes | 25 | 0.85 (0.77 to 0.91) | | 0.93 (0.87 to 0.97)
US | Adults | Blinding index tests | no | 14 | 0.80 (0.67 to 0.90) | 1.64 (0.62 to 3.86) | 0.89 (0.76 to 0.96) | 1.28 (0.38 to 3.85)
US | Adults | Blinding index tests | yes | 24 | 0.87 (0.80 to 0.92) | | 0.91 (0.82 to 0.95)
US | Children | Pre-specified positivity criteria | no | 50 | 0.87 (0.83 to 0.91) | 1.43 (0.79 to 2.62) | 0.90 (0.86 to 0.93) | 1.48 (0.82 to 2.88)
US | Children | Pre-specified positivity criteria | yes | 35 | 0.91 (0.86 to 0.94) | | 0.93 (0.89 to 0.96)
US | Children | Blinding ref. std. to index test results | no | 78 | 0.88 (0.85 to 0.91) | 1.68 (0.57 to 5.51) | 0.92 (0.89 to 0.94) | 0.84 (0.29 to 2.56)
US | Children | Blinding ref. std. to index test results | yes | 7 | 0.93 (0.82 to 0.98) | | 0.90 (0.77 to 0.96)
US | Children | All pts. received same ref. std. | no | 68 | 0.88 (0.84 to 0.91) | 1.84 (0.88 to 3.89) | 0.93 (0.91 to 0.95) | 0.17 (0.08 to 0.35)
US | Children | All pts. received same ref. std. | yes | 17 | 0.93 (0.87 to 0.96) | | 0.71 (0.56 to 0.82)
US | Children | All pts. included in the analysis | no | 22 | 0.88 (0.80 to 0.93) | 1.17 (0.58 to 2.28) | 0.92 (0.86 to 0.96) | 0.90 (0.44 to 1.89)
US | Children | All pts. included in the analysis | yes | 63 | 0.89 (0.85 to 0.92) | | 0.91 (0.88 to 0.94)
US | Children | Pathology (100%) | no | 66 | 0.88 (0.84 to 0.91) | 1.46 (0.73 to 2.82) | 0.93 (0.91 to 0.95) | 0.24 (0.12 to 0.48)
US | Children | Pathology (100%) | yes | 19 | 0.91 (0.85 to 0.95) | | 0.77 (0.64 to 0.86)
US | Children | Consecutive/random sample | no | 39 | 0.87 (0.81 to 0.91) | 1.50 (0.82 to 2.70) | 0.94 (0.91 to 0.96) | 0.53 (0.28 to 0.98)
US | Children | Consecutive/random sample | yes | 46 | 0.91 (0.86 to 0.94) | | 0.89 (0.84 to 0.92)
US | Children | Blinding index tests | no | 32 | 0.86 (0.79 to 0.91) | 1.53 (0.86 to 2.97) | 0.91 (0.86 to 0.94) | 1.17 (0.62 to 2.15)
US | Children | Blinding index tests | yes | 53 | 0.90 (0.87 to 0.93) | | 0.92 (0.88 to 0.94)
US | Mixed | Pre-specified positivity criteria | no | 73 | 0.85 (0.80 to 0.89) | 1.29 (0.78 to 2.23) | 0.87 (0.82 to 0.90) | 1.91 (1.13 to 3.25)
US | Mixed | Pre-specified positivity criteria | yes | 52 | 0.88 (0.83 to 0.92) | | 0.93 (0.89 to 0.95)
US | Mixed | Blinding ref. std. to index test results | no | 116 | 0.86 (0.82 to 0.89) | 1.37 (0.52 to 3.88) | 0.89 (0.86 to 0.92) | 1.20 (0.43 to 3.42)
US | Mixed | Blinding ref. std. to index test results | yes | 9 | 0.89 (0.77 to 0.96) | | 0.91 (0.79 to 0.97)
US | Mixed | All pts. received a ref. std. | no | 11 | 0.87 (0.74 to 0.95) | 0.89 (0.34 to 2.23) | 0.91 (0.80 to 0.97) | 0.78 (0.28 to 2.26)
US | Mixed | All pts. received a ref. std. | yes | 114 | 0.86 (0.83 to 0.89) | | 0.89 (0.86 to 0.92)
US | Mixed | All pts. received same ref. std. | no | 95 | 0.89 (0.86 to 0.92) | 0.38 (0.21 to 0.67) | 0.91 (0.89 to 0.93) | 0.39 (0.21 to 0.72)
US | Mixed | All pts. received same ref. std. | yes | 30 | 0.75 (0.65 to 0.83) | | 0.80 (0.70 to 0.88)
US | Mixed | All pts. included in the analysis | no | 34 | 0.78 (0.68 to 0.85) | 2.15 (1.24 to 4.14) | 0.88 (0.81 to 0.93) | 1.28 (0.67 to 2.31)
US | Mixed | All pts. included in the analysis | yes | 91 | 0.89 (0.85 to 0.91) | | 0.90 (0.87 to 0.93)
US | Mixed | Pathology (100%) | no | 99 | 0.89 (0.86 to 0.91) | 0.35 (0.19 to 0.62) | 0.91 (0.88 to 0.93) | 0.43 (0.22 to 0.83)
US | Mixed | Pathology (100%) | yes | 26 | 0.73 (0.61 to 0.82) | | 0.81 (0.71 to 0.89)
US | Mixed | Consecutive/random sample | no | 53 | 0.83 (0.76 to 0.88) | 1.58 (0.90 to 2.71) | 0.88 (0.83 to 0.92) | 1.24 (0.71 to 2.28)
US | Mixed | Consecutive/random sample | yes | 72 | 0.88 (0.84 to 0.92) | | 0.90 (0.87 to 0.93)
US | Mixed | Blinding index tests | no | 52 | 0.85 (0.79 to 0.90) | 1.18 (0.70 to 2.06) | 0.89 (0.85 to 0.93) | 1.05 (0.60 to 1.80)
US | Mixed | Blinding index tests | yes | 73 | 0.87 (0.83 to 0.91) | | 0.90 (0.86 to 0.93)

CT = computed tomography; MRI = magnetic resonance imaging; N = number; pts. = patients; US = ultrasound Sensitivity, relative sensitivity, specificity, and relative specificity values are medians and 95% central credible intervals when 5 or more studies were available; medians and minimum to maximum values are reported when <5 studies were available; when a single study was available we report the estimate from that study.

These results suggest that study conduct may have affected estimates of test performance in meta-analyses of imaging tests. However, our analyses relied on information that was often poorly reported in the primary studies and meta-regression results were often imprecise, indicating substantial uncertainty. Because each risk of bias item was examined individually, and because different items may be correlated between them and with other study characteristics that may affect performance estimates, we do not believe that definitive conclusions about specific items can be reached.

### Classifiers and Computer-Aided Diagnosis

We also identified 52 studies of various multivariable classifiers (other than diagnostic scores). We did not extract detailed information from these studies because they generally did not report results in a way that would allow the use of the classifiers in current practice or described software that is not currently applicable. For completeness, a list of these studies is provided in Appendix E.

### Test Performance of Diagnostic Laparoscopy

Fifty-five studies, published between 1974 and 2014, reported information on the test performance of diagnostic laparoscopy. The sample sizes ranged from 23 to 1899, and prevalence of appendicitis ranged from 3 to 95 percent, with a median of 65 percent.

The reporting of methods and test performance outcomes in these studies was less complete than that of studies of other tests. In addition, studies had heterogeneous (and often incompletely reported) policies for the management of cases when laparoscopy did not reveal an inflamed appendix or no other pathology. Such differences can influence the estimates of test performance and for this reason we did not perform any quantitative synthesis for the test performance of diagnostic laparoscopy. It is important to note that patients included in studies of diagnostic laparoscopy (e.g., have more severe symptoms, or have atypical findings in other) are different from patients included in studies of non-invasive tests (even if the selection criteria are not clearly presented). Thus, indirect comparisons among test categories are not likely to be meaningful.

Because of the generally poor reporting, quality assessment of these studies was challenging. Most reported their criteria for a positive laparoscopic examination, but did not discuss how and when it was established. The reference standard varied across studies and populations. Generally, more than 90 percent of enrolled patients were included in the analysis and received a reference standard, but in approximately half of the studies there was differential verification.

Sixteen studies looked at laparoscopy in women of reproductive age. This was the only subgroup reported on in more than two studies. Mean and median ages ranged from 21 to 30. Prevalence ranged from 39 to 92 percent of the population (median 59%). These results are reported along with the others below.

#### Tests Positive for Appendicitis

Generally, tests were reported as positive for appendicitis when the appendix appeared inflamed, though the precise definition varied across studies. Forty-two studies reported on this outcome. The median total positive diagnoses in those receiving diagnostic laparoscopy was 64 percent (min 23%, max 100%, 25^th^ percentile 51%, 75^th^ percentile 78%). The median correct diagnoses of appendicitis in those receiving diagnostic laparoscopy was 57 percent (min 16%, max 100%, 25^th^ percentile 47%, 75^th^ percentile 75%). The median incorrect diagnoses of appendicitis in those receiving diagnostic laparoscopy was 0 percent (min 0%, max 21%, 25^th^ percentile 0 %, 75^th^ percentile 6%).

In 16 studies of women of reproductive age, the median total positive diagnoses in those receiving diagnostic laparoscopy was 64 percent (min 22%, max 92%, 25^th^ percentile 56%, 75^th^ percentile 74%). The median correct diagnoses of appendicitis in those receiving diagnostic laparoscopy was 57 percent (min 16%, max 92%, 25^th^ percentile 53%, 75^th^ percentile 68%). The median proportion of incorrect diagnoses of appendicitis in those receiving diagnostic laparoscopy was 3 percent (min 0%, max 1%, 25^th^ percentile 0%, 75^th^ percentile 6.5%).

#### Sensitivity and Specificity

For the 54 studies for which they could be calculated, the median sensitivity and specificity were 100 and 89 percent, respectively. However, there was a wide range with sensitivity ranging from 37 to 100 percent (25^th^ percentile 95%, 75^th^ percentile 100%) and specificity ranging from 0 to 100 percent (25^th^ percentile 73%, 75^th^ percentile 100%). This variability likely reflects the heterogeneous populations evaluated in these studies (which often do not describe the details of patient selection).

In the 16 studies that reported on women of reproductive age, the median sensitivity was 100 percent (min 90%, max100%, 25^th^ percentile 100%, 75^th^ percentile 100%), and the median specificity was 89 percent (min 73%, max 100%, 25^th^ percentile 79%, 75^th^ percentile 100%).

#### Tests Positive for Other Pathology

Forty-one studies reported some information on other pathology diagnosed at laparoscopy. The median proportion of patients with non-appendiceal pathology identified was 22 percent (min 0%, max 71%, 25^th^ percentile 11.5%, 75^th^ percentile 34%). Only six small studies reported that other pathology was found when appendicitis was also present. The median was 5 percent (min 0.5%, max 20%, 25^th^ percentile 2%, 75^th^ percentile 13%). In nine studies of women of reproductive age, the median proportion of patients with non-appendiceal pathology identified was 23 percent (min 6%, max 40%, 25^th^ percentile 18%, 75^th^ percentile 26%), none were in patients who also had appendicitis.

#### Appendix not Visualized (Indeterminate Findings)

Twenty-six studies reported at least partially on inability to visualize the appendix. The median was 6 percent (min 1%, max 51%, 25^th^ percentile 3%, 75^th^ percentile 10%). These were slightly more likely to be negative than positive. Median proportions were 2.6 percent and 1 percent, respectively. The range for patients without appendicitis was 0 to 51 percent (25^th^ percentile 1%, 75^th^ percentile 6%). The range for those with appendicitis was 0 to 30 percent (25^th^ percentile 0%, 75^th^ percentile 7%). In ten studies of women of reproductive age, the median was 5 percent (min 3%, max 17%, 25^th^ percentile 4.5%, 75^th^ percentile 8%). In this population, there was little difference between those with and without appendicitis. The median proportion with appendicitis was 3.5 percent (min 0%, max 10%, 25^th^ percentile 0%, 75^th^ percentile 6%). The median proportion without appendicitis was 3 percent (min 1%, max 19%, 25^th^ percentile 2%, 75^th^ percentile 6%).

#### No Cause Found

Thirty-five studies gave information on cases in which the appendix appeared normal and no other pathology was found. The median percentage of patients who had diagnostic laparoscopy with no pathology found was 11 percent (min 5%, max 26%, 25^th^ percentile 8%, 75^th^ percentile 18%). Again, these were more likely to be patient without appendicitis. The median was 4 percent with appendicitis and 9 percent without. The range for patients without appendicitis was 2 to 29 percent (25^th^ percentile 5%, 75^th^ percentile 14%). The range for those with appendicitis was 1 to 9 percent (25^th^ percentile 1%, 75^th^ percentile 5%), but these were less likely to be reported (9 studies).

In ten studies of women of reproductive age, the percentage of patients who had diagnostic laparoscopy with no pathology found was only reported for those without appendicitis. The median was 13 percent (min 2%, max 29%, 25^th^ percentile 8%, 75^th^ percentile 19%).

#### Risk of Bias in Studies of Diagnostic Laparoscopy

Most studies enrolled patients using a consecutive or random sampling method, one explicitly stated that the authors used a convenience sample, and the sampling method was unclear in 25. Thirty-one studies avoided inappropriate exclusions, but this could not be assessed in 24.

In 46 studies it was clear that the index test results were interpreted without knowledge of the results of the reference standard, but this was unclear in nine. Only two studies reported that the criterion for a positive diagnostic laparoscopy was prespecified, 52 were unclear, and one clearly did not use a prespecified threshold. Only four studies clearly stated that the reference standard results were interpreted without knowledge of the results of the index test; 51 were unclear.

The reference standard varied widely among studies from all receiving pathologic diagnosis to some receiving pathologic diagnosis and others receiving some sort of followup. In 40 studies the reference standard was deemed likely to correctly classify the target condition, one clearly was not, and in 14 studies it was unclear. Fifteen studies reported an appropriate interval between index tests and reference standard, six clearly did not have an appropriate interval, 13 were unclear, and in 21 this was not applicable because all patients had verification by pathology. Fifty studies had all patients receiving a reference standard, one had partial verification, and four were unclear. Nearly all studies (53) included all patients in the analysis, one did not, and the other as unclear. However, because of the fact that the reference standard varied based on index test in some studies, 24 studies had all patients receive the same reference standard, 28 had patients receiving different reference standards, and three were unclear.

### Comparative Assessments of Test Performance

Information on comparative test performance was sparse. The majority of included studies assessed a single index test; thus allowing only indirect comparisons among tests of interest (i.e., comparisons based on the test specific estimates presented in the preceding sections of this chapter). Because studies differ in many ways, including the patient populations they sample, the selection criteria they use, and the specific implementation of the various test strategies, cross-study comparisons provide only weak evidence regarding comparative test performance (because any differences in test performance may be attributable to cross-study differences in factors other than specific test assessed). For this reason, our assessment of comparative test performance relied primarily on randomized and non-randomized direct comparisons (i.e., within-study) of tests.

#### Randomized Comparisons of Alternative Tests

Thirty-six RCTs reported information on comparative test performance; all studies had a parallel arm design (i.e., none used a paired design). Overall, on the basis of items from the Cochrane risk of bias tool, RCTs were deemed to be at moderate risk of bias. Details on the risk of bias of individual studies are presented in the next chapter of this report (Key Question 2) because the studies assessed outcomes beyond test performance. Results on selected test performance comparison are summarized in Tables 22 to 25; additional extracted data are presented in Appendix F. Data were sparse because each possible contrast (between alternative test strategies or versions of a test strategy) were typically examined by one or two trials and because not all trials reported information on the same outcomes. Studies were small, produced imprecise results, therefore we could not make any definitive conclusions about the relative test performance of the strategies compared based on RCTs.

Table 22 Test performance comparisons in randomized trials – CT versus standard of care

Author, Year [PMID] | Contrast | Sensitivity Group 1 | Sensitivity Group 2 | Difference in Sensitivity | Specificity Group 1 | Specificity Group 2 | Difference in Specificity | Accuracy Group 1 | Accuracy Group 2 | Difference in Accuracy
Hong, 2003 [14588157] | Clinical observation and abdominal/pelvic CT vs. clinical observation alone (women of reproductive age) | 5/5 | 11/11 | (−0.25 to 0.25); p = 1.000 | 22/24 | 7/8 | 0.04 (−0.21 to 0.30); p = 0.748 | 27/29 | 18/19 | −0.02 (−0.15 to 0.12); p = 0.814
| Clinical observation and abdominal/pelvic CT vs. Clinical observation alone (total study population) | 30/33 | 42/42 | −0.09 (−0.20 to 0.02); p = 0.096 | 42/45 | 19/26 | 0.20 (0.02 to 0.39); p = 0.032 | 72/78 | 61/68 | 0.03 (−0.07 to 0.12); p = 0.585
Lopez, 2007 [18186378] | Clinical observation and abdominal/pelvic CT vs. clinical observation alone | 17/19 | 22/22 | −0.11 (−0.26 to 0.05); p = 0.188 | 22/23 | 21/24 | 0.08 (−0.07 to 0.24); p = 0.307 | 39/42 | 43/46 | −0.01 (−0.11 to 0.10); p = 0.908
Walker, 2000 [11182396] | Limited CT scan with colorectal contrast vs. standard management | 30/32 | 29/29 | −0.06 (−0.16 to 0.04); p = 0.226 | 25/25 | 27/34 | 0.21 (0.06 to 0.35); p = 0.006 | 55/57 | 56/63 | 0.08 (−0.02 to 0.17); p = 0.102

CI = confidence interval; CT = computed tomography

Trial groups are numbered in the order they are described in the corresponding “Contrast”. Differences between groups are calculated by subtracting group 2 values from group 1 values and are presented with corresponding 95% CIs.

Table 23 Test performance comparisons in randomized trials – alternative CT strategies

Author, Year [PMID] | Contrast | Sensitivity Group 1 | Sensitivity Group 2 | Difference in Sensitivity | Specificity Group 1 | Specificity Group 2 | Difference in Specificity | Accuracy Group 1 | Accuracy Group 2 | Difference in Accuracy
Hekimoglu, 2011 [22191292] | IV and oral contrast enhanced CT vs. IV contrast-enhanced CT (Radiologist 1) | 31/32 | 21/25 | 0.13 (−0.03 to 0.28); p = 0.105 | 67/68 | 71/75 | 0.04 (−0.02 to 0.10); p = 0.194 | 98/100 | 92/100 | 0.06 (0.00 to 0.12); p = 0.049
| IV and oral contrast enhanced CT vs. IV contrast-enhanced CT (Radiologist 2) | 30/32 | 18/25 | 0.22 (0.02 to 0.41); p = 0.029 | 66/68 | 67/75 | 0.08 (0.00 to 0.16); p = 0.060 | 96/100 | 85/100 | 0.11 (0.03 to 0.19); p = 0.007
Hershko, 2007 [17566826] | IV and oral contrast-enhanced CT vs. nonenhanced CT (Radiologist 1) | 43/43 | 19/21 | 0.10 (−0.04 to 0.23); p = 0.171 | 36/41 | 30/35 | 0.02 (−0.13 to 0.17); p = 0.789 | 79/84 | 49/56 | 0.07 (−0.03 to 0.17); p = 0.201
| IV and oral contrast-enhanced CT vs. rectal contrast-enhanced CT (Radiologist 1) | 43/43 | 37/39 | 0.05 (−0.03 to 0.13); p = 0.216 | 36/41 | 36/39 | −0.05 (−0.18 to 0.09); p = 0.499 | 79/84 | 73/78 | (−0.07 to 0.08); p = 0.904
Kepner, 2012 [22633722] | IV contrast-enhanced CT vs. IV and oral contrast-enhanced CT | 41/41 | 35/35 | (−0.05 to 0.05); p = 1.000 | 72/73 | 75/78 | 0.02 (−0.03 to 0.08); p = 0.335 | 113/114 | 110/113 | 0.02 (−0.02 to 0.05); p = 0.309
Hershko, 2007 [17566826] | Rectal contrast-enhanced CT vs. nonenhanced CT (Radiologist 1) | 37/39 | 19/21 | 0.04 (−0.10 to 0.19); p = 0.548 | 36/39 | 30/35 | 0.07 (−0.08 to 0.21); p = 0.366 | 73/78 | 49/56 | 0.06 (−0.04 to 0.16); p = 0.243
Mittal, 2004 [15136349] | Standard triple-contrast abdominopelvic CT scan vs. focused pelvic scan with rectal contrast only | 43/44 | 36/36 | −0.02 (−0.09 to 0.04); p = 0.488 | 4/8 | 3/3 | −0.50 (−0.96 to −0.04); p = 0.033 | 47/52 | 39/39 | −0.10 (−0.19 to −0.01); p = 0.034
Kim, 2012 [22533576] | Standard-dose CT vs. low-dose CT | 171/180 | 156/165 | (−0.04 to 0.05); p = 0.850 | 244/260 | 250/268 | (−0.04 to 0.05); p = 0.792 | 415/440 | 406/433 | (−0.03 to 0.04); p = 0.730

CI = confidence interval; CT = computed tomography; IV = intravenous

Trial groups are numbered in the order they are described in the corresponding “Contrast”. Differences between groups are calculated by subtracting group 2 values from group 1 values and are presented with corresponding 95% CIs.

Table 24 Test performance comparisons in randomized trials – CT versus US

Author, Year [PMID] | Contrast | Sensitivity Group 1 | Sensitivity Group 2 | Difference in Sensitivity | Specificity Group 1 | Specificity Group 2 | Difference in Specificity | Accuracy Group 1 | Accuracy Group 2 | Difference in Accuracy
Horton, 2000 [10930484] | CT vs. US | 36/37 | 23/25 | 0.05 (−0.07 to 0.17); p = 0.381 | 9/12 | 1/3 | 0.42 (−0.17 to 1.00); p = 0.164 | 45/49 | 24/28 | 0.06 (−0.09 to 0.21); p = 0.426
Kaiser, 2002 [12034928] | US + CT vs. US only | 133/135 | 94/109 | 0.12 (0.05 to 0.19); p < 0.001 | 162/182 | 165/174 | −0.06 (−0.11 to 0.00); p = 0.042 | 295/317 | 259/283 | 0.02 (−0.03 to 0.06); p = 0.481

CI = confidence interval; CT = computed tomography; US = ultrasound

Trial groups are numbered in the order they are described in the corresponding “Contrast”. Differences between groups are calculated by subtracting group 2 values from group 1 values and are presented with corresponding 95% CIs.

Table 25 Test performance comparisons in randomized trials – multivariable diagnostic scores versus no scores

Author, Year [PMID] | Contrast | Sensitivity Group 1 | Sensitivity Group 2 | Difference in Sensitivity | Specificity Group 1 | Specificity Group 2 | Difference in Specificity | Accuracy Group 1 | Accuracy Group 2 | Difference in Accuracy
Lintula, 2009 [18841382] | Management based on a diagnostic scoring system for children vs. standard clinical assessment and management | 24/24 | 26/27 | (−0.06 to 0.14); p = 0.467 | 37/42 | 23/33 | 0.18 (0.00 to 0.37); p = 0.051 | 61/66 | 49/60 | 0.11 (−0.01 to 0.22); p = 0.071
Lintula, 2010 [20379739] | Management based on a diagnostic scoring system for children vs. standard clinical assessment and management | 45/52 | 32/36 | −0.02 (−0.16 to 0.11); p = 0.739 | 26/44 | 36/45 | −0.21 (−0.40 to −0.02); p = 0.028 | 71/96 | 68/81 | −0.10 (−0.22 to 0.02); p = 0.099

CI = confidence interval

Trial groups are numbered in the order they are described in the corresponding “Contrast”. Differences between groups are calculated by subtracting group 2 values from group 1 values and are presented with corresponding 95% CIs.

#### Nonrandomized Comparisons of Alternative Tests

Non-randomized studies of test performance were not synthesized with RCTs because the latter were deemed to be at substantial risk of bias (confounding and selection bias) and often provided inadequate information to understand their design (see below).

##### Nonrandomized Comparisons of CT and US

Fifty-three studies reported results in cohorts using both CT and US as index tests, potentially permitting direct (within-study) nonrandomized comparisons of these modalities. Ten studies investigated CT as a replacement for US, 13 investigated US as a triage test for CT, and 30 studies were unclear about the actual role of testing that was being evaluated (studies often used convenience samples of patients that were selected using criteria that were often not reported; results from these studies are presented in Figure 11 for completeness; though these studies suggested that CT generally has better test performance than US, the strength of this evidence was itself weakened by the lack of information on the exact study design).

Figure 11 Test performance results in studies evaluating both CT and US as index tests

CT = computed tomography; OR = odds ratio; PMID = PubMed identification number; US = ultrasound

Forest plot of results from studies assessing CT and US as index tests. Studies are ordered by the magnitude of the difference between the diagnostic OR of CT and US and are labeled by their first author, year of publication, and PMID. Both panels: top group of studies = studies evaluating US as a triage test for CT; middle group of studies = studies evaluating CT as a replacement test for US, bottom = studies where the role of testing evaluated was unclear. Capital letters in the y-axis label denote the population enrolled: A = adults; C = children; M = mixed; R = women of reproductive age; P = pregnant women. Left panel: diagnostic ORs for CT (black circles) and US (white circles), with corresponding confidence intervals; greater values denote better test performance. Right panel relative ORs comparing the test performance of CT and US (relative ORs are not shown for studies evaluating US as a triage test); values > 1 denote better test performance by CT (as compared to US). X-axis scale is logarithmic on both panels. For paired designs we have assumed that the correlation between the diagnostic ORs of the tests being compared is 0 (this correlation was not reported in the primary studies). This is a conservative assumption (i.e., it leads to wide confidence intervals) because the correlation is generally expected to be positive, and accounting for it would result in narrower confidence intervals compared to those depicted in the graph.

This figure shows a forest plot of results from studies assessing CT and US as index tests. Studies are labeled by their first author, year of publication, and PMID. Capital letters in the y-axis label denote the population enrolled. The left panel shows diagnostic ORs for CT (black circles) and US (white circles), with corresponding confidence intervals; greater values denote better test performance. the right panel shows relative ORs comparing the test performance of CT and US. In both panels, the top group of studies are studies evaluating US as a triage test for CT, the middle group of studies are studies evaluating CT as a replacement test for US, and the bottom group of studies are studies where the role of testing evaluated was unclear. X-axis scale is logarithmic on both panels. For paired designs we have assumed that the correlation between the diagnostic ORs of the tests being compared is 0 (this correlation was not reported in the primary studies). This is a conservative assumption (i.e., it leads to wide confidence intervals) because the correlation is generally expected to be positive, and accounting for it would result in narrower confidence intervals compared to those depicted in the graph. In general, these plots show that CT had better test performance than US.

Nine of the studies had a paired design (both tests applied to the same patient group) and 44 had a parallel group design (separate groups of patients received each test). Figure 11 presents diagnostic ORs from these studies (higher values indicate better performance) and relative diagnostic ORs (comparing CT vs. US; values higher than 1 indicate that CT had better test performance that US). In general, CT had better test performance than US, when used as a replacement test. In the triage context, CT had high test performance (diagnostic odds ratios higher than 10 and often higher than 100) in patient populations selected on the basis of US results (typically, nondiagnostic US findings, or negative findings in the presence of symptoms suggestive of appendicitis).

##### Nonrandomized Comparisons of MRI and US

Eight studies reported results in cohorts using both MRI and US as index tests, potentially permitting direct (within-study) nonrandomized comparisons of these modalities. Four studies investigated MRI as a replacement for US, one investigated US as a triage test for MRI, and three studies were unclear about the actual role of testing that was being evaluated (these studies tended to use convenience samples of patients that were selected for a specific test using criteria that were often not reported; this studies were included in the review for completeness; however, the strength of the evidence they provide is weakened by the lack of information on the exact study design). Four of the studies had a paired design (both tests applied to the same patient group) and four had a parallel group design (separate groups of patients received each test). Studies investigating MRI as a replacement test suggested that MRI, when used as a replacement test for US has greater test performance, however the available studies are few and have produced rather imprecise results.

##### Nonrandomized Comparisons of Diagnostic Scores

Eight studies reported direct comparisons among alternative diagnostic scores for appendicitis.68–70 25,71–74 Three studies included children, one included women of reproductive age, and four included mixed populations. Five of the studies reported results on three or more score cutoffs, and their results are shown in Figure 12. Across all eight studies, differences in test performance between scores were small; this was particularly true for the comparison of the Alvarado and PAS scores applied to children with suspected acute appendicitis. The one exception was a study that compared a multivariable diagnostic score based on clinical symptoms and signs versus a score combining the same clinical variables with the addition of US: incorporation of US information improved test performance substantially, with respect to both sensitivity and specificity.74

Figure 12 Receiver operating characteristic curves from studies comparing two or more appendicitis diagnostic scores

Mod. = modified; PAS = pediatric appendicitis score; US = ultrasound

Each panel represents a within-study comparison among two or more diagnostic scores. Study results were used to reconstruct the empirical receiver operating characteristic curves. In the study by Galindo et al. the empirical ROC curve appears to not be monotonic; we have verified our data extraction against the paper and we believe that this may be the results of a reporting or typographical error in the publication.

This figure includes five line graphs, showing 1-specificity (x axis, range 0.0 to 1.0) versus sensitivity (y axis, range 0.0 to 1.0) for a within-study comparison among two or more diagnostic scores. Study results were used to reconstruct the empirical receiver operating characteristic curves. The first three show Alvarado compared to Pediatric Appendicitis Score in children. Athough the shape of the curves differs somewhat, the Alvarado and PAS score lines are very closely aligned. In the foruth graph, showing a study by Galindo et al., the empirical ROC curve appears to not be monotonic; we have verified our data extraction against the paper and we believe that this may be the results of a reporting or typographical error in the publication. In this figure, the Galinod score plus US line is more sensitive and specific than the classic Galindo score line. The final graph shows similar performance between the modified Alvarado, Eskelinen, and Ohman scores, though none is particularly specific or sensitive.

## Key Question 2 What is the comparative effectiveness of alternative diagnostic tests, alone or in combination, for patients with RLQ pain and suspected acute appendicitis?

### Included Studies With Information on the Comparative Effectiveness of Alternative Test Strategies

Fifty-four studies provided information on the comparative effectiveness of alternative test strategies (36 RCTs and 18 NRCSs) in patients with RLQ pain. We only considered RCTs and NRCSs for the assessment of comparative effectiveness. Indirect (cross-study) comparisons for such outcomes are likely to be confounded by factors that differ across studies. We only considered NRCSs that enrolled at least 1000 patients because comparative effectiveness outcomes are relatively rare; as such, a large sample is needed to obtain reliable estimates of effect – especially if statistical adjustments for possible confounders are to be performed. Detailed information from the included RCTs and NRCS is presented in Appendix F; key study characteristics and findings are summarized below. Because pregnant women are underrepresented in RCTs and NRCSs of alternative test strategies, we collected information on fetal and maternal outcomes from non-comparative cohort studies that enrolled at least 10 patients. Many of the included studies were small and may have produced unstable estimates of event rates, as well as treatment effects. Furthermore, selection criteria differed substantially among trials (as would be expected by the very different nature of the compared test modalities), rendering indirect comparisons uninformative.

### Computed Tomography Versus Routine Management or Clinical Assessment

Seven RCTs75–83 (described in 9 publications) with a total of 1177 participants compared the use of CT imaging to routine management in the diagnosis of appendicitis and reported comparative effectiveness outcomes (Table 26). Four studies reported details of adequate random sequence generation,76,78–80,82 and two studies described adequate allocation concealment procedures.76 Two studies described blinding of outcome assessors to group assignment76,82 Loss to followup was greater than 10% in three studies.75,76,78

Table 26 Randomized comparisons of CT versus routine management with respect to clinical outcomes and resource utilization

Comparison | Outcome | Author, Year [PMID] | Outcome Rate or Mean in Group 1 | Outcome Rate or Mean in Group 2 | Between-Group Difference^*^
CT vs. routine management | Deaths | Ng, 2002 [12480851] | 0/57 (0.0%) | 7/63 (11.1%) | −0.11 (−0.19 to −0.03); p = 0.008
CT vs. routine management | Deaths | Sala, 2007 [17901913] | 6/99 (6.1%) | 11/99 (11.1%) | −0.05 (−0.13 to 0.03); p = 0.203
CT vs. routine management | Length of Stay | Hong, 2003 [14588157] | 2.00 days (2.10) | 2.30 days (2.30) | −0.30 days (−1.59 to 0.99); p = 0.648 (women of reproductive age)
CT vs. routine management | Length of Stay | Hong, 2003 [14588157] | 2.20 days (2.20) | 2.40 days (3.20) | −0.20 days (−1.10 to 0.70); p = 0.664 (all patients)
CT vs. routine management | Length of Stay | Ng, 2002 [12480851] | 5.30 days | 6.40 days | −1.10 days
CT vs. routine management | Negative appendectomy | Walker, 2000 [11182396] | 2/65 (3.1%) | 7/63 (11.1%) | −0.14 (−0.29 to 0.01); p = 0.060
CT vs. routine management | Perforations | Hong, 2003 [14588157] | 7/78 (9.0%) | 4/68 (5.9%) | 0.03 (−0.05 to 0.12); p = 0.474
CT vs. routine management | Perforations | Ng, 2002 [12480851] | 1/57 (1.8%) | 5/63 (7.9%) | −0.06 (−0.14 to 0.01); p = 0.106
CT vs. routine management | Time to Surgery | Hong, 2003 [14588157] | 27.40 hours (34.10) | 10.80 hours (6.40) | 16.60 hours (3.86 to 29.34); p = 0.011 (women of reproductive age)
CT vs. routine management | Time to Surgery | Hong, 2003 [14588157] | 18.70 hours (18.80) | 10.60 hours (8.40) | 8.10 hours (3.47 to 12.73); p = 0.001 (all patients)

CT=computed tomography

* Risk difference for binary outcomes; mean difference for continuous outcomes. For continuous outcomes, p-values are missing when studies did not report adequate data to calculate them.

Hong et al. (2003) reported no significant difference between clinical observation alone versus clinical observation and abdominopelvic CT in terms of perforations (p = 0.4) among adults evaluated for possible acute appendicitis. In the clinical observation group, there were four perforations in 68 patients, while in the clinical observation plus CT group, there were seven perforations in 78 patients. The mean length of hospital stay was also not significant (p = 0.55) at 2.4 (± 3.2) days in the clinical observation group and 2.2 (± 2.2) days in the clinical observation and CT group. However, the mean time from presentation to surgery was significantly less in the clinical observation group (P <0.01), at 10.6 hours as compared to 18.7 hours in the clinical observation and CT group.75

Lopez et al. (2007) also compared clinical observation alone versus clinical observation and abdominopelvic CT among women of childbearing age with possible acute appendicitis. There were no perforations in either group, and both groups reported a median days of hospital stay at 1 day (range: clinical observation alone 0 to 7 days, clinical observation plus CT 0 to 6 days; p = 0.22).78

Walker et al. (2000) reported a higher negative appendectomy rate in the standard care group (7 of 36), as compared to the group that had a limited CT scan versus colorectal contrast (2 of 38; p = 0.08), among adult patients receiving surgical consultation for appendicitis.83

Lee et al. (2007) compared selective versus mandatory CT imaging in adult patients presenting with acute right lower quadrant pain and suspected acute appendicitis. They reported a difference of 8.2 percent (95% CI, −8.0, 24.4) for perforations, with a rate of 18.4 percent (7 of 38) in the selective imaging group and 10.3% (4 of 39) in the mandatory imaging group. The difference in negative appendectomy rates was 11.3 percent (95% CI, −3.5, 26.3), with a rate of 13.9 percent (6 of 43) in the selective imaging group and 2.6 percent (1 of 39 patients) in the mandatory imaging group. The mandatory CT group had 0.9 hour longer mean time from ED triage to surgery, 10.9 (±6.9) hours as compared to 10 (±7) hours in the selective imaging group.76

Lehtimaki et al. (2013) compared selective and mandatory CT imaging among patients presenting to a surgical emergency department with acute abdominal pain lasting more than 2 hours and less than 7 days. There was one negative appendectomy in 111 patients in the selective group, and one negative appendectomy in 143 patients in the mandatory group (p > 0.99). The mean length of hospital stay was significantly shorter (p = .01) in the selective group (2.5 days, min 0, max 21) as compared to the mandatory group (3.7 days, min 0, max 32).77

Three publications presenting results from the study by Ng et al. (original publication 2002; additional information presented in 2007 and 2010) reported outcomes for the same cohort of adult patients with acute abdominopelvic pain admitted under the care of the surgical team in a single academic hospital and randomized to either current standard practice versus early CT (within 24 hours). Both groups had a median five days’ hospital stay (p = 0.2), but there were significantly more deaths in the standard care group (7 of 63) than in the early CT group (0 of 55; p = 0.014).79–81 Of note, mortality was not an a priori endpoint for this study. Two of these studies also reported information on the impact of testing on diagnostic confidence. Both reported that diagnostic confidence increased between admission and 24 hours after admission in both groups, but that the increase was not significantly greater in the CT group (25.2%) than in the standard care group (24.9%; p = 0.098).79,81

Sala et al. (2009) randomized patients presenting to the “on-call” surgeons with acute “nonspecific” abdominal pain to current standard practice versus CT within one hour. This study also reported length of stay and mortality. The median length of hospital stay for the standard care group was 5.3 days (25^th^ percentile 2 days, 75^th^ percentile 9.5 days), and the median for the early CT group was 4.2 days (25^th^ percentile 1.1 days, 75^th^ percentile 7.6 days). There were 11 deaths within 6 months in the standard care group, as compared to six of 99 in the early CT group (p = 0.31).82

Seven large NRCS with a total of 149,422 participants compared the use of CT imaging to routine management in the diagnosis of appendicitis and reported comparative effectiveness outcomes.84–90 One study was prospective, with more than 90 percent follow-up;86 the others were retrospective.

McGory et al. reported a non-significant difference in negative appendectomy rate in 4731 patients with a CT scan (8%) versus 70721 patients who did not have a CT scan (9.4%; p = 0.36). However, there were statistically significantly more cases of appendicitis with abscess in the CT group (18.6%) compared to the non-CT group (9.3%). (p < 0.001), and mean and median length of stay was statistically significantly longer in the CT group (mean 5.46 ± 5.21 days; median 4, min 0, max 83) than the non-CT group (mean 3.28 ± 4.04 days; median 2, min 0, max 289) (p < 0.001).84

Raja et al. and Wagner et al. found significant differences in the negative appendectomy rate between patients with and without CT before surgery. Raja et al. reported a negative appendectomy rate of 1.7 percent in a group of 637 patients, 97.5 percent of whom had a CT scan and 23 percent in a group of 971 patients only one percent of whom had a CT scan (p < 0.001).86 Wagner et al. also found a lower negative appendectomy rate in 1070 patients who had CT scan (7.2%) compared to 129 patients who did not (14%; p = 0.007).89 Bachur et. al reported on 55,227 children based on age. For children under five, they found that CT reduced the negative appendectomy rate significantly (p < 0.001; boys: OR 0.18; 95% CI 0.12 to 0.28; girls: OR 0.11; 95% CI 0.07 to 0.18) from approximately 22 percent without CT to approximately 5 percent with CT, but for children between five and ten (boys: p = 0.123; OR 0.68; 95% CI 0.42 to 1.11; girls: p = 0.236; OR 0.78; 95% CI 0.51 to 1.18) and children over ten (boys: p = 0.556; OR 1.10; 95%CI 0.79 to 1.57; girls: p = 0.598; OR 1.07; 95%CI 0.83 to 1.38) the reduction was not significant.90 Petrosyan et al. reported similar overall negative appendectomy rates between the groups (with CT 6%, 31 of 546; without CT 6%; 23 of 383), but in to patients with an Alvarado scores of 5 to 7, the CT group had a lower negative appendectomy rate (3.3%; 12 of 357) than the non-CT group (6.2%; 20 of 321) (mean difference 2.9%, 95% CI: 0.3% to 6%).85 Tsao et al. reported a lower perforated appendix rate in children who had a CT scan (24.6%, 159 of 646) than those who did not (33.8%, 117 of 346).88

Shalligram et al. reported significant differences between 11,340 men (18 to 55 years old)who had a CT scan as part of their diagnostic workup and 1888 who did not. Mean length of stay was statistically significantly longer for those with CT scan (1.66 ± 1.63 days) than those who did not (1.37 ± 0.6 days) (p < 0.001). However, readmission within 30 days, morbidity, and ICU admission were lower in the CT group. Readmission within 30 days was 1.8 percent in the CT group compared to 5.13% in the non-CT group (p < 0.001). Morbidity was 0.86 percent in the CT group, compared to 2.2 percent in the non-CT group (p < 0.001). The rate of ICU admissions was also lower in the CT group (1.38%) compared to the non-CT group (1.8%), but this was not significant (p = 0.19).

### Alternative Types of Computed Tomography

Four RCTs,91–94 with a total of 1,441 participants, compared different types of CT imaging for the diagnosis of appendicitis and reported comparative effectiveness outcomes (Table 27). One study reported details of random sequence generation, adequate allocation concealment procedures, and blinding of outcome assessors to group assignment.93 All studies had loss to follow-up of less than 10 percent. Three of these studies looked at differing contrast regimens for CT. Mittal et al. (2004) compared CT scans with rectal contrast only versus scans using oral, rectal, and intravenous contrast among patients with an “uncertain” diagnosis of appendicitis aged 6 years of age or older. They reported similar negative appendectomy rates in the two groups, 7.7 percent (3 of 39) in the rectal contrast group and 8 percent (4 of 48; p > 0.99) in the triple contrast group. The perforation rate was lower in the rectal contrast group (3%, 1 of 36) than in the triple contrast group (30%, 13 of 44; p = 0.002); one patient in each group died of sepsis due to perforated appendicitis (p > 0.99). However, the mean time from emergency department presentation to operation was lower in the triple contrast group (8.3 hours) than the rectal contrast group (12.2 hours).94 Hersko et al. (2007), in a randomized study of a mixed patient population (16 to 83 years of age) with suspected acute appendicitis found that with no contrast, the negative appendectomy rate of CT was 25 percent (7 of 28), while with intravenous and oral contrast it was lower at 10 percent (5 of 48; p = 0.112 vs. no contrast) and with rectal contrast even lower at 7 percent (3 of 42; p = 0.08 vs. no contrast; omnibus p = 0.07 across all 3 groups).91 Kepner et al. (2012) reported a shorter mean time from emergency department presentation to disposition in the group with intravenous contrast enhanced CT alone (6:41; 25^th^ percentile 5:03, 75^th^ percentile 8:49) as compared to the group that had both oral and intravenous contrast (8:12; 25^th^ percentile 6:40, 75^th^ percentile 9:44).

Table 27 Randomized comparisons of alternative types of CT with respect to clinical outcomes and resource utilization

Comparison | Outcome | Author, Year [PMID] | Outcome Rate or Mean in Group 1 | Outcome Rate or Mean in Group 2 | Between-Group Difference^*^
IV and oral contrast-enhanced CT vs. Nonenhanced CT | Negative appendectomy | Hershko, 2007 [17566826] | 5/84 (6.0%) | 7/56 (12.5%) | −0.15 (−0.33 to 0.04); p = 0.117
Mandatory CT vs. Selective CT | Length of Stay | Lehtimaki, 2013 [23715771] | 3.70 days | 2.50 days | 1.20 days
Mandatory CT vs. Selective CT | Negative appendectomy | Lee, 2007 [17192450] | 1/72 (1.4%) | 6/80 (7.5%) | −0.11 (−0.23 to 0.00); p = 0.052
Mandatory CT vs. Selective CT | Negative appendectomy | Lehtimaki, 2013 [23715771] | 1/143 (0.7%) | 1/111 (0.9%) | 0.00 (−0.02 to 0.02); p = 0.859
Mandatory CT vs. Selective CT | Perforations | Lee, 2007 [17192450] | 4/39 (10.3%) | 7/38 (18.4%) | −0.08 (−0.24 to 0.07); p = 0.304
Rectal contrast-enhanced CT vs. nonenhanced CT | Negative appendectomy | Hershko, 2007 [17566826] | 3/78 (3.8%) | 7/56 (12.5%) | −0.18 (−0.36 to −0.00); p = 0.050
Standard triple-contrast abdominopelvic CT scan vs. Focused pelvic scan with rectal contrast only | Negative appendectomy | Mittal, 2004 [15136349] | 4/52 (7.7%) | 3/39 (7.7%) | 0.01 (−0.11 to 0.12); 0.02 p = 0.913
Standard triple-contrast abdominopelvic CT scan vs. Focused pelvic scan with rectal contrast only | Perforations | Mittal, 2004 [15136349] | 13/52 (25.0%) | 1/39 (2.6%) | 0.22 (0.10 to 0.35); p = 0.001
Standard triple-contrast abdominopelvic CT scan vs. Focused pelvic scan with rectal contrast only | Time to Surgery | Mittal, 2004 [15136349] | 8.30 hours (0.40) | 12.20 hours (0.30) | −3.90 hours (−4.04 to −3.76); p < 0.001
Standard-dose CT vs. Low-dose CT | Negative appendectomy | Kim, 2012 [22533576] | 6/447 (1.3%) | 6/444 (1.4%) | 0.00 (−0.04 to 0.03); p = 0.890
Standard-dose CT vs. Low-dose CT | Perforations | Kim, 2012 [22533576] | 42/447 (9.4%) | 44/444 (9.9%) | −0.01 (−0.04 to 0.03); p = 0.795
IV + oral contrast CT vs. rectal contrast CT | Negative appendectomy | Hershko, 2007 [17566826] | 5/84 (6.0%) | 3/78 (3.8%) | 0.03 (−0.08 to 0.15); 0.04 p = 0.581

CT=computed tomography; IV=intravenous

* Risk difference for binary outcomes; mean difference for continuous outcomes. For continuous outcomes, p-values are missing when studies did not report adequate data to calculate them.

Kim et al. randomized patients with suspected acute appendicitis (15 to 44 years of age) to low-dose versus standard-dose CT and examined perforation and negative appendectomy rates, median time from CT to appendectomy, and median number of days of hospital stay. Only median time from CT to appendectomy showed a statistically significant difference (p = 0.02) with standard dose CT shorter (5.6 hours, 25^th^ percentile 3.4, 75^th^ percentile 9.2) than low-dose CT (7.1 hours, 25^th^ percentile 4.3, 75^th^ percentile 11.7). Median length of hospital stay was not significantly shorter (p = 0.54) in the standard dose group (3.2 days; 25^th^ percentile 2.5, 75^th^ percentile 4.1) than in the low-dose group (3.4 days; 25^th^ percentile 2.7, 75^th^ percentile 4.1). The standard dose CT group had a perforation rate of 23.3 percent (42 of 180) and the low-dose CT group had a rate of 26.5 percent (44 of 166), but this difference was not statistically significant (p = 0.46). The negative appendectomy rate was also similar between the two groups (6 of 186, 3.2% standard-dose CT; 6 of 172, 3.5% low-dose CT; p > 0.99).93

One NRCS95 of 3764 patients examined patients receiving abdominopelvic CT during a 12 month period to compare non-oral contrast examination (2668 patients) versus traditional CT (with IV and oral contrast; 1096 patients). The authors found that the median turn-around time from test order to complete examination was 1.82 hours versus 2.36 hours (p<0.001); the median turn-around time from order to final interpretation was 2.9 and 3.5 hours (p<0.001); and the overall emergency department length of stay was 7.46 hours versus 8.18 hours (p=0.003), for the non-oral contrast group versus the traditional CT group, respectively.

### Computed Tomography Versus US

Two RCTs (reported in 3 publications96–98) with a total of 689 participants compared CT imaging to US for the diagnosis of appendicitis and reported comparative effectiveness outcomes (Table 28). Neither trial reported details of random sequence generation, adequate allocation concealment procedures, or blinding of outcome assessors to group assignment. One trial followed less than 90% of participants for appendicitis outcomes96 and the second trial restricted its examination of changes in diagnostic decision-making to those participants who had received both initial and final diagnoses from physicians with similar levels of expertise (209 of 600; 35% of enrolled participants).98

Table 28 Randomized comparisons of CT versus US with respect to clinical outcomes and resource utilization

Comparison | Author, Year [PMID] | Outcome | Outcome Rate or Mean in Group 1 | Outcome Rate or Mean in Group 2 | Between-Group Difference^*^
CT + US vs. US | Kaiser, 2002 [12034928] | Negative appendectomy | 5/317 (1.6%) | 4/283 (1.4%) | (−0.02 to 0.02); p = 0.867
CT vs. US | Horton, 2000 [10930484] | Negative appendectomy | 4/70 (5.7%) | 4/70 (5.7%) | (−0.08 to 0.08); p = 1.000

CT=computed tomography; US=ultrasound

* Risk difference for binary outcomes; mean difference for continuous outcomes. For continuous outcomes, p-values are missing when studies did not report adequate data to calculate them.

These studies reported outcomes for both groups for negative appendectomy rates. Horton et al. (2000) reported the same rate for both the US and CT groups (6%; 4 of 70) among patients 18 to 65 years old who presented to an emergency department with a diagnosis of possible appendicitis but had an atypical presentation after initial evaluation.96 Kaiser et al. reported an overall negative appendectomy rate of 3.7 percent (9 of 244), of which four were in the US only group and five were in the US plus CT group, in a RCT of children with clinically suspected acute appendicitis admitted to the emergency department of a single academic hospital.97 Kaiser et al. (2004) also reported on the impact of testing on change in management outcomes. Because the difference in impact on surgeon decisionmaking between the groups was not significant (z = 0.89), the groups were analyzed together. In total 347 of 600 children had their management changed after imaging, including 11 unnecessary operations possibly avoided, and 28 missed appendicitis avoided. In 18 cases, the imaging was false negative, but 17 of these children had appendectomy based on clinical diagnosis.98

Three NRCS30,99,100 with a total of more than 11,419 participants compared CT imaging to US for the diagnosis of appendicitis and reported comparative effectiveness outcomes. Only two reported on other outcomes. The SCOAP Collaborative reported a significantly higher negative appendectomy rate in the group that had US (10.4%) compared to the group that had CT (4.1%) (p < 0.001).30 Raval et al. reported a significantly lower negative appendectomy rate in children who had only CT scans (3.6%) compared to those who had only US (6.5%) or those who had US and CT (6.6%) (p < 0.001 for CT vs. US and for CT vs. US and CT). The perforation rate was significantly lower in children who had US only (29.8%) than those who had CT only (31.8%) or US and CT (36.3%) (p = 0.004 for US vs. CT and US vs. US and CT). Time from admission to surgery was also significantly longer in children who had US and CT (15.4 hours) compared to US only (7.4 hours) or CT only (9.6 hours) (p < 0.01 for US and CT vs. CT and US and CT vs. US), although it was not stated whether these were mean or median times.99

### US Versus Routine Management or Clinical Assessment

Two RCTs101–105 with a total of 1102 participants compared the use of US to routine management in the diagnosis of appendicitis and reported comparative effectiveness outcomes (Table 29). One trial described random sequence generation by coin toss and did not report adequate allocation concealment procedures101 and the second trial did not describe random sequence generation or adequate allocation concealment procedures.102–105 Both trials followed more than 90% of participants for some outcomes, but fewer than 90% of participants for other outcomes.

Table 29 Randomized comparisons of US versus no imaging with respect to clinical outcomes and resource utilization

Comparison | Author, Year [PMID] | Outcome | Outcome Rate or Mean in Group 1 | Outcome Rate or Mean in Group 2 | Between-Group Difference^*^
Routine management and US vs. Routine management alone | Lindelius, 2009 [19625549] | Length of Stay | 4.30 days (2.40) | 5.40 days (5.70) | −1.10 days (−1.98 to −0.22); p = 0.014
US informed by Alvarado score vs. clinical assessment and management | Douglas, 2000 [11030676] | Duration of hospitalization | 53.40 hours | 54.50 hours | −1.10 hours
US informed by Alvarado score vs. clinical assessment and management | Douglas, 2000 [11030676] | Duration of hospitalization | 45.00 hours | 40.50 hours | 4.50 hours
US informed by Alvarado score vs. clinical assessment and management | Douglas, 2000 [11030676] | Perforations | 14/160 (8.8%) | 10/142 (7.0%) | 0.02 (−0.04 to 0.08); p = 0.582
US informed by Alvarado score vs. clinical assessment and management | Douglas, 2000 [11030676] | Time to Surgery | 7.00 hours | 10.20 hours | −3.20 hours (total population)
US informed by Alvarado score vs. clinical assessment and management | Douglas, 2000 [11030676] | Time to Surgery | 7.00 hours | 13.10 hours | −6.10 hours (children)

US=ultrasound

* Risk difference for binary outcomes; mean difference for continuous outcomes. For continuous outcomes, p-values are missing when studies did not report adequate data to calculate them.

Douglas et al. (2000) compared US and clinical assessment in 302 patients older than 6 years old, referred to the surgical service of a single academic hospital with suspected appendicitis. The only significant difference between the groups was for time to therapeutic operation (p = 0.016). The mean time to operation was shorter in the US group (7 hours; 95% CI: 5.9 to 8.1) than in the clinical assessment group (10.2 hours; 95% CI: 7.9 to 13). Duration of hospital stay was not significantly different between the groups (p = 0.99). The mean length of stay was similar in the two groups (53.4 hours, 95% CI: 47 to 60 in the US group; 54.5 hours; 95% CI: 46 to 63 in the clinical assessment group). The perforation rate was similar between the two groups (14 of 160, 8.8% with US; 10 of 142, 7% with clinical assessment; p = 0.58). Both groups had a single readmission for complications. In the US group, one patient was readmitted for drainage of an abscess, while in the clinical assessment group, one patient was readmitted for an early small bowel obstruction.101

Lindelius et al. compared routine management with routine management plus US. They reported a non-significant difference for mean length of hospital stay (p = 0.964). The US group had a slightly lower mean length of stay (4.3 ± 5.7 days) than routine management (5.4 ± 5.7 days). The US group also had a not statistically significant (p = 0.733) lower number of total hospital days over 2 years followup (mean 6 ± 26.3 days; median 0, min 0, max 462 days) than routine management (mean 8.7 ± 35.6 days; median 0, min 0, max 470 days). Two patients in the US group died within 7 days and a third died within 6 weeks. No patients in the routine management group died.103,104 They also reported that US helped in making the diagnosis in 49.5 percent of patients and was considered misleading in 10.2 percent.105

Two NRCS90,106 with a total of 57,553 participants compared US to no imaging for the diagnosis of appendicitis and reported comparative effectiveness outcomes. Even-Bendahan et al. reported a 6.5 percent negative appendectomy rate in the 1069 children who had US if they were equivocal followed by CT as needed and 13.2 percent in those who had no diagnostic imaging.106 Bachur et al. reported that for boys under five, US increased the negative appendectomy rate significantly (p < 0.008; OR 2.07; 95% CI 1.21 to 3.54), but for girls under five (p < 0.13; OR 1.54; 95% CI 0.88 to 2.68) and all children between five and ten (boys: p = 0.61; OR 0.87; 95% CI 0.52 to 1.47; girls: p = 0.636; OR 0.87; 95% CI 0.49 to 1.55) and children over ten (boys: p = 0.122; OR 0.56; 95% CI 0.27 to 1.17; girls: p = 0.897; OR 1.03; 95% CI 0.64 to 1.67) US resulted in a nonsignificantly lower negative appendectomy rate.90

### Any Imaging Versus No Imaging

Two NRCS30,90 with an approximate total of 74,554 participants compared US, CT, and/or MRI to no imaging for the diagnosis of appendicitis and reported comparative effectiveness outcomes. The SCOAP Collaborative reported a significantly lower negative appendectomy rate in the group that had CT, US, or MRI (4.5%) compared to the group that had no imaging (15.4%; p < 0.001). Perforation rates were slightly lower in the CT, US, or MRI group (15.8%) compared to the non-imaging group (15.6%), but this difference was not significant (p = 0.16).30 Bachur et. al reported that for children under five, US or CT decreased the negative appendectomy rate significantly for girls under five (p = 0.011; OR = 0.24; 95% CI 0.08 to 0.72), but not significantly for boys under five (p < 0.125; OR = 0.56; 95% CI 0.27 to 1.17). For children between five and ten (boys: p = 0.36; OR = 1.55; 95% CI 0.60 to 3.98; girls: p = 0.14; OR = 1.83; 95% CI 0.83 to 4.02) and boys over ten (boys: p = 0.97; OR = 0.98; 95% CI 0.34 to 2.85), CT or US resulted in a non-significantly higher negative appendectomy rate. In girls over 10, CT or US resulted in a significantly higher negative appendectomy rate (p < 0.001; OR = 1.97; 95% CI 1.42 to 2.74)90

### Score-Based Managements Versus Routine Management or Non–Score-Based Clinical Assessment

Four RCTs with a total of 657 participants compared the use of scores to routine management in the diagnosis of appendicitis and reported comparative effectiveness outcomes (Table 30).107–110 One trial described both details of random sequence generation and an adequate allocation concealment procedure,108 and two trials described only details of random sequence generation.107,110 The third did not describe randomization or allocation procedures.109 No trial described blinding of outcome assessors and no trial described any loss to follow-up for any outcome.

Table 30 Randomized comparisons of scores versus no scores with respect to clinical outcomes and resource utilization

Comparison | Author, Year [PMID] | Outcome | Outcome Rate or Mean in Group 1 | Outcome Rate or Mean in Group 2 | Between-Group Difference^*^
Alvarado vs. standard practice | Farahnak, 2007 [17870498] | Duration of hospitalization | 42.61 hours (62.48) | 66.27 hours (61.89) | −23.66 hours (−61.27 to 13.95); p = 0.218
Alvarado vs. standard practice | Farahnak, 2007 [17870498] | Perforations | 0/21 (0.0%) | 1/21 (4.8%) | −0.05 (−0.17 to 0.07); p = 0.446
Alvarado vs. standard practice | Farahnak, 2007 [17870498] | Time to Surgery | 6.39 hours (9.93) | 11.09 hours (10.04) | −4.70 hours (−12.23 to 2.83); p = 0.221
Pediatric score vs. standard practice | Lintula, 2009 [18841382] | Deaths | 0/66 (0.0%) | 0/60 (0.0%) | 0 (−0.03 to 0.03); p = 1.00
Pediatric score vs. standard practice | Lintula, 2009 [18841382] | Length of Stay | 2.70 days (1.80) | 2.90 days (1.10) | −0.20 days (−0.72 to 0.32); p = 0.447
Pediatric score vs. standard practice | Lintula, 2009 [18841382] | Negative appendectomy | 5/66 (7.6%) | 11/60 (18.3%) | −0.12 (−0.32 to 0.08); p = 0.249
Pediatric score vs. standard practice | Lintula, 2009 [18841382] | Perforations | 21/66 (31.8%) | 24/60 (40.0%) | −0.08 (−0.25 to 0.09); p = 0.338
Pediatric score vs. standard practice | Lintula, 2010 [20379739] | Negative appendectomy | 8/96 (8.3%) | 7/81 (8.6%) | −0.03 (−0.17 to 0.11); p = 0.680
Pediatric score vs. standard practice | Lintula, 2010 [20379739] | Perforations | 3/96 (3.1%) | 3/81 (3.7%) | −0.01 (−0.06 to 0.05); p = 0.833
Alvarado + US depending on the score value vs. standard practice | Shah, 2008 [not indexed] | Length of stay | 61.3 hours (NR) | 62.5 hours (NR) | 0.9 hours (no additional information reported)
Alvarado + US depending on the score value vs. standard practice | Shah, 2008 [not indexed] | Delayed treatment and perforation | 5/150 (3.3%) | 3/158 (1.9%; this percentage was reported as 11.91% in the paper but that number was inconsistent with the count of events provided in tables and in the text) | 0.014 (−0.0 to 0.05); p = 0.432
Alvarado + US depending on the score value vs. standard practice | Shah, 2008 [not indexed] | Non-therapeutic operations | 2/150 (1.3%) | 7/158 (4.4%) | −0.031 (−0.06 to 0.006); p=0.101
Alvarado + US depending on the score value vs. standard practice | Shah, 2008 [not indexed] | Delayed treatment in association with perforation and non-therapeutic operations | 7/150 (4.6%) | 10/158 (6.3%) | −0.017 (−0.067 to 0.034); p=0.521

NR = nor reported

* Risk difference for binary outcomes; mean difference for continuous outcomes. Values in parentheses are 95% confidence intervals. For continuous outcomes, p-values are missing when studies did not report adequate data to calculate them.

Farahnak et al. (2007) randomized patients referred to the emergency service with an “impermanent” diagnosis of acute appendicitis to standard clinical management versus management according to the Alvarado score. They found significant differences in mean time to surgery and duration of hospitalization between patients randomized to either standard clinical management or management according to the Alvarado score. The mean time from randomization to surgery was statistically significantly less (p = 0.03) in 10 patients in the Alvarado group (6.39 ± 9.93 hours; median 2.05, min 0.4, max 32.4, IQR 7.39) than in 10 patients in the standard care group (11.09 ± 10.04 hours; median 8.35, min 2.4, max 37.1, IQR 5.55). Mean length of stay was also shorter in the 21 patients in the Alvarado group (42.61 ± 62.48 hours; median 37 hours, min 0.3, max 290.5, IQR 58.4) than in the 21 patients in the standard care group (66.27 ± 61.89 hours; median 60.40, min 0.3, max 280.2, IQR 40.7) (p = 0.034). The perforation rate was similar in the two groups (1 of 21, 4.8% in the Alvarado group; 0 of 21, 0% in the standard care group; p > 0.99).107

In two separate trials, Lintula et al. evaluated the Lintula score in pediatric (2009) and adult (2010) populations. In the pediatric population, the negative appendectomy rate was lower in the Lintula score group (17%; 5 of 29) than in the standard clinical assessment group (29%; 11 of 38; p = 0.05). Perforation rates were similar (21 of 66, 32% in the score group; 24 of 60, 40% in the standard clinical assessment group; p = 0.36). The score group had a perforation rate of 88 percent (21 of 24) and an abscess rate of 8.3 percent (2 of 24), and the standard clinical assessment group had a perforation rate of 89 percent (24 of 27) and an abscess rate of 8.3 percent (2 of 27). Mean length of hospital stay was also reported as not significant. The mean length of stay in the score group was 2.7 (± 1.8) days, and the mean length of stay in the standard clinical assessment group was 2.9 (± 1.1) days. There were no deaths in either group, but one patient in each group had a post-surgical wound infection.108 In adults, they also found non-significant differences between the groups in terms of negative appendectomy rate, number of perforations or abscesses, and length of stay. The negative appendectomy rate (8 of 60, 13% in the score group vs. 7 of 43, 16% in the standard assessment group; p = 0.78), the perforation rate (3 of 60, 5% in the score group; 3 of 43, 7% in the standard assessment group; p = 0.69), and the abscess rate (2 of 60, 3% in the score group; 0 of 43, 0% in the standard assessment group; p = 0.51). The mean length of stay was 2.2 (± 1.8) days in the score group as compared to 2.3 (± 2.6) days in the standard clinical assessment group.109

Shah et al. (2008) randomized a group of 308 patients (both adults and children) who had a provisional diagnosis of appendicitis to an intervention group (Alvarado score and US based on the results of the score assessment) versus a control group of “clinical diagnosis”. In the intervention group patients with an Alvarado score of 3 or less did not undergo ultrasound, those with a score of 4 to 8 underwent US, and those with a score of 9 or 10 were deemed candidates for surgery and US was optional. Patients in the control group were not evaluated with the Alvarado score and did not undergo US. The authors found that average length of stay (61.3 hours in the intervention group and 62.5 hours in the control group), the rate of non-therapeutic operations (1.3% vs. 4.4%), the rate of delayed treatment and perforation (3.3% vs. 1.9%), and the rate of all adverse outcomes (delayed treatment in association with perforation and non-therapeutic operations, 4.7% vs. 6.3%) were not statistically significantly different between groups.

One NRCS111 with 1,484 participants reported comparative effectiveness outcomes. They reported that the negative appendectomy rate was higher in patients who had a diagnostic score as part of their workup (10.2%; 13 of 127) compared to those who did not (8.4%; 18 of 214), but the difference was not significant (p = 0.57). The negative laparotomy rate was lower in patients who had a diagnostic score as part of their workup (3.4%; 8 of 233) compared to those who did not (3.9%; 14 of 358), but again the difference was not significant (p = 0.83). There were fewer perforated appendixes in the scores group (14.9%; 17 of 114) than in the non-scores group (19.4%; 38 of 196) (p = 0.32). The scores group had a significantly lower delayed appendectomy (≥ 2 days) rate (1.8%; 2 of 114 vs. 7.7%; 15 of 196 in the non-scores group; p = 0.03), as well as a significantly lower delayed discharge (≥ 10 days) rate (11.4%; 13 of 114 vs. 21.6%; 43 of 199 in the non-scores group; p = 0.02).111

### Diagnostic Laparoscopy Versus Open Diagnostic Exploration

Bruwer (2003) compared the use of diagnostic laparoscopy to open diagnostic exploration in a RCT of 34 premenopausal women (15 to 45 years old) in whom a decision to perform surgical exploration made.112 The trial described random sequence generation procedures, but did not describe procedures for allocation concealment or blinding of outcome assessors. No participants were lost for any other outcomes. They found that there were fewer negative appendectomies in the diagnostic laparoscopy group (2 of 11) than in the open appendectomy group (7 of 16), but the difference was not statistically significant (p=0.23). The difference in length of stay was reported not to be significant, though the laparoscopy group had a slightly shorter mean length of stay (3 ± 1.6 days) than the open group (3.7 ± 1.1 days).

One NRCS113 of 1899 patients compared the diagnostic performance (see Key Question 1) and complications of laparoscopic (1043 patients) versus open (856) approaches for patients with presumed acute appendicitis. The authors found that the laparoscopic approach had a higher rate of intra-abdominal abscess formation (3.9% vs. 2.2%; p=0.055) and lower rate of wound infection (1.5% vs. 7%; p<0.001) compared to the open approach.

### Diagnostic Laparoscopy Versus No Laparoscopy

Three RCTs114–116 with a total of 334 participants compared the use of diagnostic laparoscopy to routine management in the diagnosis of appendicitis and reported comparative effectiveness outcomes. Two of the trials did not describe random sequence generation procedures, procedures for allocation concealment, or blinding of outcome assessors.114,116 The other described adequate random sequence and allocation concealment procedures, but did not disrobe blinding.115 One study reported fewer than 90% of participants were followed for well-being outcomes, but no participants were described as lost for any other outcomes.114 The others reported no participants lost for any outcomes extracted in this review.115 116

Decadt et al. reported that participants randomized to early laparoscopy had a median time to operation of 10 hours (min 2, max 39), while those randomized to active observation and noninvasive investigation had a median time to operation of 39 hours (min 15, max 119). Length of hospital stay was two days (min 1, max 13) in each group (p = 0.87).114 Gaitan et al. reported that the time to diagnosis was shorter in the group that had laparoscopy within 24 hours of admission (1.41 ± 1.06 days) than in the group that had clinical observation and conventional diagnosis (2.32 ± 2.3days).115 Morino et al. reported that the mean time to operation was 7.5 hours in the immediate laparoscopy group compared to 69.1 (± 50.9 hours) the observation group, and the mean duration of hospital stay was shorter (3.7 ± 0.8 days) in the immediate laparoscopy group when compared to the observation group (4.7 ± 2.4 days).116

### Diagnostic Laparoscopy Versus Immediate Appendectomy

Six RCTs, all enrolling women of reproductive age, with a total of 461 participants compared the use of diagnostic laparoscopy to immediate appendectomy and reported comparative effectiveness outcomes.117–122 No trial described random sequence generation procedures, procedures for allocation concealment, or blinding of outcome assessors. All outcomes were reported for greater than 90% of participants in each trial.

All five studies that reported negative appendectomy rates found them to be lower in the diagnostic laparoscopy group compared to the immediate appendectomy group. Jadallah et al. (1994) reported a rate of 13.3 percent (4 of 30) in the diagnostic laparoscopy group compared to 36 percent (18 of 50) in the immediate open appendectomy group.117 Laine et al. (1997) reported a rate of 5.9 percent (1 of 17) in the diagnostic laparoscopy group compared to 44 percent (11 of 25) in the immediate open appendectomy group.118 Larsson et al. (2001) reported a rate of 9 percent (4 of 44) in the diagnostic laparoscopy group compared to 34 percent (18 of 55) in the immediate open appendectomy group. They reported that the relative risk of removing a healthy appendix was 6.6 (95% CI 2 to 21) for open compared to laparoscopic group119 Olsen et al. (1993) reported a rate of 7 percent (2 of 30) in the diagnostic laparoscopy group compared to 37 percent (11 of 30) in the immediate appendectomy group.120 van Dalen et al. (2003) reported a rate of 4 percent (1 of 25) in the diagnostic laparoscopy group compared to 26 percent (8 of 31) in the immediate appendectomy group.121

Five studies also reported on length of stay. Jadallah et al. reported a slightly shorter median length of stay (2 days, min <1, max 7) in the diagnostic laparoscopy group compared to the immediate open appendectomy group (3 days, min 1, max 18). Mean length of stay was 2.33 and 3.1 days, respectively. The p-value was <0.001 when comparing laparoscopy alone (no appendectomy) to appendectomy without laparoscopy.117 Laine et al. reported a slightly longer length of stay for diagnostic laparoscopy (2.7 ± 0.3 days) compared to immediate open appendectomy (2.3 ± 0.1 days).118 Olsen et al. also reported a slightly longer length of stay for diagnostic laparoscopy (3.8 days; min 1, max 8) compared to immediate appendectomy (3.2 days; min 1, max 7; p = 0.25).120 van Dalen et al. reported a statistically significantly shorter mean length of stay for diagnostic laparoscopy (4 days; min 1, max 9) than immediate appendectomy (4.9 days; min 2, max 11; p = 0.01).121 Tzovaras et al. reported that both groups had a mean length of stay of two days, but the range for diagnostic laparoscopy was one to nine days, while it was one to seven days for open appendectomy.122

Four NRCS89,123–125 with 5497 participants reported comparative effectiveness outcomes for diagnostic laparoscopy versus open appendectomy. All four studies reported on negative appendectomy rates. Barrat et al. reported that the negative appendectomy rate was significantly lower for those who had laparoscopy (8.2%; 24 of 290) than those who had open appendectomy (25.4%; 236 of 930) (p = 0.015).125 Wagner et al. also reported that the negative appendectomy rate was lower for those who had laparoscopy (7.3%) than those who had open appendectomy (8.4%), but it was not significant (p = 0.53).89 Akbar et al. reported a higher negative appendectomy rate in diagnostic laparoscopy participants (24.5%; 63 of 256) than in those that had open appendectomy (13% 178 of 1357).123 Ekeh et al. also reported a significantly higher negative appendectomy rate in laparoscopy patients (23.3%) than in those that had open appendectomy (14%) (p < 0.001).124 Only one study reported on time from ED to surgery, which was significantly longer for laparoscopy participants (mean 10.8 ± 9 hours) than for open appendectomy patients (9.75 ± 8.5 hours; p = 0.0333).124

### Clinical Outcomes and Resource Utilization in Pregnant Women With Suspected Acute Appendicitis

Eight studies126–132,133 reported information on clinical outcomes and resource utilization for pregnant women. These studies were mostly small and only a few gave comparative results.

Three studies reported negative appendectomy rates for pregnant women. One reported a negative appendectomy rate with MRI of 8 of 27.^130^ A second reported a negative appendectomy rate of 1 of 20 in patients who first had US then MRI.133 The third reported negative appendectomy rates of 7 of 13 for clinical evaluation, 20 of 55 for US, 1 of 13 for US and CT, and 3 of 5 for CT alone.126 Only one study reported that repeat imaging was necessary; two MRI patients required repeat imaging to visualize contrast material in the cecum.131

Four studies reported information on delay in diagnosis. Two studies, one of MRI and the other of laboratory findings, reported that there were no delays caused by the diagnostic process or test findings.127,128 A third study reported that operative delay due to diagnostic delay was significantly correlated with maternal morbidity.132 and a fourth reported that there were three perforations due to diagnostic delay in a cohort of 36 patients.129

## Key Question 3 What are the harms of diagnostic tests per se, and what are the treatment-related harms of test-directed treatment for tests used to diagnose RLQ pain and suspected acute appendicitis?

### Included Studies With Information on Adverse Events

Of 925 included studies, only 82 mentioned harms related to diagnostic tests: 17 RCTs76,78,82,83,91,93,94,97,110,112,114,116–118,120–122; 12 NRCS100,113,125,134–142; and 53 diagnostic cohort studies.129,132,143–193 Eight (3 RCTs78,91,94 and 5 diagnostic cohort studies159,162,165–167) reported an absence of adverse events for all tests except diagnostic laparoscopy (see Table 31). The fact that so few studies reported harms raises concerns about selective outcome reporting. The studies that mentioned at least one harm are included in Tables 32 to 35 and are discussed briefly below.

Table 31 Studies that reported that no adverse events occurred

Study Design | Study | Test | Contrast Route of Administration | N | Population | Summary
RCT | Mittal et al., 2004, 15136349^94^ | Standard vs. focused CT | IV, oral, rectal vs. rectal only | 91 | mixed | There were no complications as a result of the procedures in either group. No morbidities due to the CT scans were reported in either group.
RCT | Lopez et al., 2007, 18186378^78^ | CT vs. clinical observation | oral, IV | 95 | women of childbearing age | No complications were associated with this radiologic protocol.
RCT | Hersko et al., 2007, 17566826^91^ | Unenhanced vs. rectal contrast enhanced vs. IV and oral contrast enhanced CT | none used vs. rectal vs. IV and oral | 232 | adults | “CT-related complications, such as contrast material sensitivity reactions, aspiration, or renal failure, were not observed in any of the study groups.” “All techniques were found to be safe and no CT-related complications were observed.”
Diagnostic cohort studies | Brandt et al., 2003, 14509318^159^ | CT | oral, IV contrast | 330 | adults | There were no complications attributable to the CT scans obtained
Diagnostic cohort studies | Johnson et al., 2012, 22623558^165^ | MRI | NR | 42 | children | All patients enrolled in the study were able to complete the examination.
Diagnostic cohort studies | Leeuwenburgh et al., 2013, 23481162^162^ | CT and/or MRI | none used | 230 | adults | No adverse events occurred during imaging.
Diagnostic cohort studies | Kipper et al., 2000, 10716317^166^ | Tc-99m | NR | 49 | mixed | No serious adverse events were attributable to LeuTech injection, and vital signs did not significantly change after injection. One patient with a history of asthma had a brief episode of shortness of breath 1 hour after injection that completely resolved without intervention. This occurrence was believed to be unrelated to the LeuTech injection because of timing and the manner in which it resolved.
Diagnostic cohort studies | Wong et al., 1997, 9404876^167^ | Tc-99m | NR | 51 | mixed | No patients developed any side effects, adverse reactions, or complications.

CT = computed tomography; IV = intravenous; MRI = magnetic resonance imaging

Table 32 Reported contrast-related adverse events

Study Design | Study | Test | Contrast Route of Administration | N | Population | Summary
RCT | Lee et al.,2007, 17192450^76^ | CT | oral and IV | 152 | adults | Selective CT imaging: 1 case of recurrent vomiting secondary to oral contrast ingestion. Routine CT imaging 4 cases of recurrent vomiting secondary to oral contrast ingestion.
RCT | Walker et al., 2000, 11182396^83^ | CT | rectal | 65 | adults | “Rectal contrast for the CT scan was well tolerated by the majority of patients. One patient refused more than 200 cc of rectal contrast and other received no contrast at all.”
RCT | Kaiser et al., 2002, 12034928^97^ | CT | IV | 600 | children | No severe adverse drug reactions. 1/600 = mild skin rash limited to the chest that resolved spontaneously within 10 minutes.
Diagnostic cohort studies | Hershko et al., 2002, 12455796^163^ | CT | oral and IV | 308 | adults | One case of Gastrografin-induced chemical pneumonitis. The patient required mechanical ventilation for three days and recovered completely.
Diagnostic cohort studies | Kan et al., 2001, 11770917^164^ | CT or US, Hydrocolonic | rectal | 31 | adults | “All 31 patients were able to hold the rectally administered contrast material until completion of both hydrocolonic US and appendiceal CT.”
Diagnostic cohort studies | Laituri et al., 2011, 21470628^152^ | CT | oral | 1561 | children | Vomiting in 243, nasogastric intubation in 84, time to scan average 2 hours (estimated time to scan without contrast 1 hour).
Diagnostic cohort studies | Rao et al., 1997, 8988203^155^ | CT | rectal | 99 | mixed | This bowel contrast medium regimen was well tolerated by our patients.
Diagnostic cohort studies | Wise et al., 2001, 11264081^161^ | CT | oral, IV, rectal | 100 | adults | Leakage of rectal contrast in 12 cases, nausea or vomiting in 3 cases, extravasation of IV contrast material in 1 case

CT = computed tomography; IV = intravenous

Table 33 Reported radiation dose

Study Design | Study | Test | Contrast Route of Administration | N | Population | Radiation Dose (Mean)
RCT | Kim et al.,2012, 22533576^93^ | CT vs. LDCT | IV | 891 | mixed | Standard CT: median dose-length product = 521 mGy × cm (IQR = 448–564); low-dose CT: median dose-length product = 116 mGy × cm (IQR = 94–124)
RCT | Sala et al. 82 | CT vs. XRAY | IV | 99 | adults | CT = 9 mSv; XRAY = 0.82 mSv
RCT | Morino et al.116 | Immediate laparoscopy vs. observation | NR | 104 | adults | Immediate lap: 1.1 ± 1 mSv (range 0.1–2.1 mSv); observation: 2.2 ± 5.1 mSv (range 0–22 mSv
NRCS | Kim et al., 2011, 21633052^135^ | CT vs. LDCT | IV contrast | 257 | adults | Standard CT: median dose-length product = 544 mGy · cm (range, 303–672 mGy · cm; IQR = 518–578 mGy · cm); low dose: median dose-length product = 122 mGy · cm (range, 76–145 mGy · cm; IQR = 118–126 mGy · cm)
NRCS | Didier et al., 2014, 24996812^140^ | CT (2008–2010) vs. iDose CT (2010–2012) | oral, IV | 386 | children | Mean size-specific dose estimate: CT = 12.6 +− 2.5 mGy, iDose CT = 6.8 +− 2.6 mGy; mean volume CT dose index: CT = 7.3 +− 2.3 mGy, iDose CT = 4.0 +− 2.0 mGy
NRCS | Sharp et al., 2014, 24888854^141^ | CT Children’s Hospital (CH) vs CT Outside Hospital (OH) | oral, IV | 263 | children | Mean dose length product (mGycm) CH: 143.54 +− 41.19, OH: 586.25 +− 521.59; mean volume computed tomography dose length index (mGy) CH: 4.89 +− 2.64, OH: 16.98 +− 15.58; mean size specific dose estimate (mGy) CH: 3.81 +− 2.02, OH: 26.71 +− 23.1
NRCS | Karabulut et al., 2014, 24513314^142^ | LD CT vs. CT | none | 104 | mixed | LDCT calculated mean effective radiation doses: males 1.2 mSv, females 2.2 mSv; CT calculated mean effective radiation doses: males 1.5 mSv, females 2.0 mSv
Diagnostic cohort studies | Ghotbi et al., 2006, 17041792^150^ | CT | NR | 24 | children | 4 mGy
Diagnostic cohort studies | Pickhardt, 2011, 21690593^153^ | CT | oral and IV in the majority of patients | 2871 | adults | 10–15 mSv
Diagnostic cohort studies | Poletti, 2011, 21805194^154^ | US + LDCT + CT protocol | oral | 183 | adults | Algorithm = 3.23 mSv; LDCT = 1.7 mSv (women), 1.2 mSv (men); CT = 10.2 mSv (women), and 7.2 mSv (men)
Diagnostic cohort studies | Keyzer, 2004, 15155894^151^ | CT | none | 95 | adults | mean dose at 100 effective mAs: 5.2 mSv for males and 7.1 mSv for females, mean dose at 30 effective mAs: 1.4 mSv for males and 2.2 mSv for females
Diagnostic cohort studies | Lazarus, 2000, 17709829^191^ | CT | various | 80 | pregnant women | The mean radiation dose delivered was 16 mGy (1.6 rad) (range, 4–45 mGy [0.4–4.5 rad]).
Diagnostic cohort studies | Seo, 2009, 19542400^157^ | LDCT + CT | none for LDCT, IV for standard CT | 207 | mixed | LDCT = 4.2 mSv; CT = 8 mSv; Combined = 12.2 mSv

CT = computed tomography; IV = intravenous; LDCT = low-dose CT; MRI = magnetic resonance imaging

Table 34 Other adverse events

Study Design | Study | Test | Contrast Route of Administration | N | Population | Summary
RCT | Shah et al., 2008 [not indexed in PubMed]110 | US/Alvarado vs. clinical | N/A | 308 | mixed | Delayed treatment (operated after 10 hours from randomization) in association with perforation: 5 perforations in Alvarado/US vs, 3 in clinical group. Intervention group: 1 subcutaneous abscess; clinical group: 1 intestinal obstruction.
Diagnostic cohort studies | Acosta et al., 2005, 15633057^158^ | CT | rectal | 94 | children | One child was unable to tolerate the procedure.
Diagnostic cohort studies | Dickson et al., 1985, 4026364^160^ | rectal exam | NR | 201 | children | A rectal examination was impossible in 5/328 exams. Admission examination: severe discomfort in 80, minor discomfort in 121. Discharge examination: severe discomfort in 34, minor discomfort in 88.
Diagnostic cohort studies | Rypins et al., 2002, 11807363^156^ | Tc-99m | NR | 248 | mixed | No serious or severe adverse events were reported. 17/203 reported 20 mild and 4 moderate adverse events (none definitely drug related). The most commonly reported adverse events were vasodilation (8), dyspnea (3), syncope (2), headache (2), and dizziness (2). Nine patients experienced significant changes in vital signs (none drug related).
Diagnostic cohort studies | Leeuwenburgh et al., 2013, 23481162^162^ | MRI | none used | 223 | adults | “In seven patients, an MR examination could not be performed because of claustrophobia or unexpected technical failure.”
Diagnostic cohort studies | Wise et al., 2001, 11264081^161^ | oral contrast administration, then US, then unenhanced CT, then CT with IV contrast, then CT with colonic contrast material, then US – in the other half of patients, this order was reversed | oral, IV, rectal | 100 | adults | Average discomfort score: CT: 4.2 in focused scans with oral contrast, 6.7 in focused scans with oral, IV, and rectal contrast, and 5.3 in abdominopelvic scans with oral and IV contrast. US: 6.1 with oral contrast and 6.7 with oral, IV, and rectal contrast.
Diagnostic cohort studies | Cobben, 2004, 15333354^127^ | MRI | no contrast | 12 | pregnant women | All 12 patients and fetuses were exposed to unknown bioeffects of MRI.
Diagnostic cohort studies | Pedrosa, 2009, 19244044^130^ | MRI | oral | 148 | pregnant women | One patient refused to complete the MRI protocol
Diagnostic cohort studies | Thieme, 2014, 24135892^193^ | MRI | none used | 104 | children | Patients returning the survey reported on the following parameters: long duration = 58% (30/52), painful = 10% (5/52), tolerance = 53% (28/52), lying on the MRI gantry as burdensome = 32.7% (17/52), preference for MRI over US = 55.8% (29/52) immediate and 51.8% (27/52) after 3 months

CT = computed tomography; IV = intravenous; MRI = magnetic resonance imaging; RCT = randomized controlled trial

Table 35 Reported surgical complications of diagnostic laparoscopy

Study Design | Study | N | Population | Summary of Surgical Complications
RCTs | Laine et al., 1997, 9069134^118^ | 25 | women of childbearing age | No complications related to laparoscopy. 1 postoperative ileus (not caused by the laparoscopic part of the operation).
RCTs | Olsen et al., 1992, 8369940^120^ | 30 | women of childbearing age | No complications related to laparoscopy.
RCTs | Jadallah et al., 1994, 8186313^117^ | 100 | women of childbearing age | No complications related to laparoscopy; 2 wound infections in laparoscopic appendectomy group.
RCTs | Van Dalen et al., 2003, 12739123^121^ | 63 | women of childbearing age | No complications related to laparoscopy.
RCTs | Bruwer et al., 2003, 14768141^112^ | 34 | women of childbearing age | Laparoscopy: 1 spillage of purulent matter into the lower abdomen. Open appendectomy: 2 wound infections, 1 adhesive small bowel obstruction.
RCTs | Decadt et al., 1999, 10583282^114^ | 59 | adults | Laparoscopy: 7 abdominal pain that persisted for at least 1 month after discharge, 5 wound infections, 1 wound dehiscence after laparotomy, 1 readmission with respiratory symptoms and shoulder tip pain, and 1 death from a massive pulmonary embolus 5 days after laparotomy. Open appendectomy: 15 abdominal pain persisting for at least 1 month, 4 wound infections, and 1 death 7 days after discharge from a presumed pulmonary embolism.
RCTs | Tzovaras et al., 2007, 17219281^122^ | 54 | mixed | Laparoscopy: 4 wound infections, 1 trocar site hematoma, 3 pelvic collections, 1 DVT. Open: 3 wound infections, 1 urinary retention
RCTs | Morino et al., 2006, 17122613^116^ | 104 | adults | Immediate laparoscopy: 1 urinary tract infection, 1 trocar site infection; observation 1 severe anemia.
NRCSs | Ragland et al., 1988, 2792080^137^ | 21 | women of childbearing age | 1 perforation of the transverse colon with the pneumoneedle
NRCSs | Tronin et al., 1996, 9050636^138^ | 1000 | mixed | 1 perforation of the small bowel
NRCSs | Moberg et al., 2000, 1180408^139^ | 500 | adults | No intraoperative complications were seen in either group. Laparoscopy: complication rate = 6.6%, 1 reoperation for mesoappendix bleeding, 3 readmitted within 30 days because of intra-abdominal infection, 3 converted to open appendectomy, 1 death. Primary open appendectomy: complication rate = 12.3%.
NRCSs | Schirmer et al., 1992, 8506965^139^ | 68 | mixed | No complications of any type with diagnostic laparoscopy alone (n=6); open appendectomy (n=54): 1 death, 5 wound complications, 18.9% complication rate; diagnostic laparoscopy + laparoscopic appendectomy (n=47): 2 wound complications, 10.6% complication rate; laparoscopy + open appendectomy (n=15): 2 wound complications, 46.7% complication rate.
NRCSs | Barrat et al., 1999, 9950123^125^ | 1285 | adults | No mortality in either group.
NRCSs | Kollias et al.,1994, 7980256^136^ | 167 | mixed | Laparoscopy (n=93): 3 wound infections, 1 ileus, 1 hemolytic anemia, 1 aspiration pneumonia, 1 infected hydrocele. Open (n=74) 4 wound infections, 2 ileus, 1 UTI.
NRCSs | Sadot et al., 2013, 24016703^113^ | 1899 | mixed | Laparoscopy (n=1043): 41 intra-abdominal abscess, 16 wound infections; Open and laparoscopy (n=1899) 9 small bowel obstructions, 1 inadvertent enterotomy, 1 required reoperation for leakage from the cecum resection line, 1 small bowel obstruction, 1 intractable abdominal pain
Diagnostic cohort studies | Ng et al., 2008, 18259838^182^ | 787 | mixed | 1 wound infection, 1 intra-abdominal abscess, 1 ileus, 1 respiratory tract infection, 1 laryngeal spasm post-intubation
Diagnostic cohort studies | Clarke et al., 1986, 2937361^170^ | 46 | adults | 1 wound infection and 1 minor tear of the small bowel
Diagnostic cohort studies | Cristalli et al., 1991, 1839575^173^ | 31 | mixed | No post-operative complications
Diagnostic cohort studies | Spirtos et al., 1987, 2948388^184^ | 86 | women of childbearing age | No complications from laparoscopy; laparotomy: 4 wound infections, 2 pelvic abscess, 1 pulmonary embolism, 1 ileus
Diagnostic cohort studies | Diehl et al., 1981, 6457704^175^ | 25 | mixed | no complications resulted directly from the procedure
Diagnostic cohort studies | Cox et al., 1993, 8216060^172^ | 81 | mixed | 5 operative complications: 3 appendix ruptured during manipulation, 1 left inferior epigastric artery was ruptured by the 5 mm LIF port, 1 extra peritoneal insufflation; 5 post-operative complications: 3 prolonged ileus, 1 fever, 1 wound infection
Diagnostic cohort studies | Graham et al., 1999, 10615200^176^ | 85 | mixed | 2 small intraperitoneal collections, 1 umbilical wound infection, 1 perioperative arrhythmia, 1 pneumothorax secondary to a patent pleuroperitoneal canal, 1 chest infection
Diagnostic cohort studies | Borgstein et al., 1997, 9294274^169^ | 161 | women of childbearing age | 1 bleeding from the trocar site, which required abdominal wall exploration
Diagnostic cohort studies | Mutter et al., 1998, 9817258^181^ | 36 | mixed | No major complications. Minor complications: 1 insufflation in cecal wall, 1 preoperative hemorrhage on 2mm port site, 1 postoperative parietal hematoma required reoperation for removal
Diagnostic cohort studies | in’t Hof et al., 2004, 15386320^148^ | 103 | adults | 3 wound infections, 2 intra-abdominal abscesses, 1 tertiary peritonitis and enterocutaneous fistula
Diagnostic cohort studies | Lee et al., 2001, 11343547^149^ | 76 | mixed | 1 wound infection
Diagnostic cohort studies | DeCou et al., 2004, 14745576^174^ | 30 | children | 1 suture reaction at the umbilical incision, 1 pelvic fluid collection
Diagnostic cohort studies | Konstantinidis et al., 2008, 18373452^179^ | 1024 | mixed | Complication rate was 5.7% (52 patients), consisting mostly of minor complications. There were no major intraoperative complications. There were no intra-abdominal abscesses postoperatively. Wound-infection rate was 1.1%. We had 3 patients with an abdominal-wall hematoma at the trocar sites. Two of them were managed intraoperatively. The 3rd patient was treated conservatively after surgery. There was no mortality.
Diagnostic cohort studies | Jones et al., 2011, 21688285^178^ | 146 | mixed | 1 wound infection, 3 intra-abdominal collection
Diagnostic cohort studies | Gurrado et al., 2009, 20334502^177^ | 1024 | Mixed | Minor: 1 wound infection, 1 pneumonia, 1 ilium. Major: 4 intraabdominal abscesses, 5 intestinal obstructions, 1 hemorrhage, 2 bowel perforation, 1 bladder perforation, 1 cecal dehiscence, 2 cecal leakage
Diagnostic cohort studies | Linos et al., 1999, 10194691^180^ | 121 | women of childbearing age | 2 injury to inferior epigastric artery, 1 bladder injury caused by suprapubic trocar
Diagnostic cohort studies | Ates et al., 2008, 18373441^168^ | 74 | mixed | Other than a chest infection observed in 1 patient, there was no operative complication; no death and, postoperatively, none of our patients had a leak or residual intra-abdominal abscess in this study.
Diagnostic cohort studies | Moberg, 1998, 9845129^145^ | 1043 | mixed | Perioperative complications: 2 intestinal lesions, 1 mesoappendiceal bleeding. Postoperative complications: 12 wound infections, 20 prolonged fever, 8 hematoma, 21 ileus, 23 DVT, 5 lung complications, 1 pseudomembranous enterocolitis, 18 intrabdominal infections, 3 bleeding, 1 pulmonary embolism, 5 coronary related complications, 3 deaths, 1 ruptured aortic aneurism
Diagnostic cohort studies | Thorell, 1999, 10494640^143^ | 77 | women of childbearing age | No complications developed during the hospital stay
Diagnostic cohort studies | Wagner, 1996, 8703146^147^ | 267 | mixed | 4 wound infections, 4 wound hematoma, 4 pneumonia, 1 early obstruction, 1 pancreatitis, 1 intraabdominal hematoma, 5 abscess, 1 bleeding from appendiceal artery, 1 acute abdominal pain and fever, 1 cecal phlegmon, 1 intraabdominal sepsis, 1, death
Diagnostic cohort studies | Bagnato et al., 1992, 1387169^144^ | 23 | mixed | 1 postoperative pelvic abscess, 1 minor abdominal wall cellulitis
Diagnostic cohort studies | Kuster, 1992, 1416436^146^ | 38 | adults | No morbidity or mortality
Diagnostic cohort studies | Connor et al., 1994, 7856985^171^ | 85 | mixed | 1 bladder perforation, 1 postoperative abscess, 1 prolonged ileus, 1 wound infection
Diagnostic cohort studies | Ilce et al., 2013, 24353684^192^ | 84 | children | 1 appendix stump was opened postoperatively and repaired by laparotomy 3 days after the first operation. No postoperative mortalities.

NRCS = nonrandomized comparative study; RCT = randomized controlled trial

### Contrast-Related Adverse Events

Eight studies (3 RCTs76,83,97 and 5 diagnostic cohort152,155,161,163,164) reported on adverse events related to contrast administration. Of these, three reported that the contrast was well tolerated.83,155,164 Twelve studies of CT (of 247 included for Key Question 1), two of MRI (of 35), two of nuclear medicine (of 31), and one of US (of 301) reported data on contrast related harms. Full results by study are in Table 32.

Of the two RCTs that reported contrast-related harms, one reported five cases of vomiting after oral contrast in 152 patients, one in the group that got selective CT imaging (n=80) and four in the group that got CT imaging standard (n=72).76 A second reported a mild skin rash after intravenous contrast administration that resolved spontaneously within 10 minutes in the CT group (n=317; n total = 600).97

In the diagnostic cohort studies, one reported that a single patient of 308 had Gastrografin-induced chemical pneumonitis; this patient required mechanical ventilation for three days and recovered completely.163 Another reported that of 100 patients, there was leakage of colonic contrast material in 12 cases, nausea or vomiting three cases, and extravasation of intravenous contrast material one case.161 A third reported that of 1561 patients given oral contrast before CT, 243 vomited at least once, 84 required nasogastric intubation, and the average wait time before CT scan was an hour longer (2 hours) than for those who did not have contrast.152

### Exposure to Ionizing Radiation

No studies reported direct evidence on the effect of ionizing radiation on patient relevant outcomes.

Twelve studies (3 RCTs,82,93,116 4 NRCS,135,140–142 and 5 cohort studies150,151,153,154,157 reported radiation doses, and two of these154,157 discussed strategies to reduce CT-related radiation exposure in a population (of a total of 247 CT studies included for Key Question 1). Reported mean CT radiation doses ranged from 7.2 to 15 mSv in adults;82,151,153,154 in children, the mean reported dose was 4 mSv; and in a mixed-age population, the mean reported dose was 8 mSv.157 Reported mean low-dose computed tomography (LDCT) radiation doses ranged from 1.2 to 4.2 mSv in adult and mixed populations.93,154,157 Specific results for each study are in Table 33.

Both of the RCTs that reported evidence for this outcome in terms of CT compared standard CT radiation doses with radiation doses from another diagnostic modality. One RCT looked at the difference between low- and standard-dose CT in 891 participants and reported a median dose-length product for radiation from standard CT at 521 mGy × cm (IQR = 448–564); for LDCT, the median dose-length product for LDCT was about a quarter as much, at 116 mGy × cm (IQR = 94–124).93 The second RCT compared current standard practice (plain radiography of the supine abdomen and erect chest, as well as CT if it was deemed necessary) with an early CT protocol that used abdominopelvic scans on a 16 detector scanner with intravenous contrast. The authors reported that the CT protocol had a mean radiation dose of 9 mSv, while the dose for the plain radiography was only 0.82 mSv.82 The third RCT reported mean radiation dose for patients who either received immediate laparoscopy (1.1±1 mSv) or underwent observation before laparoscopy (2.2±5.1 mSv).116

Three retrospective NRCS and one prospective NRCS reported radiation doses between different arms of CT in mixed and pediatric populations. In 2011, Kim et al. reported the same radiation doses for CT and LDCT as in their 2012 RCT (standard CT: median dose-length product = 544 mGy × cm; LDCT: median dose-length product = 122 mGy × cm).135 In a prospective NRCS, Karabulut et al. compared low-dose dual slice CT versus multidetector row CT in a mixed population. They found similar calculated mean effective radiation doses between low-dose CT (1.2 and 2.2 mSv for male and female patients, respectively) and multidetector CT (1.5 and 2.0 mSv for male and female patients, respectively).142

In 2014, Didier et al. reported lower radiation doses in a pediatric population with a change in CT protocol in 2010. The mean size-specific dose estimate and volume CT dose index with the standard protocol between 2008 and October 18, 2010 were 12.6 mGy (SD 2.5 mGy) and 7.3 mGy (SD 2.3 mGy), respectively. Between October 19, 2010 and 2012, the scans were performed using iterative reconstruction technique software, and the mean size-specific dose estimate and volume CT dose indexes dropped to 6.8 mGy (SD 2.6 mGy) and 4 mGy (SD 2 mGy), respectively (p<0.0001).140 Sharp et al. reported lower CT radiation doses in children in children’s versus outside hospitals. The mean dose length product was 143.54 mGycm (SD 41.19 mGycm) in the children’s hospital as compared to 586.25 mGycm (SD 521.59 mGycm) in the outside hospital (p<0.001); the mean volume computed tomography dose length index was 4.89 mGy (SD 2.64 mGy) in the children’s hospital and 16.98 mGy (SD 15.58 mGy) in the outside hospital (p<0.001); and the mean size-specific dose estimate was 3.81 mGy (SD 2.02 mGy), in the children’s hospital and 26.71mGy (SD 23.1 mGy) in the outside hospital (p<0.001).141

There were five diagnostic cohort studies reporting on this outcome. One study in which everyone first had a LDCT then a standard CT reported a total radiation dose of 12.2 mSv (8 mSv from the standard CT plus 4.2 mSv from the low-dose CT).157 A second study reported on the evaluation of an algorithm, in which patients were first evaluated by US then, in the case of indeterminate US findings or negative US findings with high clinical suspicion of appendicitis, the patient received a low-dose CT exam. If the low-dose CT exam was indeterminate, the patient had a standard CT. The authors of this study reported an actual mean dose with the algorithm of 3.23 mSv, which was significantly lower (p < 0.0001) than the hypothetical mean dose if a standard CT had been systematically performed at admission (9.02 mSv).154 One study of pregnant women reported a mean radiation dose of 16 mGy (range 4 to 45 mGy) for CT.191

### Maternal/Fetal Adverse Events

Six studies (3 studies of US, of 301 included for Key Question 1); 3 of MRI (of 35); and 2 of multiple clinical and lab tests (of 217); some studies evaluated more than one test) reported information on maternal outcomes. One study of MRI reported that 17 patients without appendicitis progressed to uneventful labor and delivery.188 A second study of MRI reported that not using oral contrast sped up the imaging process.189 Four reported that there was no maternal mortality.129,185–187

Seven studies (5 studies of US (of 301); 2 of MRI (of 35); 1 of CT (of 247); and 1 of clinical symptoms and signs (of 137); some studies evaluated more than one test) reported information on fetal outcomes. Barloon et al. in a study of US reported that 18 of 22 patients had a normal term delivery; there were two spontaneous abortions (in patients with no clinical or sonographic evidence of acute appendicitis) and two elective abortions.185 Kapan et al. in a study of US and several clinical and laboratory tests reported that all 20 women delivered healthy infants.186 Lim et al. in a study of US only reported fetal outcomes for two of the 45 participants. One was a spontaneous abortion in a case of surgically confirmed acute appendicitis without perforation, and the other was a premature delivery in a patient with no evidence of appendicitis at followup through delivery.187 Fonseca et al. reported on a clinical/US pathway versus MRI in 75 patients. They reported a total of nine adverse fetal outcomes (5/31 who had MRI and 4/44 in the US or clinical group), none were in the perioperative period (OR 1.09, 95% CI 0.90–1.31; p = 0.47).194

Freeland et al. reported outcomes for US, MRI, and CT. In the US group, one patient, who had an open appendectomy in the first trimester, developed severe preeclampsia and had a premature delivery at 33 weeks (this patient also had a diagnostic CT), there was one fetal demise after a negative open appendectomy, but neither the fetal demise nor the early delivery was related directly to the appendectomy, and one patient with perforated appendicitis had abruptio-placentae and vaginal hemorrhage. Only one patient had MRI, and she delivered a healthy baby at term. Among thirteen patients who had a diagnostic CT, nine delivered healthy infants, one who had an open appendectomy in the first trimester developed severe preeclampsia and had a premature delivery at 33 weeks (see above), and three were lost to followup.190 Lazarus et al. reported fetal outcomes for 55 of 80 patients who had CT. Fifty-one had a live infant at or near term, one had a premature delivery of a live 30-week infant three days after CT-diagnosed gastric cancer, two had spontaneous vaginal delivery of a nonviable fetus (one at 18 weeks with sepsis after normal CT and normal laparotomy, and one at 22 weeks with chorioamnionitis, 5 days after normal CT). There was one fetal demise at 26 weeks (four weeks after a CT examination with normal findings).191 Tamir et al. reported that on a group evaluated on symptoms and signs, there were seven therapeutic abortions, two perioperative spontaneous abortions (first trimester), and four without appendicitis had severe perinatal morbidity or mortality.132 Two studies of MRI reported on other harms in pregnant women. One reported that “all 12 patients and fetuses were exposed to unknown bioeffects of MRI.”127 The other reported that patient tolerance of the MRI environment represents an additional concern in terms of successful implementation, but noted that only one patient refused to complete the MRI protocol.130

### Other Adverse Events of Imaging Tests

One RCT110 and six diagnostic cohort studies156,158,160–162,193 reported on a variety of other adverse events. For details by study, see Table 34.

In an RCT of standard clinical management versus an Alvarado/US pathway, Shah et al. found that a delay of over 10 hours from randomization to operation was associated with perforation in 5 of 100 patients in the US/Alvarado group and 3 of 110 patients in the clinical management group. They also noted two complications: a subcutaneous abscess in the scar in the intervention group and a subacute intestinal obstruction in the control group.

One reported that one child in a sample of 94 was unable to tolerate the CT procedure;158 they did not give any further details. A second study measured discomfort in 100 patients who underwent US and CT on a scale of 0–10, where 10 was the most discomfort. The imaging pathway for half of the patients was oral contrast administration, then US, then unenhanced CT, then CT with intravenous contrast, then CT with colonic contrast material, then US; in the other half of patients, this order was reversed They found that in general US produced more discomfort (average scores of 6.1 with oral contrast and 6.7 with oral, intravenous, and rectal contrast) than CT (average score 4.2 in focused scans with oral contrast, 6.7 in focused scans with oral, IV, and rectal contrast, and 5.3 in abdominopelvic scans with oral and intravenous contrast).161 A study of Tc-99m labeled white blood cells reported that “of the 203 patients injected with LeuTech, 17 (8%) reported 20 mild and 4 moderate adverse events. None of these events were reported as definitely drug related. The most commonly reported adverse events were vasodilation (n=8), dyspnea (n=3), syncope (n=2), headache (n=2), and dizziness (n=2). Nine (4.4%) patients experienced significant changes in vital signs; however, none was assessed as drug related.”156 In a study of rectal examinations, a rectal examination proved impossible on five of 328 occasions. Eighty children experienced severe and 121 minor discomfort during rectal examination at the time of hospital admission; at the examination before hospital discharge, severe discomfort was found in 34 and minor discomfort in 88 children.”160 Leeuwenburgh et al. reported that seven patients could not complete the MRI procedure because of claustrophobia or unexpected technical failure;162 they did not report how many of them had a claustrophobic reaction or give any further details. A final study reported on the results of a survey sent to 104 children after US and MRI. Of the total 52 that responded, 52 percent reported that MRI had a long duration, 10 percent found it painful, 53 percent reported tolerance, 32.7 percent found lying on the MRI gantry as burdensome, and 55.8 percent reported a preference for MRI over US immediately following the procedure; that number dropped to 51.8 percent after 3 months.193

### Surgical Complications Related to Diagnostic Laparoscopy

Thirty-four studies of diagnostic laparoscopy (of 55 included for Key Question 1) mentioned surgery related harms. Eight RCTs (469 patients) and eight NRCSs (4084 patients) described complications related to laparoscopy as compared to open appendectomy; twenty-five diagnostic cohort studies (5553 patients) reported on complications of diagnostic laparoscopy. In general the rates of specific complications were low (generally less than 10% and in most cases less than 2%); however, few studies attributed specific adverse events to diagnostic laparoscopy (as opposed to additional surgical intervention). Nine studies, including five RCTs, reported that there were no complications related to the diagnostic laparoscopic procedure.

Four RCTs reported no complications or adverse events in the study group that had diagnostic laparoscopy.117,118,120,121 Two of these studies reported harms that were not caused by the laparoscopic part of the operation: one postoperative ileus and two wound infections.117,118 One RCT compared immediate laparoscopy with observation. Morino et al. reported that in the immediate laparoscopy group there was no mortality, one urinary tract infection, and one trocar site infection. In the observation group, there was also no mortality, and adverse events were limited to a single case of severe anemia.116 Three RCTs compared laparoscopic versus open surgery. One RCT reported that in the laparoscopy group, one patient of 18 had spillage of purulent matter into the lower abdomen; in the open appendectomy group there were two wound infections and one adhesive small bowel obstruction in 16 patients.112 Another RCT reported laparoscopy complications in 14 of 59 patients, including abdominal pain that persisted for at least one month after discharge (n=7), wound infection (n=5), wound dehiscence after laparotomy (n=1), readmission with respiratory symptoms and shoulder tip pain (n=1), and death from a massive pulmonary embolus 5 days after laparotomy despite full thromboprophylaxis. In the open group, 19 of 61 patients had complications, including abdominal pain persisting for at least 1 month (n=15), wound infection (n=4), and one death seven days after discharge from a presumed pulmonary embolism.114 The third RCT reported more harms with laparoscopic surgery than open, including wound infections (4 of 59 in the early laparoscopic group and 3 of 61 in the open group), one trocar site hematoma, three pelvic collections, and one case of DVT in the laparoscopic group and 1 urinary retention in the open group.122

Eight NRCS described complications related to laparoscopy as compared to open appendectomy. One reported only that there was no mortality in either group.125 The second reported that there were no intraoperative complications in either group, but that in the diagnostic laparoscopy group the complication rate was 6.6 percent (n=376). In the group that got an operation immediately, the complication rate was higher, 12.3 (n=124) percent. Specifically, the superficial wound infection rate was significantly lower in the diagnostic laparoscopy group than in the primary open surgery group (p = 0.020), while the intra-abdominal infection rate did not differ between the groups (t9 = 0.15). One patient in the laparoscopic appendectomy group required reoperation for mesoappendix bleeding, three were readmitted within 30 days after surgery because of intra-abdominal infection and three were converted to open appendectomy group because of subileus (no operation needed), prolonged pyrexia, or intestinal fistula. One patient in the laparoscopy group died, a 93-year-old woman who was discharged in good condition 6 days after a laparoscopic appendectomy but died in her home 12 days after surgery for unknown reasons.139 A third study reported no complications of any type in the six patients who had diagnostic laparoscopy alone. In the 54 patients who had open appendectomy, there were five wound complications and one death. In the 47 patients who had diagnostic laparoscopy followed by laparoscopic appendectomy there were two wound complications. In the 15 patients who had laparoscopy and open appendectomy there were two wound complications.183 A recent comparative study of 1043 patients reported that the laparoscopic approach had a higher rate of intra-abdominal abscess (3.9% compared with 2.2% in the open group; p=0.055), but a lower rate of wound infections (1.5% versus 7% for the open group; p <0.0001).113 Another NRCS comparing diagnostic laparoscopy and open appendectomy reported that among the 93 diagnostic laparoscopy patients, there were three wound infections, one ileus, one hemolytic anemia, one case of aspiration pneumonia, and one infected hydrocele. In the open appendectomy group (n=74), there were four wound infections, two ileus, and one UTI.136 Two other NRCS reported perforations, one of the small bowel,138 and one of the transverse colon with the pneumoneedle.137

Twenty-five diagnostic cohort studies143–149,168–184,192 reported on complications of diagnostic laparoscopy in 5469 patients. Five studies reported that there were no complications.143,146,173,175,184 Two studies reported a total four deaths145,147. Others reported 37 wound infections,145,147–149,170–172,176–179,182 27 cases of ileus,145,171,172,177,182 23 deep venous thromboses,145 22 cases of fever (one with acute abdominal pain),145,147,172 18 intrabdominal infections,145 17 hematomas (4 wound, 2 intraabdominal, 2 abdominal wall, 1 parietal, and 8 unspecified),145,147,179,181 14 abscess,144,147,148,171,177,182 13 chest or respiratory infections,145,147,168,176,177,182 six perforations (3 bowel and 3 bladder),170,171,177,180 six fluid collection,174,176,178 six bleeding or hemorrhage,145,168,177,181 six intestinal obstructions,147,177 five coronary related complications,145 three inferior epigastric artery injury,172,180 three appendix ruptured on removal,172 two intestinal lesions,145 two cases of cecal leakage,177 one cecal dehiscence,177 one insufflation in cecal wall,181 one cecal phlegmon,147 one appendiceal artery hemorrhage,147 a perioperative arrhythmia and a pneumothorax,176 one case of pancreatitis,147 one case of intraabdominal sepsis,147 a laryngeal spasm post-intubation,182 a reaction to the abdominal sutures,174 one tertiary peritonitis and enterocutaneous fistula,148 a minor abdominal wall cellulitis,144 one case of mesoappendiceal bleeding,145 one pseudomembranous enterocolitis,145 one pulmonary embolism,145 one ruptured aortic aneurysm,145, and one reoperation to repair the appendix stump.192 Further details are presented in Table 35.