# References

1 Paulson EK, Kalady MF, Pappas TN. Clinical practice. Suspected appendicitis. The New England journal of medicine. Jan. 16. 2003;348(3):236-42. [pmid: 12529465].
2 Addiss DG, Shaffer N, Fowler BS, et al. The epidemiology of appendicitis and appendectomy in the United States. American journal of epidemiology. Nov. 1990;132(5):910-25. [pmid: 2239906].
3 Ferri FF. Ferri’s Clinical Advisor: Instant Diagnosis and Treatment, 2002. W.B. Saunders Company. 2003.
4 Parks NA, Schroeppel TJ. Update on imaging for acute appendicitis. The Surgical clinics of North America. Feb. 2011;91(1):141-54. [pmid: 21184905].
5 Wolfe J, Henneman P. Acute Appendicitis. Marx J, Hockberger R, Walls R, editors. Rosen’s Emergency Medicine. Philadelphia. Mosby/Elsevier. 2010:1193-9.
6 Andersson RE, Lambe M. Incidence of appendicitis during pregnancy. International journal of epidemiology. Dec. 2001;30(6):1281-5. [pmid: 11821329].
7 Zingone F, Sultan AA, Humes DJ, et al. Risk of acute appendicitis in and around pregnancy: a population-based cohort study from England. Annals of surgery. Feb. 2015;261(2):332-7. [pmid: 24950289].
8 Howell JM, Eddy OL, Lukens TW, et al. Clinical policy: Critical issues in the evaluation and management of emergency department patients with suspected appendicitis. Annals of emergency medicine. Jan. 2010;55(1):71-116. [pmid: 20116016].
9 Humes DJ, Simpson J. Clinical presentation of acute appendicitis: clinical signs - laboratory findings - clinical scores, Alvarado score and derivative scores. Keyzer C, Gevenois PA, editors. Imaging of acute appendicitis in adults and children. Springer-Verlag. 2011.
10 Andersson RE. Meta-analysis of the clinical and laboratory diagnosis of appendicitis. The British journal of surgery. Jan. 2004;91(1):28-37. [pmid: 14716790].
11 Bundy DG, Byerley JS, Liles EA, et al. Does this child have appendicitis?. JAMA : the journal of the American Medical Association. Jul. 25. 2007;298(4):438-51. [pmid: 17652298].
12 Hallan S, Asberg A. The accuracy of C-reactive protein in diagnosing acute appendicitis--a meta-analysis. Scandinavian journal of clinical and laboratory investigation. Aug. 1997;57(5):373-80. [pmid: 9279962].
13 Al-Khayal KA, Al-Omran MA. Computed tomography and ultrasonography in the diagnosis of equivocal acute appendicitis. A meta-analysis. Saudi medical journal. Feb. 2007;28(2):173-80. [pmid: 17268692].
14 Barger RL Jr, Nandalur KR. Diagnostic performance of magnetic resonance imaging in the detection of appendicitis in adults: a meta-analysis. Academic radiology. Oct. 2010;17(10):1211-6. [pmid: 20634107].
15 Blumenfeld YJ, Wong AE, Jafari A, et al. MR imaging in cases of antenatal suspected appendicitis--a meta-analysis. The journal of maternal-fetal & neonatal medicine : the official journal of the European Association of Perinatal Medicine, the Federation of Asia and Oceania Perinatal Societies, the International Society of Perinatal Obstet. Mar. 2011;24(3):485-8. [pmid: 20695758].
16 Doria AS, Moineddin R, Kellenberger CJ, et al. US or CT for Diagnosis of Appendicitis in Children and Adults? A Meta-Analysis. Radiology. Oct. 2006;241(1):83-94. [pmid: 16928974].
17 Krajewski S, Brown J, Phang PT, et al. Impact of computed tomography of the abdomen on clinical outcomes in patients with acute right lower quadrant pain: a meta-analysis. Canadian journal of surgery Journal canadien de chirurgie. Feb. 2011;54(1):43-53. [pmid: 21251432].
18 Terasawa T, Blackmore CC, Bent S, et al. Systematic review: computed tomography and ultrasonography to detect acute appendicitis in adults and adolescents. Annals of internal medicine. Oct. 5. 2004;141(7):537-46. [pmid: 15466771].
19 Greenhalgh R, Punwani S, Taylor SA. Is MRI routinely indicated in pregnant patients with suspected appendicitis after equivocal ultrasound examination?. Abdominal imaging. Jan–Feb. 2008;33(1):21-5. [pmid: 17874265].
20 Carroll PJ, Gibson D, El-Faedy O, et al. Surgeon-performed ultrasound at the bedside for the detection of appendicitis and gallstones: systematic review and meta-analysis. American journal of surgery. 2012. Jun. 28. [pmid: 22748292].
21 Liu JL, Wyatt JC, Deeks JJ, et al. Systematic reviews of clinical decision tools for acute abdominal pain. Health Technol Assess. Nov. 2006;10(47):1-167. iii. iv. [pmid: 17083855].
22 Alvarado A. A practical score for the early diagnosis of acute appendicitis. Annals of emergency medicine. May. 1986;15(5):557-64. [pmid: 3963537].
23 Ohle R, O’Reilly F, O’Brien KK, et al. The Alvarado score for predicting acute appendicitis: a systematic review. BMC medicine. 2011;9:139. [pmid: 22204638].
24 Kulik DM, Uleryk EM, Maguire JL. Does this child have appendicitis? A systematic review of clinical prediction rules for children with acute abdominal pain. Journal of clinical epidemiology. Jan. 2013;66(1):95-104. [pmid: 23177898].
25 Escriba A, Gamell AM, Fernandez Y, et al. Prospective validation of two systems of classification for the diagnosis of acute appendicitis. Pediatric emergency care. Mar. 2011;27(3):165-9. [pmid: 21346681].
26 Samuel M. Pediatric appendicitis score. Journal of pediatric surgery. Jun. 2002;37(6):877-81. [pmid: 12037754].
27 Korndorffer JR Jr, Fellinger E, Reed W. SAGES guideline for laparoscopic appendectomy. Surgical endoscopy. Apr. 2010;24(4):757-61. [pmid: 19787402].
28 Fahimi J, Herring A, Harries A, et al. Computed tomography use among children presenting to emergency departments with abdominal pain. Pediatrics. Nov. 2012;130(5):e1069-75. [pmid: 23045569].
29 Tsze DS, Asnis LM, Merchant RC, et al. Increasing computed tomography use for patients with appendicitis and discrepancies in pain management between adults and children: an analysis of the NHAMCS. Annals of emergency medicine. May. 2012;59(5):395-403. [pmid: 21802777].
30 Drake FT, Florence MG, Johnson MG, et al. Progress in the diagnosis of appendicitis: a report from Washington State’s Surgical Care and Outcomes Assessment Program. Annals of surgery. Oct. 2012;256(4):586-94. [pmid: 22964731].
31 Bachur RG, Hennelly K, Callahan MJ, et al. Advanced radiologic imaging for pediatric appendicitis, 2005–2009: trends and outcomes. The Journal of pediatrics. Jun. 2012;160(6):1034-8. [pmid: 22192815].
32 Mittal MK, Dayan PS, Macias CG, et al. Performance of ultrasound in the diagnosis of appendicitis in children in a multicenter cohort. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Jul. 2013;20(7):697-702. [pmid: 23859583].
33 Hryhorczuk AL, Mannix RC, Taylor GA. Pediatric abdominal pain: use of imaging in the emergency department in the United States from 1999 to 2007. Radiology. Jun. 2012;263(3):778-85. [pmid: 22535565].
34 Dingemann J, Ure B. Imaging and the use of scores for the diagnosis of appendicitis in children. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al] = Zeitschrift fur Kinderchirurgie. Jun. 2012;22(3):195-200. [pmid: 22767172].
35 Jaffe TA, Miller CM, Merkle EM. Practice patterns in imaging of the pregnant patient with abdominal pain: a survey of academic centers. AJR American journal of roentgenology. Nov. 2007;189(5):1128-34. [pmid: 17954650].
36 Wallace GW, Davis MA, Semelka RC, et al. Imaging the pregnant patient with abdominal pain. Abdominal imaging. Oct. 2012;37(5):849-60. [pmid: 22160283].
37 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Medical decision making : an international journal of the Society for Medical Decision Making. Apr–Jun. 1991;11(2):88-94. [pmid: 1907710].
38 Collaborative S, Cuschieri J, Florence M, et al. Negative appendectomy and imaging accuracy in the Washington State Surgical Care and Outcomes Assessment Program. Annals of surgery. Oct. 2008;248(4):557-63. [pmid: 18936568].
39 Clinical policy: critical issues for the initial evaluation and management of patients presenting with a chief complaint of nontraumatic acute abdominal pain. Annals of emergency medicine. Oct. 2000;36(4):406-15. [pmid: 11020699].
40 Flum DR, Morris A, Koepsell T, et al. Has misdiagnosis of appendicitis decreased over time? A population-based analysis. JAMA : the journal of the American Medical Association. Oct. 10. 2001;286(14):1748-53. [pmid: 11594900].
41 Ponsky TA, Huang ZJ, Kittle K, et al. Hospital- and patient-level characteristics and the risk of appendiceal rupture and negative appendectomy in children. JAMA : the journal of the American Medical Association. Oct. 27. 2004;292(16):1977-82. [pmid: 15507583].
42 Nance ML, Adamson WT, Hedrick HL. Appendicitis in the young child: a continuing diagnostic challenge. Pediatric emergency care. Jun. 2000;16(3):160-2. [pmid: 10888451].
43 Newman K, Ponsky T, Kittle K, et al. Appendicitis 2000: variability in practice, outcomes, and resource utilization at thirty pediatric hospitals. Journal of pediatric surgery. Mar. 2003;38(3):372-9. discussion -9. [pmid: 12632352].
44 Rothrock SG, Green SM, Dobson M, et al. Misdiagnosis of appendicitis in nonpregnant women of childbearing age. The Journal of emergency medicine. Jan–Feb. 1995;13(1):1-8. [pmid: 7782616].
45 Brown JJ, Wilson C, Coleman S, et al. Appendicitis in pregnancy: an ongoing diagnostic dilemma. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Feb. 2009;11(2):116-22. [pmid: 18513191].
46 Katz DS, Klein MA, Ganson G, et al. Imaging of abdominal pain in pregnancy. Radiologic clinics of North America. Jan. 2012;50(1):149-71. [pmid: 22099493].
47 Long SS, Long C, Lai H, et al. Imaging strategies for right lower quadrant pain in pregnancy. AJR American journal of roentgenology. Jan. 2011;196(1):4-12. [pmid: 21178041].
48 Kraemer M, Franke C, Ohmann C, et al. Acute appendicitis in late adulthood: incidence, presentation, and outcome. Results of a prospective multicenter acute abdominal pain study and a review of the literature. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Nov. 2000;385(7):470-81. [pmid: 11131250].
49 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD). 2008.
50 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. International journal of surgery (London, England). 2010;8(5):336-41. [pmid: 20171303].
51 Whiting P, Westwood M, Beynon R, et al. Inclusion of methodological filters in searches for diagnostic test accuracy studies misses relevant studies. Journal of clinical epidemiology. Jun. 2011;64(6):602-7. [pmid: 21075596].
52 Whiting PF, Weswood ME, Rutjes AW, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC medical research methodology. 2006;6:9. [pmid: 16519814].
53 Whiting P, Rutjes AW, Dinnes J, et al. Development and validation of methods for assessing the quality of diagnostic accuracy studies. Health Technol Assess. Jun. 1. 2004;8(25):iii-234. [pmid: 15193208].
54 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC medical research methodology. Nov. 10. 2003;3:25. [pmid: 14606960].
55 Wells GSB, O’Connell J, Robertson J, Peterson V, Welch V. The Newcastle-Ottawa scale (NOS) for assessing the quality of nonrandomised studies in meta-analysis. Available from: http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Last accessed July 23, 2014.
56 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
57 Hayen A, Macaskill P, Irwig L, et al. Appropriate statistical methods are required to assess diagnostic tests for replacement, add-on, and triage. Journal of clinical epidemiology. Aug. 2010;63(8):883-91. [pmid: 20079607].
58 Olkin I. Diagnostic statistical procedures in medical meta-analyses. Statistics in medicine. Sep. 15–30. 1999;18(17–18):2331-41. [pmid: 10474143].
59 Chu H, Cole SR. Bivariate meta-analysis of sensitivity and specificity with sparse data: a generalized linear mixed model approach. Journal of clinical epidemiology. Dec. 2006;59(12):1331-2. author reply 2–3. [pmid: 17098577].
60 Reitsma JB, Glas AS, Rutjes AW, et al. Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. Journal of clinical epidemiology. Oct. 2005;58(10):982-90. [pmid: 16168343].
61 Zwinderman AH, Bossuyt PM. We should not pool diagnostic likelihood ratios in systematic reviews. Statistics in medicine. Feb. 28. 2008;27(5):687-97. [pmid: 17611957].
62 Arends LR, Hamza TH, van Houwelingen JC, et al. Bivariate random effects meta-analysis of ROC curves. Medical decision making : an international journal of the Society for Medical Decision Making. Sep–Oct. 2008;28(5):621-38. [pmid: 18591542].
63 Rutter CM, Gatsonis CA. A hierarchical regression approach to meta-analysis of diagnostic test accuracy evaluations. Statistics in medicine. Oct. 15. 2001;20(19):2865-84. [pmid: 11568945].
64 Dahabreh IJ, Trikalinos TA, Lau J, et al. An Empirical Assessment of Bivariate Methods for Meta-Analysis of Test Accuracy. Rockville (MD). 2012.
65 Singh S, Chang SM, Matchar DB, et al. Grading a Body of Evidence on Diagnostic Tests. Chang SM, Matchar DB, Smetana GW, Umscheid CA, editors. Methods Guide for Medical Test Reviews. Rockville (MD). 2012.
66 Lau JW. Deceit and fraud in medical research - education is the way forward. International journal of surgery (London, England). 2006;4(2):131. [pmid: 17462329].
67 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. [pmid: 21784880].
68 Horzic M, Salamon A, Kopljar M, et al. Analysis of scores in diagnosis of acute appendicitis in women. Collegium antropologicum. Jun. 2005;29(1):133-8. [pmid: 16117311].
69 Schneider C, Kharbanda A, Bachur R. Evaluating appendicitis scoring systems using a prospective pediatric cohort. Annals of emergency medicine. Jun. 2007;49(6):778-84. 84 e1. [pmid: 17383771].
70 Andersson M, Andersson RE. The appendicitis inflammatory response score: a tool for the diagnosis of acute appendicitis that outperforms the Alvarado score. World journal of surgery. Aug. 2008;32(8):1843-9. [pmid: 18553045].
71 Mandeville K, Pottker T, Bulloch B, et al. Using appendicitis scores in the pediatric ED. The American journal of emergency medicine. Nov. 2011;29(9):972-7. [pmid: 20674221].
72 de Castro SM, Unlu C, Steller EP, et al. Evaluation of the appendicitis inflammatory response score for patients with acute appendicitis. World journal of surgery. Jul. 2012;36(7):1540-5. [pmid: 22447205].
73 Kirkil C, Karabulut K, Aygen E, et al. Appendicitis scores may be useful in reducing the costs of treatment for right lower quadrant pain. Ulusal travma ve acil cerrahi dergisi = Turkish journal of trauma & emergency surgery : TJTES. Jan. 2013;19(1):13-9. [pmid: 23588973].
74 Galindo Gallego M, Fadrique B, Nieto MA, et al. Evaluation of ultrasonography and clinical diagnostic scoring in suspected appendicitis. The British journal of surgery. Jan. 1998;85(1):37-40. [pmid: 9462380].
75 Hong JJ, Cohn SM, Ekeh AP, et al. A prospective randomized study of clinical assessment versus computed tomography for the diagnosis of acute appendicitis. Surgical infections. Fall. 2003;4(3):231-9. [pmid: 14588157].
76 Lee CC, Golub R, Singer AJ, et al. Routine versus selective abdominal computed tomography scan in the evaluation of right lower quadrant pain: a randomized controlled trial. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Feb. 2007;14(2):117-22. [pmid: 17192450].
77 Lehtimaki T, Juvonen P, Valtonen H, et al. Impact of routine contrast-enhanced CT on costs and use of hospital resources in patients with acute abdomen. Results of a randomised clinical trial. European radiology. Sep. 2013;23(9):2538-45. [pmid: 23715771].
78 Lopez PP, Cohn SM, Popkin CA, et al. The use of a computed tomography scan to rule out appendicitis in women of childbearing age is as accurate as clinical examination: a prospective randomized trial. The American surgeon. Dec. 2007;73(12):1232-6. [pmid: 18186378].
79 Ng CS, Palmer CR. Analysis of diagnostic confidence: application to data from a prospective randomized controlled trial of CT for acute abdominal pain. Acta Radiol. May. 2010;51(4):368-74. [pmid: 20350244].
80 Ng CS, Watson CJ, Palmer CR, et al. Evaluation of early abdominopelvic computed tomography in patients with acute abdominal pain of unknown cause: prospective randomised study. BMJ. Dec. 14. 2002;325(7377):1387. [pmid: 12480851].
81 Ng CS, Palmer CR. Analysis of diagnostic confidence and diagnostic accuracy: a unified framework. The British journal of radiology. Mar. 2007;80(951):152-60. [pmid: 17329682].
82 Sala E, Beadsmoore C, Gibbons D, et al. Unexpected changes in clinical diagnosis: early abdomino-pelvic computed tomography compared with clinical evaluation. Abdominal imaging. Nov. 2009;34(6):783-7. [pmid: 17901913].
83 Walker S, Haun W, Clark J, et al. The value of limited computed tomography with rectal contrast in the diagnosis of acute appendicitis. American journal of surgery. Dec. 2000;180(6):450-4. discussion 4–5. [pmid: 11182396].
84 McGory ML, Zingmond DS, Nanayakkara D, et al. Negative appendectomy rate: influence of CT scans. The American surgeon. Oct. 2005;71(10):803-8. [pmid: 16468523].
85 Petrosyan M, Estrada J, Chan S, et al. CT scan in patients with suspected appendicitis: clinical implications for the acute care surgeon. European surgical research Europaische chirurgische Forschung Recherches chirurgicales europeennes. 2008;40(2):211-9. [pmid: 17998781].
86 Raja AS, Wright C, Sodickson AD, et al. Negative appendectomy rate in the era of CT: an 18-year perspective. Radiology. Aug. 2010;256(2):460-5. [pmid: 20529988].
87 Shaligram A, Pallati P, Simorov A, et al. Do you need a computed tomographic scan to evaluate suspected appendicitis in young men: an administrative database review. American journal of surgery. Dec. 2012;204(6):1025-30. discussion 30. [pmid: 23022250].
88 Tsao K, St Peter SD, Valusek PA, et al. Management of pediatric acute appendicitis in the computed tomographic era. The Journal of surgical research. Jun. 15. 2008;147(2):221-4. [pmid: 18498874].
89 Wagner PL, Eachempati SR, Soe K, et al. Defining the current negative appendectomy rate: for whom is preoperative computed tomography making an impact?. Surgery. Aug. 2008;144(2):276-82. [pmid: 18656636].
90 Bachur RG, Hennelly K, Callahan MJ, et al. Diagnostic imaging and negative appendectomy rates in children: effects of age and gender. Pediatrics. May. 2012;129(5):877-84. [pmid: 22508920].
91 Hershko DD, Awad N, Fischer D, et al. Focused helical CT using rectal contrast material only as the preferred technique for the diagnosis of suspected acute appendicitis: a prospective, randomized, controlled study comparing three different techniques. Diseases of the colon and rectum. Aug. 2007;50(8):1223-9. [pmid: 17566826].
92 Kepner AM, Bacasnot JV, Stahlman BA. Intravenous contrast alone vs intravenous and oral contrast computed tomography for the diagnosis of appendicitis in adult ED patients. The American journal of emergency medicine. Nov. 2012;30(9):1765-73. [pmid: 22633722].
93 Kim K, Kim YH, Kim SY, et al. Low-dose abdominal CT for evaluating suspected appendicitis. The New England journal of medicine. Apr. 26. 2012;366(17):1596-605. [pmid: 22533576].
94 Mittal VK, Goliath J, Sabir M, et al. Advantages of focused helical computed tomographic scanning with rectal contrast only vs triple contrast in the diagnosis of clinically uncertain acute appendicitis: a prospective randomized study. Arch Surg. May. 2004;139(5):495-9. discussion 9–500. [pmid: 15136349].
95 Razavi SA, Johnson JO, Kassin MT, et al. The impact of introducing a no oral contrast abdominopelvic CT examination (NOCAPE) pathway on radiology turn around times, emergency department length of stay, and patient safety. [pmid: 24902657].
96 Horton MD, Counter SF, Florence MG, et al. A prospective trial of computed tomography and ultrasonography for diagnosing appendicitis in the atypical patient. American journal of surgery. May. 2000;179(5):379-81. [pmid: 10930484].
97 Kaiser S, Frenckner B, Jorulf HK. Suspected appendicitis in children: US and CT--a prospective randomized study. Radiology. Jun. 2002;223(3):633-8. [pmid: 12034928].
98 Kaiser S, Jorulf H, Soderman E, et al. Impact of radiologic imaging on the surgical decision-making process in suspected appendicitis in children. Academic radiology. Sep. 2004;11(9):971-9. [pmid: 15350578].
99 Raval MV, Deans KJ, Rangel SJ, et al. Factors associated with imaging modality choice in children with appendicitis. The Journal of surgical research. Sep. 2012;177(1):131-6. [pmid: 22507689].
100 van Randen A, Lameris W, van Es HW, et al. A comparison of the accuracy of ultrasound and computed tomography in common diagnoses causing acute abdominal pain. European radiology. Jul. 2011;21(7):1535-45. [pmid: 21365197].
101 Douglas CD, Macpherson NE, Davidson PM, et al. Randomised controlled trial of ultrasonography in diagnosis of acute appendicitis, incorporating the Alvarado score. BMJ. Oct. 14. 2000;321(7266):919-22. [pmid: 11030676].
102 Lindelius A, Pettersson H, Adami J, et al. Patient factors influencing the effect of surgeon-performed ultrasound on the acute abdomen. Critical ultrasound journal. Dec. 2010;2(3):97-105. [pmid: 21290005].
103 Lindelius A, Torngren S, Nilsson L, et al. Randomized clinical trial of bedside ultrasound among patients with abdominal pain in the emergency department: impact on patient satisfaction and health care consumption. Scandinavian journal of trauma, resuscitation and emergency medicine. 2009;17:60. [pmid: 19941671].
104 Lindelius A, Torngren S, Pettersson H, et al. Role of surgeon-performed ultrasound on further management of patients with acute abdominal pain: a randomised controlled clinical trial. Emergency medicine journal : EMJ. Aug. 2009;26(8):561-6. [pmid: 19625549].
105 Lindelius A, Torngren S, Sonden A, et al. Impact of surgeon-performed ultrasound on diagnosis of abdominal pain. Emergency medicine journal : EMJ. Aug. 2008;25(8):486-91. [pmid: 18660395].
106 Even-Bendahan G, Lazar I, Erez I, et al. Role of imaging in the diagnosis of acute appendicitis in children. Clinical pediatrics. Jan–Feb. 2003;42(1):23-7. [pmid: 12635978].
107 Farahnak M, Talaei-Khoei M, Gorouhi F, et al. The Alvarado score and antibiotics therapy as a corporate protocol versus conventional clinical management: randomized controlled pilot study of approach to acute appendicitis. The American journal of emergency medicine. Sep. 2007;25(7):850-2. [pmid: 17870498].
108 Lintula H, Kokki H, Kettunen R, et al. Appendicitis score for children with suspected appendicitis. A randomized clinical trial. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Nov. 2009;394(6):999-1004. [pmid: 18841382].
109 Lintula H, Kokki H, Pulkkinen J, et al. Diagnostic score in acute appendicitis. Validation of a diagnostic score (Lintula score) for adults with suspected appendicitis. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Jun. 2010;395(5):495-500. [pmid: 20379739].
110 Shah NA, Islam M, Sabir IA, Mehreen T, Khan M. Diagnostic accuracy of clinical examination versus combination of abdominal ultrasound and alvarado score, in patients with acute appendicitis. JPMI - Journal of Postgraduate Medical Institute [serial on the Internet]. 2008;(1). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/585/CN-00792585/frame.html.
111 Ohmann C, Franke C, Yang Q. Clinical benefit of a diagnostic score for appendicitis: results of a prospective interventional study. German Study Group of Acute Abdominal Pain. Arch Surg. Sep. 1999;134(9):993-6. [pmid: 10487595].
112 Bruwer F, Coetzer M, Warren BL. Laparoscopic versus open surgical exploration in premenopausal women with suspected acute appendicitis. South African journal of surgery Suid-Afrikaanse tydskrif vir chirurgie. Nov. 2003;41(4):82-5. [pmid: 14768141].
113 Sadot E, Keidar A, Shapiro R, et al. Laparoscopic accuracy in prediction of appendiceal pathology: oncologic and inflammatory aspects. American journal of surgery. Nov. 2013;206(5):805-9. [pmid: 24016703].
114 Decadt B, Sussman L, Lewis MP, et al. Randomized clinical trial of early laparoscopy in the management of acute non-specific abdominal pain. The British journal of surgery. Nov. 1999;86(11):1383-6. [pmid: 10583282].
115 Gaitan H, Angel E, Sanchez J, et al. Laparoscopic diagnosis of acute lower abdominal pain in women of reproductive age. International journal of gynaecology and obstetrics: the official organ of the International Federation of Gynaecology and Obstetrics. Feb. 2002;76(2):149-58. [pmid: 11818109].
116 Morino M, Pellegrino L, Castagna E, et al. Acute nonspecific abdominal pain: A randomized, controlled trial comparing early laparoscopy versus clinical observation. Annals of surgery. Dec. 2006;244(6):881-6. discussion 6–8. [pmid: 17122613].
117 Jadallah FA, Abdul-Ghani AA, Tibblin S. Diagnostic laparoscopy reduces unnecessary appendicectomy in fertile women. The European journal of surgery = Acta chirurgica. Jan. 1994;160(1):41-5. [pmid: 8186313].
118 Laine S, Rantala A, Gullichsen R, et al. Laparoscopic appendectomy-is it worthwhile? A prospective, randomized study in young women. Surgical endoscopy. Feb. 1997;11(2):95-7. [pmid: 9069134].
119 Larsson PG, Henriksson G, Olsson M, et al. Laparoscopy reduces unnecessary appendicectomies and improves diagnosis in fertile women. A randomized study. Surgical endoscopy. Feb. 2001;15(2):200-2. [pmid: 11285968].
120 Olsen JB, Myren CJ, Haahr PE. Randomized study of the value of laparoscopy before appendicectomy. The British journal of surgery. Jul. 1993;80(7):922-3. [pmid: 8369940].
121 van Dalen R, Bagshaw PF, Dobbs BR, et al. The utility of laparoscopy in the diagnosis of acute appendicitis in women of reproductive age. Surgical endoscopy. Aug. 2003;17(8):1311-3. [pmid: 12739123].
122 Tzovaras G, Liakou P, Baloyiannis I, et al. Laparoscopic appendectomy: differences between male and female patients with suspected acute appendicitis. World journal of surgery. Feb. 2007;31(2):409-13. [pmid: 17219281].
123 Akbar F, Yousuf M, Morgan RJ, et al. Changing management of suspected appendicitis in the laparoscopic era. Annals of the Royal College of Surgeons of England. Jan. 2010;92(1):65-8. [pmid: 20056066].
124 Ekeh AP, Wozniak CJ, Monson B, et al. Laparoscopy in the contemporary management of acute appendicitis. American journal of surgery. Mar. 2007;193(3):310-3. discussion 3–4. [pmid: 17320525].
125 Barrat C, Catheline JM, Rizk N, et al. Does laparoscopy reduce the incidence of unnecessary appendicectomies?. Surgical laparoscopy & endoscopy. Jan. 1999;9(1):27-31. [pmid: 9950123].
126 Wallace CA, Petrov MS, Soybel DI, et al. Influence of imaging on the negative appendectomy rate in pregnancy. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Jan. 2008;12(1):46-50. [pmid: 17963012].
127 Cobben LP, Groot I, Haans L, et al. MRI for clinically suspected appendicitis during pregnancy. AJR American journal of roentgenology. Sep. 2004;183(3):671-5. [pmid: 15333354].
128 Frisenda R, Roty AR Jr, Kilway JB, et al. Acute appendicitis during pregnancy. The American surgeon. Aug. 1979;45(8):503-6. [pmid: 507547].
129 Masters K, Levine BA, Gaskill HV, et al. Diagnosing appendicitis during pregnancy. American journal of surgery. Dec. 1984;148(6):768-71. [pmid: 6507749].
130 Pedrosa I, Lafornara M, Pandharipande PV, et al. Pregnant patients suspected of having acute appendicitis: effect of MR imaging on negative laparotomy rate and appendiceal perforation rate. Radiology. Mar. 2009;250(3):749-57. [pmid: 19244044].
131 Pedrosa I, Levine D, Eyvazzadeh AD, et al. MR imaging evaluation of acute appendicitis in pregnancy. Radiology. Mar. 2006;238(3):891-9. [pmid: 16505393].
132 Tamir IL, Bongard FS, Klein SR. Acute appendicitis in the pregnant patient. American journal of surgery. Dec. 1990;160(6):571-5. discussion 5–6. [pmid: 2252115].
133 Unal A, Sayharman SE, Ozel L, et al. Acute abdomen in pregnancy requiring surgical management: a 20-case series. European journal of obstetrics, gynecology, and reproductive biology. Nov. 2011;159(1):87-90. [pmid: 21831513].
134 Cavusoglu YH, Erdogan D, Karaman A, et al. Do not rush into operating and just observe actively if you are not sure about the diagnosis of appendicitis. Pediatric surgery international. Mar. 2009;25(3):277-82. [pmid: 19184052].
135 Kim SY, Lee KH, Kim K, et al. Acute appendicitis in young adults: low- versus standard-radiation-dose contrast-enhanced abdominal CT for diagnosis. Radiology. Aug. 2011;260(2):437-45. [pmid: 21633052].
136 Kollias J, Harries RH, Otto G, et al. Laparoscopic versus open appendicectomy for suspected appendicitis: a prospective study. The Australian and New Zealand journal of surgery. Dec. 1994;64(12):830-5. [pmid: 7980256].
137 Ragland J, de la Garza J, McKenney J. Peritoneoscopy for the diagnosis of acute appendicitis in females of reproductive age. Surgical endoscopy. 1988;2(1):36-8. [pmid: 2972080].
138 Tronin RJ, Burova VA, Grinberg AA. Laparoscopic diagnosis of acute appendicitis in women. The Journal of the American Association of Gynecologic Laparoscopists. Feb. 1996;3(2):257-61. [pmid: 9050636].
139 Moberg AC, Montgomery A. Introducing diagnostic laparoscopy for patients with suspected acute appendicitis. Surgical endoscopy. Oct. 2000;14(10):942-7. [pmid: 11080408].
140 Didier RA, Vajtai PL, Hopkins KL. Iterative reconstruction technique with reduced volume CT dose index: diagnostic accuracy in pediatric acute appendicitis. [pmid: 24996812].
141 Sharp NE, Raghavan MU, Svetanoff WJ, et al. Radiation exposure - how do CT scans for appendicitis compare between a free standing children’s hospital and non-dedicated pediatric facilities?. Journal of pediatric surgery. Jun. 2014;49(6):1016-9. discussion 9. [pmid: 24888854].
142 Karabulut N, Kiroglu Y, Herek D, et al. Feasibility of low-dose unenhanced multi-detector CT in patients with suspected acute appendicitis: comparison with sonography. [pmid: 24513314].
143 Thorell A, Grondal S, Schedvins K, et al. Value of diagnostic laparoscopy in fertile women with suspected appendicitis. The European journal of surgery = Acta chirurgica. Aug. 1999;165(8):751-4. [pmid: 10494640].
144 Bagnato VJ. Laparoscopy for the management of appendicitis. Journal of the Mississippi State Medical Association. Jul. 1992;33(7):249-51. [pmid: 1387169].
145 Moberg AC, Ahlberg G, Leijonmarck CE, et al. Diagnostic laparoscopy in 1043 patients with suspected acute appendicitis. The European journal of surgery = Acta chirurgica. Nov. 1998;164(11):833-40. discussion 41. [pmid: 9845129].
146 Kuster GG, Gilroy SB. The role of laparoscopy in the diagnosis of acute appendicitis. The American surgeon. Oct. 1992;58(10):627-9. [pmid: 1416436].
147 Wagner M, Aronsky D, Tschudi J, et al. Laparoscopic stapler appendectomy. A prospective study of 267 consecutive cases. Surgical endoscopy. Sep. 1996;10(9):895-9. [pmid: 8703146].
148 in’t Hof KH, van Lankeren W, Krestin GP, et al. Surgical validation of unenhanced helical computed tomography in acute appendicitis. The British journal of surgery. Dec. 2004;91(12):1641-5. [pmid: 15386320].
149 Lee SL, Walsh AJ, Ho HS. Computed tomography and ultrasonography do not improve and may delay the diagnosis and treatment of acute appendicitis. Arch Surg. May. 2001;136(5):556-62. [pmid: 11343547].
150 Ghotbi N, Ohtsuru A, Ogawa Y, et al. Pediatric CT scan usage in Japan: results of a hospital survey. Radiation medicine. Oct. 2006;24(8):560-7. [pmid: 17041792].
151 Keyzer C, Tack D, de Maertelaer V, et al. Acute appendicitis: comparison of low-dose and standard-dose unenhanced multi-detector row CT. Radiology. Jul. 2004;232(1):164-72. [pmid: 15155894].
152 Laituri CA, Fraser JD, Aguayo P, et al. The lack of efficacy for oral contrast in the diagnosis of appendicitis by computed tomography. The Journal of surgical research. Sep. 2011;170(1):100-3. [pmid: 21470628].
153 Pickhardt PJ, Lawrence EM, Pooler BD, et al. Diagnostic performance of multidetector computed tomography for suspected acute appendicitis. Annals of internal medicine. Jun. 21. 2011;154(12):789-96. W-291. [pmid: 21690593].
154 Poletti PA, Platon A, De Perrot T, et al. Acute appendicitis: prospective evaluation of a diagnostic algorithm integrating ultrasound and low-dose CT to reduce the need of standard CT. European radiology. Dec. 2011;21(12):2558-66. [pmid: 21805194].
155 Rao PM, Rhea JT, Novelline RA, et al. Helical CT technique for the diagnosis of appendicitis: prospective evaluation of a focused appendix CT examination. Radiology. Jan. 1997;202(1):139-44. [pmid: 8988203].
156 Rypins EB, Kipper SL, Weiland F, et al. 99m Tc anti-CD 15 monoclonal antibody (LeuTech) imaging improves diagnostic accuracy and clinical management in patients with equivocal presentation of appendicitis. Annals of surgery. Feb. 2002;235(2):232-9. [pmid: 11807363].
157 Seo H, Lee KH, Kim HJ, et al. Diagnosis of acute appendicitis with sliding slab ray-sum interpretation of low-dose unenhanced CT and standard-dose i.v. contrast-enhanced CT scans. AJR American journal of roentgenology. Jul. 2009;193(1):96-105. [pmid: 19542400].
158 Acosta R, Crain EF, Goldman HS. CT can reduce hospitalization for observation in children with suspected appendicitis. Pediatric radiology. May. 2005;35(5):495-500. [pmid: 15633057].
159 Brandt MM, Wahl WL. Liberal use of CT scanning helps to diagnose appendicitis in adults. The American surgeon. Sep. 2003;69(9):727-31. discussion 31–2. [pmid: 14509318].
160 Dickson AP, MacKinlay GA. Rectal examination and acute appendicitis. Archives of disease in childhood. Jul. 1985;60(7):666-7. [pmid: 4026364].
161 Wise SW, Labuski MR, Kasales CJ, et al. Comparative assessment of CT and sonographic techniques for appendiceal imaging. AJR American journal of roentgenology. Apr. 2001;176(4):933-41. [pmid: 11264081].
162 Leeuwenburgh MM, Wiarda BM, Wiezer MJ, et al. Comparison of imaging strategies with conditional contrast-enhanced CT and unenhanced MR imaging in patients suspected of having appendicitis: a multicenter diagnostic performance study. Radiology. Jul. 2013;268(1):135-43. [pmid: 23481162].
163 Hershko DD, Sroka G, Bahouth H, et al. The role of selective computed tomography in the diagnosis and management of suspected acute appendicitis. The American surgeon. Nov. 2002;68(11):1003-7. [pmid: 12455796].
164 Kan JH, Fines BP, Funaki B. Conventional and hydrocolonic US of the appendix with CT correlation performed by on-call radiology residents. Academic radiology. Dec. 2001;8(12):1208-14. [pmid: 11770917].
165 Johnson AK, Filippi CG, Andrews T, et al. Ultrafast 3-T MRI in the evaluation of children with acute lower abdominal pain for the detection of appendicitis. AJR American journal of roentgenology. Jun. 2012;198(6):1424-30. [pmid: 22623558].
166 Kipper SL, Rypins EB, Evans DG, et al. Neutrophil-specific 99mTc-labeled anti-CD15 monoclonal antibody imaging for diagnosis of equivocal appendicitis. Journal of nuclear medicine : official publication, Society of Nuclear Medicine. Mar. 2000;41(3):449-55. [pmid: 10716317].
167 Wong DW, Vasinrapee P, Spieth ME, et al. Rapid detection of acute appendicitis with Tc-99m-labeled intact polyvalent human immune globulin. Journal of the American College of Surgeons. Dec. 1997;185(6):534-43. [pmid: 9404876].
168 Ates M, Sevil S, Bulbul M. Routine use of laparoscopy in patients with clinically doubtful diagnosis of appendicitis. Journal of laparoendoscopic & advanced surgical techniques Part A. Apr. 2008;18(2):189-93. [pmid: 18373441].
169 Borgstein PJ, Gordijn RV, Eijsbouts QA, et al. Acute appendicitis--a clear-cut case in men, a guessing game in young women. A prospective study on the role of laparoscopy. Surgical endoscopy. Sep. 1997;11(9):923-7. [pmid: 9294274].
170 Clarke PJ, Hands LJ, Gough MH, et al. The use of laparoscopy in the management of right iliac fossa pain. Annals of the Royal College of Surgeons of England. Mar. 1986;68(2):68-9. [pmid: 2937361].
171 Connor TJ, Garcha IS, Ramshaw BJ, et al. Diagnostic laparoscopy for suspected appendicitis. The American surgeon. Feb. 1995;61(2):187-9. [pmid: 7856985].
172 Cox MR, McCall JL, Wilson TG, et al. Laparoscopic appendicectomy: a prospective analysis. The Australian and New Zealand journal of surgery. Nov. 1993;63(11):840-7. [pmid: 8216060].
173 Cristalli BG, Izard V, Jacob D, et al. Laparoscopic appendectomy using a clip applier. Surgical endoscopy. 1991;5(4):176-8. [pmid: 1839575].
174 DeCou JM, Gauderer MW, Boyle JT, et al. Diagnostic laparoscopy with planned appendectomy: an integral step in the evaluation of unexplained right lower quadrant pain. Pediatric surgery international. Feb. 2004;20(2):123-6. [pmid: 14745576].
175 Diehl JT, Eisenstat MS, Gillinov S, et al. The role of peritoneoscopy in the diagnosis of acute abdominal conditions. Cleveland Clinic quarterly. Fall. 1981;48(3):325-30. [pmid: 6457704].
176 Grabham JA, Sutton C, Nicholson ML. A case for the removal of the ‘normal’ appendix at laparoscopy for suspected acute appendicitis. Annals of the Royal College of Surgeons of England. Jul. 1999;81(4):279-80. [pmid: 10615200].
177 Gurrado A, Faillace G, Bottero L, et al. Laparoscopic appendectomies: experience of a surgical unit. Minimally invasive therapy & allied technologies : MITAT : official journal of the Society for Minimally Invasive Therapy. 2009;18(4):242-7. [pmid: 20334502].
178 Jones GE, Kreckler S, Shah A, et al. Increased use of laparoscopy in acute right iliac fossa pain - is it good for patients?. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Feb. 2012;14(2):237-42. [pmid: 21689285].
179 Konstantinidis KM, Anastasakou KA, Vorias MN, et al. A decade of laparoscopic appendectomy: presentation of 1,026 patients with suspected appendicitis treated in a single surgical department. Journal of laparoendoscopic & advanced surgical techniques Part A. Apr. 2008;18(2):248-58. [pmid: 18373452].
180 Linos DA, Vlitaki M, Peppas G, et al. Laparoscopy in the context of lower abdominal pain in young women. Journal of laparoendoscopic & advanced surgical techniques Part A. Feb. 1999;9(1):39-43. [pmid: 10194691].
181 Mutter D, Navez B, Gury JF, et al. Value of microlaparoscopy in the diagnosis of right iliac fossa pain. American journal of surgery. Oct. 1998;176(4):370-2. [pmid: 9817258].
182 Ng S, Fleming FJ, Drumm J, et al. Current trends in the management of acute appendicitis. Irish journal of medical science. Jun. 2008;177(2):121-5. [pmid: 18259838].
183 Schirmer BD, Schmieg RE Jr, Dix J, et al. Laparoscopic versus traditional appendectomy for suspected appendicitis. American journal of surgery. Jun. 1993;165(6):670-5. [pmid: 8506965].
184 Spirtos NM, Eisenkop SM, Spirtos TW, et al. Laparoscopy--a diagnostic aid in cases of suspected appendicitis. Its use in women of reproductive age. American journal of obstetrics and gynecology. Jan. 1987;156(1):90-4. [pmid: 2948388].
185 Barloon TJ, Brown BP, Abu-Yousef MM, et al. Sonography of acute appendicitis in pregnancy. Abdominal imaging. Mar–Apr. 1995;20(2):149-51. [pmid: 7787719].
186 Kapan S, Bozkurt MA, Turhan AN, et al. Management of acute appendicitis in pregnancy. Ulusal travma ve acil cerrahi dergisi = Turkish journal of trauma & emergency surgery : TJTES. Jan. 2013;19(1):20-4. [pmid: 23588974].
187 Lim HK, Bae SH, Seo GS. Diagnosis of acute appendicitis in pregnant women: value of sonography. AJR American journal of roentgenology. Sep. 1992;159(3):539-42. [pmid: 1503019].
188 Singh AK, Desai H, Novelline RA. Emergency MRI of acute pelvic pain: MR protocol with no oral contrast. Emergency radiology. Mar. 2009;16(2):133-41. [pmid: 18649091].
189 Vu L, Ambrose D, Vos P, et al. Evaluation of MRI for the diagnosis of appendicitis during pregnancy when ultrasound is inconclusive. The Journal of surgical research. Sep. 2009;156(1):145-9. [pmid: 19560166].
190 Freeland M, King E, Safcsak K, et al. Diagnosis of appendicitis in pregnancy. American journal of surgery. Dec. 2009;198(6):753-8. [pmid: 19969125].
191 Lazarus E, Mayo-Smith WW, Mainiero MB, et al. CT in the evaluation of nontraumatic abdominal pain in pregnant women. Radiology. Sep. 2007;244(3):784-90. [pmid: 17709829].
192 Ilce Z, Yildiz T, Isleyen M. The role of laparoscopy in suspicious abdomen pain in children. Pak J Med Sci. Jul. 2013;29(4):1042-5. [pmid: 24353684].
193 Thieme ME, Leeuwenburgh MM, Valdehueza ZD, et al. Diagnostic accuracy and patient acceptance of MRI in children with suspected appendicitis. [pmid: 24135892].
194 Fonseca AL, Schuster KM, Kaplan LJ, et al. The use of magnetic resonance imaging in the diagnosis of suspected appendicitis in pregnancy: shortened length of stay without increase in hospital charges. JAMA Surg. Jul. 2014;149(7):687-93. [pmid: 24871698].
195 Lu B, Gatsonis C. Efficiency of study designs in diagnostic randomized clinical trials. Statistics in medicine. Apr. 30. 2013;32(9):1451-66. [pmid: 23071073].
196 Hall EJ, Brenner DJ. Cancer risks from diagnostic radiology. The British journal of radiology. May. 2008;81(965):362-78. [pmid: 18440940].