# Methods

The methods for this systematic review follow the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (available at www.effectivehealthcare.ahrq.gov/); methods and results are reported in accordance with the Preferred Reporting Items for Systematic Reviews and Meta-analyses (PRISMA) checklist.50

## AHRQ Task Order Officer, Stakeholder Input, and Review Protocol

The AHRQ Task Order Officer (TOO) was responsible for overseeing all aspects of this project. A panel of key informants gave input on the key questions (KQs) to be examined; these KQs were posted on AHRQ‘s EHC website for public comment from April 17 to May 14, 2013 and revised in response to comments. We then drafted a protocol for the systematic review and recruited a panel of technical experts to provide high-level content and methodological input throughout the development of the review. The TEP included representatives of professional societies, experts in the diagnosis and treatment of RLQ abdominal pain and appendicitis (including emergency physicians, radiologists, and surgeons), and a patient representative. The finalized protocol is posted on the EHC Web site at http://effectivehealthcare.ahrq.gov/ehc/products/528/1827/Appendicitis-protocol-131209.pdf. The PROSPERO registration number for this review is CRD42013006480.

## Analytic Framework

We used an analytic framework (Figure 1) that maps the Key Questions within the context of populations, interventions, comparators, and outcomes of interest.

Figure 1 Analytic framework

KQ = Key Question; RLQ = right lower quadrant; S & S = symptoms and signs

This figure depicts the Key Questions within the context of the PICO (Population, Intervention, Comparator, Outcome) criteria. The figure illustrates how diagnostic test choice will result in the KQ1 outcome of diagnosis, which will lead to KQ2 outcomes, including clinical and patient centered outcomes (bowel perforation, fistula formation, infectious complications, diagnostic delay, length of hospital stay, fetal-maternal outcomes, and mortality) and intermediate outcomes, such as change in diagnostic thinking and change in therapeutic decisionmaking, which then lead to test directed treatment and thus to the patient centered outcomes listed above. KQ3 outcomes include harms of testing and harms of test-directed treatment, and KQ 1b and 2b look at modifiers of test performance or comparative effectiveness across the process.

## Inclusion and Exclusion Criteria

### Populations and Conditions of Interest

The population of interest for all Key Questions was patients with acute RLQ abdominal pain (≤ 7 days duration) for whom appendicitis is considered in the differential diagnosis. Separate analyses were performed for the following populations:

- Children (age <18 years); we initially planned additional analyses for subgroups of very young children (<2 years and 2–5 years of age); however, data were inadequate for examining these subgroups
- Adults (age ≥ 18 years)
- Nonpregnant women of reproductive age
- Pregnant women
- Elderly (age ≥65 years)

### Interventions

For all Key Questions, the interventions of interest were diagnostic tests (alone or in combination) for diagnosing appendicitis, including clinical signs (e.g., psoas sign, obturator sign, Rovsing sign), clinical symptoms (e.g., fever, migrating pain, guarding), laboratory tests (e.g., white blood cell count, C-reactive protein concentration, left shift), multivariate diagnostic scores (including clinical prediction and decision rules, e.g., Alvarado score, Pediatric Appendicitis Score, other predictive models), imaging tests (e.g., US; multidetector or helical CT with or without contrast administered orally, rectally, or intravenously, MRI with or without contrast; abdominal X-ray); nuclear imaging studies; and diagnostic laparoscopy.

### Comparators (Index and Reference Standard Tests)

For all Key Questions, the comparators were alternative tests or test combinations (as listed above) or clinical observation.

### Outcomes

For Key Question 1, the outcome of interest was test performance, as assessed by sensitivity, specificity, or other measures of accuracy; using pathology or clinical followup as the reference standard. For Key Question 2, we looked for the following outcomes: impact on diagnostic thinking (e.g., change in diagnosis after testing; change in subsequent diagnostic approach after obtaining initial test results) and impact on therapeutic decisionmaking (e.g., change in treatment plan after testing; time from admission to surgery). We also looked at the following patient-centered and resource utilization outcomes: “negative” appendectomy rate, bowel perforation (ruptured appendix), fistula formation, infectious complications (abscess formation, peritonitis, sepsis, stump appendicitis), delay in diagnosis (time from presentation to definitive diagnosis; time from presentation to initiation of treatment; time from presentation to resolution of pain), length of hospital stay, fetal/maternal outcomes (for pregnant women; including premature labor, pregnancy loss, fetal morbidity, fetal mortality, maternal morbidity, maternal mortality), and mortality. For Key Question 3, we considered adverse effects of interventions, including direct harms of testing (e.g., harms from exposure to ionizing radiation, allergic reactions/kidney injury caused by contrast agents) harms of test-directed treatment (indirect).

When outcome definitions were not provided by the included studies, we adopted the terms used by the studies at face value.

### Timing

Studies were considered regardless of duration of followup.

### Setting

All health care settings were considered.

### Study Design and Additional Criteria

Given the large expected number of potentially relevant studies to be reviewed in full text, the scope of the project had to be constrained operationally to ensure feasibility. Several approaches that could be used to achieve this aim were discussed with Key Informants during Topic Refinement and the TEP members (in preparation of this protocol). Based on these discussions and preliminary literature scans, we opted to use the following approach:

- For studies assessing test performance outcomes (i.e. for a subset of the studies pertaining to Key Question 1), we relied on previously completed systematic reviews (when available) to identify relevant studies and obtain specific data items (see following paragraph). We updated these reviews to include more recent studies identified through literature searches.
- For index tests where no relevant systematic review of test performance meeting our selection criteria (see following paragraph) could be identified, we performed a de novo systematic review.
- For studies that directly compare alternative tests (for all outcomes of interest) and for studies (comparative or noncomparative) reporting outcomes other than test performance (e.g., change in diagnostic thinking, impact on therapeutic decisionmaking, clinical outcomes, and harms) we performed a de novo review, because these topics were not addressed adequately by the reviews that were available when we designed our protocol.

We used existing systematic reviews to identify studies with test performance outcomes (Key Question 1). Systematic reviews were considered as potential sources of eligible studies if they met the following criteria:

- Reported the bibliographic databases searched and any additional sources of included studies.
- Used explicit criteria for selecting primary studies of the populations and index tests of interest (as described in section 2, above).
- Examined test performance outcomes.
- Provided a list of included studies that allowed the retrieval of the corresponding full text publications.

## Literature Search and Abstract Screening

Appendix A describes our literature search strategies. Searches were conducted in PubMed^®^, EMBASE^®^, the Cochrane Central Register of Controlled Trials, and the Cumulative Index to Nursing and Allied Health Literature (CINAHL^®^) databases to identify primary research studies meeting our criteria (last search on August 6, 2014, for PubMed; August 12, 2014, for all other databases). We also used the PubMed^®^ search results to identify systematic reviews of the tests of interest (last search July 31, 2013; the search for systematic reviews was not updated because our search for primary studies covered recent years adequately). We did not restrict searches by year of publication. A common set of 200 abstracts (in 2 pilot rounds, each with 100 abstracts) were screened by all reviewers, and discrepancies were discussed in order to standardize screening practices and ensure understanding of screening criteria by all team members. The remaining citations were split into nonoverlapping sets, each screened by two reviewers independently. Discrepancies were resolved by consensus involving a third investigator.

## Study Selection and Eligibility Criteria

Potentially eligible citations (i.e., abstracts considered potentially relevant by consensus) were obtained in full text and reviewed for eligibility on the basis of the predefined inclusion criteria. A single reviewer examined all articles; a second reviewer examined a subset of 350 articles independently. Disagreements regarding article eligibility were resolved by consensus involving a third reviewer.

We included only English-language studies during full text review because our preliminary searches indicated that non–English-language studies had small sample sizes and represented a small proportion of the evidence for any given test modality; as such, their exclusion is unlikely to have affected our conclusions. We excluded studies published exclusively in abstract form (e.g., conference proceedings) because they are typically not peer reviewed, only partially report results, and may change substantially when fully published. The lists of included and excluded studies (organized by reason for exclusion) are in Appendix B.

We asked the TEP to provide citations of potentially relevant articles. Additional studies were identified through the perusal of reference lists of eligible studies, published clinical practice guidelines, relevant narrative and systematic reviews, conference proceedings, and Scientific Information Packages from manufacturers. All articles identified through these sources were screened for eligibility against the same criteria as for articles identified through literature searches. The final list of included studies was reviewed by the TEP to ensure that no key publications had been missed.

## Data Abstraction and Management

Previously published reviews were used as sources of eligible single index test studies of test performance and as sources of data for objective data elements from these studies (bibliographic study information, characteristics of included populations, and counts of individuals stratified by diagnostic test result and disease status). For all studies, EPC investigators extracted data elements using standardized operational definitions (e.g., elements of study design, risk of bias assessment) from the full text of primary study publications.

Data was extracted into Word or Excel data extraction forms and will be uploaded to the Systematic Review Data Repository (SRDR, http://srdr.ahrq.gov/home/index) upon submission of the Final Report. The forms included elements that address population characteristics, sample size, study design, descriptions of the index and reference standard tests of interest, analytic details, and outcome data. We pilot tested the forms on several studies extracted by all team members to ensure consistency in operational definitions.

A single reviewer extracted data from each eligible study of test performance; one reviewer extracted and a second reviewer verified data from NRCSs and RCTs. For RCTs, when possible, data were extracted according to the intention-to-treat principle. We verified the data extraction and risk of bias assessment in a random sample of 368 non-comparative test performance studies (reporting 1487separate pairs of sensitivity and specificity). Overall, we found that agreement was excellent in capturing information about the index and reference standard tests and numerical information on test performance. Agreement was less good for some risk of bias items (complete and non-differential verification and inappropriate exclusions). These items were re-extracted for all included studies following a series of standardization exercises to ensure consistent application of our operational definitions.

We contacted authors (a) to clarify information reported in the papers that is hard to interpret (e.g., inconsistencies between tables and text); (b) to obtain missing data on key subgroups of interest when not available in the published reports (e.g., pregnant women, women of reproductive age, children); and (c) to verify suspected overlap between study populations in publications from the same group of investigators. Author contact was by email (to the corresponding author of each study), with a primary contact attempt (once all eligible studies had been identified) and up to two reminder emails (approximately 2 and 4 weeks after the first attempt).

## Assessment of the Risk of Bias of Individual Studies

We assessed the risk of bias for each individual study using the assessment methods detailed by the AHRQ Methods Guide. We used items from the updated QUADAS 2 instrument to assess the risk of bias of the diagnostic test studies included in the review (these studies comprised the majority of the available studies).51–54 The items we selected assessed four domains for risk of bias related to patient selection, use of the index test, use of the reference standard test, and patient flow and timing. For studies of other designs, we used appropriate sets of items to assess risk of bias: for NRCSs, we used items from the Newcastle-Ottawa scale;55 for RCTs, we used items from the Cochrane Risk of Bias tool.56

We did not calculate “composite” quality scores. Instead, we assessed and reported each methodological quality item (as Yes, No, or Unclear/Not Reported) for each eligible study. We rated each study as being of low, intermediate, or high risk of bias on the basis of adherence to accepted methodological principles. Generally, studies with low risk of bias have the following features: lowest likelihood of confounding due to comparison to a randomized controlled group; a clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting inconsistencies; clear reporting of dropouts, and a dropout rate less than 10 percent; and no other apparent source of bias. Studies with moderate risk of bias are susceptible to some bias but not sufficiently to invalidate results. They do not meet all the criteria for low risk of bias owing to some deficiencies, but none are likely to introduce major bias. Studies with moderate risk of bias may not be randomized or may be missing information, making it difficult to assess limitations and potential problems. Studies with high risk of bias are those with indications of bias that may invalidate the reported findings (e.g., observational studies not adjusting for any confounders, studies using historical controls, or studies with very high dropout rates). These studies have serious errors in design, analysis, or reporting and contain discrepancies in reporting or have large amounts of missing information. We discuss the handling of high risk of bias studies in the following sections.

In quantitative analyses, we performed subgroup analyses to assess the impact of each risk of bias item on the meta-analytic results. The grading was outcome specific, such that a given study that reports its primary outcome well but did an incomplete analysis of a secondary outcome was graded of different quality for the two outcomes. Studies of different designs were graded within the context of their study design.

## Evidence Synthesis

We summarized the included studies qualitatively and present important features of the study populations, designs, interventions, outcomes, and results in summary tables. Population characteristics of interest include age, sex, duration of symptoms, and clinical presentation at enrollment. Design characteristics include methods of population selection and sampling, and follow-up duration. Test characteristics include aspects specific to each diagnostic test of interest (e.g., the use and route of administration of contrast agents for imaging tests), the specific definitions of clinical signs, and the components and their weights for clinical prediction rules (the surgical approach for diagnostic laparoscopy, etc.). We present information on test performance, harms, intermediate and terminal outcomes, and resource utilization. Of note, all studies evaluating the test performance of the same single index test in a similar patient population were synthesized jointly, regardless of their source (our own literature searches or previously published reviews).

For each comparison of interest, we judged whether the eligible studies were sufficiently similar to be combined in a meta-analysis on the basis of clinical heterogeneity of patient populations and testing strategies, as well as methodological heterogeneity of study designs and outcomes reported. We performed analyses appropriate for the specific role of testing evaluated in each study (replacement, triage, add-on) whenever possible.57 However, the complexity of the differential diagnosis of RLQ pain and limited reporting of relevant information in published studies limited our ability to distinguish between alternative test roles.

Studies employed a variety of different diagnostic methods (e.g., different imaging modalities, clinical symptoms and signs, laboratory measurements, and combinations thereof). We have based our judgments on the similarity of available tests on technical descriptions of the modalities used in each study (e.g., whether studies used similar imaging technologies or similar clinical examination protocols). We sought input from TEP members to define groups of “sufficiently similar” studies for synthesis (including meta-analysis) during later stages of the review as questions arose. Of note, the material used to solicit TEP input did not include any data on outcome results extracted from the studies (to limit the potential for bias). The determination on the appropriateness of meta-analysis was made before any data analysis. We did not base the decision to perform a meta-analysis on statistical criteria for heterogeneity. Such criteria are often inadequate (e.g., low power when the number of studies is small) and do not account for the ability to explore and explain heterogeneity by examining study-level characteristics. Instead, we used clinical criteria to assess study exchangeability (e.g., we considered whether studies enrolled populations selected using similar inclusion criteria, with comparable baseline risk of appendicitis, and assessed using similar imaging technologies or other tests). The main analyses include all relevant studies.

Analyses were performed separately for the following patient populations: children, women of reproductive age, pregnant women, and the elderly. Subgroup analyses (e.g., by clinical presentation at diagnosis, aspects of specific test modalities, etc.) were also performed. The concordance of findings across subgroup analyses was evaluated qualitatively (in all instances) and quantitatively (using meta-regression, when the data allowed). We considered the following potential modifiers of test performance or other outcomes in meta-regression analyses: patient characteristics (e.g., age, sex, clinical presentation at enrollment), test characteristics (e.g., extent of imaging field, use of contrast agents and route of administration), clinician and facility factors (e.g., setting of test use), and date of publication (≥2005 vs. earlier). We also performed subgroup analyses by individual risk of bias items to assess the impact of each risk of bias item on the results of the meta-analysis. We evaluated the robustness of our findings in sensitivity analyses that exclude studies at high risk of bias. Some studies examining the test performance of imaging tests reported classification results from multiple raters. In our main analyses we used results from the rater that had the highest sum of sensitivity plus specificity (i.e., the rater that had a sum of estimated sensitivity and specificity closest to 2). As a worst-case sensitivity analysis we also repeated all analyses using results from the rater that had the lowest sum of sensitivity plus specificity. In addition, some studies of imaging tests reported information on indeterminate test results (in some cases separately by final diagnostic status, in other cases without any information on final diagnosis). In our main analyses, indeterminate test results were excluded. To explore the impact of indeterminate results on test performance we performed two “extreme case” sensitivity analyses, one where all indeterminate results with unknown (not reported) final diagnostic status were considered false positive and one where all were considered false negative. In these sensitivity analyses, all indeterminate results with known diagnostic status were considered in the corresponding false result category (i.e., indeterminate results in patients with a final diagnosis of appendicitis were considered false negative and indeterminate results in unaffected individuals were considered false positive).58

When five or more sufficiently similar studies evaluated the test performance of the same test in the same population, we used a bivariate-bivariate normal meta-analysis model to obtain summary sensitivity and specificity estimates.59,60 We used the summary sensitivity and specificity estimates to calculate summary positive and negative likelihood ratios (LRs).61 We also used the estimates from the bivariate model to construct summary receiver operating characteristic (ROC) curves using the model proposed by Rutter and Gatsonis.62,63 For parallel arm studies comparing alternative test strategies with respect to clinical outcomes and resource utilization, we planned to perform meta-analyses when there were more than three unique, sufficiently similar studies evaluating the same intervention and comparator and reporting the same outcomes; however, no such instances were identified. All meta-analyses were conducted using Bayesian methods with flat (uninformative) priors;64 models were fit with Markov chain Monte Carlo methods. Sensitivity analyses (including leave-one-out analyses, analyses assuming a fixed effects model, and reanalyses after excluding a group of studies) were undertaken where considered appropriate (e.g., in the presence of studies with outlying effect sizes or evidence of temporal changes in effect sizes). Heterogeneity was assessed visually by inspecting plots of study estimates in the ROC space and by examining the posterior distribution of the between-study heterogeneity parameters (for logit-sensitivity and logit-specificity). We explored between-study heterogeneity using subgroup and meta-regression analyses, by extending the binomial-bivariate normal model to include study-level covariates.

In cases when only a subset of the available studies could be quantitatively combined (e.g., when some studies are judged to be so clinically different from others as to be excluded from meta-analysis), we synthesized findings across all studies qualitatively by taking into account the magnitude and direction of effects and estimates of performance.

## Grading the Strength of Evidence

We followed the Methods Guide49 to evaluate the strength of the body of evidence for each Key Question with respect to the following domains: risk of bias, consistency, directness, precision, and reporting bias.49,65 Briefly, we defined the risk of bias (low, medium, or high) on the basis of the study design and the methodological quality of the studies. Generally, lack of studies at low risk of bias or inconsistencies among groups of studies at different levels of risk of bias led to downgrading the strength of the evidence. We rated the consistency of the data as no inconsistency, inconsistency present, or not applicable (if there is only one study available). We did not use rigid counts of studies as standards of evaluation (e.g., four of five studies agree, therefore the data are consistent); instead, we assessed the direction, magnitude, and statistical significance of all studies and made a determination. We describe our logic where studies are not unanimous. We assessed directness of the evidence (“direct” vs. “indirect”) on the basis of the use of surrogate outcomes or the need for indirect comparisons. We assessed the precision of the evidence as precise or imprecise on the basis of the degree of certainty surrounding each effect estimate. A precise estimate is one that allows for a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions and that therefore precludes a conclusion.

The majority of studies to be included in this review are observational cohorts, reporting on outcomes of test performance, utilizing one or more index tests on all study participants. However, we found a small number of parallel group, randomized or non-randomized, comparative studies of alternative test strategies (e.g., reporting comparisons between alternative tests). We did not combine the results of randomized and non-randomized studies statistically. Instead, we qualitatively evaluated similarities and differences in study populations, diagnostic methods, and outcomes among study designs. These comparisons inform our judgments on applicability of study findings to clinical practice.

The potential for reporting bias (“suspected” vs. “not suspected”) was evaluated with respect to publication bias, selective outcome reporting bias, and selective analysis reporting bias. For reporting bias, we made qualitative dispositions rather than perform formal statistical tests to evaluate differences in the effect sizes between more precise (larger) and less precise (smaller) studies. Although these tests are often referred to as tests for publication bias; reasons other than publication bias can lead to a statistically significant result, including “true” heterogeneity between smaller and larger studies, other biases, and chance, rendering the interpretation of the tests nonspecific and the tests noninformative.66,67 Therefore, instead of relying on statistical tests, we evaluated the reported results across studies qualitatively, on the basis of completeness of reporting (separately for each outcome of interest), number of enrolled patients, and numbers of observed events. Judgment on the potential for selective outcome reporting bias was based on reporting patterns for each outcome of interest across studies. We acknowledge that both types of reporting bias are difficult to reliably detect on the basis of data available in published research studies (i.e., without access to study protocols and detailed analysis plans). Because such assessments are inherently subjective, we explicitly present all operational decisions and the rationale for our judgment on reporting bias in the Results and Discussion sections.

Finally, we rated the strength of the body of evidence using four levels: high, moderate, low, and insufficient.49 These describe our level of confidence that the evidence reflects the true effect for the major comparisons of interest.

## Assessing Applicability

We followed the Methods Guide49 to evaluate the applicability of included studies to patient populations of interest. We evaluated studies separately by important clinical subgroups: children, women of reproductive age, pregnant women, and the elderly. Applicability to the population of interest was also judged separately on the basis of duration of symptoms before enrollment, outcomes (e.g., test performance, impact on diagnostic thinking and clinical decisionmaking, clinical outcomes), and setting of care (e.g., whether patients were recruited in an academic, tertiary, or primary care setting).

## Peer Review

The initial draft report was pre-reviewed by the TOO and an AHRQ Associate Editor. Following revisions, the draft report was sent to invited peer reviewers and was simultaneously uploaded to the AHRQ Web site where it was available for public comment for 30 days. All reviewer comments (both invited and from the public) were collated and individually addressed. The revised report and the EPC’s responses to invited and public reviewers’ comments were again reviewed by the TOO and Associate Editor prior to completion of the report. The authors of the report had final discretion as to how the report was revised based on the reviewer comments, with oversight by the TOO and Associate Editor. A disposition of comments report will be made available online, 3 months after the Agency posts the final systematic review on the EHC Web site.