# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Roland E. Andersson, M.D., Ph.D.
  Linköping University
  Linköping, Sweden
- Richard Bachur, M.D.
  Harvard Medical School
  Boston, MA
- Esther H. Chen, M.D.
  University of California, San Francisco/San Francisco General Hospital
  Department of Emergency Medicine
  Associate Professor of Emergency Medicine
  San Francisco, CA
- Anthony Chow, M.D.
  Division of Infectious Diseases
  University of British Columbia Vancouver Hospital
  Vancouver, BC, Canada
- Andrea S. Doria, M.D., Ph.D., M.Sc.
  The Hospital for Sick Children
  Toronto, ON, Canada
- Sherif Emil, M.D., C.M.
  Pediatric General and Thoracic Surgery
  The Montreal Children’s Hospital
  McGill University Health Centre
  Montreal, QC, Canada
- Tyler Hughes, M.D.
  McPherson Hospital
  McPherson, KS
- Anupam Kharbanda, M.D., M.Sc.
  Director of Research, Emergency Services
  Associate PEM Fellowship Director
  Department of Pediatric Emergency Medicine
  Children’s Hospitals and Clinics of Minnesota
  Minneapolis, MN
- Martin P. Smith, M.D.
  Beth Israel Deaconess Medical Center
  Harvard Medical School
  Boston, MA
- Daniel Dante Yeh, M.D.
  Massachusetts General Hospital
  Division of Trauma, Emergency Surgery and Surgical Critical Care
  Boston, MA