# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Anthony Chow, M.D.
  Division of Infectious Diseases
  University of British Columbia Vancouver Hospital
  Vancouver, BC, Canada
- Tyler Hughes, M.D.
  McPherson Hospital
  McPherson, KS
- Douglas Katz, M.D., FACR
  Vice Chairman of Research and Education
  Winthrop Radiology Associates
  Winthrop-University Hospital, Department of Radiology
  Director of Body CT, Winthrop-University Hospital
  Mineola, NY
- Anupam Kharbanda, M.D., M.Sc.
  Director of Research, Emergency Services
  Associate PEM Fellowship Director
  Department of Pediatric Emergency Medicine
  Children’s Hospitals and Clinics of Minnesota
  Minneapolis, MN
- Susan Promes, M.D.
  University of California San Francisco School of Medicine
  San Francisco, CA
- David Rahn, M.D.
  University of Texas Southwestern
  Dallas, TX
- Martin P. Smith, M.D.
  Beth Israel Deaconess Medical Center
  Harvard Medical School
  Boston, MA
- Daniel Dante Yeh, M.D.
  Massachusetts General Hospital
  Division of Trauma, Emergency Surgery and Surgical Critical Care
  Boston, MA