# Discussion

## Key Findings and Strength of Evidence Assessment

This Comparative Effectiveness Review synthesizes evidence from more than 900 studies on the diagnosis of RLQ pain and suspected acute appendicitis to answer Key Questions related to test performance, patient-relevant outcomes, and test-related harms. The literature on the test performance of various clinical symptoms and signs, laboratory and imaging tests, and multivariable diagnostic scores is vast, but consists almost exclusively of studies assessing the test performance of individual index tests. Information on test performance of multiple tests applied jointly and conditional test performance (i.e., test performance among patients already examined with other tests) was very limited. The few studies that provided information on more than one index tests were typically not designed with the goal of providing comparative information and cross-study comparisons cannot provide reliable evidence on relative performance. We found very limited information on the test performance or comparative effectiveness of diagnostic pathways (i.e., well-defined sequences of diagnostic and treatment steps). Comparisons of the test performance of alternative test strategies had to rely on indirect (cross-study) evidence. We believe that the available evidence can support fairly strong conclusions about the test performance of individual tests, but is often insufficient to support conclusions about their comparative effectiveness. In this section we briefly summarize our assessment of the strength of evidence for key outcomes (Table 36). Of note, strength of evidence grades reflect our confidence in the evidence underlying the report’s conclusions and should not be interpreted as clinical recommendations. For example, “insufficient” strength of evidence for a comparison between two tests means that the available evidence does not allow us to confidently estimate the difference in test performance between the two tests; it does not mean that we believe the tests to have (or not have) similar performance.

Table 36 Assessment of the strength of evidence for test performance and modifiers of test performance

Test or Comparison Between Tests | Strength of Evidence | Risk of Bias | Precision | Directness | Consistency | Adults | Children | Elderly | Women of Reproductive Age | Pregnant Women
Diagnostic test performance
WBC count | Moderate | Intermediate-high | Somewhat imprecise | Direct | Somewhat inconsistent | 26 studies Sens: 0.81 (0.74 to 0.87) Spec: 0.54 (0.42 to 0.64) | 41 studies Sens: 0.80 (0.73 to 0.85) Spec: 0.65 (0.56 to 0.73) | 3 studies Sens: 0.71 (0.69 to 0.77) Spec: 0.50 (0.38 to 0.70) | 2 studies Sens: 0.64 (0.60 to 0.69) Spec: 0.67 (0.67 to 0.67) | 6 studies Sens: 0.63 (0.21 to 0.92) Spec: 0.75 (0.38 to 0.95)
CRP | Low | Intermediate-high | Imprecise | Direct | Somewhat inconsistent | 15 studies Sens: 0.84 (0.73 to 0.92) Spec: 0.67 (0.50 to 0.81) | 22 studies Sens: 0.73 (0.66 to 0.80) Spec: 0.72 (0.61 to 0.81) | 2 studies Sens: 0.91 (0.91 to 0.92) Spec: 0.21 (0.17 to 0.25) | 3 studies Sens: 0.79 (0.44 to 0.97) Spec: 0.70 (0.33 to 0.93) | 1 study Sens: 0.68 Spec: 0.50
Measures based on the CBC and differential | Low | Intermediate-high | Imprecise | Direct | Somewhat inconsistent; but available data limit our ability to assess consistency | Please see the Results section for the test performance of various test combinations
Alvarado score (low risk cut-off) | Moderate | Intermediate | Somewhat imprecise | Direct | Somewhat inconsistent | 3 studies Sens: 0.91 (0.89 to 0.93) Spec: 0.31 (0.24 to 0.78) | 6 studies Sens: 0.99 (0.92 to 1.00) Spec: 0.48 (0.24 to 0.74) | No studies | 2 studies Sens: 0.99 (0.98 to 1.00) Spec: 0.24 (0.22 to 0.25) | No studies
Alvarado score (high risk cut-off) | Moderate | Intermediate | Somewhat imprecise | Direct | Somewhat inconsistent | 16 studies Sens: 0.80 (0.60 to 0.93) Spec: 0.71 (0.50 to 0.85) | 9 studies Sens: 0.83 (0.73 to 0.91) Spec: 0.81 (0.63 to 0.92) | No studies | 5 studies Sens: 0.70 (0.35 to 0.92) Spec: 0.91 (0.65 to 0.99) | No studies
PAS | Low | Intermediate | Imprecise | Direct | Consistent | No studies | 5 studies Sens: 0.03 (0.00 to 0.13) Spec: 1.00 (0.99 to 1.00) | No studies | No studies | No studies
CT | Moderate-High | Intermediate | Precise | Direct | Consistent | 72 studies Sens: 0.96 (0.95 to 0.97) Spec: 0.96 (0.93 to 0.97) | 34 studies Sens: 0.96 (0.94 to 0.98) Spec: 0.92 (0.85 to 0.96) | 4 studies Sens: 1.00 (0.94 to 1.00) Spec: 1.00 (0.43 to 1.00) | 11 studies Sens: 0.99 (0.96 to 1.00) Spec: 0.91 (0.75 to 0.97) | 5 studies Sens: 0.99 (0.96 to 1.00) Spec: 0.91 (0.75 to 0.97)
MRI | Low | Intermediate | Imprecise | Direct | Consistent | 7 studies Sens: 0.95 (0.88 to 0.98) Spec: 0.92 (0.87 to 0.95) | 7 studies Sens: 0.97 (0.87 to 1.00) Spec: 0.96 (0.84 to 0.99) | No studies | 1 study Sens: 1.00 Spec: 0.86 | 11 studies Sens: 0.98 (0.92 to 1.00) Spec: 0.98 (0.96 to 1.00)
US | Moderate | Intermediate-high | Precise | Direct | Somewhat inconsistent | 38 studies Sens: 0.85 (0.79 to 0.90) Spec: 0.90 (0.83 to 0.95) | 85 studies Sens: 0.89 (0.86 to 0.92) Spec: 0.91 (0.89 to 0.94) | No studies | 11 studies Sens: 0.72 (0.51 to 0.88) Spec: 0.92 (0.75 to 0.98) | 13 studies Sens: 0.72 (0.45 to 0.92) Spec: 0.95 (0.84 to 0.99)
Laparoscopy | Moderate | Intermediate-high | Somewhat imprecise | Direct | Somewhat inconsistent | Please see the Results section for a complete description of results related to diagnostic laparoscopy
Modification of test performance
All factors | Insufficient | Intermediate or high | Typically imprecise | Indirect (meta-regression) | Not possible to assess consistency on the basis of available data (assessments relied on cross-study comparisons) | The evidence on the effect of patient- and test-related characteristics on test performance was limited and exclusively derived from indirect comparisons. There were indications that aspects of study design characteristics affect test performance but the effects are often unpredictable in direction and do not have direct clinical relevance.

CT = computed tomography; MRI = magnetic resonance imaging; PAS = Pediatric Appendicitis Score; Sens = sensitivity; Spec = specificity; US = ultrasound; WBC = white blood cell

Ratings reflect our trust in the estimates of test performance (from individual studies or meta-analyses) and should not be construed as clinical recommendations.

### Test Performance

Clinical symptoms and signs, including classical signs of peritoneal irritation, fever, and various assessments of abdominal pain, appeared to have limited test performance when used in isolation (positive likelihood ratios smaller than 5; negative likelihood ratios larger than 0.2) in all the populations of interest to this report. Among laboratory tests WBC, CRP, and tests derived from combinations of measurements on the complete blood count and differential had test performance that was generally higher compared to that of clinical symptoms and signs (especially with respect to sensitivity using a low risk threshold) but still rather limited (e.g., in terms of summary LRs). Because studies did not allow an examination of the performance of multiple tests applied jointly, and because conditional test performance was not reported uniformly across studies, the clinical implications of the relatively limited test performance of many non-imaging tests are not clear. Furthermore, signs and symptoms are variable within patient (over the course of disease) and among patients, and it is hard to assess their performance based on test performance. Importantly, the clinical examination forms the basis of the investigation of acute abdominal pain and suspected acute appendicitis and – even if poorly reported – all studies of imaging tests use some form of clinical examination for patient selection.

Multivariable diagnostic scores appeared to have test performance that was superior to the individual clinical signs, symptoms, or laboratory tests they included, but still rather limited (e.g., in terms of summary likelihood ratios). Of note, the majority of studies assessed scores that had been developed before the widespread availability of CT and US imaging, suggesting that their results may be less applicable to current clinical practice.

Among imaging tests, CT and MRI had high sensitivity and specificity, resulting in clinically relevant summary likelihood ratios. CT had been investigated by a large number of diagnostic cohort studies, leading to precise estimates of test performance in all populations of interest to this report. Although there were no reported short-term harms from ionizing radiation, it does present a long-term risk, particularly in children and pregnant women. In contrast, MRI had been investigated in a relatively small number of studies mainly focused on pregnant women. US had lower test performance and resulted in substantially greater proportion of non-diagnostic examinations, compared to both CT and MRI, across populations of interest. US was investigated by a large number of studies and results were somewhat heterogeneous, suggesting that the average estimate of test performance may not apply to all populations for which US is considered. A possible explanation for this heterogeneity is the operator dependence of the test performance of US and the fact that studies had been conducted in different settings.

Diagnostic laparoscopy appeared to have good test performance; however, studies were poorly reported and differed in their policies regarding removal of the appendix when no pathology was macroscopically visible, which may bias test performance results. Furthermore, patients included in studies of diagnostic laparoscopy are different from patients included in studies of non-invasive tests. Therefore, our results for the test performance of laparoscopy should not be compared with the other diagnostic tests reviewed in this report.

For all diagnostic tests, we emphasize that test performance is not directly related to clinical outcomes, and high sensitivity and specificity do not necessarily imply improvements in outcomes, such as perforations, abscesses, or other infectious complications.

### Comparative Test Performance

Comparisons among tests with respect to test performance relied on a small number of RCTs of moderate risk of bias, a relatively small number of direct comparisons among index tests in diagnostic cohort studies that were not designed to obtain comparative information, and indirect comparisons across single index test studies enrolling diverse populations in heterogeneous clinical settings. There was evidence of moderate strength that CT has superior overall test performance compared to US and produces fewer non-diagnostic results. Similarly, MRI appeared to have better test performance than US, but the strength of evidence was deemed low. The strength of the evidence on comparisons among other imaging tests and among multivariable diagnostic scores was deemed insufficient.

### Patient-Relevant Outcomes

The evidence is insufficient for patient relevant outcomes. We based our assessment of the comparative effectiveness of alternative tests primarily on RCTs because indirect (across studies) comparisons of outcomes other than test performance are susceptible to bias due to differences among the populations included. We found only a few RCTs, which assessed a range of comparisons across different modalities (or different versions of the same modality), and as such did not provide definitive evidence for any of the possible pairwise contrasts they evaluated.

### Adverse Events of Testing

The evidence is insufficient for adverse events. Information on harms was often incomplete and poorly reported. Only a minority of the included studies provided information on test-related harms, raising concerns about selective outcome and analysis reporting. The majority of the studies providing information on adverse events did not report the definitions or ascertainment methods they used. Importantly, no information was available from studies meeting our selection criteria regarding the effects of ionizing ration. Information was particularly limited on fetal and maternal outcomes of various diagnostic modalities applied during pregnancy for the investigation of acute appendicitis.

## Limitations of the Evidence Base

The evidence base regarding the diagnosis of acute appendicitis is limited in the following ways:

- Studies reporting information on test performance outcomes were at moderate to high risk of bias. Differential verification (the use of a different reference standard test depending on the results of the index test) and partial verification (the failure to apply the reference standard on the included patients) were common, particularly in studies that were not surgical series (generally, studies with a lower prevalence of appendicitis). Studies with complete and non-differential verification tended to be surgical cohorts reporting exclusively on patients undergoing appendectomy that are not representative of all patients with acute RLQ pain. In addition, poor reporting of information on study design hampered our risk of bias assessment.
- Studies provided limited information to assess the impact of various patient-, technical implementation-, operator-, or system-related factors on the test performance of the tests of interest. For example, the impact of patient age, sex, contrast use (for CT), operator experience, and setting of care on test performance and patient-relevant outcomes could not be fully explored.
- Information on the comparative effectiveness of alternative testing strategies (e.g., sequential use of tests as part of a diagnostic algorithm) with respect to test performance, patient-relevant outcomes, and resource use was limited. Direct (within study) comparisons of test performance and impact of testing strategies on clinical outcomes were scarce. Studies have not compared diagnostic algorithms (e.g., combinations of tests applied in sequence such that the results of earlier tests determine the choice of subsequent tests). When two or more index tests were evaluated in the same study, the role of testing that was being examined (add-on, replacement, triage) was often unclear.
- In studies of diagnostic scores, multivariable models were often developed and evaluated in the same patient sample. The lack of separation between the training and testing datasets (or any attempt at internal validation of the model) generally leads to optimistic (too high) estimates of test performance. The lack of external validation (replication) also limited our ability to assess the generalizability of many diagnostic scores.
- Few RCTs compared alternative test strategies with respect to patient-relevant outcomes. The few trials reporting patient-relevant outcomes were fragmented across heterogeneous comparisons of alternative testing strategies. The trials often used suboptimal methods for randomized sequence generation, allocation concealment, and blinding, or they provided information that was too limited to assess these aspects of study design. Many had sample sizes that were too small to reliably detect small or moderate differences between the strategies being compared.
- In contrast to the RCTs, NRCSs of alternative testing strategies attained large sample sizes but often reported unadjusted analyses (or analyses adjusted only for a small number of potential confounders) that do not allow drawing strong conclusions about the comparative effectiveness of alternative test strategies.

## Strengths and Limitations of This Review

Previous reviews on this topic have focused on special patients populations (e.g., children only or pregnant women only), have largely focused on test performance outcomes, have not assessed harms systematically, or have focused on a very limited spectrum of study designs (e.g., comparative prospective cohort studies only). Our work provides a comprehensive, up-to-date summary of the evidence on the diagnosis of RLQ pain and suspected acute appendicitis. For many of the examined tests and patient populations, this review is the first to be conducted; for some important modalities that have been to some extent investigated in previous meta-analyses (e.g., CT, MRI, US, and multivariable diagnostic scores), our work includes a much larger number of studies (and a greater total number of patients) compared to previous reviews. This allows us to provide accurate estimates of test performance in different patient populations that can be used to inform clinical decisions (especially if used as inputs in decision and simulation modeling studies) and to identify evidence gaps to inform the planning of future research.

Nonetheless, several limitations—which to some extent reflect the limitations of the underlying evidence base—need to be considered when interpreting our results. The body of evidence consisted of studies that we deemed to be of moderate to high risk of bias on the basis of aspects of their design and conduct. In some cases, methodological shortcomings and poor reporting limited our ability to draw strong conclusions, despite the availability of a large number of relevant studies.

Information for several outcomes of interest was not reported from all available studies. We were most concerned about selective outcome and analysis reporting for patient-relevant outcomes and harms. Furthermore, the selective publication of favorable or unfavorable evidence on any given test (i.e., publication bias) may have affected our results. Statistical methods for the detection of publication bias have general limitations that limit their usefulness; empirical studies in diagnostic test meta-analyses have demonstrated that existing methods are inadequate.

Information on study- or population-level characteristics that could be modifiers of test performance, patient-relevant outcomes, and adverse events was incomplete or poorly reported in the included studies. Thus, our ability to explore between-study heterogeneity using meta-regression was limited. Furthermore, because we relied on published information and did not obtain individual patient data from any of the included studies, we were unable to evaluate the impact of patient- or lesion-level factors on outcomes of interest. Although worthwhile, individual patient meta-analysis of diagnostic studies in acute appendicitis would be very challenging to undertake given the large number of available studies, each reporting findings for different test modalities, and employing alternative definitions of positive index and reference standard tests.

The reference standard in the reviewed studies was a combination of pathologic examination following appendectomy (for index test positive patients) and clinical followup (for index test negative patients); in many studies a substantial proportion of included patients were not assessed with a reference standard. Differential and incomplete verification can bias the estimation of test performance measures.

We assumed that pathological diagnosis and clinical followup have negligible measurement error (i.e., that they represent a “gold” standard). It is unlikely that this assumption is exactly true (e.g., pathologic examination may have some diagnostic error, and clinical followup provides less than perfectly accurate information). Consequently, it is likely that estimates of test performance are biased, and the direction of this bias is hard to predict, particularly at the meta-analysis level. However, we believe that the error rate of this reference standard is low enough that its influence on our estimates is relatively small.

Finally, we did not address contextual factors (e.g., availability of equipment, trained readers) that are important determinants of the adoption of specific diagnostic strategies in particular settings.

## Applicability of Review Findings

In general, the existing evidence on alternative diagnostic tests for the diagnosis of acute RLQ pain and suspected acute appendicitis appears to be applicable to clinical practice in the U.S. The included studies enrolled patients representative of the age and sex distribution of patients seeking care for right lower quadrant abdominal pain in the U.S. and evidence on test performance was available for all commonly used modalities. Information on adults and children was often separately reported allowing the assessment of test performance in these patient subgroups. However, information was more limited for patients at the extremes of age (i.e., children younger than 5 years or the elderly), pregnant women, and women of reproductive age; in some cases decisions for these will have to rely on extrapolation of results from population subgroups with more available information (and thus applicability assessments are not possible). Approximately one third of the studies in this review were conducted in the U.S, and the vast majority was carried out in either the U.S. or in industrialized European or Asian countries. Care settings varied across studies and included academic and non-academic centers, and patient populations were sampled at emergency departments, from surgical cohorts, or from mixed populations.

Assessing the applicability of studies on clinical symptoms and signs was challenging: the pathophysiologic rationale for many of these tests is well established. However, many of the relevant studies were conducted before the widespread availability of imaging modalities, and thus their findings may reflect test performance in a population with more advanced disease or populations selected for a high probability of appendicitis (e.g., surgical cohorts). Studies of laboratory and imaging tests evaluated “stable” technologies (e.g., white blood cell count) or had been conducted in recent years (e.g., many studies of CRP, CT, and US had been conducted from 2005 onwards). In meta-regression analyses comparing test performance in the last decade against earlier years there was no evidence that the performance of laboratory or imaging tests has changed significantly over time; however, the indirect nature of meta-regression comparisons and the low precision of meta-regression estimates limits the strength of these findings. In contrast, the applicability of the evidence on most multivariable diagnostic scores may be somewhat limited because most were developed before the era of widespread availability of imaging. The lack of external validation for most diagnostic scores also limits the applicability of these results. The findings of studies on diagnostic laparoscopy may also be less applicable because they were conducted before the widespread availability of diagnostic imaging.

## Evidence Gaps and Ongoing Research

Table 37 summarizes the evidence gaps with regards to the Key Questions of diagnostic test performance, patient-relevant outcomes, and adverse events.

Table 37 Evidence gaps for the diagnosis of right lower quadrant abdominal pain and suspected acute appendicitis

Key Question | Category | Evidence Gap
Test performance | Population | Limited information on all populations for MRI Relatively limited information on women of reproductive age, pregnant women, and the elderly for tests other than MRI
Test performance | Interventions & Comparators | Limited information on MRI Limited information on combinations of tests and alternative test algorithms
Test performance | Outcomes | Test performance outcomes (sensitivity, specificity, area under the ROC curve, etc.)
Test performance | Modifiers of test performance | Optimal imaging method for specific subgroups of patients, different presentations of patients with right lower quadrant pain, and physician- or system-level factors
Comparative test performance | Population | All populations of interest
Comparative test performance | Interventions & Comparators | All tests of interest to this report; particularly imaging modalities in common use (CT, MRI) and emerging technologies (e.g., MRI, novel multivariable diagnostic scores) Combinations of tests, especially alternative test algorithms combining more than one tests, in sequence or in parallel
Comparative test performance | Outcomes | Test performance outcomes (sensitivity, specificity, area under the ROC curve, etc.)
Comparative test performance | Modifiers of test performance | Preferred imaging method for specific subgroups of patients, different presentations of patients with right lower quadrant pain, and physician- or system-level factors
Patient-centered outcomes and resource utilization | Population | All populations of interest
Patient-centered outcomes and resource utilization | Interventions & Comparators | All tests of interest to this report; particularly imaging modalities in common use (e.g., CT, MRI) and emerging technologies (e.g., MRI, novel multivariable diagnostic scores) Combinations of tests, especially alternative test algorithms combining more than one tests, in sequence or in parallel
Patient-centered outcomes and resource utilization | Outcomes | Impact on diagnostic thinking and therapeutic decisionmaking; bowel perforation (ruptured appendix), fistula formation, infectious complications (abscess formation, peritonitis, sepsis, stump appendicitis), delay in diagnosis (time from presentation to definitive diagnosis; time from presentation to initiation of treatment; time from presentation to resolution of pain), length of hospital stay, and mortality.
Patient-centered outcomes and resource utilization | Modifiers of comparative effectiveness | Information on factors that affect the incidence of adverse events is sparse. Unclear what subgroups of patients and lesions may be most likely to experience adverse events
Test-related harms | Population | All populations of interest; particularly individuals at the extremes of age and pregnant women
Test-related harms | Interventions & Comparators | All tests of interest to this report; particularly imaging modalities in common use (e.g., CT, MRI) and emerging technologies (e.g., MRI, new multivariable diagnostic scores) Combinations of tests, especially alternative test algorithms combining more than one tests, in sequence or in parallel
Test-related harms | Outcomes | Direct harms of testing (e.g., harms from exposure to ionizing radiation, allergic reactions/kidney injury caused by contrast agents); fetal/maternal outcomes (for pregnant women; including premature labor, pregnancy loss, fetal morbidity, fetal mortality, maternal morbidity, maternal mortality); harms of test-directed treatment
Test-related harms | Modifiers of adverse events | Limited information was available for key adverse events of interest. Reporting in existing studies was inconsistent and potentially selective. Outcome ascertainment was not standardized.

CT = computed tomography; MRI = magnetic resonance imaging; ROC = receiver operating characteristic curve; US = ultrasound

## Future Research Needs

### Studies of Diagnostic Test Performance

- Cohort studies of test performance would provide useful information particularly for diagnostic tests that have not been studied adequately (e.g., MRI in all relevant patient populations), and to compare the performance of tests for which comparative information is limited (e.g., direct comparisons of CT vs. US; comparisons between CT with contrast administered via alternative routes).
- Such diagnostic cohort studies (and comparative studies in particular) are also needed to evaluate the test performance of combinations of tests and testing strategies by estimating conditional test performance and by developing and validating (internally and in independent datasets) multivariable diagnostic tools. For example, they could examine the use of US as a triage test for CT or MRI, or the use of multivariable diagnostic scores to select patients who can be monitored without immediate imaging or treatment (e.g., low risk patients who can be managed with wait-and-see strategies), those who need imaging, and those who need the initiation of treatment without imaging. They can also provide information to determine how patient- and test-related factors affect performance (i.e., to examine whether test performance depends on easily identifiable patient characteristics).
- Research on the natural history of acute appendicitis, specifically on whether (and how often) cases of appendicitis can resolve on their own and the rate of recurrence among such cases is needed. Studies of natural history (e.g., among patients deemed to be appropriate candidates for medical management or wait-and-see strategies) are necessary for evaluating the impact of tests in decision and simulation modeling studies (see below) and also to inform the design of studies of alternative test-and-treatment strategies (including studies of the sequencing of multiple tests and the timing of examinations). Of note, the test performance of diagnostic tests may vary during different time-points in the development of acute appendicitis (e.g., laboratory tests may be highly sensitive for cases associated with more severe inflammation).
- Paired test study designs, in which all index tests are applied to all enrolled patients (so that each patient has results from every test of interest), are generally more efficient than parallel arm designs and should be considered when planning future studies.195
- Cohort studies assessing the performance of tests that have been evaluated extensively (e.g., CT and US) are most needed for specific patient populations (e.g., pregnant women, young children, and the elderly); for other tests (e.g., MRI) further research is needed in all patient populations. Comparative studies are needed for all tests and all populations. Ideally, future studies of test performance will be large (powered to achieve adequate precision), prospectively designed, multicenter investigations enrolling patients representative of those seen in clinical practice. Studies should prespecify the criteria for a positive test, use standardized diagnostic criteria for the diagnosis of appendicitis and use followup for an adequate period of time (1–2 weeks) for patients who do not undergo surgery, and have as complete a followup as possible. Studies that evaluate two or more index tests should provide a detailed description of the role of testing they are evaluating (triage, add-on, replacement) and report data in enough detail to allow statistical analyses appropriate for that evaluation.57
- Multivariable diagnostic scores provide an appealing way to combine information from multiple clinical symptoms and signs, laboratory tests, and (possibly) US. Multivariable scores may be particularly useful in identifying the subgroup of patients who are at low risk for appendicitis and who may be candidates for wait-and-see strategies or less aggressive imaging strategies. Cohort studies for the development and validation of such scores should use state-of-the science methods for model development and internal and external validation.
- Future research needs to be better reported and studies should adhere to established reporting guidelines (e.g., Standards for the Reporting of Diagnostic accuracy studies; www.stard-statement.org/).

### Studies of Patient-Relevant Outcomes and Resource Utilization

- Cohort studies of diagnostic test strategies can also be used to study the impact of tests on patient-relevant and resource utilization outcomes. For tests with well-understood performance characteristics such studies may use randomized designs. For example randomized trials may be used to identify the preferred route of administration of contrast for CT scanning or to compare strategies of US triage followed by CT versus CT for all patients. In many cases, however, randomized comparisons of alternative test strategies are unlikely to be fruitful because existing studies indicate that many of the competing tests have sensitivities and specificities that are fairly similar and close to 1. Under these conditions RCTs comparing alternative test strategies would need to enroll very large numbers of participants to allow reliable comparisons. If randomized studies are deemed necessary, consideration should be given to paired randomized designs, because they are more efficient than parallel arm trials.
- Large-scale observational prospective studies could be used to evaluate the effectiveness of alternative test strategies with respect to short and long-term patient-relevant outcomes and to explore factors that may modify the effect of tests on these outcomes. Such studies would need to collect detailed information on baseline factors that may be associated with the choice of test strategy and the outcomes of interest (e.g., duration of pain, signs, symptoms and laboratory test results before imaging, patient characteristics, etc.), in order to attempt to address confounding bias. Comparisons across methods should be performed only among patients that would be candidates for assessment with all methods being compared.
- Decision and simulation modeling can be used to determine whether randomized or non-randomized cohort studies assessing patient-relevant outcomes and resource utilization are necessary and to guide their design. Models can also be used to synthesize evidence on test performance, impact of tests on clinical decisions, treatment effectiveness, resource utilization (and when relevant, economic costs), and patient preferences to guide clinical decisionmaking. We think that the results of the current review provide a solid basis for conducting such modeling studies.

### Studies of Test-Related Adverse Events

- Future studies should report complete information on test-related adverse events, using pre-specified criteria and careful ascertainment methods. Research is particularly needed among special populations (e.g., young children, pregnant women, the elderly) and tests that have been less commonly examined (e.g., MRI with gadolinium).
- Mathematical modeling studies can be used to combine data on the effective radiation dose received during alternative CT-based approaches (e.g., abdominopelvic vs. focused CT; low-dose vs. standard-dose CT, etc.) with external information on long-term radiation effects. Such studies appear to represent the most feasible approach to investigate the impact of testing on long-term cancer risk. 196

## Conclusions

The literature on the test performance of clinical symptoms and signs, laboratory and imaging tests, and multivariable diagnostic scores for the diagnosis of acute appendicitis is large, but consists almost exclusively of studies at moderate risk of bias (primarily due to differential and incomplete verification). The few studies that assess multiple tests are typically not designed with the goal of providing comparative information. Thus, the available evidence supports fairly strong conclusions about the performance of individual tests, but is largely insufficient to support conclusions about comparative effectiveness, especially with respect to clinical outcomes. Clinical symptoms and signs and laboratory tests have relatively limited test performance when used in isolation. Their combination in multivariable scores is promising, but the best-studied scores had been developed before the widespread use of imaging modalities and more recently developed scores have not yet been studied adequately. All three major imaging modalities have adequate test performance. Evidence on CT is mature for most patient populations of interest. In contrast, MRI has been investigated by fewer studies, many of which focus on its use for pregnant women. US produces non-diagnostic scans more often than CT or MRI, and, when a diagnosis is possible, its performance appears to be somewhat worse than CT and MRI. Beyond test performance, information on patient-relevant outcomes and resource utilization is very limited. Information on test-related harms (e.g., adverse events due to radiation) is provided only by a minority of studies and is poorly reported. More research, much of which could be accomplished through non-randomized studies, is needed to establish the performance of understudied patient populations (very young children, women of reproductive age, the elderly) and modalities (e.g., MRI, multivariable scores), compare competing tests, identify factors that affect performance, and to evaluate the impact of testing strategies on patient-relevant outcomes, resource utilization, and harms. Perhaps most importantly, given the large volume of accumulated evidence on the test performance of various tests, decision and simulation modeling (e.g., decision analysis, simulation modeling of the impact of radiation on long term outcomes) should be used to guide decisionmaking and to inform the design of future studies.