# Risk of Bias Assessment for Studies of Test Performance

Table F1 Risk of bias assessment for studies of test performance

Variable | Definitions
Extractor 1 | Extractor initials
study_author | First author in the publication
study_year | Year of publication
study_pmid | PMID of the publication If single publication reports multiple studies (eg. Retrospective and prospective cohorts with complete information), complete separate risk of bias row for each, labeled pmid_a, pmid_b …
Was a consecutive or random sample of patients enrolled? | Do the authors state that (1) patients were enrolled consecutively? OR (2) Discuss a random sampling scheme for selecting patients for inclusion?
Was a case-control design avoided? | Did the study enroll preferentially affected and unaffected individuals? In most cases this should be “YES”, because of our selection criteria. Occasionally we should expect some “UNCLEAR”
Did the study avoid inappropriate exclusions? | Where more than 10% of enrolled patients excluded for any reason other than unavailability of index test results? YES: <=10% of enrolled patients were excluded for reasons other than the unavailability of index test results YES: >10% of enrolled patients were excluded for reasons other than the unavailability of index test results UNCLEAR: we cannot distinguish between the above two categories (includes cases where data on the % excluded are not reported, or cases where the reasons for exclusion are not reported and the total proportion of excluded patients is >10%. If the total % excluded is <10% - even if reasons are not reported – the study gets a “YES”).
Were the index test results interpreted without knowledge of the results of the reference standard? | Where index test assessors blinded to the reference standard results? YES: blinding is explicitly mentioned, or the authors clearly describe a process by which index test results were “called” before reference standard results were available NO: explicitly states or can confidently infer that no blinding of index test assessors was in place UNCLEAR: not reported or not enough information to be certain
If a threshold was used, was it prespecified? | Was the criterion for positive index test results defined a priori? E.g. is it stated that it was determined in the study protocol? Is it stated that it was determined based on the literature? YES: a priori determined (protocol, literature-based, prior studies) NO: clearly determined using data from the same study (e.g., determined via ROC analysis) UNCLEAR: not reported or not enough information to be certain
Is the reference standard likely to correctly classify the target condition? | Was the reference standard pathology OR followup of 14 days or more for 90% of the analyzed population? YES: >=90% or more of analyzed patients had pathology OR 14-day (or longer) followup NO: <90% of patients had pathology OR 14-day (or longer) followup UNCLEAR: not reported or not enough information to be certain
Were the reference standard results interpreted without knowledge of the results of the index test? | Where reference standard test assessors blinded to the index test results? YES: blinding is explicitly mentioned, or the authors clearly describe a process by which reference standard test results were “called” with no knowledge of index test results NO: explicitly states or can confidently infer that no blinding of reference standard test assessors was in place UNCLEAR: not reported or not enough information to be certain
Was there an appropriate interval between index tests and reference standard? | If pathology was used on all patients: enter NOT APPLICABLE If followup was used as the reference standard at least for sum patients, was is >14 days? YES: followup was available for 14-days or more on >=90% of patients NO: followup was less than 14-days for >10% of patients UNCLEAR: not reported or not enough information to be certain Note: this variable will be correlated strongly with the “appropriateness of ref. standard” question.
Did all patients receive a reference standard? | Was [underlined: any acceptable] reference standard test used for >=90% of patients? YES: >= 90% of patients used an acceptable reference standard (pathology OR followup of any duration) NO: <90% of patients used an acceptable reference standard UNCLEAR: not reported or not enough information to be certain
Did all patients receive the same reference standard? | Was [underlined: the same reference] standard test used for >=90% of patients? YES: >= 90% had pathology as the reference standard YES: >= 90% had followup of any duration as the reference standard NO: <90% of patients used the same reference standard (all other cases where the proportion is reported and is <90% for each of the reference standards used) UNCLEAR: not reported or not enough information to be certain
Were all patients included in the analysis? | Was the percentage of patients included in the analysis >=90% of the patients enrolled in the study? YES: >= 90% of patients enrolled were analyzed (i.e., in 2×2 table) NO: <90% of patients enrolled were analyzed (i.e., in 2×2 table) UNCLEAR: not reported or not enough information to be certain