# Classifiers and Computer-Aided Diagnosis

Studies that met the review inclusion criteria and reported information on the test performance of classifiers and methods for computer-aided diagnosis are listed in Table E1.

Table E1 Studies on test performance of classifiers and methods for computer-aided diagnosis

Author | Year | Journal | Title
I. D. Adams | 1986 | Br Med J (Clin Res Ed) | Computer aided diagnosis of acute abdominal pain: a multicentre study
T. I. Anatol and Y. Holder | 1995 | West Indian Med J | A scoring system for use in the diagnosis of acute abdominal pain in childhood
T. I. Anatol and Y. Holder | 1995 | J R Coll Surg Edinb | A multivariate analysis of childhood abdominal pain in Trinidad
R. H. Birkhahn | 2006 | Am J Surg | Classifying patients suspected of appendicitis with regard to likelihood
M. Blazadonakis | 1996 | Artif Intell Med | Deep assessment of machine learning techniques using patient treatment in acute abdominal pain in children
I. D. Burton | 1987 | Aust N Z J Surg | Acute appendicitis in childhood: a feasibility study of computer-assisted diagnosis
P. C. Clifford | 1986 | Ann R Coll Surg Engl | The acute abdomen: management with microcomputer aid
N. J. Crichton | 1987 | Stat Med | Some points on the use of ‘independent Bayes’ to diagnose acute abdominal pain
F. T. De Dombal | 1973 | Proc R Soc Lond B Biol Sci | Surgical diagnosis assisted by a computer
F. T. de Dombal | 1979 | Scand J Gastroenterol Suppl | Acute abdominal pain--an O.M.G.E. survey
F. T. de Dombal | 1991 | BMJ | Can computer aided teaching packages improve clinical care in patients with acute abdominal pain?
F. T. de Dombal and J. C. Horrocks | 1978 | Methods Inf Med | Use of receiver operating characteristic (ROC) curves to evaluate computer confidence threshold and clinical performance in the diagnosis appendicitis
F. T. De Dombal | 1974 | Br Med J | Human and computer-aided diagnosis of abdominal pain: further report with emphasis on performance of clinicians
F. T. de Dombal | 1972 | Br Med J | Computer-aided diagnosis of acute abdominal pain
F. T. deDombal | 1975 | J R Coll Physicians Lond | Computer-aided diagnosis and decision-making in the acute abdomen
J. A. Dickson | 1985 | Lancet | Computer-assisted diagnosis of acute abdominal pain in childhood
J. A. Dickson | 1988 | Scand J Gastroenterol Suppl | Acute abdominal pain in children
F. H. Edwards and R. S. Davies | 1984 | Surg Gynecol Obstet | Use of a Bayesian algorithm in the computer-assisted diagnosis of appendicitis
N. H. Edwards | 1986 | Comput Methods Programs Biomed | The accuracy of a Bayesian computer program for diagnosis and teaching in acute abdominal pain of childhood
M. Eskelinen | 1994 | Int J Biomed Comput | Acute appendicitis in patients over the age of 65 years; comparison of clinical and computer based decision making
M. Eskelinen | 1994 | Scand J Gastroenterol | Sex-specific diagnostic scores for acute appendicitis
K. J. Farion | 2008 | Int J Med Inform | Prospective evaluation of the MET-AP system providing triage plans for acute pediatric abdominal pain
G. Fenyo | 1987 | Scand J Gastroenterol Suppl | Computer-aided diagnosis of 233 acute abdominal cases at Nacka Hospital Sweden
J. M. Gronroos | 1994 | Clin Chem | Phospholipase A2, C-reactive protein, and white blood cell count in the diagnosis of acute appendicitis
A. A. Gunn | 1976 | J R Coll Surg Edinb | The diagnosis of acute abdominal pain with computer analysis
A. A. Gunn | 1991 | Baillieres Clin Gastroenterol | The acute abdomen: the role of computer-assisted diagnosis
J. C. Horrocks | 1976 | Can J Surg | Computer-aided diagnosis of gastroenterologic diseases in Sherbrooke: preliminary report
J. C. Horrocks | 1972 | Br Med J | Computer-aided diagnosis: description of an adaptable system, and operational experience with 2,034 cases
J. K. Ikonen | 1983 | Ann Chir Gynaecol | Presentation and diagnosis of acute abdominal pain in Finland: a computer aided study
O. J. Kirkeby and C. Riso | 1987 | Scand J Gastroenterol Suppl | Use of a computer system for diagnosing acute abdominal pain in a small hospital
M. W. Kurzynski | 1987 | Comput Biol Med | Diagnosis of acute abdominal pain using a three-stage classifier
P. C. Lawrence | 1987 | Ann R Coll Surg Engl | Acute abdominal pain: computer aided diagnosis by non-medically qualified staff
D. J. Leaper | 1972 | Br Med J | Computer-assisted diagnosis of abdominal pain using "estimates" provided by clinicians
Y. H. Lee | 2013 | Artif Intell Med | A preclustering-based ensemble learning technique for acute appendicitis diagnoses
K. C. Lin | 2007 | Acta Paediatr Taiwan | Discriminant analysis of serum inflammatory biomarkers which differentiate pediatric appendicitis from other acute abdominal diseases
W. A. McAdam | 1990 | Ann R Coll Surg Engl | Twelve years’ experience of computer-aided diagnosis in a district general hospital
W. Michalowski | 2001 | Paediatr Child Health | Triage of the child with abdominal pain: A clinical algorithm for emergency patient management
C. Ohmann | 1996 | Artif Intell Med | Evaluation of automatic knowledge acquisition techniques in the diagnosis of acute abdominal pain. Acute Abdominal Pain Study Group
E. Pesonen | 1997 | Stud Health Technol Inform | Is neural network better than statistical methods in diagnosis of acute appendicitis?
E. Pesonen | 1996 | Int J Biomed Comput | Comparison of different neural network algorithms in the diagnosis of acute appendicitis
B. Puppe | 1995 | Methods Inf Med | Evaluating four diagnostic methods with acute abdominal pain cases
S. L. Reynolds and D. M. Jaffe | 1992 | Pediatr Emerg Care | Diagnosing abdominal pain in a pediatric emergency department
S. Sakai | 2007 | J Med Syst | Comparison of the levels of accuracy of an artificial neural network model and a logistic regression model for the diagnosis of acute appendicitis
D. R. Shah | 1999 | MD Comput | The utilization of a neural network system in the diagnosis of appendicitis
C. S. Son | 2012 | BMC Med Inform Decis Mak | A hybrid decision support model to discover informative knowledge in diagnosing acute appendicitis
G. C. Sutton | 1989 | Lancet | How accurate is computer-aided diagnosis?
J. Wellwood | 1992 | Ann R Coll Surg Engl | How does computer-aided diagnosis improve the management of acute abdominal pain?
J. M. Wellwood and D. J. Spiegelhalter | 1989 | Br J Hosp Med | Computers and the diagnosis of acute abdominal pain
P. D. Wilson | 1975 | Br Med J | Simplified computer-aided diagnosis of acute abdominal pain
O. Yoldas | 2012 | Am J Emerg Med | Artificial neural networks in the diagnosis of acute appendicitis
M. Zorman | 2001 | Stud Health Technol Inform | Comparison of three databases with a decision tree approach in the medical field of acute appendicitis