# Sensitivity Analyses for Studies of Imaging Tests

Table D1 Sensitivity analysis assuming indeterminate results are false positives

Test | Population | N studies [affected/unaffected] | Sensitivity | Specificity | LR+ | LR−
CT | Adults | 27 [3396/6517] | 0.96 (0.93 to 0.98) | 0.87 (0.79 to 0.93) | 7.54 (4.60 to 13.27) | 0.05 (0.02 to 0.09)
CT | Children | 12 [1517/1634] | 0.94 (0.90 to 0.97) | 0.76 (0.51 to 0.91) | 3.96 (1.91 to 9.98) | 0.08 (0.04 to 0.15)
CT | Elderly | 1 [17/27] | 1.00 | 1.00 | . | 0.00
CT | Women of reproductive age | 3 [180/277] | 0.98 (0.84 to 1.00) | 0.92 (0.25 to 0.94) | 12.00 (1.12 to 15.46) | 0.02 (0.00 to 0.64)
CT | Pregnant women | 3 [22/80] | 1.00 (0.92 to 1.00) | 0.98 (0.89 to 1.00) | 34.50 (9.00 to 60.00) | 0.00 (0.00 to 0.08)
CT | Mixed | 31 [4230/6788] | 0.95 (0.93 to 0.97) | 0.86 (0.79 to 0.91) | 6.91 (4.52 to 10.90) | 0.06 (0.04 to 0.09)
MRI | Adults | 4 [249/256] | 0.94 (0.85 to 1.00) | 0.82 (0.60 to 0.97) | 5.25 (2.50 to 33.00) | 0.07 (0.00 to 0.16)
MRI | Children | 3 [133/261] | 0.93 (0.89 to 1.00) | 0.98 (0.89 to 0.99) | 47.60 (9.20 to 72.89) | 0.07 (0.00 to 0.11)
MRI | Pregnant women | 8 [71/558] | 0.95 (0.86 to 1.00) | 0.91 (0.70 to 0.98) | 10.22 (3.09 to 46.50) | 0.05 (0.01 to 0.17)
MRI | Mixed | 3 [167/136] | 0.92 (0.86 to 0.98) | 0.77 (0.48 to 1.00) | 3.06 (1.78 to 4.35) | 0.14 (0.02 to 0.16)
TC99M NUCLEAR | adults | 1 [10/24] | 0.90 | 0.96 | 21.60 | 0.10
TC99M NUCLEAR | Children | 2 [21/60] | 0.80 (0.70 to 0.91) | 0.78 (0.70 to 0.86) | 4.51 (2.30 to 6.73) | 0.27 (0.11 to 0.43)
TC99M NUCLEAR | Women of reproductive age | 2 [16/45] | 0.66 (0.43 to 0.89) | 0.87 (0.74 to 1.00) | 1.63 (1.63 to 1.63) | 0.44 (0.11 to 0.78)
TC99M NUCLEAR | Mixed | 5 [144/282] | 0.92 (0.72 to 0.99) | 0.92 (0.63 to 0.99) | 11.54 (2.18 to 119.60) | 0.09 (0.01 to 0.38)
US | adults | 10 [633/1188] | 0.73 (0.56 to 0.86) | 0.31 (0.09 to 0.64) | 1.05 (0.72 to 2.07) | 0.89 (0.33 to 3.43)
US | Children | 31 [2364/6559] | 0.84 (0.75 to 0.91) | 0.70 (0.52 to 0.83) | 2.80 (1.73 to 5.11) | 0.23 (0.13 to 0.39)
US | Women of reproductive age | 1 [27/84] | 0.93 | 0.95 | 19.44 | 0.08
US | Pregnant women | 11 [156/421] | 0.48 (0.32 to 0.65) | 0.12 (0.02 to 0.42) | 0.55 (0.34 to 0.97) | 4.43 (1.04 to 26.01)
US | Mixed | 41 [3889/5445] | 0.86 (0.80 to 0.91) | 0.61 (0.41 to 0.78) | 2.19 (1.41 to 3.93) | 0.23 (0.14 to 0.42)

Table D2 Sensitivity analysis assuming indeterminate results are false negatives

Test | Population | N studies [affected/unaffected] | Sensitivity | Specificity | LR+ | LR−
CT | Adults | 27 [3636/6277] | 0.94 (0.89 to 0.97) | 0.89 (0.81 to 0.94) | 8.81 (4.94 to 16.94) | 0.07 (0.04 to 0.12)
CT | Children | 12 [1600/1551] | 0.90 (0.86 to 0.95) | 0.80 (0.53 to 0.93) | 4.44 (1.96 to 12.42) | 0.12 (0.07 to 0.18)
CT | Elderly | 1 [17/27] | 1.00 | 1.00 | . | 0.00
CT | Women of reproductive age | 3 [180/277] | 0.98 (0.84 to 1.00) | 0.92 (0.25 to 0.94) | 12.00 (1.12 to 15.46) | 0.02 (0.00 to 0.64)
CT | Pregnant women | 3 [22/80] | 1.00 (0.92 to 1.00) | 0.98 (0.89 to 1.00) | 34.50 (9.00 to 60.00) | 0.00 (0.00 to 0.08)
CT | Mixed | 31 [4322/6696] | 0.94 (0.91 to 0.96) | 0.88 (0.82 to 0.92) | 7.77 (5.15 to 12.08) | 0.07 (0.04 to 0.11)
MRI | Adults | 4 [249/256] | 0.94 (0.85 to 1.00) | 0.82 (0.60 to 0.97) | 5.25 (2.50 to 33.00) | 0.07 (0.00 to 0.16)
MRI | Children | 3 [133/261] | 0.93 (0.89 to 1.00) | 0.98 (0.89 to 0.99) | 47.60 (9.20 to 72.89) | 0.07 (0.00 to 0.11)
MRI | Pregnant women | 8 [71/558] | 0.95 (0.86 to 1.00) | 0.91 (0.70 to 0.98) | 10.22 (3.09 to 46.50) | 0.05 (0.01 to 0.17)
MRI | Mixed | 3 [167/136] | 0.92 (0.86 to 0.98) | 0.77 (0.48 to 1.00) | 3.06 (1.78 to 4.35) | 0.14 (0.02 to 0.16)
TC99M NUCLEAR | adults | 1 [10/24] | 0.90 | 0.96 | 21.60 | 0.10
TC99M NUCLEAR | Children | 2 [21/60] | 0.80 (0.70 to 0.91) | 0.78 (0.70 to 0.86) | 4.51 (2.30 to 6.73) | 0.27 (0.11 to 0.43)
TC99M NUCLEAR | Women of reproductive age | 2 [16/45] | 0.66 (0.43 to 0.89) | 0.87 (0.74 to 1.00) | 1.63 (1.63 to 1.63) | 0.44 (0.11 to 0.78)
TC99M NUCLEAR | Mixed | 5 [144/282] | 0.92 (0.72 to 0.99) | 0.92 (0.63 to 0.99) | 11.54 (2.18 to 119.60) | 0.09 (0.01 to 0.38)
US | adults | 10 [662/1159] | 0.71 (0.53 to 0.85) | 0.34 (0.09 to 0.69) | 1.07 (0.70 to 2.27) | 0.87 (0.34 to 3.31)
US | Children | 31 [2856/6067] | 0.74 (0.61 to 0.85) | 0.82 (0.66 to 0.91) | 4.03 (2.12 to 8.63) | 0.32 (0.19 to 0.50)
US | Women of reproductive age | 1 [27/84] | 0.93 | 0.95 | 19.44 | 0.08
US | Pregnant women | 11 [184/393] | 0.44 (0.27 to 0.65) | 0.17 (0.03 to 0.55) | 0.55 (0.31 to 1.12) | 3.18 (0.88 to 17.76)
US | Mixed | 41 [4524/4810] | 0.79 (0.71 to 0.85) | 0.75 (0.55 to 0.88) | 3.12 (1.74 to 6.43) | 0.28 (0.19 to 0.43)