# Studies Assessing the Test Performance of Clinical Signs and Symptoms, Laboratory and Imaging Tests, and Multivariable Diagnostic Scores

Table C1 Test performance of clinical signs and symptoms

Table C2 Risk of bias, studies of the test performance of clinical signs and symptoms, laboratory tests, and imaging tests

Table C3 Test performance of multivariable diagnostic scores

Table C4 Risk of bias, studies of multivariable diagnostic scores

Table C5 RCT study design

Table C6 RCT test performance outcomes

Table C7 RCT risk of bias

Table C8 RCT other outcomes

Table C9 RCT harms

Table C10 NRCS study design

Table C11 NRCS test performance outcomes

Table C12 NRCS risk of bias

Table C13 NRCS other outcomes

Table C14 NRCS harms