# List of Included and Excluded Studies

## B-1. Included Studies

1 Abbas MH, Choudhry MN, Hamza N, Ali B, Amin AA, Ammori BJ. Admission Levels of Serum Amyloid A and Procalcitonin are More Predictive of the Diagnosis of Acute Appendicitis Compared With C-reactive Protein. [pmid: 24910938].
2 Abdeldaim Y, Mahmood S, Mc Avinchey D. The Alvarado score as a tool for diagnosis of acute appendicitis. Irish medical journal. Jan. 2007;100(1):342. [pmid: 17380927].
3 Abo A, Shannon M, Taylor G, et al. The influence of body mass index on the accuracy of ultrasound and computed tomography in diagnosing appendicitis in children. Pediatric emergency care. Aug. 2011;27(8):731-6. [pmid: 21811194].
4 Abou Merhi B, Khalil M, Daoud N. Comparison of Alvarado score evaluation and clinical judgment in acute appendicitis. [pmid: 24783903].
5 Abu-Yousef MM, Bleicher JJ, Maher JW, et al. High-resolution sonography of acute appendicitis. AJR American journal of roentgenology. Jul. 1987;149(1):53-8. [pmid: 3296711].
6 Acar A, Keskek M, Isman FK, et al. Serum chitotriosidase activity in acute appendicitis: preliminary results. The American journal of emergency medicine. Jun. 2012;30(5):775-7. [pmid: 21641156].
7 Acosta R, Crain EF, Goldman HS. CT can reduce hospitalization for observation in children with suspected appendicitis. Pediatric radiology. May. 2005;35(5):495-500. [pmid: 15633057].
8 Adams DH, Fine C, Brooks DC. High-resolution real-time ultrasonography. A new tool in the diagnosis of acute appendicitis. American journal of surgery. Jan. 1988;155(1):93-7. [pmid: 3277469].
9 Adams ID, Chan M, Clifford PC, et al. Computer aided diagnosis of acute abdominal pain: a multicentre study. British medical journal (Clinical research ed). Sep. 27. 1986;293(6550):800-4. [pmid: 3094664].
10 Adesunkanmi AR. Acute appendicitis: a prospective study of 54 cases. West African journal of medicine. Oct–Dec. 1993;12(4):197-200. [pmid: 8199059].
11 Agrawal CS, Adhikari S, Kumar M. Role of serum C-reactive protein and leukocyte count in the diagnosis of acute appendicitis in Nepalese population. Nepal Medical College journal : NMCJ. Mar. 2008;10(1):11-5. [pmid: 18700623].
12 Ahmad TA, Shelbaya E, Razek SA, et al. Experience of laparoscopic management in 100 patients with acute abdomen. Hepato-gastroenterology. May–Jun. 2001;48(39):733-6. [pmid: 11462915].
13 Ahmed I, Boulter MK, Lobo DN. The SLAPPA (significance of lower abdominal/periumbilical piercing as a predictor of acute appendicitis) audit. Sexual health. Sep. 2006;3(3):195-6. [pmid: 17044228].
14 Ahn SH, Mayo-Smith WW, Murphy BL, et al. Acute nontraumatic abdominal pain in adult patients: abdominal radiography compared with CT evaluation. Radiology. Oct. 2002;225(1):159-64. [pmid: 12355000].
15 Akbar F, Yousuf M, Morgan RJ, et al. Changing management of suspected appendicitis in the laparoscopic era. Annals of the Royal College of Surgeons of England. Jan. 2010;92(1):65-8. [pmid: 20056066].
16 Akhtar W, Ali S, Arshad M, et al. Focused abdominal CT scan for acute appendicitis in children: can it help in need?. JPMA The Journal of the Pakistan Medical Association. May. 2011;61(5):474-6. [pmid: 22204183].
17 Al Hilli Z, Prichard RS, Roche-Nagle G, et al. Emergency appendicectomy in the era of laparoscopy: a one-year audit. Irish journal of medical science. Dec. 2009;178(4):473-7. [pmid: 19350346].
18 Al Qahtani HH, Muhammad AA. Alvarado score as an admission criterion for suspected appendicitis in adults. Saudi journal of gastroenterology : official journal of the Saudi Gastroenterology Association. May. 2004;10(2):86-91. [pmid: 19861831].
19 Al-Ajerami Y. Sensitivity and specificity of ultrasound in the diagnosis of acute appendicitis. Eastern Mediterranean health journal. La revue de sante de la Mediterranee orientale = al-Majallah al-sihhiyah li-sharq al-mutawassit. Jan. 2012;18(1):66-9. [pmid: 22360013].
20 Alam B, Malik Z, Ibrar M, Tariq Abdullah M, Waqar SH, Zahid MA. High total leukocyte count in the diagnosis of acute appendicitis. Journal of Medical Sciences (Peshawar). 2014;22(2):84-8. PMID:.
21 Albano MC, Ross GW, Ditchek JJ, et al. Resident interpretation of emergency CT scans in the evaluation of acute appendicitis. Academic radiology. Sep. 2001;8(9):915-8. [pmid: 11724048].
22 Albu E, Miller BM, Choi Y, et al. Diagnostic value of C-reactive protein in acute appendicitis. Diseases of the colon and rectum. Jan. 1994;37(1):49-51. [pmid: 8287747].
23 Al-Gaithy ZK. Clinical value of total white blood cells and neutrophil counts in patients with suspected appendicitis: retrospective study. World journal of emergency surgery : WJES. 2012;7(1):32. [pmid: 23031349].
24 Al-Hashemy AM, Seleem MI. Appraisal of the modified Alvarado Score for acute appendicits in adults. Saudi medical journal. Sep. 2004;25(9):1229-31. [pmid: 15448772].
25 Alkhuzaie J, Al Mehza J, Bucheery A, Khuder H, Eid R, Ali NA. Could preoperative ultrasound examination improve the final outcome of appendectomies?. Bahrain Medical Bulletin. 2013;35(4). PMID:.
26 Allemann F, Cassina P, Rothlin M, et al. Ultrasound scans done by surgeons for patients with acute abdominal pain: a prospective study. The European journal of surgery. Acta chirurgica. Oct. 1999;165(10):966-70. [pmid: 10574106].
27 Allister L, Bachur R, Glickman J, et al. Serum markers in acute appendicitis. The Journal of surgical research. Jun. 1. 2011;168(1):70-5. [pmid: 20097375].
28 Al-Mulhim AA. Acute appendicitis in pregnancy. A review of 52 cases. International surgery. Jul–Sep. 1996;81(3):295-7. [pmid: 9028994].
29 Alnjadat I, Abdallah B. Alvarado versus RIPASA score in diagnosing acute appendicitis. Rawal Medical Journal. 2013;38(2):147-51. PMID:.
30 Alobaidi M, Shirkhoda A. Value of bone window settings on CT for revealing appendicoliths in patients with appendicitis. AJR American journal of roentgenology. Jan. 2003;180(1):201-5. [pmid: 12490503].
31 al-Saigh AH. C-reactive protein in the differential diagnosis of the acute abdomen, especially acute appendicitis. Journal of the Royal College of Surgeons of Edinburgh. Aug. 1992;37(4):238-40. [pmid: 1383518].
32 Alshehri MY, Ibrahim A, Abuaisha N, et al. Value of rebound tenderness in acute appendicitis. East African medical journal. Aug. 1995;72(8):504-6. [pmid: 7588144].
33 Althoubaity FK. Suspected acute appendicitis in female patients. Trends in diagnosis in emergency department in a University Hospital in Western region of Saudi Arabia. Saudi medical journal. Nov. 2006;27(11):1667-73. [pmid: 17106538].
34 Alvarado A. A practical score for the early diagnosis of acute appendicitis. Annals of emergency medicine. May. 1986;15(5):557-64. [pmid: 3963537].
35 Amalesh T, Shankar M, Shankar R. CRP in acute appendicitis--is it a necessary investigation?. International journal of surgery (London, England). 2004;2(2):88-9. [pmid: 17462226].
36 Amini M, Alizade SH, Cyrus A, Khodam S, Rafeeie M, Hasanpur A, Solhi H. Does pethidine hydrochloride analgesia in patients with acute appendicitis alter the diagnostic accuracy of clinical evaluation: A randomized double-blind clinical trial. International Journal of Medical Toxicology and Forensic Medicine [serial on the Internet]. 2012;(2). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/287/CN-00982287/frame.html. Last accessed.
37 Amland PF, Skaane P, Ronningen H, et al. Ultrasonography and parameters of inflammation in acute appendicitis. A comparison with clinical findings. Acta chirurgica Scandinavica. Mar. 1989;155(3):185-9. [pmid: 2662692].
38 Anatol TI, Holder Y. A multivariate analysis of childhood abdominal pain in Trinidad. Journal of the Royal College of Surgeons of Edinburgh. Apr. 1995;40(2):99-103. [pmid: 7776284].
39 Anatol TI, Holder Y. A scoring system for use in the diagnosis of acute abdominal pain in childhood. The West Indian medical journal. Jun. 1995;44(2):67-9. [pmid: 7667974].
40 Andersen B, Nielsen TF. Appendicitis in pregnancy: diagnosis, management and complications. Acta obstetricia et gynecologica Scandinavica. Oct. 1999;78(9):758-62. [pmid: 10535336].
41 Andersen M, Lilja T, Lundell L, et al. Clinical and laboratory findings in patients subjected to laparotomy for suspected acute appendicitis. Acta chirurgica Scandinavica. 1980;146(1):55-63. [pmid: 7376784].
42 Anderson SW, Soto JA, Lucey BC, et al. Abdominal 64-MDCT for suspected appendicitis: the use of oral and IV contrast material versus IV contrast material only. AJR American journal of roentgenology. Nov. 2009;193(5):1282-8. [pmid: 19843742].
43 Andersson M, Andersson RE. The appendicitis inflammatory response score: a tool for the diagnosis of acute appendicitis that outperforms the Alvarado score. World journal of surgery. Aug. 2008;32(8):1843-9. [pmid: 18553045].
44 Andersson RE, Hugander AP, Ghazi SH, et al. Diagnostic value of disease history, clinical presentation, and inflammatory parameters of appendicitis. World journal of surgery. Feb. 1999;23(2):133-40. [pmid: 9880421].
45 Andersson RE, Hugander AP, Ghazi SH, et al. Why does the clinical diagnosis fail in suspected appendicitis?. The European journal of surgery. Acta chirurgica. Oct. 2000;166(10):796-802. [pmid: 11071167].
46 Ang A, Chong NK, Daneman A. Pediatric appendicitis in “real-time”: the value of sonography in diagnosis and treatment. Pediatric emergency care. Oct. 2001;17(5):334-40. [pmid: 11673709].
47 Anielski R, Kusnierz-Cabala B, Szafraniec K. An evaluation of the utility of additional tests in the preoperative diagnostics of acute appendicitis. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Nov. 2010;395(8):1061-8. [pmid: 19924436].
48 Anteby SO, Schenker JG, Polishuk WZ. The value of laparoscopy in acute pelvic pain. Annals of surgery. Apr. 1975;181(4):484-6. [pmid: 124158].
49 Antevil J, Rivera L, Langenberg B, et al. The influence of age and gender on the utility of computed tomography to diagnose acute appendicitis. The American surgeon. Oct. 2004;70(10):850-3. [pmid: 15529835].
50 Antevil JL, Rivera L, Langenberg BJ, et al. Computed tomography-based clinical diagnostic pathway for acute appendicitis: prospective validation. Journal of the American College of Surgeons. Dec. 2006;203(6):849-56. [pmid: 17116553].
51 Applegate KE, Sivit CJ, Salvator AE, et al. Effect of cross-sectional imaging on negative appendectomy and perforation rates in children. Radiology. Jul. 2001;220(1):103-7. [pmid: 11425980].
52 Arnbjornsson E. Scoring system for computer-aided diagnosis of acute appendicitis. The value of prospective versus retrospective studies. Annales chirurgiae et gynaecologiae. 1985;74(4):159-66. [pmid: 3909908].
53 Arooj S, Mansoor M, Amir I. Ultrasound for the diagnosis of acute appendicitis: A hospital based study. Pakistan Journal of Medical and Health Sciences. 2013;7(4):1177-80. PMID:.
54 Artiko V, Petrovic M, Sobic-Saranovic D, et al. Detection of gastrointestinal and abdominal infections by 99mTc-antigranulocyte antibodies. Hepato-gastroenterology. Jul–Aug. 2009;56(93):1053-8. [pmid: 19760940].
55 Asadi M, Mehrabi Bahar M, Sadeghi R, et al. Value of polyclonal human immunoglobulin tagged with (9)(9)mTc for detecting acute appendicitis in patients with intermediate probability of appendicitis. World journal of surgery. Aug. 2011;35(8):1798-802. [pmid: 21553201].
56 Asfar S, Safar H, Khoursheed M, et al. Would measurement of C-reactive protein reduce the rate of negative exploration for acute appendicitis?. Journal of the Royal College of Surgeons of Edinburgh. Feb. 2000;45(1):21-4. [pmid: 10815376].
57 Ashdown HF, D’Souza N, Karim D, et al. Pain over speed bumps in diagnosis of acute appendicitis: diagnostic accuracy study. BMJ. 2012;345:e8012. [pmid: 23247977].
58 Ashindoitiang JA, Atoyebi AO, Arogundade RA. The value of plain abdominal radiographs in management of abdominal emergencies in Luth. Nigerian quarterly journal of hospital medicine. Jul–Sep. 2008;18(3):170-4. [pmid: 19062484].
59 Ashraf K, Ashraf O, Bari V, et al. Role of focused appendiceal computed tomography in clinically equivocal acute appendicitis. JPMA The Journal of the Pakistan Medical Association. May. 2006;56(5):200-3. [pmid: 16767943].
60 Assefa G, Meseret S, Nigussie Y. The role of ultrasound in diagnosing acute appendicictis. Ethiopian medical journal. Jan. 2006;44(1):67-74.
61 Ates M, Sevil S, Bulbul M. Routine use of laparoscopy in patients with clinically doubtful diagnosis of appendicitis. Journal of laparoendoscopic & advanced surgical techniques Part A. Apr. 2008;18(2):189-93. [pmid: 18373441].
62 Avcu S, Cetin FA, Arslan H, et al. The value of diffusion-weighted imaging and apparent diffusion coefficient quantification in the diagnosis of perforated and nonperforated appendicitis. Diagnostic and interventional radiology (Ankara, Turkey). Mar–Apr. 2013;19(2):106-10. [pmid: 23266968].
63 Bachar I, Perry ZH, Dukhno L, Mizrahi S, Kirshtein B. Diagnostic value of laparoscopy, abdominal computed tomography, and ultrasonography in acute appendicitis. [pmid: 24134071].
64 Bachur RG, Dayan PS, Bajaj L, et al. The effect of abdominal pain duration on the accuracy of diagnostic imaging for pediatric appendicitis. Annals of emergency medicine. Nov. 2012;60(5):582-90 e3. [pmid: 22841176].
65 Bachur RG, Hennelly K, Callahan MJ, et al. Advanced radiologic imaging for pediatric appendicitis, 2005–2009: trends and outcomes. The Journal of pediatrics. Jun. 2012;160(6):1034-8. [pmid: 22192815].
66 Bachur RG, Hennelly K, Callahan MJ, et al. Diagnostic imaging and negative appendectomy rates in children: effects of age and gender. Pediatrics. May. 2012;129(5):877-84. [pmid: 22508920].
67 Bagnato VJ. Laparoscopy for the management of appendicitis. Journal of the Mississippi State Medical Association. Jul. 1992;33(7):249-51. [pmid: 1387169].
68 Bainbridge J. The accuracy of ultrasound diagnosis of appendicitis: an audit. Ultrasound. 2005;13(2):126-9. Language: English. Entry Date: 20071019. Revision Date: 20121228. Publication Type: journal article.
69 Baldisserotto M, Marchiori E. Accuracy of noncompressive sonography of children with appendicitis according to the potential positions of the appendix. AJR American journal of roentgenology. Nov. 2000;175(5):1387-92. [pmid: 11044049].
70 Baldisserotto M, Peletti AB. Is colour Doppler sonography a good method to differentiate normal and abnormal appendices in children?. Clinical radiology. Apr. 2007;62(4):365-9. [pmid: 17331831].
71 Balthazar EJ, Birnbaum BA, Yee J, et al. Acute appendicitis: CT and US correlation in 100 patients. Radiology. Jan. 1994;190(1):31-5. [pmid: 8259423].
72 Balthazar EJ, Megibow AJ, Siegel SE, et al. Appendicitis: prospective evaluation with high-resolution CT. Radiology. Jul. 1991;180(1):21-4. [pmid: 2052696].
73 Balthazar EJ, Rofsky NM, Zucker R. Appendicitis: the impact of computed tomography imaging on negative appendectomy and perforation rates. The American journal of gastroenterology. May. 1998;93(5):768-71. [pmid: 9625125].
74 Barbee CL, Gilsdorf RB. Diagnostic peritoneal lavage in evaluating acute abdominal pain. Annals of surgery. Jun. 1975;181(6):853-6. [pmid: 1138636].
75 Barloon TJ, Brown BP, Abu-Yousef MM, et al. Sonography of acute appendicitis in pregnancy. Abdominal imaging. Mar–Apr. 1995;20(2):149-51. [pmid: 7787719].
76 Barrat CCJ, Rizk N, Champault GG. Diagnosing pediatric appendicitis: usefulness of oratory markers. [pmid: 20825931].
77 Barrat C, Catheline JM, Rizk N, et al. Does laparoscopy reduce the incidence of unnecessary appendicectomies?. Surgical laparoscopy & endoscopy. Jan. 1999;9(1):27-31. [pmid: 9950123].
78 Barron B, Hanna C, Passalaqua AM, et al. Rapid diagnostic imaging of acute, nonclassic appendicitis by leukoscintigraphy with sulesomab, a technetium 99m-labeled antigranulocyte antibody Fab’ fragment. LeukoScan Appendicitis Clinical Trial Group. Surgery. Mar. 1999;125(3):288-96. [pmid: 10076613].
79 Bates MF, Khander A, Steigman SA, Tracy TF Jr, Luks FI. Use of white blood cell count and negative appendectomy rate. [pmid: 24379236].
80 Bayraktutan U, Oral A, Kantarci M, Demir M, Ogul H, Yalcin A, Kaya I, Salman AB, Yigiter M, Okur A. Diagnostic performance of diffusion-weighted MR imaging in detecting acute appendicitis in children: comparison with conventional MRI and surgical findings. [pmid: 24151201].
81 Bealer JF, Colgin M. S100A8/A9: a potential new diagnostic aid for acute appendicitis. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Mar. 2010;17(3):333-6. [pmid: 20370768].
82 Becker T, Kharbanda A, Bachur R. Atypical clinical features of pediatric appendicitis. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Feb. 2007;14(2):124-9. [pmid: 17192449].
83 Behan RB, Jarwar MK, Kumar P, et al. Diagnostic accuracy of alvarado scoring system in the management of acute appendicitis. Pakistan Journal of Medical and Health Sciences. 2010;4(4). PMID:.
84 Beltran MA, Almonacid J, Vicencio A, et al. Predictive value of white blood cell count and C-reactive protein in children with appendicitis. Journal of pediatric surgery. Jul. 2007;42(7):1208-14. [pmid: 17618882].
85 Bendeck SE, Nino-Murcia M, Berry GJ, et al. Imaging for suspected appendicitis: negative appendectomy and perforation rates. Radiology. Oct. 2002;225(1):131-6. [pmid: 12354996].
86 Berry J Jr, Malt RA. Appendicitis near its centenary. Annals of surgery. Nov. 1984;200(5):567-75. [pmid: 6385879].
87 Bhatt M, Joseph L, Ducharme FM, et al. Prospective validation of the pediatric appendicitis score in a Canadian pediatric emergency department. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Jul. 2009;16(7):591-6. [pmid: 19549016].
88 Bhattacharjee PK, Chowdhury T, Roy D. Prospective evaluation of modified Alvarado score for diagnosis of acute appendicitis. Journal of the Indian Medical Association. May. 2002;100(5):310-1. 4. [pmid: 12418631].
89 Biersack HJ, Overbeck B, Ott G, et al. Tc-99m labeled monoclonal antibodies against granulocytes (BW 250/183) in the detection of appendicitis. Clinical nuclear medicine. May. 1993;18(5):371-6. [pmid: 8508569].
90 Bilbey JH, Gibney RG, Cooperberg PL. Ultrasonography in acute appendicitis. Canadian Association of Radiologists journal. Journal l’Association canadienne des radiologistes. Feb. 1989;40(1):22-4. [pmid: 2647214].
91 Birchard KR, Brown MA, Hyslop WB, et al. MRI of acute abdominal and pelvic pain in pregnant patients. AJR American journal of roentgenology. Feb. 2005;184(2):452-8. [pmid: 15671363].
92 Birchley D. Comment on: diagnostic value of inflammatory markers. Annals of the Royal College of Surgeons of England. Sep. 2009;91(6):538. author reply -9. [pmid: 19723423].
93 Birchley D. Patients with clinical acute appendicitis should have pre-operative full blood count and C-reactive protein assays. Annals of the Royal College of Surgeons of England. Jan. 2006;88(1):27-32. [pmid: 16460636].
94 Birkhahn RH, Briggs M, Datillo PA, et al. Classifying patients suspected of appendicitis with regard to likelihood. American journal of surgery. Apr. 2006;191(4):497-502. [pmid: 16531143].
95 Blalock JB Jr. Improving diagnostic accuracy in appendicitis. Alabama medicine : journal of the Medical Association of the State of Alabama. Oct. 1989;59(4):13-7. [pmid: 2610191].
96 Blazadonakis M, Moustakis V, Charissis G. Deep assessment of machine learning techniques using patient treatment in acute abdominal pain in children. Artificial intelligence in medicine. Nov. 1996;8(6):527-42. [pmid: 8985539].
97 Boehnert MU, Zimmermann H, Exadaktylos AK. O knowledge, where art thou? Evidence and suspected appendicitis. Journal of evaluation in clinical practice. Dec. 2009;15(6):1177-9. [pmid: 20367723].
98 Bolton JP, Craven ER, Croft RJ, et al. An assessment of the value of the white cell count in the management of suspected acute appendicitis. The British journal of surgery. Nov. 1975;62(11):906-8. [pmid: 1191953].
99 Bond GR, Tully SB, Chan LS, et al. Use of the MANTRELS score in childhood appendicitis: a prospective study of 187 children with abdominal pain. Annals of emergency medicine. Sep. 1990;19(9):1014-8.
100 Bondi M, Miller R, Zbar A, et al. Improving the diagnostic accuracy of ultrasonography in suspected acute appendicitis by the combined transabdominal and transvaginal approach. The American surgeon. Jan. 2012;78(1):98-103.
101 Bonello JC, Abrams JS. The significance of a “positive” rectal examination in acute appendicitis. Diseases of the colon and rectum. Mar. 1979;22(2):97-101. [pmid: 428284].
102 Borgstein PJ, Gordijn RV, Eijsbouts QA, et al. Acute appendicitis--a clear-cut case in men, a guessing game in young women. A prospective study on the role of laparoscopy. Surgical endoscopy. Sep. 1997;11(9):923-7. [pmid: 9294274].
103 Bower RJ, Bell MJ, Ternberg JL. Diagnostic value of the white blood count and neutrophil percentage in the evaluation of abdominal pain in children. Surgery, gynecology & obstetrics. Apr. 1981;152(4):424-6. [pmid: 7209769].
104 Brandt MM, Wahl WL. Liberal use of CT scanning helps to diagnose appendicitis in adults. The American surgeon. Sep. 2003;69(9):727-31. discussion 31–2. [pmid: 14509318].
105 Brewer BJ, Golden GT, Hitch DC, et al. Abdominal pain. An analysis of 1,000 consecutive cases in a University Hospital emergency room. American journal of surgery. Feb. 1976;131(2):219-23. [pmid: 1251963].
106 Brooks DW Jr, Killen DA. ROENTGENOGRAPHIC FINDINGS IN ACUTE APPENDICITIS. Surgery. Mar. 1965;57:377-84. [pmid: 14261578].
107 Bruwer F, Coetzer M, Warren BL. Laparoscopic versus open surgical exploration in premenopausal women with suspected acute appendicitis. South African journal of surgery Suid-Afrikaanse tydskrif vir chirurgie. Nov. 2003;41(4):82-5. [pmid: 14768141].
108 Bullard M, Sookram S, Campana B. The impact of parenteral opioid analgesics on sonographic and clinical diagnostic accuracy for suspected acute appendicitis. Cjem. Oct. 1999;1(3):196-7. [pmid: 17659136].
109 Bulus H, Tas A, Morkavuk B, et al. Can the efficiency of modified Alvarado scoring system in the diagnosis acute appendicitis be increased with tenesmus?. Wiener klinische Wochenschrift. Jan. 2013;125(1–2):16-20. [pmid: 23292641].
110 Burford JM, Dassinger MS, Smith SD. Surgeon-performed ultrasound as a diagnostic tool in appendicitis. Journal of pediatric surgery. Jun. 2011;46(6):1115-20. [pmid: 21683208].
111 Burton ID. Acute appendicitis in childhood: a feasibility study of computer-assisted diagnosis. The Australian and New Zealand journal of surgery. Dec. 1987;57(12):933-4. [pmid: 3326570].
112 Butler JA, Marcus CS, Henneman PL, et al. Evaluation of Tc-99m leukocyte scan in the diagnosis of acute appendicitis. The Journal of surgical research. May. 1987;42(5):575-9. [pmid: 3586627].
113 Caglayan K, Gunerhan Y, Koc A, et al. The role of computerized tomography in the diagnosis of acute appendicitis in patients with negative ultrasonography findings and a low Alvarado score. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Sep. 2010;16(5):445-8. [pmid: 21038123].
114 Caiazzo DP, Pennacchio E, Lisanti F, et al. Combination of MANTRELS score and abdominal ultrasound for the diagnosis of acute appendicitis in the emergency department: A randomized prospective study. Chirurgia. 2010;23(4):99-101. PMID:.
115 Cakirer S, Basak M, Colakoglu B, et al. Diagnosis of acute appendicitis with unenhanced helical CT: a study of 130 patients. Emergency radiology. Sep. 2002;9(3):155-61. [pmid: 15290575].
116 Campbell JP, Gunn AA. Plain abdominal radiographs and acute abdominal pain. The British journal of surgery. Jun. 1988;75(6):554-6. [pmid: 3395821].
117 Cannon JA, Kopp HS. The questionable value of the leukocyte count and differential count in the diagnosis of acute appendicitis. Western journal of surgery, obstetrics, and gynecology. May. 1954;62(5):312-5. [pmid: 13157341].
118 Cardall T, Glasser J, Guss DA. Clinical value of the total white blood cell count and temperature in the evaluation of patients with suspected appendicitis. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Oct. 2004;11(10):1021-7. [pmid: 15466143].
119 Cavusoglu YH, Erdogan D, Karaman A, et al. Do not rush into operating and just observe actively if you are not sure about the diagnosis of appendicitis. Pediatric surgery international. Mar. 2009;25(3):277-82. [pmid: 19184052].
120 Ceres L, Alonso I, Lopez P, et al. Ultrasound study of acute appendicitis in children with emphasis upon the diagnosis of retrocecal appendicitis. Pediatric radiology. 1990;20(4):258-61. [pmid: 2186346].
121 Ceydeli A, Lavotshkin S, Yu J, et al. When should we order a CT scan and when should we rely on the results to diagnose an acute appendicitis?. Current surgery. Nov–Dec. 2006;63(6):464-8. [pmid: 17084779].
122 Cha SH, Kim SH, Lee ES, et al. Saline-filled appendiceal ultrasonography in clinically equivocal acute appendicitis. Abdominal imaging. Nov–Dec. 1996;21(6):525-9. [pmid: 8875877].
123 Cha SW, Kim IY, Kim YW. Quantitative measurement of elasticity of the appendix using shear wave elastography in patients with suspected acute appendicitis. [pmid: 25051242].
124 Chabanova E, Balslev I, Achiam M, et al. Unenhanced MR Imaging in adults with clinically suspected acute appendicitis. European journal of radiology. Aug. 2011;79(2):206-10. [pmid: 20347539].
125 Chakhunashvili L, Inasaridze A, Svanidze S, et al. Procalcitonin as the biomarker of inflammation in diagnostics of pediatric appendicular peritonitis and for the prognosis of early postoperative complications. Georgian medical news. Dec. 2005;(129):78-81. [pmid: 16444038].
126 Chan I, Bicknell SG, Graham M. Utility and diagnostic accuracy of sonography in detecting appendicitis in a community hospital. AJR American journal of roentgenology. Jun. 2005;184(6):1809-12. [pmid: 15908535].
127 Chan MY, Tan C, Chiu MT, et al. Alvarado score: an admission criterion in patients with right iliac fossa pain. The surgeon : journal of the Royal Colleges of Surgeons of Edinburgh and Ireland. Feb. 2003;1(1):39-41.
128 Chan MY, Teo BS, Ng BL. The Alvarado score and acute appendicitis. Annals of the Academy of Medicine, Singapore. Sep. 2001;30(5):510-2. [pmid: 11603135].
129 Chang CC, Tsai CY, Lin CC, et al. Comparison between technetium-99m hexamethylpropyleneamineoxide labeled white blood cell abdomen scan and abdominal sonography to detect appendicitis in children with an atypical clinical presentation. Hepato-gastroenterology. Mar–Apr. 2003;50(50):426-9. [pmid: 12749239].
130 Chang CC, Wong YC, Wang LJ, Wu CH, Chen HW, Huang CC, Wan YL. Computed tomography diagnostic values of acute appendicitis in different patient subgroups. Chinese Journal of Radiology (Taiwan). 2013;38(1):9-14. PMID:.
131 Chang YJ, Kong MS, Hsia SH, et al. Usefulness of ultrasonography in acute appendicitis in early childhood. Journal of pediatric gastroenterology and nutrition. May. 2007;44(5):592-5. [pmid: 17460492].
132 Chee CP, Somasundaram K. Acute appendicitis: the significance of “positive” rectal examination and the position of the vermiform appendix. Singapore medical journal. Oct. 1982;23(5):265-8. [pmid: 7157006].
133 Chen CY, Zhao LL, Lin YR, Wu KH, Wu HP. Different urinalysis appearances in children with simple and perforated appendicitis. [pmid: 24055480].
134 Chen SC, Chen KM, Wang SM, et al. Abdominal sonography screening of clinically diagnosed or suspected appendicitis before surgery. World journal of surgery. May. 1998;22(5):449-52. [pmid: 9564286].
135 Chen SC, Lin FY, Hsieh YS, et al. Accuracy of ultrasonography in the diagnosis of peritonitis compared with the clinical impression of the surgeon. Arch Surg. Feb. 2000;135(2):170-3. discussion 4. [pmid: 10668876].
136 Chen SC, Wang HP, Hsu HY, et al. Accuracy of ED sonography in the diagnosis of acute appendicitis. The American journal of emergency medicine. Jul. 2000;18(4):449-52. [pmid: 10919537].
137 Chen SC, Wang SM. C-reactive protein in the diagnosis of acute appendicitis. The American journal of emergency medicine. Jan. 1996;14(1):101-3. [pmid: 8630133].
138 Cheng KS, Shiau YC, Lin CC, et al. Comparison between technetium-99m hexamethylpropyleneamineoxide labeled white blood cell abdomen scan and abdominal sonography to detect appendicitis in female patients with an atypical clinical presentation. Hepato-gastroenterology. Jan–Feb. 2003;50(49):136-9. [pmid: 12630009].
139 Chesbrough RM, Burkhard TK, Balsara ZN, et al. Self-localization in US of appendicitis: an addition to graded compression. Radiology. May. 1993;187(2):349-51. [pmid: 8475271].
140 Chi CH, Shiesh SC, Chen KW, et al. C-reactive protein for the evaluation of acute abdominal pain. The American journal of emergency medicine. May. 1996;14(3):254-6. [pmid: 8639195].
141 Chin JY, Goldstraw E, Lunniss P, et al. Evaluation of the utility of abdominal CT scans in the diagnosis, management, outcome and information given at discharge of patients with non-traumatic acute abdominal pain. The British journal of radiology. Sep. 2012;85(1017):e596-602. [pmid: 22919012].
142 Chiu YH, Chen JD, Wang SH, et al. Whether intravenous contrast is necessary for CT diagnosis of acute appendicitis in adult ED patients?. Academic radiology. Jan. 2013;20(1):73-8. [pmid: 22951113].
143 Chiu YH, Chen JD, Tiu CM, Chou YH, Lam C, Chen RJ. Maximum outer appendiceal diameter as a criterion of acute appendicitis: Evaluation at computerized tomography. Journal of Experimental and Clinical Medicine(Taiwan). 2013;5(3):97-100. PMID:.
144 Cho CS, Buckingham JM, Pierce M, et al. Computed tomography in the diagnosis of equivocal appendicitis. The Australian and New Zealand journal of surgery. Sep. 1999;69(9):664-7. [pmid: 10515341].
145 Choi D, Park H, Lee YR, et al. The most useful findings for diagnosing acute appendicitis on contrast-enhanced helical CT. Acta Radiol. Nov. 2003;44(6):574-82. [pmid: 14616200].
146 Choi HJ, Lee JH, Kang BS. Remote CT reading using an ultramobile PC and web-based remote viewing over a wireless network. Journal of telemedicine and telecare. Jan. 2012;18(1):26-31. [pmid: 22067287].
147 Choi YH, Fischer E, Hoda SA, et al. Appendiceal CT in 140 cases. Diagnostic criteria for acute and necrotizing appendicitis. Clinical imaging. Jul–Aug. 1998;22(4):252-71. [pmid: 9699047].
148 Chong CF, Adi MI, Thien A, et al. Development of the RIPASA score: a new appendicitis scoring system for the diagnosis of acute appendicitis. Singapore medical journal. Mar. 2010;51(3):220-5. [pmid: 20428744].
149 Chong CF, Thien A, Mackie AJ, et al. Comparison of RIPASA and Alvarado scores for the diagnosis of acute appendicitis. Singapore medical journal. May. 2011;52(5):340-5. [pmid: 21633767].
150 Choudhary S, Andley R, Sharma VP, et al. Assessment of leucocytic count in the diagnosis of acute appendicitis. Journal of the Indian Medical Association. Mar. 1. 1980;74(5):85-7. [pmid: 7410859].
151 Choudhri AF, Carr TM 3rd, Ho CP, et al. Handheld device review of abdominal CT for the evaluation of acute appendicitis. Journal of digital imaging. Aug. 2012;25(4):492-6. [pmid: 22146833].
152 Christopher FL, Lane MJ, Ward JA, et al. Unenhanced helical CT scanning of the abdomen and pelvis changes disposition of patients presenting to the emergency department with possible acute appendicitis. The Journal of emergency medicine. Jul. 2002;23(1):1-7. [pmid: 12217464].
153 Chu LL, Webb EM, Stengel JW, Yeh BM, Lu Y, Coakley FV. CT of acute appendicitis: can diagnostic accuracy serve as a practical performance metric for readers specialized in abdominal imaging?. [pmid: 24080371].
154 Clarke PJ, Hands LJ, Gough MH, et al. The use of laparoscopy in the management of right iliac fossa pain. Annals of the Royal College of Surgeons of England. Mar. 1986;68(2):68-9. [pmid: 2937361].
155 Clifford PC, Chan M, Hewett DJ. The acute abdomen: management with microcomputer aid. Annals of the Royal College of Surgeons of England. Jul. 1986;68(4):182-4. [pmid: 3538984].
156 Cobben L, Groot I, Kingma L, et al. A simple MRI protocol in patients with clinically suspected appendicitis: results in 138 patients and effect on outcome of appendectomy. European radiology. May. 2009;19(5):1175-83. [pmid: 19137303].
157 Cobben LP, Groot I, Haans L, et al. MRI for clinically suspected appendicitis during pregnancy. AJR American journal of roentgenology. Sep. 2004;183(3):671-5. [pmid: 15333354].
158 Colak T, Gungor F, Ozugur S, et al. The value of 99mTc-HMPAO labelled white blood cell scintigraphy in acute appendicitis patients with an equivocal clinical presentation. European journal of nuclear medicine. May. 2001;28(5):575-80. [pmid: 11383861].
159 Colvin JM, Bachur R, Kharbanda A. The presentation of appendicitis in preadolescent children. Pediatric emergency care. Dec. 2007;23(12):849-55. [pmid: 18091591].
160 Connor TJ, Garcha IS, Ramshaw BJ, et al. Diagnostic laparoscopy for suspected appendicitis. The American surgeon. Feb. 1995;61(2):187-9. [pmid: 7856985].
161 Corey D, Chang CK, Cembrowski GS. Disheartened: need ROC curve. American journal of clinical pathology. Apr. 1984;81(4):542-4. [pmid: 6702761].
162 Corso FA. Laparoscopic appendectomy. International surgery. Jul–Sep. 1994;79(3):247-50. [pmid: 7883506].
163 Coursey CA, Nelson RC, Moreno RD, et al. Appendicitis, body mass index, and CT: is CT more valuable for obese patients than thin patients?. The American surgeon. Apr. 2011;77(4):471-5. [pmid: 21679558].
164 Coursey CA, Nelson RC, Patel MB, et al. Making the diagnosis of acute appendicitis: do more preoperative CT scans mean fewer negative appendectomies? A 10-year study. Radiology. Feb. 2010;254(2):460-8. [pmid: 20093517].
165 Cox MR, McCall JL, Wilson TG, et al. Laparoscopic appendicectomy: a prospective analysis. The Australian and New Zealand journal of surgery. Nov. 1993;63(11):840-7. [pmid: 8216060].
166 Crady SK, Jones JS, Wyn T, et al. Clinical validity of ultrasound in children with suspected appendicitis. Annals of emergency medicine. Jul. 1993;22(7):1125-9. [pmid: 8517561].
167 Crichton NJ, Fryer JG, Spicer CC. Some points on the use of ‘independent Bayes’ to diagnose acute abdominal pain. Statistics in medicine. Dec. 1987;6(8):945-59. [pmid: 3326104].
168 Cristalli BG, Izard V, Jacob D, et al. Laparoscopic appendectomy using a clip applier. Surgical endoscopy. 1991;5(4):176-8. [pmid: 1839575].
169 Daly CP, Cohan RH, Francis IR, et al. Incidence of acute appendicitis in patients with equivocal CT findings. AJR American journal of roentgenology. Jun. 2005;184(6):1813-20. [pmid: 15908536].
170 Davidson PM, Douglas CD, Hosking CS. Graded compression ultrasonography in the assessment of the “tough decision” acute abdomen in childhood. Pediatric surgery international. 1999;15(1):32-5. [pmid: 9914351].
171 Davies AH, Bernau F, Salisbury A, et al. C-reactive protein in right iliac fossa pain. Journal of the Royal College of Surgeons of Edinburgh. Aug. 1991;36(4):242-4. [pmid: 1941740].
172 Davies AH, Mastorakou I, Cobb R, et al. Ultrasonography in the acute abdomen. The British journal of surgery. Oct. 1991;78(10):1178-80. [pmid: 1958978].
173 de Castro SM, Unlu C, Steller EP, et al. Evaluation of the appendicitis inflammatory response score for patients with acute appendicitis. World journal of surgery. Jul. 2012;36(7):1540-5. [pmid: 22447205].
174 de Dombal FT, Dallos V, McAdam WA. Can computer aided teaching packages improve clinical care in patients with acute abdominal pain?. BMJ. Jun. 22. 1991;302(6791):1495-7. [pmid: 1855017].
175 de Dombal FT, Horrocks JC. Use of receiver operating characteristic (ROC) curves to evaluate computer confidence threshold and clinical performance in the diagnosis appendicitis. Methods of information in medicine. Jul. 1978;17(3):157-61. [pmid: 357911].
176 De Dombal FT, Leaper DJ, Horrocks JC, et al. Human and computer-aided diagnosis of abdominal pain: further report with emphasis on performance of clinicians. British medical journal. Mar. 2. 1974;1(5904):376-80. [pmid: 4594585].
177 de Dombal FT, Leaper DJ, Staniland JR, et al. Computer-aided diagnosis of acute abdominal pain. British medical journal. Apr. 1. 1972;2(5804):9-13. [pmid: 4552594].
178 de Dombal FT. Acute abdominal pain--an O.M.G.E. survey. Scandinavian journal of gastroenterology Supplement. 1979;56:29-43. [pmid: 396663].
179 De Dombal FT. Surgical diagnosis assisted by a computer. Proceedings of the Royal Society of London Series B, Containing papers of a Biological character Royal Society (Great Britain). Dec. 21. 1973;184(1077):433-40. [pmid: 4149144].
180 Dearing DD, Recabaren JA, Alexander M. Can computed tomography scan be performed effectively in the diagnosis of acute appendicitis without the added morbidity of rectal contrast?. The American surgeon. Oct. 2008;74(10):917-20. [pmid: 18942613].
181 Decadt B, Sussman L, Lewis MP, et al. Randomized clinical trial of early laparoscopy in the management of acute non-specific abdominal pain. The British journal of surgery. Nov. 1999;86(11):1383-6. [pmid: 10583282].
182 DeCou JM, Gauderer MW, Boyle JT, et al. Diagnostic laparoscopy with planned appendectomy: an integral step in the evaluation of unexplained right lower quadrant pain. Pediatric surgery international. Feb. 2004;20(2):123-6. [pmid: 14745576].
183 deDombal FT. Computer-aided diagnosis and decision-making in the acute abdomen. Journal of the Royal College of Physicians of London. Apr. 1975;9(3):211-8. [pmid: 1095734].
184 Deibener-Kaminsky J, Lesesve JF, Kaminsky P. Leukocyte differential for acute abdominal pain in adults. Laboratory hematology : official publication of the International Society for Laboratory Hematology. Mar. 2011;17(1):1-5. [pmid: 21421538].
185 DeLaney AR, Raviola CA, Weber PN, et al. Improving diagnosis of appendicitis. Early autologous leukocyte scanning. Arch Surg. Oct. 1989;124(10):1146-51. discussion 51–2. [pmid: 2802977].
186 Denizbasi A, Unluer EE. The role of the emergency medicine resident using the Alvarado score in the diagnosis of acute appendicitis compared with the general surgery resident. European journal of emergency medicine : official journal of the European Society for Emergency Medicine. Dec. 2003;10(4):296-301. [pmid: 14676508].
187 Deutsch AA, Zelikovsky A, Reiss R. Laparoscopy in the prevention of unnecessary appendicectomies: a prospective study. The British journal of surgery. Jun. 1982;69(6):336-7. [pmid: 6211208].
188 Dey S, Mohanta PK, Baruah AK, et al. Alvarado scoring in acute appendicitis-a clinicopathological correlation. The Indian journal of surgery. Aug. 2010;72(4):290-3. [pmid: 21938190].
189 Di Cesare A, Parolini F, Morandi A, et al. Do we need imaging to diagnose appendicitis in children?. African journal of paediatric surgery : AJPS. Apr–Jun. 2013;10(2):68-73. [pmid: 23860049].
190 Dickenson AJ, Mackie IP, Peel AL, et al. Diagnostic laparoscopy for suspected appendicitis: only useful in young women. International journal of surgical investigation. 1999;1(4):343-6. [pmid: 12774459].
191 Dickson AP, MacKinlay GA. Rectal examination and acute appendicitis. Archives of disease in childhood. Jul. 1985;60(7):666-7. [pmid: 4026364].
192 Dickson JA, Edwards N, Jones AP. Computer-assisted diagnosis of acute abdominal pain in childhood. Lancet. Jun. 15. 1985;1(8442):1389-90. [pmid: 2861336].
193 Dickson JA, Jones A, Telfer S, et al. Acute abdominal pain in children. Scandinavian journal of gastroenterology Supplement. 1988;144:43-6. [pmid: 3043647].
194 Didier RA, Vajtai PL, Hopkins KL. Iterative reconstruction technique with reduced volume CT dose index: diagnostic accuracy in pediatric acute appendicitis. [pmid: 24996812].
195 Diehl JT, Eisenstat MS, Gillinov S, et al. The role of peritoneoscopy in the diagnosis of acute abdominal conditions. Cleveland Clinic quarterly. Fall. 1981;48(3):325-30. [pmid: 6457704].
196 Dilley A, Wesson D, Munden M, et al. The impact of ultrasound examinations on the management of children with suspected appendicitis: a 3-year analysis. Journal of pediatric surgery. Feb. 2001;36(2):303-8. [pmid: 11172421].
197 Dixon JM, Elton RA, Rainey JB, et al. Rectal examination in patients with pain in the right lower quadrant of the abdomen. BMJ. Feb. 16. 1991;302(6773):386-8. [pmid: 2004144].
198 D’Lppolito G, de Mello GG, Szejnfeld J. The value of unenhanced CT in the diagnosis of acute appendicitis. Sao Paulo medical journal. Revista paulista de medicina. Nov–Dec. 1998;116(6):1838-45. [pmid: 10349191].
199 Dolgin SE, Beck AR, Tartter PI. The risk of perforation when children with possible appendicitis are observed in the hospital. [pmid: 1411888].
200 Doraiswamy NV. Leucocyte counts in the diagnosis and prognosis of acute appendicitis in children. The British journal of surgery. Nov. 1979;66(11):782-4. [pmid: 519164].
201 Douglas CD, Macpherson NE, Davidson PM, et al. Randomised controlled trial of ultrasonography in diagnosis of acute appendicitis, incorporating the Alvarado score. BMJ. Oct. 14. 2000;321(7266):919-22. [pmid: 11030676].
202 Drake FT, Kotagal M, Simmons LE, Parr Z, Dighe MK, Flum DR. Single institution and statewide performance of ultrasound in diagnosing appendicitis in pregnancy. [pmid: 24913357].
203 Drake FT, Florence MG, Johnson MG, et al. Progress in the diagnosis of appendicitis: a report from Washington State’s Surgical Care and Outcomes Assessment Program. Annals of surgery. Oct. 2012;256(4):586-94. [pmid: 22964731].
204 D’Souza C, Martis J, Vaidyanathan V. Diagnostic efficacy of modified alvarado score over graded compression ultrasonography. Nitte University Journal of Health Science [serial on the Internet]. 2013;(3). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/116/CN-00914116/frame.html. Last accessed.
205 D’Souza N, Karim D, Sunthareswaran R. Bilirubin; a diagnostic marker for appendicitis. [pmid: 24080115].
206 Dueholm S, Bagi P, Bud M. Laboratory aid in the diagnosis of acute appendicitis. A blinded, prospective trial concerning diagnostic value of leukocyte count, neutrophil differential count, and C-reactive protein. Diseases of the colon and rectum. Oct. 1989;32(10):855-9. [pmid: 2676422].
207 Dunning PG, Goldman MD. The incidence and value of rectal examination in children with suspected appendicitis. Annals of the Royal College of Surgeons of England. Jul. 1991;73(4):233-4. [pmid: 1863045].
208 Duzgun AP, Bugdayci G, Sayin B, et al. Serum D-lactate: a useful diagnostic marker for acute appendicitis. Hepato-gastroenterology. Jul–Aug. 2007;54(77):1483-6. [pmid: 17708281].
209 Edwards FH, Davies RS. Use of a Bayesian algorithm in the computer-assisted diagnosis of appendicitis. Surgery, gynecology & obstetrics. Mar. 1984;158(3):219-22. [pmid: 6367112].
210 Edwards NH. The accuracy of a Bayesian computer program for diagnosis and teaching in acute abdominal pain of childhood. Computer methods and programs in biomedicine. Oct. 1986;23(2):155-60. [pmid: 3536285].
211 Ege G, Akman H, Sahin A, et al. Diagnostic value of unenhanced helical CT in adult patients with suspected acute appendicitis. The British journal of radiology. Sep. 2002;75(897):721-5. [pmid: 12200239].
212 Ekeh AP, Wozniak CJ, Monson B, et al. Laparoscopy in the contemporary management of acute appendicitis. American journal of surgery. Mar. 2007;193(3):310-3. discussion 3–4. [pmid: 17320525].
213 el Ferzli G, Ozuner G, Davidson PG, et al. Barium enema in the diagnosis of acute appendicitis. Surgery, gynecology & obstetrics. Jul. 1990;171(1):40-2. [pmid: 2360147].
214 Elangovan S. Clinical and laboratory findings in acute appendicitis in the elderly. The Journal of the American Board of Family Practice/American Board of Family Practice. Mar–Apr. 1996;9(2):75-8. [pmid: 8659268].
215 Elghany EA, Ali GG. Multidetector row helical CT and US in diagnosing appendicitis. Egyptian Journal of Radiology and Nuclear Medicine. 2011;42(2):139-45. PMID:.
216 Elikashvili I, Tay ET, Tsung JW. The effect of point-of-care ultrasonography on emergency department length of stay and computed tomography utilization in children with suspected appendicitis. [pmid: 24673672].
217 Emery M, Jones J, Brown M. Clinical application of infrared thermography in the diagnosis of appendicitis. The American journal of emergency medicine. Jan. 1994;12(1):48-50. [pmid: 8285972].
218 Emil S, Mikhail P, Laberge JM, et al. Clinical versus sonographic evaluation of acute appendicitis in children: a comparison of patient characteristics and outcomes. Journal of pediatric surgery. May. 2001;36(5):780-3. [pmid: 11329589].
219 Emmanuel A, Murchan P, Wilson I, et al. The value of hyperbilirubinaemia in the diagnosis of acute appendicitis. Annals of the Royal College of Surgeons of England. Apr. 2011;93(3):213-7. [pmid: 21477433].
220 English DC, Allen W, Coppola ED, et al. Excessive dependence on the leukocytosis cue in diagnosing appendicitis. The American surgeon. Jun. 1977;43(6):399-402. [pmid: 869331].
221 Enochsson L, Gudbjartsson T, Hellberg A, et al. The Fenyo-Lindberg scoring system for appendicitis increases positive predictive value in fertile women--a prospective study in 455 patients randomized to either laparoscopic or open appendectomy. Surgical endoscopy. Oct. 2004;18(10):1509-13. [pmid: 15791379].
222 Erdem H, Cetinkunar S, Das K, Reyhan E, Deger C, Aziret M, Bozkurt H, Uzun S, Sozen S, Irkorucu O. Alvarado, Eskelinen, Ohhmann and Raja Isteri Pengiran Anak Saleha Appendicitis scores for diagnosis of acute appendicitis. [pmid: 24379631].
223 Ergul E, Ucar AE, Ozgun YM, et al. Family history of acute appendicitis. JPMA The Journal of the Pakistan Medical Association. Nov. 2008;58(11):635-7. [pmid: 19024138].
224 Eriksson S, Granstrom L, Bark S. Laboratory tests in patients with suspected acute appendicitis. Acta chirurgica Scandinavica. Feb. 1989;155(2):117-20. [pmid: 2741614].
225 Eriksson S, Granstrom L, Carlstrom A. The diagnostic value of repetitive preoperative analyses of C-reactive protein and total leucocyte count in patients with suspected acute appendicitis. Scandinavian journal of gastroenterology. Dec. 1994;29(12):1145-9. [pmid: 7886405].
226 Eriksson S, Granstrom L, Olander B, et al. Leucocyte elastase as a marker in the diagnosis of acute appendicitis. The European journal of surgery. Acta chirurgica. Dec. 1995;161(12):901-5. [pmid: 8775633].
227 Eriksson S, Granstrom L, Olander B, et al. Sensitivity of interleukin-6 and C-reactive protein concentrations in the diagnosis of acute appendicitis. The European journal of surgery. Acta chirurgica. Jan. 1995;161(1):41-5. [pmid: 7727605].
228 Erkasap S, Ates E, Ustuner Z, et al. Diagnostic value of interleukin-6 and C-reactive protein in acute appendicitis. Swiss surgery. Schweizer Chirurgie = Chirurgie suisse = Chirurgia svizzera. 2000;6(4):169-72. [pmid: 10967943].
229 Escriba A, Gamell AM, Fernandez Y, et al. Prospective validation of two systems of classification for the diagnosis of acute appendicitis. Pediatric emergency care. Mar. 2011;27(3):165-9. [pmid: 21346681].
230 Eskelinen M, Ikonen J, Lipponen P. Acute appendicitis in patients over the age of 65 years; comparison of clinical and computer based decision making. International journal of bio-medical computing. Jul. 1994;36(3):239-49. [pmid: 7960209].
231 Eskelinen M, Ikonen J, Lipponen P. Sex-specific diagnostic scores for acute appendicitis. Scandinavian journal of gastroenterology. Jan. 1994;29(1):59-66. [pmid: 8128177].
232 Eskelinen M, Ikonen J, Lipponen P. The value of history-taking, physical examination, and computer assistance in the diagnosis of acute appendicitis in patients more than 50 years old. Scandinavian journal of gastroenterology. Apr. 1995;30(4):349-55. [pmid: 7610351].
233 Estey A, Poonai N, Lim R. Appendix not seen: the predictive value of secondary inflammatory sonographic signs. Pediatric emergency care. Apr. 2013;29(4):435-9. [pmid: 23528502].
234 Even-Bendahan G, Lazar I, Erez I, et al. Role of imaging in the diagnosis of acute appendicitis in children. Clinical pediatrics. Jan–Feb. 2003;42(1):23-7. [pmid: 12635978].
235 Evetts BK, Foley CR, Latimer RG, et al. Tc-99 hexamethylpropyleneamineoxide scanning for the detection of acute appendicitis. Journal of the American College of Surgeons. Aug. 1994;179(2):197-201. [pmid: 8044391].
236 Exadaktylos AK, Sadowski-Cron C, Mader P, et al. Decision making in patients with acute abdominal pain at a university and at a rural hospital: does the value of abdominal sonography differ?. World journal of emergency surgery : WJES. 2008;3:29. [pmid: 18842129].
237 Fa EM, Cronan JJ. Compression ultrasonography as an aid in the differential diagnosis of appendicitis. Surgery, gynecology & obstetrics. Oct. 1989;169(4):290-8. [pmid: 2675357].
238 Farahnak M, Talaei-Khoei M, Gorouhi F, et al. The Alvarado score and antibiotics therapy as a corporate protocol versus conventional clinical management: randomized controlled pilot study of approach to acute appendicitis. The American journal of emergency medicine. Sep. 2007;25(7):850-2. [pmid: 17870498].
239 Farion KJ, Michalowski W, Rubin S, et al. Prospective evaluation of the MET-AP system providing triage plans for acute pediatric abdominal pain. International journal of medical informatics. Mar. 2008;77(3):208-18. [pmid: 17321199].
240 Farooqui W, Pommergaard HC, Burcharth J, Eriksen JR. The diagnostic value of a panel of serological markers in acute appendicitis. [pmid: 24737847].
241 Fedko M, Bellamkonda VR, Bellolio MF, Hess EP, Lohse CM, Laack TA, Laughlin MJ Jr, Campbell RL. Ultrasound evaluation of appendicitis: importance of the 3 × 2 table for outcome reporting. [pmid: 24512887].
242 Fefferman NR, Roche KJ, Pinkney LP, et al. Suspected appendicitis in children: focused CT technique for evaluation. Radiology. Sep. 2001;220(3):691-5. [pmid: 11526268].
243 Fente BG, Echem RC. Prospective evaluation of the Bengezi and Al-Fallouji modified Alvarado score for presumptive accurate diagnosis of acute appendicitis in University of Port Harcourt Teaching Hospital, Port Harcourt. Nigerian journal of medicine : journal of the National Association of Resident Doctors of Nigeria. Oct–Dec. 2009;18(4):398-401. [pmid: 20120145].
244 Fenyo G, Clamp SE, de Dombal FT, et al. Computer-aided diagnosis of 233 acute abdominal cases at Nacka Hospital Sweden. Scandinavian journal of gastroenterology Supplement. 1987;128:178. [pmid: 3306897].
245 Fenyo G, Lindberg G, Blind P, et al. Diagnostic decision support in suspected acute appendicitis: validation of a simplified scoring system. The European journal of surgery. Acta chirurgica. Nov. 1997;163(11):831-8. [pmid: 9414043].
246 Fenyo G. Routine use of a scoring system for decision-making in suspected acute appendicitis in adults. Acta chirurgica Scandinavica. Sep. 1987;153(9):545-51. [pmid: 3321809].
247 Fergusson JA, Hitos K, Simpson E. Utility of white cell count and ultrasound in the diagnosis of acute appendicitis. ANZ journal of surgery. Nov. 2002;72(11):781-5. [pmid: 12437687].
248 Filiz AI, Aladag H, Akin ML, et al. The role of d-lactate in differential diagnosis of acute appendicitis. Journal of investigative surgery : the official journal of the Academy of Surgical Research. Aug. 2010;23(4):218-23. [pmid: 20690847].
249 Fleischman RJ, Devine MK, Yagapen MA, Steichen AJ, Hansen ML, Zigman AF, Spiro DM. Evaluation of a novel pediatric appendicitis pathway using high- and low-risk scoring systems. [pmid: 24076607].
250 Foley CR, Latimer RG, Rimkus DS. Detection of acute appendicitis by technetium 99 HMPAO scanning. The American surgeon. Dec. 1992;58(12):761-5. [pmid: 1456603].
251 Fonseca AL, Schuster KM, Kaplan LJ, Maung AA, Lui FY, Davis KA. The use of magnetic resonance imaging in the diagnosis of suspected appendicitis in pregnancy : shortened length of stay without increase in hospital charges. [pmid: 24871698].
252 Ford RD, Passinault WJ, Morse ME. Diagnostic ultrasound for suspected appendicitis: does the added cost produce a better outcome?. The American surgeon. Nov. 1994;60(11):895-8. [pmid: 7978690].
253 Fox JC, Hunt MJ, Zlidenny AM, et al. Retrospective analysis of emergency department ultrasound for acute appendicitis. The California journal of emergency medicine/California Chapter of the American Academy of Emergency Medicine. May. 2007;8(2):41-5. [pmid: 20440399].
254 Fox JC, Solley M, Anderson CL, et al. Prospective evaluation of emergency physician performed bedside ultrasound to detect acute appendicitis. European journal of emergency medicine : official journal of the European Society for Emergency Medicine. Apr. 2008;15(2):80-5. [pmid: 18446069].
255 Franke C, Bohner H, Yang Q, et al. Ultrasonography for diagnosis of acute appendicitis: results of a prospective multicenter trial. Acute Abdominal Pain Study Group. World journal of surgery. Feb. 1999;23(2):141-6. [pmid: 9880422].
256 Freeland M, King E, Safcsak K, et al. Diagnosis of appendicitis in pregnancy. American journal of surgery. Dec. 2009;198(6):753-8. [pmid: 19969125].
257 Frisenda R, Roty AR Jr, Kilway JB, et al. Acute appendicitis during pregnancy. The American surgeon. Aug. 1979;45(8):503-6. [pmid: 507547].
258 Fuchs JR, Schlamberg JS, Shortsleeve MJ, et al. Impact of abdominal CT imaging on the management of appendicitis: an update. The Journal of surgical research. Jul. 2002;106(1):131-6. [pmid: 12127818].
259 Fujii Y, Hata J, Futagami K, et al. Ultrasonography improves diagnostic accuracy of acute appendicitis and provides cost savings to hospitals in Japan. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Jun. 2000;19(6):409-14. [pmid: 10841063].
260 Funaki B, Grosskreutz SR, Funaki CN. Using unenhanced helical CT with enteric contrast material for suspected appendicitis in patients treated at a community hospital. AJR American journal of roentgenology. Oct. 1998;171(4):997-1001. [pmid: 9762983].
261 Fung HS, Lau S, Siu JCW, et al. Audit of ultrasonography for diagnosis of acute appendicitis: A retrospective study. Journal of the Hong Kong College of Radiologists. 2008;11(3):108-11. PMID:.
262 Gai H. Acute abdominal pain. Actual surgical aspects of sonography. Surgical endoscopy. 1988;2(1):28-35. [pmid: 3051464].
263 Gaitan H, Angel E, Sanchez J, et al. Laparoscopic diagnosis of acute lower abdominal pain in women of reproductive age. International journal of gynaecology and obstetrics: the official organ of the International Federation of Gynaecology and Obstetrics. Feb. 2002;76(2):149-58. [pmid: 11818109].
264 Gaitini D, Beck-Razi N, Mor-Yosef D, et al. Diagnosing acute appendicitis in adults: accuracy of color Doppler sonography and MDCT compared with surgery and clinical follow-up. AJR American journal of roentgenology. May. 2008;190(5):1300-6. [pmid: 18430847].
265 Galindo Gallego M, Fadrique B, Nieto MA, et al. Evaluation of ultrasonography and clinical diagnostic scoring in suspected appendicitis. The British journal of surgery. Jan. 1998;85(1):37-40. [pmid: 9462380].
266 Gallagher EJ, Esses D, Lee C, et al. Randomized clinical trial of morphine in acute abdominal pain. Annals of emergency medicine. Aug. 2006;48(2):150-60. 60 e1. 4. [pmid: 16953529].
267 Gamanagatti S, Vashisht S, Kapoor A, et al. Comparison of graded compression ultrasonography and unenhanced spiral computed tomography in the diagnosis of acute appendicitis. Singapore medical journal. Jan. 2007;48(1):80-7. [pmid: 17245521].
268 Ganguli S, Raptopoulos V, Komlos F, et al. Right lower quadrant pain: value of the nonvisualized appendix in patients at multidetector CT. Radiology. Oct. 2006;241(1):175-80. [pmid: 16928971].
269 Garcia C, Rosenfield NS, Markowitz RI, et al. Appendicitis in children. Accuracy of the barium enema. American journal of diseases of children (1960). Dec. 1987;141(12):1309-12. [pmid: 3687874].
270 Garcia CJ, Rosenfield NS. The barium enema in the diagnosis of acute appendicitis. Seminars in ultrasound, CT, and MR. Aug. 1989;10(4):314-20. [pmid: 2697344].
271 Garcia Pena BM, Cook EF, Mandl KD. Selective imaging strategies for the diagnosis of appendicitis in children. Pediatrics. Jan. 2004;113(1 Pt 1):24-8. [pmid: 14702442].
272 Garcia Pena BM, Mandl KD, Kraus SJ, et al. Ultrasonography and limited computed tomography in the diagnosis and management of appendicitis in children. JAMA : the journal of the American Medical Association. Sep. 15. 1999;282(11):1041-6. [pmid: 10493202].
273 Garcia-Aguayo FJ, Gil P. Sonography in acute appendicitis: diagnostic utility and influence upon management and outcome. European radiology. 2000;10(12):1886-93. [pmid: 11305565].
274 Gendel I, Gutermacher M, Buklan G, et al. Relative value of clinical, laboratory and imaging tools in diagnosing pediatric acute appendicitis. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al]. Zeitschrift fur Kinderchirurgie. Aug. 2011;21(4):229-33. [pmid: 21480165].
275 Ghotbi N, Ohtsuru A, Ogawa Y, et al. Pediatric CT scan usage in Japan: results of a hospital survey. Radiation medicine. Oct. 2006;24(8):560-7. [pmid: 17041792].
276 Giuliano V, Giuliano C, Pinto F, et al. CT method for visualization of the appendix using a fixed oral dosage of diatrizoate--clinical experience in 525 cases. Emergency radiology. Jul. 2005;11(5):281-5. [pmid: 16133622].
277 Glauser J, Siff J, Emerman C. Emergency Department Experience With Nonoral Contrast Computed Tomography in the Evaluation of Patients for Appendicitis. [pmid: 24080721].
278 Goh PL. A simplified appendicitis score in the diagnosis of acute appendicitis. Hong Kong Journal of Emergency Medicine. 2010;17(3):230-5. PMID:.
279 Goldin AB, Khanna P, Thapa M, et al. Revised ultrasound criteria for appendicitis in children improve diagnostic accuracy. Pediatric radiology. Aug. 2011;41(8):993-9. [pmid: 21409546].
280 Goldman RD, Carter S, Stephens D, et al. Prospective validation of the pediatric appendicitis score. The Journal of pediatrics. Aug. 2008;153(2):278-82. [pmid: 18534219].
281 Golledge J, Toms AP, Franklin IJ, et al. Assessment of peritonism in appendicitis. Annals of the Royal College of Surgeons of England. Jan. 1996;78(1):11-4. [pmid: 8659965].
282 Gomes CA, Nunes TA, Fonseca Chebli JM, et al. Laparoscopy grading system of acute appendicitis: new insight for future trials. Surgical laparoscopy, endoscopy & percutaneous techniques. Oct. 2012;22(5):463-6. [pmid: 23047394].
283 Goodman DA, Goodman CB, Monk JS. Use of the neutrophil:lymphocyte ratio in the diagnosis of appendicitis. The American surgeon. Mar. 1995;61(3):257-9. [pmid: 7887542].
284 Gough IR. A study of diagnostic accuracy in suspected acute appendicitis. The Australian and New Zealand journal of surgery. Jul. 1988;58(7):555-9. [pmid: 3075891].
285 Goulder F, Simpson T. Pediatric appendicitis score: A retrospective analysis. Journal of Indian Association of Pediatric Surgeons. Oct. 2008;13(4):125-7. [pmid: 20011493].
286 Grabham JA, Sutton C, Nicholson ML. A case for the removal of the ‘normal’ appendix at laparoscopy for suspected acute appendicitis. Annals of the Royal College of Surgeons of England. Jul. 1999;81(4):279-80. [pmid: 10615200].
287 Gracey D, McClure MJ. The impact of ultrasound in suspected acute appendicitis. Clinical radiology. Jun. 2007;62(6):573-8. [pmid: 17467395].
288 Graham A, Henley C, Mobley J. Laparoscopic evaluation of acute abdominal pain. Journal of laparoendoscopic surgery. Jun. 1991;1(3):165-8. [pmid: 1836403].
289 Graham JM, Pokorny WJ, Harberg FJ. Acute appendicitis in preschool age children. American journal of surgery. Feb. 1980;139(2):247-50. [pmid: 7356110].
290 Gray DW, Dixon JM, Seabrook G, et al. Is abdominal wall tenderness a useful sign in the diagnosis of non-specific abdominal pain?. Annals of the Royal College of Surgeons of England. Jul. 1988;70(4):233-4. [pmid: 2970820].
291 Gronroos JM, Forsstrom JJ, Irjala K, et al. Phospholipase A2, C-reactive protein, and white blood cell count in the diagnosis of acute appendicitis. Clinical chemistry. Sep. 1994;40(9):1757-60. [pmid: 8070088].
292 Gronroos JM, Gronroos P. A fertile-aged woman with right lower abdominal pain but unelevated leukocyte count and C-reactive protein. Acute appendicitis is very unlikely. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Oct. 1999;384(5):437-40. [pmid: 10552288].
293 Gronroos JM. Is there a role for leukocyte and CRP measurements in the diagnosis of acute appendicitis in the elderly?. Maturitas. Mar. 15. 1999;31(3):255-8. [pmid: 10340286].
294 Groselj-Grenc M, Repse S, Dolenc-Strazar Z, et al. Interleukin-6 and lipopolysaccharide-binding protein in acute appendicitis in children. Scandinavian journal of clinical and laboratory investigation. 2007;67(2):197-206. [pmid: 17365999].
295 Groselj-Grenc M, Repse S, Vidmar D, et al. Clinical and laboratory methods in diagnosis of acute appendicitis in children. Croatian medical journal. Jun. 2007;48(3):353-61. [pmid: 17589979].
296 Grunewald B, Keating J. Should the ‘normal’ appendix be removed at operation for appendicitis?. Journal of the Royal College of Surgeons of Edinburgh. Jun. 1993;38(3):158-60. [pmid: 7687678].
297 Gunn AA. The acute abdomen: the role of computer-assisted diagnosis. Bailliere’s clinical gastroenterology. Sep. 1991;5(3 Pt 1):639-65. [pmid: 1932833].
298 Gunn AA. The diagnosis of acute abdominal pain with computer analysis. Journal of the Royal College of Surgeons of Edinburgh. May. 1976;21(3):170-2. [pmid: 781220].
299 Gurian MS, Kovanlikaya A, Beneck D, et al. Radiologic-pathologic correlation in acute appendicitis: can we use it as a quality measure to assess interpretive accuracy of radiologists?. Clinical imaging. Nov–Dec. 2011;35(6):421-3. [pmid: 22040784].
300 Gurleyik E, Gurleyik G, Unalmiser S. Accuracy of serum C-reactive protein measurements in diagnosis of acute appendicitis compared with surgeon’s clinical impression. Diseases of the colon and rectum. Dec. 1995;38(12):1270-4. [pmid: 7497838].
301 Gurleyik G, Gurleyik E, Cetinkaya F, et al. Serum interleukin-6 measurement in the diagnosis of acute appendicitis. ANZ journal of surgery. Sep. 2002;72(9):665-7. [pmid: 12269920].
302 Gurrado A, Faillace G, Bottero L, et al. Laparoscopic appendectomies: experience of a surgical unit. Minimally invasive therapy & allied technologies : MITAT : official journal of the Society for Minimally Invasive Therapy. 2009;18(4):242-7. [pmid: 20334502].
303 Gutierrez CJ, Mariano MC, Faddis DM, et al. Doppler ultrasound accurately screens patients with appendicitis. The American surgeon. Nov. 1999;65(11):1015-7. [pmid: 10551747].
304 Gwynn LK. Appendiceal enlargement as a criterion for clinical diagnosis of acute appendicitis: is it reliable and valid?. The Journal of emergency medicine. Jul. 2002;23(1):9-14. [pmid: 12217465].
305 Gwynn LK. The diagnosis of acute appendicitis: clinical assessment versus computed tomography evaluation. The Journal of emergency medicine. Aug. 2001;21(2):119-23. [pmid: 11489398].
306 Hahn HB, Hoepner FU, Kalle T, et al. Sonography of acute appendicitis in children: 7 years experience. Pediatric radiology. Mar. 1998;28(3):147-51. [pmid: 9561531].
307 Hale DA, Molloy M, Pearl RH, et al. Appendectomy: a contemporary appraisal. Annals of surgery. Mar. 1997;225(3):252-61. [pmid: 9060580].
308 Hallan S, Asberg A, Edna TH. Additional value of biochemical tests in suspected acute appendicitis. The European journal of surgery. Acta chirurgica. Jul. 1997;163(7):533-8. [pmid: 9248988].
309 Hallan S, Asberg A, Edna TH. Estimating the probability of acute appendicitis using clinical criteria of a structured record sheet: the physician against the computer. The European journal of surgery. Acta chirurgica. Jun. 1997;163(6):427-32. [pmid: 9231854].
310 Haller O, Karlsson L, Nyman R. Can low-dose abdominal CT replace abdominal plain film in evaluation of acute abdominal pain?. Upsala journal of medical sciences. May. 2010;115(2):113-20. [pmid: 19878040].
311 Hallfeldt KK, Sohn M. Ultrasonography and acute appendicitis. Lancet. Oct. 8. 1994;344(8928):1032. [pmid: 7934421].
312 Hambidge JE. Use of skin thermometer to diagnose acute appendicitis. BMJ. Mar. 17. 1990;300(6726):722. [pmid: 2182159].
313 Hamminga JT, Hofker HS, Broens PM, et al. Evaluation of the appendix during diagnostic laparoscopy, the laparoscopic appendicitis score: a pilot study. Surgical endoscopy. May. 2013;27(5):1594-600. [pmid: 23073690].
314 Hansen AJ, Young SW, De Petris G, et al. Histologic severity of appendicitis can be predicted by computed tomography. Arch Surg. Dec. 2004;139(12):1304-8. [pmid: 15611455].
315 Hansson J, Khorram-Manesh A, Alwindawe A, Lundholm K. A model to select patients who may benefit from antibiotic therapy as the first line treatment of acute appendicitis at high probability. [pmid: 24263678].
316 Harland RN. Diagnosis of appendicitis in childhood. Journal of the Royal College of Surgeons of Edinburgh. Apr. 1991;36(2):89-90. [pmid: 2051426].
317 Hatch EI Jr, Naffis D, Chandler NW. Pitfalls in the use of barium enema in early appendicitis in children. Journal of pediatric surgery. Jun. 1981;16(3):309-12. [pmid: 7252733].
318 Hayden CK Jr, Kuchelmeister J, Lipscomb TS. Sonography of acute appendicitis in childhood: perforation versus nonperforation. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. May. 1992;11(5):209-16. [pmid: 1588691].
319 Hebert JJ, Taylor AJ, Winter TC. Comparison of colonic transit between polyethylene glycol and water as oral contrast vehicles in the CT evaluation of acute appendicitis. AJR American journal of roentgenology. Nov. 2006;187(5):1188-91. [pmid: 17056904].
320 Hee P, Viktrup L. The diagnosis of appendicitis during pregnancy and maternal and fetal outcome after appendectomy. International journal of gynaecology and obstetrics: the official organ of the International Federation of Gynaecology and Obstetrics. May. 1999;65(2):129-35. [pmid: 10405056].
321 Hekimoglu K, Yildirim UM, Karabulut E, et al. Comparison of combined oral and i.v. contrast-enhanced versus single i.v. contrast-enhanced mdct for the detection of acute appendicitis. JBR-BTR : organe de la Societe royale belge de radiologie (SRBR) = orgaan van de Koninklijke Belgische Vereniging voor Radiologie (KBVR). Sep–Oct. 2011;94(5):278-82. [pmid: 22191292].
322 Henneman PL, Marcus CS, Butler JA, et al. Appendicitis: evaluation by Tc-99m leukocyte scan. Annals of emergency medicine. Feb. 1988;17(2):111-6. [pmid: 3276246].
323 Henneman PL, Marcus CS, Butler JA, et al. Evaluation of women with possible appendicitis using technetium-99m leukocyte scan. The American journal of emergency medicine. Sep. 1990;8(5):373-8. [pmid: 2206141].
324 Henneman PL, Marcus CS, Inkelis SH, et al. Evaluation of children with possible appendicitis using technetium 99m leukocyte scan. Pediatrics. May. 1990;85(5):838-43. [pmid: 2330248].
325 Herliczek TW, Swenson DW, Mayo-Smith WW. Utility of MRI after inconclusive ultrasound in pediatric patients with suspected appendicitis: retrospective review of 60 consecutive patients. AJR American journal of roentgenology. May. 2013;200(5):969-73. [pmid: 23617477].
326 Hernandez JA, Swischuk LE, Angel CA, et al. Imaging of acute appendicitis: US as the primary imaging modality. Pediatric radiology. Apr. 2005;35(4):392-5. [pmid: 15635471].
327 Hernandez R, Jain A, Rosiere L, et al. A prospective clinical trial evaluating urinary 5-hydroxyindoleacetic acid levels in the diagnosis of acute appendicitis. The American journal of emergency medicine. Mar. 2008;26(3):282-6. [pmid: 18358937].
328 Hershko DD, Awad N, Fischer D, et al. Focused helical CT using rectal contrast material only as the preferred technique for the diagnosis of suspected acute appendicitis: a prospective, randomized, controlled study comparing three different techniques. Diseases of the colon and rectum. Aug. 2007;50(8):1223-9. [pmid: 17566826].
329 Hershko DD, Sroka G, Bahouth H, et al. The role of selective computed tomography in the diagnosis and management of suspected acute appendicitis. The American surgeon. Nov. 2002;68(11):1003-7. [pmid: 12455796].
330 Heverhagen JT, Pfestroff K, Heverhagen AE, et al. Diagnostic accuracy of magnetic resonance imaging: a prospective evaluation of patients with suspected appendicitis (diamond). Journal of magnetic resonance imaging : JMRI. Mar. 2012;35(3):617-23. [pmid: 22033948].
331 Hiersch L, Yogev Y, Ashwal E, From A, Ben-Haroush A, Peled Y. The impact of pregnancy on the accuracy and delay in diagnosis of acute appendicitis. [pmid: 24151869].
332 Himeno S, Yasuda S, Oida Y, et al. Ultrasonography for the diagnosis of acute appendicitis. The Tokai journal of experimental and clinical medicine. Apr. 2003;28(1):39-44. [pmid: 12880303].
333 Hoecker CC, Billman GF. The utility of unenhanced computed tomography in appendicitis in children. The Journal of emergency medicine. May. 2005;28(4):415-21. [pmid: 15837022].
334 Holloway JA, Westerbuhr LM, Chain J, et al. Is appendiceal computed tomography in a community hospital useful?. American journal of surgery. Dec. 2003;186(6):682-4. discussion 4. [pmid: 14672779].
335 Hong JJ, Cohn SM, Ekeh AP, et al. A prospective randomized study of clinical assessment versus computed tomography for the diagnosis of acute appendicitis. Surgical infections. Fall. 2003;4(3):231-9. [pmid: 14588157].
336 Hormann M, Paya K, Eibenberger K, et al. MR imaging in children with nonperforated acute appendicitis: value of unenhanced MR imaging in sonographically selected cases. AJR American journal of roentgenology. Aug. 1998;171(2):467-70. [pmid: 9694477].
337 Hormann M, Scharitzer M, Stadler A, et al. Ultrasound of the appendix in children: is the child too obese?. European radiology. Jun. 2003;13(6):1428-31. [pmid: 12764662].
338 Horrocks JC, Devroede G, de Dombal FT. Computer-aided diagnosis of gastroenterologic diseases in Sherbrooke: preliminary report. Canadian journal of surgery Journal canadien de chirurgie. Mar. 1976;19(2):160-4. [pmid: 769927].
339 Horrocks JC, McCann AP, Staniland JR, et al. Computer-aided diagnosis: description of an adaptable system, and operational experience with 2,034 cases. British medical journal. Apr. 1. 1972;2(5804):5-9. [pmid: 4552593].
340 Horton MD, Counter SF, Florence MG, et al. A prospective trial of computed tomography and ultrasonography for diagnosing appendicitis in the atypical patient. American journal of surgery. May. 2000;179(5):379-81. [pmid: 10930484].
341 Horzic M, Salamon A, Kopljar M, et al. Analysis of scores in diagnosis of acute appendicitis in women. Collegium antropologicum. Jun. 2005;29(1):133-8. [pmid: 16117311].
342 Hotic N, Cickusic E, Mesic D, Husaric E, Halilbasic A, Rahmanovic E. Leukocytes, C-reactive protein and interleukin-6 in acute appendicitis in children: Diagnostic value and association with histological findings. PMID:.
343 Howie CR, Gunn AA. Temperature: a poor diagnostic indicator in abdominal pain. Journal of the Royal College of Surgeons of Edinburgh. Jul. 1984;29(4):249-51. [pmid: 6481676].
344 Hsieh CH, Lu RH, Lee NH, et al. Novel solutions for an old disease: diagnosis of acute appendicitis with random forest, support vector machines, and artificial neural networks. Surgery. Jan. 2011;149(1):87-93. [pmid: 20466403].
345 Huang TH, Huang YC, Tu CW. Acute appendicitis or not: Facts and suggestions to reduce valueless surgery. Journal of Acute Medicine. 2013;3(4):142-7. PMID:.
346 Huynh V, Lalezarzadeh F, Lawandy S, et al. Abdominal computed tomography in the evaluation of acute and perforated appendicitis in the community setting. The American surgeon. Oct. 2007;73(10):1002-5. [pmid: 17983068].
347 Ikonen JK, Rokkanen PU, Gronroos P, et al. Presentation and diagnosis of acute abdominal pain in Finland: a computer aided study. Annales chirurgiae et gynaecologiae. 1983;72(6):332-6. [pmid: 6364950].
348 Ilce Z, Yildiz T, Isleyen M. The role of laparoscopy in suspicious abdomen pain in children. Pak J Med Sci. Jul. 2013;29(4):1042-5. [pmid: 24353684].
349 Incesu L, Coskun A, Selcuk MB, et al. Acute appendicitis: MR imaging and sonographic correlation. AJR American journal of roentgenology. Mar. 1997;168(3):669-74. [pmid: 9057512].
350 Incesu L, Yazicioglu AK, Selcuk MB, et al. Contrast-enhanced power Doppler US in the diagnosis of acute appendicitis. European journal of radiology. May. 2004;50(2):201-9. [pmid: 15081132].
351 Inci E, Hocaoglu E, Aydin S, et al. Efficiency of unenhanced MRI in the diagnosis of acute appendicitis: comparison with Alvarado scoring system and histopathological results. European journal of radiology. Nov. 2011;80(2):253-8. [pmid: 20655156].
352 Inci E, Kilickesmez O, Hocaoglu E, et al. Utility of diffusion-weighted imaging in the diagnosis of acute appendicitis. European radiology. Apr. 2011;21(4):768-75. [pmid: 20924585].
353 in’t Hof KH, Krestin GP, Steijerberg EW, et al. Interobserver variability in CT scan interpretation for suspected acute appendicitis. Emergency medicine journal : EMJ. Feb. 2009;26(2):92-4. [pmid: 19164615].
354 in’t Hof KH, van Lankeren W, Krestin GP, et al. Surgical validation of unenhanced helical computed tomography in acute appendicitis. The British journal of surgery. Dec. 2004;91(12):1641-5. [pmid: 15386320].
355 Isman FK, Zulfikaroglu B, Acar A, et al. Serum visfatin levels in acute appendicitis. International journal of surgery (London, England). 2010;8(3):259-60. [pmid: 20172058].
356 Israel GM, Malguria N, McCarthy S, et al. MRI vs. ultrasound for suspected appendicitis during pregnancy. Journal of magnetic resonance imaging : JMRI. Aug. 2008;28(2):428-33. [pmid: 18666160].
357 Ives EP, Sung S, McCue P, et al. Independent predictors of acute appendicitis on CT with pathologic correlation. Academic radiology. Aug. 2008;15(8):996-1003. [pmid: 18620120].
358 Izbicki JR, Knoefel WT, Wilker DK, et al. Accurate diagnosis of acute appendicitis: a retrospective and prospective analysis of 686 patients. The European journal of surgery. Acta chirurgica. Apr. 1992;158(4):227-31. [pmid: 1352137].
359 Jacobs JE, Birnbaum BA, Macari M, et al. Acute appendicitis: comparison of helical CT diagnosis focused technique with oral contrast material versus nonfocused technique with oral and intravenous contrast material. Radiology. Sep. 2001;220(3):683-90. [pmid: 11526267].
360 Jadallah FA, Abdul-Ghani AA, Tibblin S. Diagnostic laparoscopy reduces unnecessary appendicectomy in fertile women. The European journal of surgery. Acta chirurgica. Jan. 1994;160(1):41-5. [pmid: 8186313].
361 Jahn H, Mathiesen FK, Neckelmann K, et al. Comparison of clinical judgment and diagnostic ultrasonography in the diagnosis of acute appendicitis: experience with a score-aided diagnosis. The European journal of surgery. Acta chirurgica. Jun. 1997;163(6):433-43. [pmid: 9231855].
362 Jamaluddin M, Hussain SM, Ahmad H. Hyperbilirubinaemia a predictive factor for complicated acute appendicitis: a study in a tertiary care hospital. [pmid: 24392522].
363 Jang KM, Kim SH, Choi D, et al. The value of 3D T1-weighted gradient-echo MR imaging for evaluation of the appendix during pregnancy: preliminary results. Acta Radiol. Oct. 1. 2011;52(8):825-8. [pmid: 21835887].
364 Jang KM, Lee K, Kim MJ, et al. What is the complementary role of ultrasound evaluation in the diagnosis of acute appendicitis after CT?. European journal of radiology. Apr. 2010;74(1):71-6. [pmid: 19144480].
365 Jangjoo A, Varasteh AR, Bahar MM, et al. Is C-reactive protein helpful for early diagnosis of acute appendicitis?. Acta chirurgica Belgica. Jul–Aug. 2011;111(4):219-22. [pmid: 21954737].
366 Jangjoo A, Varasteh AR, Mehrabi Bahar M, et al. Is urinary 5-hydroxyindoleacetic acid helpful for early diagnosis of acute appendicitis?. The American journal of emergency medicine. May. 2012;30(4):540-4. [pmid: 21450436].
367 Jaremko JL, Crockett A, Rucker D, et al. Incidence and significance of inconclusive results in ultrasound for appendicitis in children and teenagers. Canadian Association of Radiologists journal. Journal l’Association canadienne des radiologistes. Aug. 2011;62(3):197-202. [pmid: 20493658].
368 Jasmi AY, Hassan M, Haron A, Mazlam MZ, Zawiah I, Zawiah A. Value of C-reactive protein and white cell count in the diagnosis of acute appendicitis. Asian Journal of Surgery. 1996;19(4):301-3. PMID:.
369 Jawaid A, Asad A, Motiei A, et al. Clinical scoring system: a valuable tool for decision making in cases of acute appendicitis. JPMA The Journal of the Pakistan Medical Association. Oct. 1999;49(10):254-9. [pmid: 10647233].
370 Je BK, Kim SB, Lee SH, et al. Diagnostic value of maximal-outer-diameter and maximal-mural-thickness in use of ultrasound for acute appendicitis in children. World journal of gastroenterology : WJG. Jun. 21. 2009;15(23):2900-3. [pmid: 19533813].
371 Jearwattanakanok K, Yamada S, Suntornlimsiri W, Smuthtai W, Patumanond J. Clinical scoring for diagnosis of acute lower abdominal pain in female of reproductive age. [pmid: 24396602].
372 Jearwattanakanok K, Yamada S, Suntornlimsiri W, Smuthtai W, Patumanond J. Validation of the diagnostic score for acute lower abdominal pain in women of reproductive age. [pmid: 24971177].
373 Jeffrey RB Jr, Laing FC, Lewis FR. Acute appendicitis: high-resolution real-time US findings. Radiology. Apr. 1987;163(1):11-4. [pmid: 3547490].
374 Jeffrey RB Jr, Laing FC, Townsend RR. Acute appendicitis: sonographic criteria based on 250 cases. Radiology. May. 1988;167(2):327-9. [pmid: 3282253].
375 Jersky J, Hoffman J, Shapiro J, et al. Laparoscopy in patients with suspected acute appendicitis. South African journal of surgery Suid-Afrikaanse tydskrif vir chirurgie. Dec. 1980;18(4):147-50. [pmid: 6451941].
376 Johansson EP, Rydh A, Riklund KA. Ultrasound, computed tomography, and laboratory findings in the diagnosis of appendicitis. Acta Radiol. Apr. 2007;48(3):267-73. [pmid: 17453494].
377 John H, Neff U, Kelemen M. Appendicitis diagnosis today: clinical and ultrasonic deductions. World journal of surgery. Mar–Apr. 1993;17(2):243-9. [pmid: 8511921].
378 John SK, Joseph J, Shetty SR. Avoiding negative appendectomies in rural surgical practice: is C-reactive protein estimation useful as a diagnostic tool?. The National medical journal of India. May–Jun. 2011;24(3):144-7. [pmid: 21786842].
379 Johnson AK, Filippi CG, Andrews T, et al. Ultrafast 3-T MRI in the evaluation of children with acute lower abdominal pain for the detection of appendicitis. AJR American journal of roentgenology. Jun. 2012;198(6):1424-30. [pmid: 22623558].
380 Johnson PT, Horton KM, Kawamoto S, et al. MDCT for suspected appendicitis: effect of reconstruction section thickness on diagnostic accuracy, rate of appendiceal visualization, and reader confidence using axial images. AJR American journal of roentgenology. Apr. 2009;192(4):893-901. [pmid: 19304692].
381 Jones GE, Kreckler S, Shah A, et al. Increased use of laparoscopy in acute right iliac fossa pain - is it good for patients?. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Feb. 2012;14(2):237-42. [pmid: 21689285].
382 Jones K, Pena AA, Dunn EL, et al. Are negative appendectomies still acceptable?. American journal of surgery. Dec. 2004;188(6):748-54. [pmid: 15619494].
383 Jorulf H, Hesser U, Gordon L, et al. Cost-effectiveness of sonographic diagnosis of appendicitis in children. Academic radiology. Apr. Suppl 1. 1996;3:S54-6. [pmid: 8796514].
384 Josephson T, Styrud J, Eriksson S. Ultrasonography in acute appendicitis. Body mass index as selection factor for US examination. Acta Radiol. Sep. 2000;41(5):486-8. [pmid: 11016772].
385 Kafetzis DA, Velissariou IM, Nikolaides P, et al. Procalcitonin as a predictor of severe appendicitis in children. European journal of clinical microbiology & infectious diseases : official publication of the European Society of Clinical Microbiology. Jul. 2005;24(7):484-7. [pmid: 15995845].
386 Kahramanca S, Ozgehan G, Seker D, Gokce EI, Seker G, Tunc G, Kucukpinar T, Kargici H. Neutrophil-to-lymphocyte ratio as a predictor of acute appendicitis. [pmid: 24639310].
387 Kaidu M, Oyamatu M, Sato K, et al. Diagnostic limitations of 10 mm thickness single-slice computed tomography for patients with suspected appendicitis. Radiation medicine. Feb. 2008;26(2):63-9. [pmid: 18301980].
388 Kailidou E, Pikoulis E, Katsiva V, et al. Spiral computerized tomography : a diagnostic aid in patients with atypical acute appendicitis. Acta chirurgica Belgica. Jan–Feb. 2006;106(1):47-51. [pmid: 16612913].
389 Kaiser S, Finnbogason T, Jorulf HK, et al. Suspected appendicitis in children: diagnosis with contrast-enhanced versus nonenhanced Helical CT. Radiology. May. 2004;231(2):427-33. [pmid: 15031433].
390 Kaiser S, Frenckner B, Jorulf HK. Suspected appendicitis in children: US and CT--a prospective randomized study. Radiology. Jun. 2002;223(3):633-8. [pmid: 12034928].
391 Kaiser S, Jorulf H, Soderman E, et al. Impact of radiologic imaging on the surgical decision-making process in suspected appendicitis in children. Academic radiology. Sep. 2004;11(9):971-9. [pmid: 15350578].
392 Kalan M, Talbot D, Cunliffe WJ, et al. Evaluation of the modified Alvarado score in the diagnosis of acute appendicitis: a prospective study. Annals of the Royal College of Surgeons of England. Nov. 1994;76(6):418-9. [pmid: 7702329].
393 Kamel IR, Goldberg SN, Keogan MT, et al. Right lower quadrant pain and suspected appendicitis: nonfocused appendiceal CT--review of 100 cases. Radiology. Oct. 2000;217(1):159-63. [pmid: 11012439].
394 Kamran H, Naveed D, Asad S, et al. Evaluation of modified Alvarado score for frequency of negative appendicectomies. Journal of Ayub Medical College, Abbottabad : JAMC. Oct–Dec. 2010;22(4):46-9. [pmid: 22455259].
395 Kamran H, Naveed D, Nazir A, et al. Role of total leukocyte count in diagnosis of acute appendicitis. Journal of Ayub Medical College, Abbottabad : JAMC. Jul–Sep. 2008;20(3):70-1. [pmid: 19610521].
396 Kan JH, Fines BP, Funaki B. Conventional and hydrocolonic US of the appendix with CT correlation performed by on-call radiology residents. Academic radiology. Dec. 2001;8(12):1208-14. [pmid: 11770917].
397 Kanbour A, Al Alawi A, Al Den AS, et al. Does delay in diagnosing acute appendicitis affect the outcome?. Qatar Medical Journal. 2010;19(1):40-5. PMID:.
398 Kanegaye JT, Vance CW, Parisi M, et al. Failure of technetium-99m hexamethylpropylene amine oxime leukocyte scintigraphy in the evaluation of children with suspected appendicitis. Pediatric emergency care. Oct. 1995;11(5):285-90. [pmid: 8570450].
399 Kaneko K, Tsuda M. Ultrasound-based decision making in the treatment of acute appendicitis in children. Journal of pediatric surgery. Sep. 2004;39(9):1316-20. [pmid: 15359383].
400 Kang WM, Lee CH, Chou YH, et al. A clinical evaluation of ultrasonography in the diagnosis of acute appendicitis. Surgery. Feb. 1989;105(2 Pt 1):154-9. [pmid: 2644718].
401 Kanumba ES, Mabula JB, Rambau P, et al. Modified Alvarado Scoring System as a diagnostic tool for acute appendicitis at Bugando Medical Centre, Mwanza, Tanzania. BMC surgery. 2011;11:4. [pmid: 21329493].
402 Kao CH, Lin HT, Wang YL, et al. Tc-99m HMPAO-labeled WBC scans to detect appendicitis in women. Clinical nuclear medicine. Oct. 1996;21(10):768-71. [pmid: 8896923].
403 Kapan S, Bozkurt MA, Turhan AN, et al. Management of acute appendicitis in pregnancy. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Jan. 2013;19(1):20-4. [pmid: 23588974].
404 Kapoor A, Mahajan G. Real-time elastography in acute appendicitis. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Jun. 2010;29(6):871-7. [pmid: 20498461].
405 Karabulut N, Kiroglu Y, Herek D, et al. Feasibility of low-dose unenhanced multi-detector CT in patients with suspected acute appendicitis: comparison with sonography. [pmid: 24513314].
406 Karakas SP, Guelfguat M, Leonidas JC, et al. Acute appendicitis in children: comparison of clinical diagnosis with ultrasound and CT imaging. Pediatric radiology. Feb. 2000;30(2):94-8. [pmid: 10663520].
407 Kariman H, Shojaee M, Sabzghabaei A, Khatamian R, Derakhshanfar H, Hatamabadi H. Evaluation of the Alvarado score in acute abdominal pain. [pmid: 24740332].
408 Karstrup S, Torp-Pedersen S, Roikjaer O. Ultrasonic visualisation of the inflamed appendix. The British journal of radiology. Oct. 1986;59(706):985-6. [pmid: 3533202].
409 Kaya B, Sana B, Eris C, et al. The diagnostic value of D-dimer, procalcitonin and CRP in acute appendicitis. International journal of medical sciences. 2012;9(10):909-15. [pmid: 23236260].
410 Kell MR, Power K, Winter DC, et al. Predicting outcome after appendicectomy. Irish journal of medical science. Apr–Jun. 2003;172(2):63-5. [pmid: 12930054].
411 Kentsis A, Ahmed S, Kurek K, et al. Detection and diagnostic value of urine leucine-rich alpha-2-glycoprotein in children with suspected acute appendicitis. Annals of emergency medicine. Jul. 2012;60(1):78-83 e1. [pmid: 22305331].
412 Kentsis A, Lin YY, Kurek K, et al. Discovery and validation of urine markers of acute pediatric appendicitis using high-accuracy mass spectrometry. Annals of emergency medicine. Jan. 2010;55(1):62-70 e4. [pmid: 19556024].
413 Kepner AM, Bacasnot JV, Stahlman BA. Intravenous contrast alone vs intravenous and oral contrast computed tomography for the diagnosis of appendicitis in adult ED patients. The American journal of emergency medicine. Nov. 2012;30(9):1765-73. [pmid: 22633722].
414 Keskek M, Tez M, Yoldas O, et al. Receiver operating characteristic analysis of leukocyte counts in operations for suspected appendicitis. The American journal of emergency medicine. Sep. 2008;26(7):769-72. [pmid: 18774040].
415 Kessler N, Cyteval C, Gallix B, et al. Appendicitis: evaluation of sensitivity, specificity, and predictive values of US, Doppler US, and laboratory findings. Radiology. Feb. 2004;230(2):472-8. [pmid: 14688403].
416 Keyzer C, Cullus P, Tack D, et al. MDCT for suspected acute appendicitis in adults: impact of oral and IV contrast media at standard-dose and simulated low-dose techniques. AJR American journal of roentgenology. Nov. 2009;193(5):1272-81. [pmid: 19843741].
417 Keyzer C, Tack D, de Maertelaer V, et al. Acute appendicitis: comparison of low-dose and standard-dose unenhanced multi-detector row CT. Radiology. Jul. 2004;232(1):164-72. [pmid: 15155894].
418 Keyzer C, Zalcman M, De Maertelaer V, et al. Comparison of US and unenhanced multi-detector row CT in patients suspected of having acute appendicitis. Radiology. Aug. 2005;236(2):527-34. [pmid: 16040910].
419 Khan AN, Sawan A, Likourezos A, et al. The usefulness of procalcitonin in the diagnosis of appendicitis in children: a pilot study. Emergency medicine international. 2012;2012:317504. [pmid: 23304513].
420 Khan I, ur Rehman A. Application of alvarado scoring system in diagnosis of acute appendicitis. Journal of Ayub Medical College, Abbottabad : JAMC. Jul–Sep. 2005;17(3):41-4. [pmid: 16320795].
421 Khan MN, Davie E, Irshad K. The role of white cell count and C-reactive protein in the diagnosis of acute appendicitis. Journal of Ayub Medical College, Abbottabad : JAMC. Jul–Sep. 2004;16(3):17-9. [pmid: 15631364].
422 Khan S. Elevated serum bilirubin in acute appendicitis :a new diagnostic tool. Kathmandu University medical journal (KUMJ). Apr–Jun. 2008;6(2):161-5. [pmid: 18769079].
423 Khan S. Evaluation of hyperbilirubinemia in acute inflammation of appendix: a prospective study of 45 cases. Kathmandu University medical journal (KUMJ). Jul–Sep. 2006;4(3):281-9. [pmid: 18603920].
424 Khan S. The diagnostic value of hyperbilirubinemia and total leucocyte count in the evaluation of acute appendicitis. Journal of Clinical and Diagnostic Research. 2009;3(4):1647-52. PMID:.
425 Khanal BR, Ansari MA, Pradhan S. Accuracy of ultrasonography in the diagnosis of acute appendicitis. Kathmandu University medical journal (KUMJ). Jan–Mar. 2008;6(1):70-4. [pmid: 18604118].
426 Khanzada TW, Samad A, Sushel C. Negative appendectomy rate: Can it be reduced?. Journal of the Liaquat University of Medical and Health Sciences. 2009;8(1):19-22. PMID:.
427 Kharbanda AB, Cosme Y, Liu K, et al. Discriminative accuracy of novel and traditional biomarkers in children with suspected appendicitis adjusted for duration of abdominal pain. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Jun. 2011;18(6):567-74. [pmid: 21676053].
428 Kharbanda AB, Dudley NC, Bajaj L, et al. Validation and refinement of a prediction rule to identify children at low risk for acute appendicitis. Archives of pediatrics & adolescent medicine. Aug. 2012;166(8):738-44. [pmid: 22869405].
429 Kharbanda AB, Dudley NC, Baja L. A Clinical Prediction Rule to Identify Children at Low Risk For Appendicitis. Journal of Clinical Outcomes Management. 2012;19(10):442-4. Language: English. Entry Date: 20121207. Revision Date: 20121207. Publication Type: journal article.
430 Kharbanda AB, Rai AJ, Cosme Y, et al. Novel serum and urine markers for pediatric appendicitis. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Jan. 2012;19(1):56-62. [pmid: 22221321].
431 Kharbanda AB, Taylor GA, Bachur RG. Suspected appendicitis in children: rectal and intravenous contrast-enhanced versus intravenous contrast-enhanced CT. Radiology. May. 2007;243(2):520-6. [pmid: 17456874].
432 Kharbanda AB, Taylor GA, Fishman SJ, et al. A clinical decision rule to identify children at low risk for appendicitis. Pediatrics. Sep. 2005;116(3):709-16. [pmid: 16140712].
433 Kim E, Subhas G, Mittal VK, et al. C-reactive protein estimation does not improve accuracy in the diagnosis of acute appendicitis in pediatric patients. International journal of surgery (London, England). Feb. 2009;7(1):74-7. [pmid: 19070557].
434 Kim HC, Yang DM, Lee CM, et al. Acute appendicitis: relationships between CT-determined severities and serum white blood cell counts and C-reactive protein levels. The British journal of radiology. Dec. 2011;84(1008):1115-20. [pmid: 21123307].
435 Kim K, Kim YH, Kim SY, et al. Low-dose abdominal CT for evaluating suspected appendicitis. The New England journal of medicine. Apr. 26. 2012;366(17):1596-605. [pmid: 22533576].
436 Kim K, Lee CC, Song KJ, et al. The impact of helical computed tomography on the negative appendectomy rate: a multi-center comparison. The Journal of emergency medicine. Jan. 2008;34(1):3-6. [pmid: 18022782].
437 Kim K, Rhee JE, Lee CC, et al. Impact of helical computed tomography in clinically evident appendicitis. Emergency medicine journal : EMJ. Aug. 2008;25(8):477-81. [pmid: 18660392].
438 Kim SY, Lee KH, Kim K, et al. Acute appendicitis in young adults: low- versus standard-radiation-dose contrast-enhanced abdominal CT for diagnosis. Radiology. Aug. 2011;260(2):437-45. [pmid: 21633052].
439 Kim YJ, Kim JE, Kim HS, et al. MDCT with coronal reconstruction: clinical benefit in evaluation of suspected acute appendicitis in pediatric patients. AJR American journal of roentgenology. Jan. 2009;192(1):150-2. [pmid: 19098194].
440 Kipper SL, Rypins EB, Evans DG, et al. Neutrophil-specific 99mTc-labeled anti-CD15 monoclonal antibody imaging for diagnosis of equivocal appendicitis. Journal of nuclear medicine : official publication, Society of Nuclear Medicine. Mar. 2000;41(3):449-55. [pmid: 10716317].
441 Kirkeby OJ, Riso C. Use of a computer system for diagnosing acute abdominal pain in a small hospital. Scandinavian journal of gastroenterology Supplement. 1987;128:174-6. [pmid: 3306896].
442 Kirkil C, Karabulut K, Aygen E, et al. Appendicitis scores may be useful in reducing the costs of treatment for right lower quadrant pain. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Jan. 2013;19(1):13-9. [pmid: 23588973].
443 Kitagawa M, Kotani T, Miyamoto Y, et al. Noncontrast and contrast enhanced computed tomography for diagnosing acute appendicitis: A retrospective study for the usefulness. Journal of radiology case reports. 2009;3(6):26-33. [pmid: 22470667].
444 Klein MD, Rabbani AB, Rood KD, et al. Three quantitative approaches to the diagnosis of abdominal pain in children: practical applications of decision theory. Journal of pediatric surgery. Sep. 2001;36(9):1375-80. [pmid: 11528609].
445 Kniskern JH, Eskin EM, Fletcher HS. Increasing accuracy in the diagnosis of acute appendicitis with modern diagnostic techniques. The American surgeon. Apr. 1986;52(4):222-5. [pmid: 3513683].
446 Ko YS, Lin LH, Chen DF. Laboratory aid and ultrasonography in the diagnosis of appendicitis in children. Zhonghua Minguo xiao er ke yi xue hui za zhi [Journal] Zhonghua Minguo xiao er ke yi xue hui. Nov–Dec. 1995;36(6):415-9. [pmid: 8592927].
447 Kokki H, Lintula H, Vanamo K, et al. Oxycodone vs placebo in children with undifferentiated abdominal pain: a randomized, double-blind clinical trial of the effect of analgesia on diagnostic accuracy. Archives of pediatrics & adolescent medicine. Apr. 2005;159(4):320-5. [pmid: 15809382].
448 Koksal H, Uysal B, Saribabicci R. The role of the Alvarado scoring system and ultrasonography in the diagnosis of acute appendicitis. Gazi Medical Journal. 2009;20(3):113-6.
449 Kollias J, Harries RH, Otto G, et al. Laparoscopic versus open appendicectomy for suspected appendicitis: a prospective study. The Australian and New Zealand journal of surgery. Dec. 1994;64(12):830-5. [pmid: 7980256].
450 Koning JL, Naheedy JH, Kruk PG. Diagnostic performance of contrast-enhanced MR for acute appendicitis and alternative causes of abdominal pain in children. [pmid: 24682520].
451 Konstantinidis KM, Anastasakou KA, Vorias MN, et al. A decade of laparoscopic appendectomy: presentation of 1,026 patients with suspected appendicitis treated in a single surgical department. Journal of laparoendoscopic & advanced surgical techniques Part A. Apr. 2008;18(2):248-58. [pmid: 18373452].
452 Koo HS, Kim HC, Yang DM, Kim SW, Park SJ, Ryu JK. Does computed tomography have any additional value after sonography in patients with suspected acute appendicitis?. [pmid: 23887949].
453 Korner H, Sondenaa K, Soreide JA, et al. The history is important in patients with suspected acute appendicitis. Digestive surgery. 2000;17(4):364-8. discussion 8–9. [pmid: 11053944].
454 Korner H, Soreide JA, Sondenaa K. Diagnostic accuracy of inflammatory markers in patients operated on for suspected acute appendicitis: a receiver operating characteristic curve analysis. The European journal of surgery. Acta chirurgica. Jul. 1999;165(7):679-85. [pmid: 10452263].
455 Kosloske AM, Love CL, Rohrer JE, et al. The diagnosis of appendicitis in children: outcomes of a strategy based on pediatric surgical evaluation. Pediatrics. Jan. 2004;113(1 Pt 1):29-34. [pmid: 14702443].
456 Kouame N, N’Goan-Domoua AM, N’Dri KJ, et al. The diagnostic value of indirect ultrasound signs during acute adult appendicitis. Diagnostic and interventional imaging. Mar. 2012;93(3):e24-8. [pmid: 22421290].
457 Kraemer M, Yang Q, Ohmann C. Classification of subpopulations with a minor and a major diagnostic problem in acute abdominal pain. Theoretical Surgery. 1993;8(1):6-14. PMID:.
458 Krishnamoorthi R, Ramarajan N, Wang NE, et al. Effectiveness of a staged US and CT protocol for the diagnosis of pediatric appendicitis: reducing radiation exposure in the age of ALARA. Radiology. Apr. 2011;259(1):231-9. [pmid: 21324843].
459 Kum CK, Sim EK, Goh PM, et al. Diagnostic laparoscopy: reducing the number of normal appendectomies. Diseases of the colon and rectum. Aug. 1993;36(8):763-6. [pmid: 8348867].
460 Kumar RV, Kumar RM, Pradeep Kumar NS, et al. Diagnostic value of C-reactive protein in suspected acute appendicitis--a prospective case control study. Indian journal of medical sciences. Sep. 2011;65(9):399-405. [pmid: 23508483].
461 Kurane SB, Sangolli MS, Gogate AS. A one year prospective study to compare and evaluate diagnostic accuracy of modified Alvarado score and ultrasonography in acute appendicitis, in adults. The Indian journal of surgery. Jun. 2008;70(3):125-9. [pmid: 23133039].
462 Kurzynski MW. Diagnosis of acute abdominal pain using a three-stage classifier. Computers in biology and medicine. 1987;17(1):19-27. [pmid: 3545663].
463 Kuster GG, Gilroy SB. The role of laparoscopy in the diagnosis of acute appendicitis. The American surgeon. Oct. 1992;58(10):627-9. [pmid: 1416436].
464 Kutasy B, Hunziker M, Laxamanadass G, et al. Increased incidence of negative appendectomy in childhood obesity. Pediatric surgery international. Oct. 2010;26(10):959-62. [pmid: 20640856].
465 Kutasy B, Laxamanadass G, Puri P. Is C-reactive protein a reliable test for suspected appendicitis in extremely obese children?. Pediatric surgery international. Jan. 2010;26(1):123-5. [pmid: 19855981].
466 Kwan KY, Nager AL. Diagnosing pediatric appendicitis: usefulness of laboratory markers. The American journal of emergency medicine. Nov. 2010;28(9):1009-15. [pmid: 20825931].
467 Kyriakidis AV, Alexandris I, Papoulia E, et al. C-reactive protein: Diagnostic aid in right lower quadrant abdominal pain. Annals of Gastroenterology. 2010;23(4):307-10. PMID:.
468 Laal M, Mardanloo A. Acute abdomen; pre and post-laparotomy diagnosis. International Journal of Collaborative Research on Internal Medicine and Public Health. 2009;1(5):157-65.
469 Lai V, Chan WC, Lau HY, et al. Diagnostic power of various computed tomography signs in diagnosing acute appendicitis. Clinical imaging. Jan–Feb. 2012;36(1):29-34. [pmid: 22226440].
470 Laine S, Rantala A, Gullichsen R, et al. Laparoscopic appendectomy-is it worthwhile? A prospective, randomized study in young women. Surgical endoscopy. Feb. 1997;11(2):95-7. [pmid: 9069134].
471 Laituri CA, Fraser JD, Aguayo P, et al. The lack of efficacy for oral contrast in the diagnosis of appendicitis by computed tomography. The Journal of surgical research. Sep. 2011;170(1):100-3. [pmid: 21470628].
472 Lameris W, van Randen A, Go PM, et al. Single and combined diagnostic value of clinical features and laboratory tests in acute appendicitis. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Sep. 2009;16(9):835-42. [pmid: 19689484].
473 Lamparelli MJ, Hoque HM, Pogson CJ, et al. A prospective evaluation of the combined use of the modified Alvarado score with selective laparoscopy in adult females in the management of suspected appendicitis. Annals of the Royal College of Surgeons of England. May. 2000;82(3):192-5. [pmid: 10858683].
474 Lander A. The role of imaging in children with suspected appendicitis: the UK perspective. Pediatric radiology. Jan. 2007;37(1):5-9. [pmid: 17102959].
475 Lane MJ, Katz DS, Ross BA, et al. Unenhanced helical CT for suspected acute appendicitis. AJR American journal of roentgenology. Feb. 1997;168(2):405-9. [pmid: 9016216].
476 Lane MJ, Liu DM, Huynh MD, et al. Suspected acute appendicitis: nonenhanced helical CT in 300 consecutive patients. Radiology. Nov. 1999;213(2):341-6. [pmid: 10551210].
477 Langenscheidt P, Lang C, Puschel W, et al. High rates of appendicectomy in a developing country: an attempt to contribute to a more rational use of surgical resources. The European journal of surgery. Acta chirurgica. Mar. 1999;165(3):248-52. [pmid: 10231659].
478 Larson JM, Peirce JC, Ellinger DM, et al. 1989 ARRS President’s Award. The validity and utility of sonography in the diagnosis of appendicitis in the community setting. AJR American journal of roentgenology. Oct. 1989;153(4):687-91. [pmid: 2672728].
479 Larsson PG, Henriksson G, Olsson M, et al. Laparoscopy reduces unnecessary appendicectomies and improves diagnosis in fertile women. A randomized study. Surgical endoscopy. Feb. 2001;15(2):200-2. [pmid: 11285968].
480 Latifi A, Labruto F, Kaiser S, et al. Does enteral contrast increase the accuracy of appendicitis diagnosis?. Radiologic technology. Mar–Apr. 2011;82(4):294-9. [pmid: 21406706].
481 Lau WY, Ho YC, Chu KW, et al. Leucocyte count and neutrophil percentage in appendicectomy for suspected appendicitis. The Australian and New Zealand journal of surgery. May. 1989;59(5):395-8. [pmid: 2730458].
482 Laurell H, Hansson LE, Gunnarsson U. Manifestations of acute appendicitis: a prospective study on acute abdominal pain. Digestive surgery. 2013;30(3):198-206. [pmid: 23838773].
483 Lawrence PC, Clifford PC, Taylor IF. Acute abdominal pain: computer aided diagnosis by non-medically qualified staff. Annals of the Royal College of Surgeons of England. Sep. 1987;69(5):233-4. [pmid: 3314636].
484 Lazarus E, Mayo-Smith WW, Mainiero MB, et al. CT in the evaluation of nontraumatic abdominal pain in pregnant women. Radiology. Sep. 2007;244(3):784-90. [pmid: 17709829].
485 Leaper DJ, Horrocks JC, Staniland JR, et al. Computer-assisted diagnosis of abdominal pain using “estimates” provided by clinicians. British medical journal. Nov. 11. 1972;4(5836):350-4. [pmid: 4629240].
486 Lee CC, Golub R, Singer AJ, et al. Routine versus selective abdominal computed tomography scan in the evaluation of right lower quadrant pain: a randomized controlled trial. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Feb. 2007;14(2):117-22. [pmid: 17192450].
487 Lee IK, Jung SE, Gorden DL, et al. The diagnostic criteria for right colonic diverticulitis: prospective evaluation of 100 patients. International journal of colorectal disease. Dec. 2008;23(12):1151-7. [pmid: 18704462].
488 Lee JH, Jeong YK, Hwang JC, et al. Graded compression sonography with adjuvant use of a posterior manual compression technique in the sonographic diagnosis of acute appendicitis. AJR American journal of roentgenology. Apr. 2002;178(4):863-8. [pmid: 11906864].
489 Lee JH, Jeong YK, Park KB, et al. Operator-dependent techniques for graded compression sonography to detect the appendix and diagnose acute appendicitis. AJR American journal of roentgenology. Jan. 2005;184(1):91-7. [pmid: 15615956].
490 Lee KH, Kim YH, Hahn S, et al. Added value of coronal reformations for duty radiologists and for referring physicians or surgeons in the CT diagnosis of acute appendicitis. Korean journal of radiology : official journal of the Korean Radiological Society. Apr–Jun. 2006;7(2):87-96. [pmid: 16799269].
491 Lee KH, Kim YH, Hahn S, et al. Computed tomography diagnosis of acute appendicitis: advantages of reviewing thin-section datasets using sliding slab average intensity projection technique. Investigative radiology. Jul. 2006;41(7):579-85. [pmid: 16772851].
492 Lee MW, Kim YJ, Jeon HJ, et al. Sonography of acute right lower quadrant pain: importance of increased intraabdominal fat echo. AJR American journal of roentgenology. Jan. 2009;192(1):174-9. [pmid: 19098198].
493 Lee SL, Walsh AJ, Ho HS. Computed tomography and ultrasonography do not improve and may delay the diagnosis and treatment of acute appendicitis. Arch Surg. May. 2001;136(5):556-62. [pmid: 11343547].
494 Lee YH, Hu PJ, Cheng TH, et al. A preclustering-based ensemble learning technique for acute appendicitis diagnoses. Artificial intelligence in medicine. Jun. 2013;58(2):115-24. [pmid: 23623208].
495 Leeuwenburgh MM, Jensch S, Gratama JW, Spilt A, Wiarda BM, Van Es HW, Cobben LP, Bossuyt PM, Boermeester MA, Stoker J. MRI features associated with acute appendicitis. [pmid: 24013847].
496 Leeuwenburgh MM, Stockmann HB, Bouma WH, Houdijk AP, Verhagen MF, Vrouenraets B, Cobben LP, Bossuyt PM, Stoker J, Boermeester MA. A simple clinical decision rule to rule out appendicitis in patients with nondiagnostic ultrasound results. [pmid: 24842498].
497 Leeuwenburgh MM, Wiarda BM, Jensch S, van Es HW, Stockmann HB, Gratama JW, Cobben LP, Bossuyt PM, Boermeester MA, Stoker J. Accuracy and interobserver agreement between MR-non-expert radiologists and MR-experts in reading MRI for suspected appendicitis. [pmid: 24168926].
498 Leeuwenburgh MM, Wiezer MJ, Wiarda BM, Bouma WH, Phoa SS, Stockmann HB, Jensch S, Bossuyt PM, Boermeester MA, Stoker J. Accuracy of MRI compared with ultrasound imaging and selective use of CT to discriminate simple from perforated appendicitis. [pmid: 24272981].
499 Leeuwenburgh MM, Wiarda BM, Wiezer MJ, et al. Comparison of imaging strategies with conditional contrast-enhanced CT and unenhanced MR imaging in patients suspected of having appendicitis: a multicenter diagnostic performance study. Radiology. Jul. 2013;268(1):135-43. [pmid: 23481162].
500 Lehnert BE, Gross JA, Linnau KF, et al. Utility of ultrasound for evaluating the appendix during the second and third trimester of pregnancy. Emergency radiology. Aug. 2012;19(4):293-9. [pmid: 22370694].
501 Lehtimaki T, Juvonen P, Valtonen H, et al. Impact of routine contrast-enhanced CT on costs and use of hospital resources in patients with acute abdomen. Results of a randomised clinical trial. European radiology. Sep. 2013;23(9):2538-45. [pmid: 23715771].
502 Lemieux P, Rheaume P, Levesque I, et al. Laparoscopic appendectomy in pregnant patients: a review of 45 cases. Surgical endoscopy. Aug. 2009;23(8):1701-5. [pmid: 19057956].
503 Lessin MS, Chan M, Catallozzi M, et al. Selective use of ultrasonography for acute appendicitis in children. American journal of surgery. Mar. 1999;177(3):193-6. [pmid: 10219853].
504 Levy RD, Degiannis E, Kantarovsky A, et al. Audit of acute appendicitis in a black South African population. South African journal of surgery Suid-Afrikaanse tydskrif vir chirurgie. Nov. 1997;35(4):198-202. [pmid: 9540398].
505 Li YC, Chen CY, Huang MY, et al. Significant change between primary and repeated serum laboratory tests at different time points in pediatric appendicitis. European journal of emergency medicine : official journal of the European Society for Emergency Medicine. Dec. 2012;19(6):395-9. [pmid: 22186150].
506 Lim HK, Bae SH, Seo GS. Diagnosis of acute appendicitis in pregnant women: value of sonography. AJR American journal of roentgenology. Sep. 1992;159(3):539-42. [pmid: 1503019].
507 Limchareon S, Wongsuttilert A, Boonyarit A. Efficacy of Ultrasonography in Evaluation of Suspected Appendicitis in Pediatric Population. Journal of Medical Ultrasound. 2014. ((Limchareon S., sornsupha@hotmail.com; Wongsuttilert A.) Division of Radiology and Nuclear Medicine, Faculty of Medicine, Burapha University, Chonburi, Thailand). PMID:.
508 Limpawattanasiri C. Alvarado score for the acute appendicitis in a provincial hospital. Journal of the Medical Association of Thailand. Chotmaihet thangphaet. Apr. 2011;94(4):441-9. [pmid: 21591529].
509 Lin CH, Chen JH, Li TC, et al. Children presenting at the emergency department with right lower quadrant pain. The Kaohsiung journal of medical sciences. Jan. 2009;25(1):1-9. [pmid: 19289311].
510 Lin KC, Wu HP, Huang CY, et al. Discriminant analysis of serum inflammatory biomarkers which differentiate pediatric appendicitis from other acute abdominal diseases. Acta paediatrica Taiwanica = Taiwan er ke yi xue hui za zhi. May–Jun. 2007;48(3):125-30. [pmid: 17912983].
511 Lin KH, Leung WS, Wang CP, et al. Cost analysis of management in acute appendicitis with CT scanning under a hospital global budgeting scheme. Emergency medicine journal : EMJ. Mar. 2008;25(3):149-52. [pmid: 18299362].
512 Lin WC, Lin CH. Re-appraising the role of sonography in pediatric acute abdominal pain. Iranian journal of pediatrics. Apr. 2013;23(2):177-82. [pmid: 23724179].
513 Lin WY, Kao CH, Lin HT, et al. 99Tcm-HMPAO-labelled white blood cell scans to detect acute appendicitis in older patients with an atypical clinical presentation. Nuclear medicine communications. Jan. 1997;18(1):75-8. [pmid: 9061706].
514 Lindelius A, Pettersson H, Adami J, et al. Patient factors influencing the effect of surgeon-performed ultrasound on the acute abdomen. Critical ultrasound journal. Dec. 2010;2(3):97-105. [pmid: 21290005].
515 Lindelius A, Torngren S, Nilsson L, et al. Randomized clinical trial of bedside ultrasound among patients with abdominal pain in the emergency department: impact on patient satisfaction and health care consumption. Scandinavian journal of trauma, resuscitation and emergency medicine. 2009;17:60. [pmid: 19941671].
516 Lindelius A, Torngren S, Pettersson H, et al. Role of surgeon-performed ultrasound on further management of patients with acute abdominal pain: a randomised controlled clinical trial. Emergency medicine journal : EMJ. Aug. 2009;26(8):561-6. [pmid: 19625549].
517 Lindelius A, Torngren S, Sonden A, et al. Impact of surgeon-performed ultrasound on diagnosis of abdominal pain. Emergency medicine journal : EMJ. Aug. 2008;25(8):486-91. [pmid: 18660395].
518 Linos DA, Vlitaki M, Peppas G, et al. Laparoscopy in the context of lower abdominal pain in young women. Journal of laparoendoscopic & advanced surgical techniques Part A. Feb. 1999;9(1):39-43. [pmid: 10194691].
519 Lintula H, Kokki H, Kettunen R, et al. Appendicitis score for children with suspected appendicitis. A randomized clinical trial. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Nov. 2009;394(6):999-1004. [pmid: 18841382].
520 Lintula H, Kokki H, Pulkkinen J, et al. Diagnostic score in acute appendicitis. Validation of a diagnostic score (Lintula score) for adults with suspected appendicitis. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Jun. 2010;395(5):495-500. [pmid: 20379739].
521 Lintula H, Pesonen E, Kokki H, et al. A diagnostic score for children with suspected appendicitis. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Apr. 2005;390(2):164-70. [pmid: 15723233].
522 Loke P, Tantoco J, Ferguson P, et al. Accuracy of inter-hospital paediatric appendicitis referrals. Emergency medicine Australasia : EMA. Aug. 2012;24(4):414-9. [pmid: 22862759].
523 Lopez PP, Cohn SM, Popkin CA, et al. The use of a computed tomography scan to rule out appendicitis in women of childbearing age is as accurate as clinical examination: a prospective randomized trial. The American surgeon. Dec. 2007;73(12):1232-6. [pmid: 18186378].
524 Lowe LH, Draud KS, Hernanz-Schulman M, et al. Nonenhanced limited CT in children suspected of having appendicitis: prospective comparison of attending and resident interpretations. Radiology. Dec. 2001;221(3):755-9. [pmid: 11719672].
525 Lowe LH, Penney MW, Scheker LE, et al. Appendicolith revealed on CT in children with suspected appendicitis: how specific is it in the diagnosis of appendicitis?. AJR American journal of roentgenology. Oct. 2000;175(4):981-4. [pmid: 11000148].
526 Lowe LH, Penney MW, Stein SM, et al. Unenhanced limited CT of the abdomen in the diagnosis of appendicitis in children: comparison with sonography. AJR American journal of roentgenology. Jan. 2001;176(1):31-5. [pmid: 11133533].
527 Lycopoulou L, Mamoulakis C, Hantzi E, et al. Serum amyloid A protein levels as a possible aid in the diagnosis of acute appendicitis in children. Clinical chemistry and laboratory medicine : CCLM/FESCC. 2005;43(1):49-53. [pmid: 15653442].
528 Lyons D, Waldron R, Ryan T, et al. An evaluation of the clinical value of the leucocyte count and sequential counts in suspected acute appendicitis. The British journal of clinical practice. Jun. 1987;41(6):794-6. [pmid: 3446277].
529 Macklin CP, Radcliffe GS, Merei JM, et al. A prospective evaluation of the modified Alvarado score for acute appendicitis in children. Annals of the Royal College of Surgeons of England. May. 1997;79(3):203-5. [pmid: 9196342].
530 Mahadevan M, Graff L. Prospective randomized study of analgesic use for ED patients with right lower quadrant abdominal pain. The American journal of emergency medicine. Nov. 2000;18(7):753-6. [pmid: 11103723].
531 Majewski W. Diagnostic laparoscopy for the acute abdomen and trauma. Surgical endoscopy. Oct. 2000;14(10):930-7. [pmid: 11080406].
532 Makanjuola D. The value of ultrasonography in the x-ray negative non-traumatic acute abdomen. West African journal of medicine. Apr–Jun. 1998;17(2):75-80. [pmid: 9715110].
533 Malik AA, Wani NA. Continuing diagnostic challenge of acute appendicitis: evaluation through modified Alvarado score. The Australian and New Zealand journal of surgery. Jul. 1998;68(7):504-5. [pmid: 9669364].
534 Mallick MS. Appendicitis in pre-school children: a continuing clinical challenge. A retrospective study. International journal of surgery (London, England). Oct. 2008;6(5):371-3. [pmid: 18675602].
535 Malone AJ Jr, Wolf CR, Malmed AS, et al. Diagnosis of acute appendicitis: value of unenhanced CT. AJR American journal of roentgenology. Apr. 1993;160(4):763-6. [pmid: 8456661].
536 Maluccio MA, Covey AM, Weyant MJ, et al. A prospective evaluation of the use of emergency department computed tomography for suspected acute appendicitis. Surgical infections. Fall. 2001;2(3):205-11. discussion 11–4. [pmid: 12593710].
537 Man E, Simonka Z, Varga A, Rarosi F, Lazar G. Impact of the alvarado score on the diagnosis of acute appendicitis: comparing clinical judgment, alvarado score, and a new modified score in suspected appendicitis: a prospective, randomized clinical trial. [pmid: 24705731].
538 Mandeville K, Pottker T, Bulloch B, et al. Using appendicitis scores in the pediatric ED. The American journal of emergency medicine. Nov. 2011;29(9):972-7. [pmid: 20674221].
539 Marchand A, Van Lente F, Galen RS. The assessment of laboratory tests in the diagnosis of acute appendicitis. American journal of clinical pathology. Sep. 1983;80(3):369-74. [pmid: 6881101].
540 Mardan MA, Mufti TS, Khattak IU, et al. Role of ultrasound in acute appendicitis. Journal of Ayub Medical College, Abbottabad : JAMC. Jul–Sep. 2007;19(3):72-9. [pmid: 18444596].
541 Mariadason JG, Wang WN, Wallack MK, et al. Negative appendicectomy rate as a quality metric in the management of appendicitis: impact of computed tomography, Alvarado score and the definition of negative appendicectomy. Annals of the Royal College of Surgeons of England. Sep. 2012;94(6):395-401. [pmid: 22943328].
542 Markar SRPD, Penna M, Karthikesalingam A, Bulathsinghala BK, Kumaran K, Hashemi M, Fernando R. A comparative international study on the management of acute appendicitis between a developed country and a middle income country. [pmid: 24480238].
543 Markar SR, Karthikesalingam A, Cunningham J, et al. Increased use of pre-operative imaging and laparoscopy has no impact on clinical outcomes in patients undergoing appendicectomy. Annals of the Royal College of Surgeons of England. Nov. 2011;93(8):620-3. [pmid: 22041239].
544 Markar SR, Karthikesalingam A, Falzon A, et al. The diagnostic value of neutrophil: lymphocyte ratio in adults with suspected acute appendicitis. Acta chirurgica Belgica. Sep–Oct. 2010;110(5):543-7. [pmid: 21158332].
545 Masselli G, Brunelli R, Casciani E, et al. Acute abdominal and pelvic pain in pregnancy: MR imaging as a valuable adjunct to ultrasound?. Abdominal imaging. Oct. 2011;36(5):596-603. [pmid: 21052664].
546 Masters K, Levine BA, Gaskill HV, et al. Diagnosing appendicitis during pregnancy. American journal of surgery. Dec. 1984;148(6):768-71. [pmid: 6507749].
547 McAdam WA, Brock BM, Armitage T, et al. Twelve years’ experience of computer-aided diagnosis in a district general hospital. Annals of the Royal College of Surgeons of England. Mar. 1990;72(2):140-6. [pmid: 2185682].
548 McCartan DP, Fleming FJ, Grace PA. The management of right iliac fossa pain - is timing everything?. The surgeon : journal of the Royal Colleges of Surgeons of Edinburgh and Ireland. Aug. 2010;8(4):211-7. [pmid: 20569941].
549 McCloskey K, Grover S, Vuillermin P, et al. Ovarian torsion among girls presenting with abdominal pain: a retrospective cohort study. Emergency medicine journal : EMJ. Jan. 2013;30(1):e11. [pmid: 22345311].
550 McCombe AW, Gunn AA. Laparotomy in the acute abdomen. BMJ. Dec. 7. 1991;303(6815):1476. [pmid: 1773162].
551 McDonald GP, Pendarvis DP, Wilmoth R, et al. Influence of preoperative computed tomography on patients undergoing appendectomy. The American surgeon. Nov. 2001;67(11):1017-21. [pmid: 11730216].
552 McDonough J, Stasik C 3rd, Piontkowsky Dt, et al. Can appendiceal CT scanning be utilized effectively in widespread general surgical practice?. The American surgeon. Oct. 2002;68(10):917-21. [pmid: 12412726].
553 McGory ML, Zingmond DS, Nanayakkara D, et al. Negative appendectomy rate: influence of CT scans. The American surgeon. Oct. 2005;71(10):803-8. [pmid: 16468523].
554 McKay R, Shepherd J. The use of the clinical scoring system by Alvarado in the decision to perform computed tomography for acute appendicitis in the ED. The American journal of emergency medicine. Jun. 2007;25(5):489-93. [pmid: 17543650].
555 Mekhail P, Naguib N, Yanni F, et al. Appendicitis in paediatric age group: correlation between preoperative inflammatory markers and postoperative histological diagnosis. African journal of paediatric surgery : AJPS. Sep–Dec. 2011;8(3):309-12. [pmid: 22248897].
556 Meltzer AC, Baumann BM, Chen EH, et al. Poor sensitivity of a modified Alvarado score in adults with suspected appendicitis. Annals of emergency medicine. Aug. 2013;62(2):126-31. [pmid: 23623557].
557 Memisoglu K, Karip B, Mestan M, et al. The value of preoperative diagnostic tests in acute appendicitis, retrospective analysis of 196 patients. World journal of emergency surgery : WJES. 2010;5:5. [pmid: 20181221].
558 Memon ZA, Irfan S, Fatima K, et al. Acute appendicitis: diagnostic accuracy of Alvarado scoring system. Asian journal of surgery/Asian Surgical Association. Oct. 2013;36(4):144-9. [pmid: 23726829].
559 Mendelson RM, Lindsell DR. Ultrasound examination of the paediatric “acute abdomen”: preliminary findings. The British journal of radiology. Apr. 1987;60(712):414-6. [pmid: 3555679].
560 Mentes O, Eryilmaz M, Harlak A, et al. Can D-dimer become a new diagnostic parameter for acute appendicitis?. The American journal of emergency medicine. Sep. 2009;27(7):765-9. [pmid: 19683101].
561 Mentes O, Eryilmaz M, Harlak A, et al. The value of serum fibrinogen level in the diagnosis of acute appendicitis. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Sep. 2012;18(5):384-8. [pmid: 23188598].
562 Michalowski W, Rubin S, Slowinski R, et al. Triage of the child with abdominal pain: A clinical algorithm for emergency patient management. Paediatrics & child health. Jan. 2001;6(1):23-8. [pmid: 20084204].
563 Mihmanli M, Uysalol M, Coskun H, et al. The value of 5-hydroxyindolacetic acid levels in spot urine in the diagnosis of acute appendicitis. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Jul. 2004;10(3):173-6. [pmid: 15286888].
564 Mikaelsson C, Arnbjornsson E. The value of C-reactive protein (CRP) determinations in patients with suspected acute appendicitis. Annales chirurgiae et gynaecologiae. 1984;73(5):281-4. [pmid: 6524861].
565 Millet I, Alili C, Bouic-Pages E, Curros-Doyon F, Nagot N, Taourel P. Journal club: Acute abdominal pain in elderly patients: effect of radiologist awareness of clinicobiologic information on CT accuracy. [pmid: 24261352].
566 Mills AM, Huckins DS, Kwok H, et al. Diagnostic characteristics of S100A8/A9 in a multicenter study of patients with acute right lower quadrant abdominal pain. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Jan. 2012;19(1):48-55. [pmid: 22221415].
567 Mishra DS, Magu S, Sharma N, et al. Imaging in acute abdomen. Indian journal of pediatrics. Jan. 2003;70(1):15-9. [pmid: 12619946].
568 Miskowiak J, Burcharth F. The white cell count in acute appendicitis. A prospective blind study. Danish medical bulletin. May. 1982;29(4):210-1. [pmid: 7105849].
569 Mittal MK, Dayan PS, Macias CG, et al. Performance of ultrasound in the diagnosis of appendicitis in children in a multicenter cohort. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Jul. 2013;20(7):697-702. [pmid: 23859583].
570 Mittal VK, Goliath J, Sabir M, et al. Advantages of focused helical computed tomographic scanning with rectal contrast only vs triple contrast in the diagnosis of clinically uncertain acute appendicitis: a prospective randomized study. Arch Surg. May. 2004;139(5):495-9. discussion 9–500. [pmid: 15136349].
571 Moberg AC, Ahlberg G, Leijonmarck CE, et al. Diagnostic laparoscopy in 1043 patients with suspected acute appendicitis. The European journal of surgery. Acta chirurgica. Nov. 1998;164(11):833-40. discussion 41. [pmid: 9845129].
572 Moberg AC, Montgomery A. Introducing diagnostic laparoscopy for patients with suspected acute appendicitis. Surgical endoscopy. Oct. 2000;14(10):942-7. [pmid: 11080408].
573 Mohammed AA, Daghman NA, Aboud SM, et al. The diagnostic value of C-reactive protein, white blood cell count and neutrophil percentage in childhood appendicitis. Saudi medical journal. Sep. 2004;25(9):1212-5. [pmid: 15448768].
574 Mohebbi HA, Mehrvarz S, Kashani MT, et al. Predicting negative appendectomy by using demographic, clinical, and laboratory parameters: a cross-sectional study. International journal of surgery (London, England). Apr. 2008;6(2):115-8. [pmid: 18289949].
575 Monib S, Donkol RH, Hassan A, et al. Distinct sonographic features of acute appendicitis in sickle cell disease. Annals of Saudi medicine. Jan–Feb. 2013;33(1):22-7. [pmid: 23458936].
576 Moore J, Bartholomeusz D, Wycherley A, et al. 99mTechnetium labelled leucocyte scanning in acute lower abdominal pain: can it reduce the negative appendectomy rate?. The Australian and New Zealand journal of surgery. Jun. 1995;65(6):403-5. [pmid: 7786263].
577 Moore MM, Gustas CN, Choudhary AK, et al. MRI for clinically suspected pediatric appendicitis: an implemented program. Pediatric radiology. Sep. 2012;42(9):1056-63. [pmid: 22677910].
578 Morino M, Pellegrino L, Castagna E, et al. Acute nonspecific abdominal pain: A randomized, controlled trial comparing early laparoscopy versus clinical observation. Annals of surgery. Dec. 2006;244(6):881-6. discussion 6–8. [pmid: 17122613].
579 Morris KT, Kavanagh M, Hansen P, et al. The rational use of computed tomography scans in the diagnosis of appendicitis. American journal of surgery. May. 2002;183(5):547-50. [pmid: 12034390].
580 Mosayebi Alizadeh SA, Alasti A, Nobaveh AA, Ghazavi A, Okhovat M, Rafiei M. Is CD19 an immunological diagnostic marker for acute appendicitis?. [pmid: 24375063].
581 Moteki T, Ohya N, Horikoshi H. Prospective examination of patients suspected of having appendicitis using new computed tomography criteria including “maximum depth of intraluminal appendiceal fluid greater than 2.6 mm”. Journal of computer assisted tomography. May–Jun. 2009;33(3):383-9. [pmid: 19478631].
582 Mourad J, Elliott JP, Erickson L, et al. Appendicitis in pregnancy: new information that contradicts long-held clinical beliefs. American journal of obstetrics and gynecology. May. 2000;182(5):1027-9. [pmid: 10819817].
583 Mullins ME, Kircher MF, Ryan DP, et al. Evaluation of suspected appendicitis in children using limited helical CT and colonic contrast material. AJR American journal of roentgenology. Jan. 2001;176(1):37-41. [pmid: 11133535].
584 Mun S, Ernst RD, Chen K, et al. Rapid CT diagnosis of acute appendicitis with IV contrast material. Emergency radiology. Mar. 2006;12(3):99-102. [pmid: 16362812].
585 Musunuru S, Chen H, Rikkers LF, et al. Computed tomography in the diagnosis of acute appendicitis: definitive or detrimental?. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Nov. 2007;11(11):1417-21. discussion 21–2. [pmid: 17701439].
586 Mutter D, Navez B, Gury JF, et al. Value of microlaparoscopy in the diagnosis of right iliac fossa pain. American journal of surgery. Oct. 1998;176(4):370-2. [pmid: 9817258].
587 Myers E, Kavanagh DO, Ghous H, et al. The impact of evolving management strategies on negative appendicectomy rate. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Aug. 2010;12(8):817-21. [pmid: 19508509].
588 Naffaa LN, Ishak GE, Haddad MC. The value of contrast-enhanced helical CT scan with rectal contrast enema in the diagnosis of acute appendicitis. Clinical imaging. Jul–Aug. 2005;29(4):255-8. [pmid: 15967316].
589 Nana AM, Ouandji CN, Simoens C, et al. Laparoscopic appendectomies: results of a monocentric prospective and non-randomized study. Hepato-gastroenterology. Jun. 2007;54(76):1146-52. [pmid: 17629058].
590 Naoum JJ, Mileski WJ, Daller JA, et al. The use of abdominal computed tomography scan decreases the frequency of misdiagnosis in cases of suspected appendicitis. American journal of surgery. Dec. 2002;184(6):587-9. discussion 9–90. [pmid: 12488178].
591 Nasiri S, Mohebbi F, Sodagari N, et al. Diagnostic values of ultrasound and the Modified Alvarado Scoring System in acute appendicitis. International journal of emergency medicine. 2012;5(1):26. [pmid: 22673121].
592 Nathan RO, Blackmore CC, Jarvik JG. Therapeutic impact of CT of the appendix in a community hospital emergency department. AJR American journal of roentgenology. Oct. 2008;191(4):1102-6. [pmid: 18806151].
593 Nautiyal H, Ahmad S, Keshwani NK, et al. Combined use of modified Alvarado score and USG in decreasing negative appendicectomy rate. The Indian journal of surgery. Feb. 2010;72(1):42-8. [pmid: 23133203].
594 Navarro DA, Weber PM, Kang IY, et al. Indium-111 leukocyte imaging in appendicitis. AJR American journal of roentgenology. Apr. 1987;148(4):733-6. [pmid: 3493655].
595 Navarro DA, Weber PM. Indium 111 imaging in appendicitis. Seminars in ultrasound, CT, and MR. Aug. 1989;10(4):321-5. [pmid: 2516745].
596 Navarro Fernandez JA, Tarraga Lopez PJ, Rodriguez Montes JA, et al. Validity of tests performed to diagnose acute abdominal pain in patients admitted at an emergency department. Revista espanola de enfermedades digestivas : organo oficial de la Sociedad Espanola de Patologia Digestiva. Sep. 2009;101(9):610-8. [pmid: 19803663].
597 Nelson DW, Causey MW, Porta CR, et al. Examining the relevance of the physician’s clinical assessment and the reliance on computed tomography in diagnosing acute appendicitis. American journal of surgery. Apr. 2013;205(4):452-6. [pmid: 23388421].
598 Neufeld D, Vainrib M, Buklan G, et al. Management of acute appendicitis: an imaging strategy in children. Pediatric surgery international. Feb. 2010;26(2):167-71. [pmid: 19844725].
599 Ng CS, Palmer CR. Analysis of diagnostic confidence and diagnostic accuracy: a unified framework. The British journal of radiology. Mar. 2007;80(951):152-60. [pmid: 17329682].
600 Ng CS, Palmer CR. Analysis of diagnostic confidence: application to data from a prospective randomized controlled trial of CT for acute abdominal pain. Acta Radiol. May. 2010;51(4):368-74. [pmid: 20350244].
601 Ng CS, Watson CJ, Palmer CR, et al. Evaluation of early abdominopelvic computed tomography in patients with acute abdominal pain of unknown cause: prospective randomised study. BMJ. Dec. 14. 2002;325(7377):1387. [pmid: 12480851].
602 Ng S, Fleming FJ, Drumm J, et al. Current trends in the management of acute appendicitis. Irish journal of medical science. Jun. 2008;177(2):121-5. [pmid: 18259838].
603 Ngim CF, Quek KF, Dhanoa A, Khoo JJ, Vellusamy M, Ng CS. Pediatric Appendicitis in a Developing Country: What are the Clinical Predictors and Outcome of Perforation?. [pmid: 25063462].
604 Niedzielski J, Miodek M, Sokal J, et al. Ultrasound imaging in children with acute abdominal pain - Can it help to decrease the rate of negative appendectomies?. Clinical and Experimental Medical Letters. 2010;51(3–4):221-6. PMID:.
605 Niekel RA, Lampmann LE. Graded compression sonography in acute appendicitis. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Oct. 1986;145(4):441-5. [pmid: 3022347].
606 Nordback I, Harju E. Inflammation parameters in the diagnosis of acute appendicitis. Acta chirurgica Scandinavica. Jan. 1988;154(1):43-8. [pmid: 3354283].
607 Nshuti R, Kruger D, Luvhengo TE. Clinical presentation of acute appendicitis in adults at the Chris Hani Baragwanath academic hospital. [pmid: 24533851].
608 Nural MS, Ceyhan M, Baydin A, et al. The role of ultrasonography in the diagnosis and management of non-traumatic acute abdominal pain. Internal and emergency medicine. Dec. 2008;3(4):349-54. [pmid: 18443745].
609 Ohmann C, Franke C, Yang Q. Clinical benefit of a diagnostic score for appendicitis: results of a prospective interventional study. German Study Group of Acute Abdominal Pain. Arch Surg. Sep. 1999;134(9):993-6. [pmid: 10487595].
610 Ohmann C, Moustakis V, Yang Q, et al. Evaluation of automatic knowledge acquisition techniques in the diagnosis of acute abdominal pain. Acute Abdominal Pain Study Group. Artificial intelligence in medicine. Feb. 1996;8(1):23-36. [pmid: 8963379].
611 Olsen JB, Myren CJ, Haahr PE. Randomized study of the value of laparoscopy before appendicectomy. The British journal of surgery. Jul. 1993;80(7):922-3. [pmid: 8369940].
612 Oncel M, Degirmenci B, Demirhan N, et al. Is the use of plain abdominal radiographs (PAR) a necessity for all patients with suspected acute appendicitis in emergency services?. Current surgery. May–Jun. 2003;60(3):296-300. [pmid: 14972260].
613 Ooms HW, Koumans RK, Ho Kang You PJ, et al. Ultrasonography in the diagnosis of acute appendicitis. The British journal of surgery. Mar. 1991;78(3):315-8. [pmid: 2021847].
614 Oosterhuis WP, Zwinderman AH, Teeuwen M, et al. C reactive protein in the diagnosis of acute appendicitis. The European journal of surgery. Acta chirurgica. Feb. 1993;159(2):115-9. [pmid: 8098625].
615 Ortega-Deballon P, Ruiz de Adana-Belbel JC, Hernandez-Matias A, et al. Usefulness of laboratory data in the management of right iliac fossa pain in adults. Diseases of the colon and rectum. Jul. 2008;51(7):1093-9. [pmid: 18484138].
616 Orth RC, Guillerman RP, Zhang W, Masand P, Bisset GS 3rd. Prospective comparison of MR imaging and US for the diagnosis of pediatric appendicitis. [pmid: 24646110].
617 O’Shea JS, Bishop ME, Alario AJ, et al. Diagnosing appendicitis in children with acute abdominal pain. Pediatric emergency care. Sep. 1988;4(3):172-6. [pmid: 3186519].
618 Oto A, Ernst RD, Ghulmiyyah LM, et al. MR imaging in the triage of pregnant patients with acute abdominal and pelvic pain. Abdominal imaging. Mar–Apr. 2009;34(2):243-50. [pmid: 18330616].
619 Oto A, Ernst RD, Shah R, et al. Right-lower-quadrant pain and suspected appendicitis in pregnant women: evaluation with MR imaging--initial experience. Radiology. Feb. 2005;234(2):445-51. [pmid: 15591434].
620 Owen TD, Williams H, Stiff G, et al. Evaluation of the Alvarado score in acute appendicitis. Journal of the Royal Society of Medicine. Feb. 1992;85(2):87-8. [pmid: 1489366].
621 Ozguner I, Kizilgun M, Karaman A, et al. Are neutrophil CD64 expression and interleukin-6 early useful markers for diagnosis of acute appendicitis?. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al]. Zeitschrift fur Kinderchirurgie. Apr. 2014;24(2):179-83. [pmid: 23757034].
622 Ozkan S, Duman A, Durukan P, Yildirim A, Ozbakan O. The accuracy rate of Alvarado score, ultrasonography, and computerized tomography scan in the diagnosis of acute appendicitis in our center. [pmid: 24909462].
623 Paajanen H, Mansikka A, Laato M, et al. Are serum inflammatory markers age dependent in acute appendicitis?. Journal of the American College of Surgeons. Mar. 1997;184(3):303-8. [pmid: 9060929].
624 Paajanen H, Mansikka A, Laato M, et al. Novel serum inflammatory markers in acute appendicitis. Scandinavian journal of clinical and laboratory investigation. 2002;62(8):579-84. [pmid: 12564616].
625 Paajanen H, Somppi E. Early childhood appendicitis is still a difficult diagnosis. Acta paediatrica (Oslo, Norway : 1992). Apr. 1996;85(4):459-62. [pmid: 8740305].
626 Pacharn P, Ying J, Linam LE, et al. Sonography in the evaluation of acute appendicitis: are negative sonographic findings good enough?. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Dec. 2010;29(12):1749-55. [pmid: 21098847].
627 Pakaneh MA, Fazeli MS, Ghanaati H, et al. Non-contrast spiral computed tomography in diagnosis of acute appendicitis. Iranian Journal of Radiology. 2008;5(1):1-6. PMID:.
628 Panagiotopoulou IG, Parashar D, Lin R, et al. The diagnostic value of white cell count, C-reactive protein and bilirubin in acute appendicitis and its complications. Annals of the Royal College of Surgeons of England. Apr. 2013;95(3):215-21. [pmid: 23827295].
629 Paranjape C, Dalia S, Pan J, et al. Appendicitis in the elderly: a change in the laparoscopic era. Surgical endoscopy. May. 2007;21(5):777-81. [pmid: 17285390].
630 Park HC, Jang MY, Kim IG, et al. Distal appendiceal dilatation in equivocal appendicitis may be a useful sign for prediction of normal appendix. The American surgeon. Feb. 2010;76(2):211-4. [pmid: 20336903].
631 Park JS, Jeong JH, Lee JI, et al. Accuracies of diagnostic methods for acute appendicitis. The American surgeon. Jan. 2013;79(1):101-6. [pmid: 23317620].
632 Partrick DA, Janik JE, Janik JS, et al. Increased CT scan utilization does not improve the diagnostic accuracy of appendicitis in children. Journal of pediatric surgery. May. 2003;38(5):659-62. [pmid: 12720164].
633 Passalaqua AM, Klein RL, Wegener WA, et al. Diagnosing suspected acute nonclassic appendicitis with sulesomab, a radiolabeled antigranulocyte antibody imaging agent. Journal of pediatric surgery. Sep. 2004;39(9):1338-44. [pmid: 15359387].
634 Paulson EK, Harris JP, Jaffe TA, et al. Acute appendicitis: added diagnostic value of coronal reformations from isotropic voxels at multi-detector row CT. Radiology. Jun. 2005;235(3):879-85. [pmid: 15833993].
635 Pearl RH, Hale DA, Molloy M, et al. Pediatric appendectomy. Journal of pediatric surgery. Feb. 1995;30(2):173-8. discussion 8–81. [pmid: 7738734].
636 Peck J, Peck A, Peck C. The clinical role of noncontrast helical computed tomography in the diagnosis of acute appendicitis. American journal of surgery. Aug. 2000;180(2):133-6. [pmid: 11044529].
637 Pedrosa I, Lafornara M, Pandharipande PV, et al. Pregnant patients suspected of having acute appendicitis: effect of MR imaging on negative laparotomy rate and appendiceal perforation rate. Radiology. Mar. 2009;250(3):749-57. [pmid: 19244044].
638 Pedrosa I, Levine D, Eyvazzadeh AD, et al. MR imaging evaluation of acute appendicitis in pregnancy. Radiology. Mar. 2006;238(3):891-9. [pmid: 16505393].
639 de Peixoto RO, Nunes TA, Gomes CA. Indices of diagnostic abdominal ultrasonography in acute appendicitis: influence of gender and physical constitution, time evolution of the disease and experience of radiologist. Revista do Colegio Brasileiro de Cirurgioes. Mar–Apr. 2011;38(2):105-11. [pmid: 21710048].
640 Peletti AB, Baldisserotto M. Optimizing US examination to detect the normal and abnormal appendix in children. Pediatric radiology. Nov. 2006;36(11):1171-6. [pmid: 17004079].
641 Peltola H, Ahlqvist J, Rapola J, et al. C-reactive protein compared with white blood cell count and erythrocyte sedimentation rate in the diagnosis of acute appendicitis in children. Acta chirurgica Scandinavica. Jan. 1986;152:55-8. [pmid: 3953219].
642 Pena BM, Taylor GA, Fishman SJ, et al. Effect of an imaging protocol on clinical outcomes among pediatric patients with appendicitis. Pediatrics. Dec. 2002;110(6):1088-93. [pmid: 12456904].
643 Pena BM, Taylor GA, Lund DP, et al. Effect of computed tomography on patient management and costs in children with suspected appendicitis. Pediatrics. Sep. 1999;104(3 Pt 1):440-6. [pmid: 10469767].
644 Pena BM, Taylor GA. Radiologists’ confidence in interpretation of sonography and CT in suspected pediatric appendicitis. AJR American journal of roentgenology. Jul. 2000;175(1):71-4. [pmid: 10882249].
645 Pesonen E, Eskelinen M, Juhola M. Comparison of different neural network algorithms in the diagnosis of acute appendicitis. International journal of bio-medical computing. Jan. 1996;40(3):227-33. [pmid: 8666475].
646 Pesonen E, Ikonen J, Juhola M, et al. Parameters for a knowledge base for acute appendicitis. Methods of information in medicine. May. 1994;33(2):220-6. [pmid: 8057950].
647 Pesonen E. Is neural network better than statistical methods in diagnosis of acute appendicitis?. Studies in health technology and informatics. 1997;43(Pt A):377-81. [pmid: 10179576].
648 Petroianu A, Alberti LR. Accuracy of the new radiographic sign of fecal loading in the cecum for differential diagnosis of acute appendicitis in comparison with other inflammatory diseases of right abdomen: a prospective study. Journal of medicine and life. Feb. 22. 2012;5(1):85-91. [pmid: 22574093].
649 Petrosyan M, Estrada J, Chan S, et al. CT scan in patients with suspected appendicitis: clinical implications for the acute care surgeon. European surgical research Europaische chirurgische Forschung Recherches chirurgicales europeennes. 2008;40(2):211-9. [pmid: 17998781].
650 Pickhardt PJ, Lawrence EM, Pooler BD, et al. Diagnostic performance of multidetector computed tomography for suspected acute appendicitis. Annals of internal medicine. Jun. 21. 2011;154(12):789-96. W-291. [pmid: 21690593].
651 Pickuth D, Heywang-Kobrunner SH, Spielmann RP. Suspected acute appendicitis: is ultrasonography or computed tomography the preferred imaging technique?. The European journal of surgery. Acta chirurgica. Apr. 2000;166(4):315-9. [pmid: 10817330].
652 Pickuth D, Spielmann RP. Unenhanced spiral CT for evaluating acute appendicitis in daily routine. A prospective study. Hepato-gastroenterology. Jan–Feb. 2001;48(37):140-2. [pmid: 11268950].
653 Platon A, Jlassi H, Rutschmann OT, et al. Evaluation of a low-dose CT protocol with oral contrast for assessment of acute appendicitis. European radiology. Feb. 2009;19(2):446-54. [pmid: 18797875].
654 Poh AC, Lin M, Teh HS, et al. The role of computed tomography in clinically-suspected but equivocal acute appendicitis. Singapore medical journal. Aug. 2004;45(8):379-84. [pmid: 15284932].
655 Pohl D, Golub R, Schwartz GE, et al. Appendiceal ultrasonography performed by nonradiologists: does it help in the diagnostic process?. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Apr. 1998;17(4):217-21. [pmid: 9544604].
656 Poletti PA, Platon A, De Perrot T, et al. Acute appendicitis: prospective evaluation of a diagnostic algorithm integrating ultrasound and low-dose CT to reduce the need of standard CT. European radiology. Dec. 2011;21(12):2558-66. [pmid: 21805194].
657 Pooler BD, Lawrence EM, Pickhardt PJ. Alternative diagnoses to suspected appendicitis at CT. Radiology. Dec. 2012;265(3):733-42. [pmid: 23023965].
658 Pooler BD, Lawrence EM, Pickhardt PJ. MDCT for suspected appendicitis in the elderly: diagnostic performance and patient outcome. Emergency radiology. Jan. 2012;19(1):27-33. [pmid: 22131057].
659 Poortman P, Lohle PN, Schoemaker CM, et al. Comparison of CT and sonography in the diagnosis of acute appendicitis: a blinded prospective study. AJR American journal of roentgenology. Nov. 2003;181(5):1355-9. [pmid: 14573433].
660 Poortman P, Lohle PN, Schoemaker CM, et al. Improving the false-negative rate of CT in acute appendicitis-Reassessment of CT images by body imaging radiologists: a blinded prospective study. European journal of radiology. Apr. 2010;74(1):67-70. [pmid: 19185439].
661 Poortman P, Oostvogel H, Lohle P, et al. Ultrasonography and clinical observation in women with suspected acute appendicitis: a prospective cohort study. Digestive surgery. 2009;26(2):163-8. [pmid: 19390196].
662 Poortman P, Oostvogel HJ, Bosma E, et al. Improving diagnosis of acute appendicitis: results of a diagnostic pathway with standard use of ultrasonography followed by selective use of CT. Journal of the American College of Surgeons. Mar. 2009;208(3):434-41. [pmid: 19318006].
663 Pouget-Baudry Y, Mucci S, Eyssartier E, et al. The use of the Alvarado score in the management of right lower quadrant abdominal pain in the adult. Journal of visceral surgery. Apr. 2010;147(2):e40-4. [pmid: 20692636].
664 Prabhudesai SG, Gould S, Rekhraj S, et al. Artificial neural networks: useful aid in diagnosing acute appendicitis. World journal of surgery. Feb. 2008;32(2):305-9. discussion 10–1. [pmid: 18043966].
665 Prasannan S, Zhueng TJ, Gul YA. Diagnostic value of plain abdominal radiographs in patients with acute abdominal pain. Asian journal of surgery/Asian Surgical Association. Oct. 2005;28(4):246-51. [pmid: 16234073].
666 Prendergast PM, Poonai N, Lynch T, et al. Acute appendicitis: investigating an optimal outer appendiceal diameter cut-point in a pediatric population. 2014. [pmid: 24113477].
667 Pruekprasert P, Maipang T, Geater A, et al. Accuracy in diagnosis of acute appendicitis by comparing serum C-reactive protein measurements, Alvarado score and clinical impression of surgeons. Journal of the Medical Association of Thailand. Chotmaihet thangphaet. Mar. 2004;87(3):296-303. [pmid: 15117047].
668 Puig S, Hormann M, Rebhandl W, et al. US as a primary diagnostic tool in relation to negative appendectomy: six years experience. Radiology. Jan. 2003;226(1):101-4. [pmid: 12511675].
669 Puppe B, Ohmann C, Goos K, et al. Evaluating four diagnostic methods with acute abdominal pain cases. Methods of information in medicine. Sep. 1995;34(4):361-8. [pmid: 7476467].
670 Puylaert JB, Rutgers PH, Lalisang RI, et al. A prospective study of ultrasonography in the diagnosis of appendicitis. The New England journal of medicine. Sep. 10. 1987;317(11):666-9. [pmid: 3306375].
671 Puylaert JB. Acute appendicitis: US evaluation using graded compression. Radiology. Feb. 1986;158(2):355-60. [pmid: 2934762].
672 Quillin SP, Siegel MJ. Appendicitis: efficacy of color Doppler sonography. Radiology. May. 1994;191(2):557-60. [pmid: 8153340].
673 Raftery AT. The value of the leucocyte count in the diagnosis of acute appendicitis. The British journal of surgery. Feb. 1976;63(2):143-4. [pmid: 1252716].
674 Ragland J, de la Garza J, McKenney J. Peritoneoscopy for the diagnosis of acute appendicitis in females of reproductive age. Surgical endoscopy. 1988;2(1):36-8. [pmid: 2972080].
675 Raja AS, Wright C, Sodickson AD, et al. Negative appendectomy rate in the era of CT: an 18-year perspective. Radiology. Aug. 2010;256(2):460-5. [pmid: 20529988].
676 Rajagopalan AE, Mason JH, Kennedy M, et al. The value of the barium enema in the diagnosis of acute appendicitis. Arch Surg. Apr. 1977;112(4):531-3. [pmid: 849164].
677 Ramachandran P, Sivit CJ, Newman KD, et al. Ultrasonography as an adjunct in the diagnosis of acute appendicitis: a 4-year experience. Journal of pediatric surgery. Jan. 1996;31(1):164-7. discussion 7–9. [pmid: 8632272].
678 Raman SS, Kadell BM, Vodopich DJ, et al. Patient gender-related performance of nonfocused helical computed tomography in the diagnosis of acute appendicitis. Journal of computer assisted tomography. Jul–Aug. 2003;27(4):583-9. [pmid: 12886148].
679 Raman SS, Lu DS, Kadell BM, et al. Accuracy of nonfocused helical CT for the diagnosis of acute appendicitis: a 5-year review. AJR American journal of roentgenology. Jun. 2002;178(6):1319-25. [pmid: 12034591].
680 Ramarajan N, Krishnamoorthi R, Gharahbaghian L, Pirrotta E, Barth RA, Wang NE. Clinical correlation needed: What do emergency physicians do after an equivocal ultrasound for pediatric acute appendicitis?. [pmid: 24700515].
681 Ramarajan N, Krishnamoorthi R, Barth R, et al. An interdisciplinary initiative to reduce radiation exposure: evaluation of appendicitis in a pediatric emergency department with clinical assessment supported by a staged ultrasound and computed tomography pathway. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Nov. 2009;16(11):1258-65. [pmid: 20053244].
682 Ramirez JM, Deus J. Practical score to aid decision making in doubtful cases of appendicitis. The British journal of surgery. May. 1994;81(5):680-3. [pmid: 8044545].
683 Rao PM, Feltmate CM, Rhea JT, et al. Helical computed tomography in differentiating appendicitis and acute gynecologic conditions. Obstetrics and gynecology. Mar. 1999;93(3):417-21. [pmid: 10074991].
684 Rao PM, Rhea JT, Novelline RA, et al. Effect of computed tomography of the appendix on treatment of patients and use of hospital resources. The New England journal of medicine. Jan. 15. 1998;338(3):141-6. [pmid: 9428814].
685 Rao PM, Rhea JT, Novelline RA, et al. Helical CT combined with contrast material administered only through the colon for imaging of suspected appendicitis. AJR American journal of roentgenology. Nov. 1997;169(5):1275-80. [pmid: 9353441].
686 Rao PM, Rhea JT, Novelline RA, et al. Helical CT technique for the diagnosis of appendicitis: prospective evaluation of a focused appendix CT examination. Radiology. Jan. 1997;202(1):139-44. [pmid: 8988203].
687 Rao PM, Rhea JT, Rao JA, et al. Plain abdominal radiography in clinically suspected appendicitis: diagnostic yield, resource use, and comparison with CT. The American journal of emergency medicine. Jul. 1999;17(4):325-8. [pmid: 10452424].
688 Rao PM, Rhea JT, Rattner DW, et al. Introduction of appendiceal CT: impact on negative appendectomy and appendiceal perforation rates. Annals of surgery. Mar. 1999;229(3):344-9. [pmid: 10077046].
689 Rao PM, Wittenberg J, McDowell RK, et al. Appendicitis: use of arrowhead sign for diagnosis at CT. Radiology. Feb. 1997;202(2):363-6. [pmid: 9015058].
690 Rapp EJ, Naim F, Kadivar K, et al. Integrating MR imaging into the clinical workup of pregnant patients suspected of having appendicitis is associated with a lower negative laparotomy rate: single-institution study. Radiology. Apr. 2013;267(1):137-44. [pmid: 23360736].
691 Raval MV, Deans KJ, Rangel SJ, et al. Factors associated with imaging modality choice in children with appendicitis. The Journal of surgical research. Sep. 2012;177(1):131-6. [pmid: 22507689].
692 Razavi SA, Johnson JO, Kassin MT, Applegate KE. The impact of introducing a no oral contrast abdominopelvic CT examination (NOCAPE) pathway on radiology turn around times, emergency department length of stay, and patient safety. [pmid: 24902657].
693 Regimbeau JM, Panis Y, Le P, et al. Should routine spiral computed tomography be performed in adult patients with acute abdominal pain of the right lower quadrant?. International journal of colorectal disease. Mar. 2003;18(2):126-30. [pmid: 12548414].
694 Reginelli A, Russo A, Iasiello F, Urraro F, Maresca D, Maggialetti N, Gallo MG, Antinolfi G, Stanzione F, D’Andrea A, Brunese L. Role of diagnostic imaging in the diagnosis of acute appendicitis: a comparison between ultrasound and computed tomography. [pmid: 24336623].
695 Reich B, Zalut T, Weiner SG. An international evaluation of ultrasound vs. computed tomography in the diagnosis of appendicitis. International journal of emergency medicine. 2011;4:68. [pmid: 22035447].
696 Rettenbacher T, Hollerweger A, Gritzmann N, et al. Appendicitis: should diagnostic imaging be performed if the clinical presentation is highly suggestive of the disease?. Gastroenterology. Oct. 2002;123(4):992-8. [pmid: 12360459].
697 Rettenbacher T, Hollerweger A, Macheiner P, et al. Outer diameter of the vermiform appendix as a sign of acute appendicitis: evaluation at US. Radiology. Mar. 2001;218(3):757-62. [pmid: 11230651].
698 Rettenbacher T, Hollerweger A, Macheiner P, et al. Ovoid shape of the vermiform appendix: a criterion to exclude acute appendicitis--evaluation with US. Radiology. Jan. 2003;226(1):95-100. [pmid: 12511674].
699 Rettenbacher T, Hollerweger A, Macheiner P, et al. Presence or absence of gas in the appendix: additional criteria to rule out or confirm acute appendicitis--evaluation with US. Radiology. Jan. 2000;214(1):183-7. [pmid: 10644120].
700 Reynolds SL, Jaffe DM. Diagnosing abdominal pain in a pediatric emergency department. Pediatric emergency care. Jun. 1992;8(3):126-8. [pmid: 1614900].
701 Rezak A, Abbas HM, Ajemian MS, et al. Decreased use of computed tomography with a modified clinical scoring system in diagnosis of pediatric acute appendicitis. Arch Surg. Jan. 2011;146(1):64-7. [pmid: 21242447].
702 Rhea JT, Halpern EF, Ptak T, et al. The status of appendiceal CT in an urban medical center 5 years after its introduction: experience with 753 patients. AJR American journal of roentgenology. Jun. 2005;184(6):1802-8. [pmid: 15908534].
703 Rice HE, Arbesman M, Martin DJ, et al. Does early ultrasonography affect management of pediatric appendicitis? A prospective analysis. Journal of pediatric surgery. May. 1999;34(5):754-8. discussion 8–9. [pmid: 10359177].
704 Rioux M. Sonographic detection of the normal and abnormal appendix. AJR American journal of roentgenology. Apr. 1992;158(4):773-8. [pmid: 1546592].
705 Roberts JK, Behravesh M, Dmitrewski J. Macroscopic findings at appendicectomy are unreliable: implications for laparoscopy and malignant conditions of the appendix. International journal of surgical pathology. Oct. 2008;16(4):386-90. [pmid: 18387986].
706 Rodriguez DP, Vargas S, Callahan MJ, et al. Appendicitis in young children: imaging experience and clinical outcomes. AJR American journal of roentgenology. Apr. 2006;186(4):1158-64. [pmid: 16554597].
707 Rodriguez-Sanjuan JC, Martin-Parra JI, Seco I, et al. C-reactive protein and leukocyte count in the diagnosis of acute appendicitis in children. Diseases of the colon and rectum. Oct. 1999;42(10):1325-9. [pmid: 10528772].
708 Rompel O, Huelsse B, Bodenschatz K, et al. Harmonic US imaging of appendicitis in children. Pediatric radiology. Dec. 2006;36(12):1257-64. [pmid: 17021716].
709 Rordam P, Mortensen P, Hindberg I, et al. Acute appendicitis and plasma concentration of serotonin. Acta chirurgica Scandinavica. Jul–Aug. 1987;153(7–8):437-9. [pmid: 3673452].
710 Rosengren D, Brown AF, Chu K. Radiological imaging to improve the emergency department diagnosis of acute appendicitis. Emergency medicine Australasia : EMA. Oct–Dec. 2004;16(5–6):410-6. [pmid: 15537403].
711 Ross MJ, Liu H, Netherton SJ, Eccles R, Chen PW, Boag G, Morrison E, Thompson GC. Outcomes of children with suspected appendicitis and incompletely visualized appendix on ultrasound. [pmid: 24842505].
712 Rossi P, Covarelli P, Mosci F, et al. Ultrasonography in the management of acute appendicitis. Surgical endoscopy. Jun. 1996;10(6):619-21. [pmid: 8662398].
713 Rothrock SG, Green SM, Harding M, et al. Plain abdominal radiography in the detection of acute medical and surgical disease in children: a retrospective analysis. Pediatric emergency care. Oct. 1991;7(5):281-5. [pmid: 1754487].
714 Rubin SZ, Martin DJ. Ultrasonography in the management of possible appendicitis in childhood. Journal of pediatric surgery. Jul. 1990;25(7):737-40. [pmid: 2199659].
715 Russell WS, Schuh AM, Hill JG, et al. Clinical practice guidelines for pediatric appendicitis evaluation can decrease computed tomography utilization while maintaining diagnostic accuracy. Pediatric emergency care. May. 2013;29(5):568-73. [pmid: 23611916].
716 Rypins EB, Evans DG, Hinrichs W, et al. Tc-99m-HMPAO white blood cell scan for diagnosis of acute appendicitis in patients with equivocal clinical presentation. Annals of surgery. Jul. 1997;226(1):58-65. [pmid: 9242338].
717 Rypins EB, Kipper SL, Weiland F, et al. 99m Tc anti-CD 15 monoclonal antibody (LeuTech) imaging improves diagnostic accuracy and clinical management in patients with equivocal presentation of appendicitis. Annals of surgery. Feb. 2002;235(2):232-9. [pmid: 11807363].
718 Rypins EB, Kipper SL. 99mTc-hexamethylpropyleneamine oxime (Tc-WBC) scan for diagnosing acute appendicitis in children. The American surgeon. Oct. 1997;63(10):878-81. [pmid: 9322663].
719 Rypins EB, Kipper SL. Scintigraphic determination of equivocal appendicitis. The American surgeon. Sep. 2000;66(9):891-5. [pmid: 10993624].
720 Saaiq M, Niaz-Ud-Din, Jalil A, Zubair M, Shah SA. Diagnostic accuracy of leukocytosis in prediction of acute appendicitis. [pmid: 24411549].
721 Sack U, Biereder B, Elouahidi T, et al. Diagnostic value of blood inflammatory markers for detection of acute appendicitis in children. BMC surgery. 2006;6:15. [pmid: 17132173].
722 Sadot E, Keidar A, Shapiro R, et al. Laparoscopic accuracy in prediction of appendiceal pathology: oncologic and inflammatory aspects. American journal of surgery. Nov. 2013;206(5):805-9. [pmid: 24016703].
723 Saeed K, Mehboob F, Azam V. Role of abdominal sonography in the diagnosis of acute appendicitis. Rawal Medical Journal. 2009;34(2):138-40. PMID:.
724 Saidi HS, Chavda SK. Use of a modified Alvorado score in the diagnosis of acute appendicitis. East African medical journal. Aug. 2003;80(8):411-4. [pmid: 14601782].
725 Sakai S, Kobayashi K, Toyabe S, et al. Comparison of the levels of accuracy of an artificial neural network model and a logistic regression model for the diagnosis of acute appendicitis. Journal of medical systems. Oct. 2007;31(5):357-64. [pmid: 17918689].
726 Sakhri J, Youssef S, Ben Letaifa D, et al. Acute appendicitis during pregnancy. La Tunisie medicale. Oct. 2001;79(10):521-5. [pmid: 11910692].
727 Sakover RP, Del Fava RL. Frequency of visualization of the normal appendix with the barium enema examination. The American journal of roentgenology, radium therapy, and nuclear medicine. Jun. 1974;121(2):312-7. [pmid: 4846555].
728 Sala E, Beadsmoore C, Gibbons D, et al. Unexpected changes in clinical diagnosis: early abdomino-pelvic computed tomography compared with clinical evaluation. Abdominal imaging. Nov. 2009;34(6):783-7. [pmid: 17901913].
729 Salayta W, Dahamsheh H. Appendicitis during pregnancy: Prevalence and management at Prince Hashem Ben Al-Hussein Hospital, Zarqa, Jordan. Rawal Medical Journal. 2011;36(2):104-9. PMID:.
730 Salem TA, Molloy RG, O’Dwyer PJ. Prospective study on the role of the CT scan in patients with an acute abdomen. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Sep. 2005;7(5):460-6. [pmid: 16108882].
731 Sammalkorpi HE, Mentula P, Leppaniemi A. A new adult appendicitis score improves diagnostic accuracy of acute appendicitis--a prospective study. [pmid: 24970111].
732 Samuel M. Pediatric appendicitis score. Journal of pediatric surgery. Jun. 2002;37(6):877-81. [pmid: 12037754].
733 Sand M, Trullen XV, Bechara FG, et al. A prospective bicenter study investigating the diagnostic value of procalcitonin in patients with acute appendicitis. European surgical research Europaische chirurgische Forschung Recherches chirurgicales europeennes. 2009;43(3):291-7. [pmid: 19672084].
734 Sanei B, Mahmoodieh M, Hosseinpour M. Evaluation of validity of Alvarado scoring system for diagnosis of acute appendicitis. Pakistan Journal of Medical Sciences. 2009;25(2):298-301. PMID:.
735 Santillanes G, Simms S, Gausche-Hill M, et al. Prospective evaluation of a clinical practice guideline for diagnosis of appendicitis in children. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Aug. 2012;19(8):886-93. [pmid: 22849662].
736 Santos DA, Manunga J Jr, Hohman D, et al. How often does computed tomography change the management of acute appendicitis?. The American surgeon. Oct. 2009;75(10):918-21. [pmid: 19886134].
737 Saucier A, Huang EY, Emeremni CA, Pershad J. Prospective evaluation of a clinical pathway for suspected appendicitis. [pmid: 24379237].
738 Savar A, Hiatt JR, Busuttil RW. Acute appendicitis after solid organ transplantation. Clinical transplantation. Jan–Feb. 2006;20(1):78-80. [pmid: 16556158].
739 Schellekens DH, Hulsewe KW, van Acker BA, et al. Evaluation of the diagnostic accuracy of plasma markers for early diagnosis in patients suspected for acute appendicitis. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Jul. 2013;20(7):703-10. [pmid: 23859584].
740 Schey WL. Use of barium in the diagnosis of appendicitis in children. The American journal of roentgenology, radium therapy, and nuclear medicine. May. 1973;118(1):95-103. [pmid: 4704036].
741 Schirmer BD, Schmieg RE Jr, Dix J, et al. Laparoscopic versus traditional appendectomy for suspected appendicitis. American journal of surgery. Jun. 1993;165(6):670-5. [pmid: 8506965].
742 Schneider C, Kharbanda A, Bachur R. Evaluating appendicitis scoring systems using a prospective pediatric cohort. Annals of emergency medicine. Jun. 2007;49(6):778-84. 84 e1. [pmid: 17383771].
743 Scholer SJ, Pituch K, Orr DP, et al. Use of the rectal examination on children with acute abdominal pain. Clinical pediatrics. May. 1998;37(5):311-6. [pmid: 9597298].
744 Schuh S, Man C, Cheng A, et al. Predictors of non-diagnostic ultrasound scanning in children with suspected appendicitis. The Journal of pediatrics. Jan. 2011;158(1):112-8. [pmid: 20828717].
745 Schuler JG, Shortsleeve MJ, Goldenson RS, et al. Is there a role for abdominal computed tomographic scans in appendicitis?. Arch Surg. Apr. 1998;133(4):373-6. discussion 7. [pmid: 9565116].
746 Schulte B, Beyer D, Kaiser C, et al. Ultrasonography in suspected acute appendicitis in childhood-report of 1285 cases. European journal of ultrasound : official journal of the European Federation of Societies for Ultrasound in Medicine and Biology. Dec. 1998;8(3):177-82. [pmid: 9971899].
747 Schupp CJ, Klingmuller V, Strauch K, et al. Typical signs of acute appendicitis in ultrasonography mimicked by other diseases?. Pediatric surgery international. Jul. 2010;26(7):697-702. [pmid: 20490812].
748 Schwerk WB, Wichtrup B, Rothmund M, et al. Ultrasonography in the diagnosis of acute appendicitis: a prospective study. Gastroenterology. Sep. 1989;97(3):630-9. [pmid: 2666252].
749 Schwerk WB, Wichtrup B, Ruschoff J, et al. Acute and perforated appendicitis: current experience with ultrasound-aided diagnosis. World journal of surgery. Mar–Apr. 1990;14(2):271-6. [pmid: 2183487].
750 Scott HJ, Rosin RD. The influence of diagnostic and therapeutic laparoscopy on patients presenting with an acute abdomen. Journal of the Royal Society of Medicine. Dec. 1993;86(12):699-701. [pmid: 8308808].
751 Sedlak M, Wagner OJ, Wild B, et al. Is there still a role for rectal examination in suspected appendicitis in adults?. The American journal of emergency medicine. Mar. 2008;26(3):359-60. [pmid: 18358949].
752 Sencan A, Aksoy N, Yildiz M, Okur O, Demircan Y, Karaca I. The evaluation of the validity of Alvarado, Eskelinen, Lintula and Ohmann scoring systems in diagnosing acute appendicitis in children. [pmid: 24448910].
753 Sengupta A, Bax G, Paterson-Brown S. White cell count and C-reactive protein measurement in patients with possible appendicitis. Annals of the Royal College of Surgeons of England. Mar. 2009;91(2):113-5. [pmid: 19102827].
754 Seo H, Lee KH, Kim HJ, et al. Diagnosis of acute appendicitis with sliding slab ray-sum interpretation of low-dose unenhanced CT and standard-dose i.v. contrast-enhanced CT scans. AJR American journal of roentgenology. Jul. 2009;193(1):96-105. [pmid: 19542400].
755 Sezer TO, Gulece B, Zalluhoglu N, et al. Diagnostic value of ultrasonography in appendicitis. Advances in clinical and experimental medicine : official organ Wroclaw Medical University. Sep–Oct. 2012;21(5):633-6. [pmid: 23356200].
756 Shafi SM, Afsheen M, Reshi FA. Total leucocyte count, C-reactive protein and neutrophil count: diagnostic aid in acute appendicitis. Saudi journal of gastroenterology : official journal of the Saudi Gastroenterology Association. Apr. 2009;15(2):117-20. [pmid: 19568576].
757 Shah DR, Dev VR, Brown CA. The utilization of a neural network system in the diagnosis of appendicitis. MD computing : computers in medical practice. Mar–Apr. 1999;16(2):65-7. [pmid: 10375889].
758 Shah NA, Islam M, Sabir IA, Mehreen T, Khan M. Diagnostic accuracy of clinical examination versus combination of abdominal ultrasound and alvarado score, in patients with acute appendicitis. JPMI - Journal of Postgraduate Medical Institute [serial on the Internet]. 2008;(1). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/585/CN-00792585/frame.html. Last accessed.
759 Shakhatreh HS. The accuracy of C-reactive protein in the diagnosis of acute appendicitis compared with that of clinical diagnosis. Medicinski arhiv. 2000;54(2):109-10. [pmid: 10934841].
760 Shaligram A, Pallati P, Simorov A, et al. Do you need a computed tomographic scan to evaluate suspected appendicitis in young men: an administrative database review. American journal of surgery. Dec. 2012;204(6):1025-30. discussion 30. [pmid: 23022250].
761 Sharma R, Kasliwal DK, Sharma RG. Evaluation of negative appendicectomy rate in cases of suspected acute appendicitis and to study the usefulness of ultrasonography in improving the diagnostic accuracy. The Indian journal of surgery. Oct. 2007;69(5):194-7. [pmid: 23132981].
762 Sharp NE, Raghavan MU, Svetanoff WJ, et al. Radiation exposure - how do CT scans for appendicitis compare between a free standing children’s hospital and non-dedicated pediatric facilities?. Journal of pediatric surgery. Jun. 2014;49(6):1016-9. discussion 9. [pmid: 24888854].
763 Shera AH, Nizami FA, Malik AA, et al. Clinical scoring system for diagnosis of acute appendicitis in children. Indian journal of pediatrics. Mar. 2011;78(3):287-90. [pmid: 21046287].
764 Shinbrot RG, Miller HR. Ultrasonographic evaluation of acute appendicitis. The Journal of the American Osteopathic Association. Jan. 1992;92(1):90-4. [pmid: 1559861].
765 Shirazi AS, Sametzadeh M, Kamankesh R, et al. Accuracy of sonography in diagnosis of acute appendicitis running. Pakistan journal of biological sciences: PJBS. Feb. 15. 2010;13(4):190-3. [pmid: 20437687].
766 Shreef KS, Waly AH, Abd-Elrahman S, et al. Alvarado score as an admission criterion in children with pain in right iliac fossa. African journal of paediatric surgery : AJPS. Sep–Dec. 2010;7(3):163-5. [pmid: 20859021].
767 Shrivastava UK, Gupta A, Sharma D. Evaluation of the Alvarado score in the diagnosis of acute appendicitis. Tropical gastroenterology : official journal of the Digestive Diseases Foundation. Oct–Dec. 2004;25(4):184-6. [pmid: 15912982].
768 Shung-Shung S, Yu-Chien S, Mei-Due Y, et al. Improving the diagnosis of acute appendicitis with atypical findings by Tc-99m HMPAO leukocyte scan. Nuklearmedizin Nuclear medicine. Feb. 2002;41(1):37-41. [pmid: 11917347].
769 Siddique K, Baruah P, Bhandari S, et al. Diagnostic accuracy of white cell count and C-reactive protein for assessing the severity of paediatric appendicitis. JRSM short reports. Jul. 2011;2(7):59. [pmid: 21847441].
770 Siegel MJ, Carel C, Surratt S. Ultrasonography of acute abdominal pain in children. JAMA : the journal of the American Medical Association. Oct. 9. 1991;266(14):1987-9. [pmid: 1895479].
771 Sigdel GS, Lakhey PJ, Mishra PR. Tzanakis score vs. Alvarado score in acute appendicitis. JNMA; journal of the Nepal Medical Association. Apr–Jun. 2010;49(178):96-9. [pmid: 21485591].
772 Sim JY, Kim HJ, Yeon JW, et al. Added value of ultrasound re-evaluation for patients with equivocal CT findings of acute appendicitis: a preliminary study. European radiology. Jul. 2013;23(7):1882-90. [pmid: 23392792].
773 Sim JY, Yeon JW, Kim HJ. Added value of US re-evaluation in patients with equivocal CT findings of acute appendicitis: A prospective study. Journal of Medical Imaging and Radiation Oncology. 2012;56:141. PMID:.
774 Sim KT, Picone S, Crade M, et al. Ultrasound with graded compression in the evaluation of acute appendicitis. Journal of the National Medical Association. Sep. 1989;81(9):954-7. [pmid: 2674464].
775 Simonovsky V. Sonographic detection of normal and abnormal appendix. Clinical radiology. Aug. 1999;54(8):533-9. [pmid: 10484221].
776 Simonovsky V. Ultrasound in the differential diagnosis of appendicitis. Clinical radiology. Nov. 1995;50(11):768-73. [pmid: 7489627].
777 Singh AK, Desai H, Novelline RA. Emergency MRI of acute pelvic pain: MR protocol with no oral contrast. Emergency radiology. Mar. 2009;16(2):133-41. [pmid: 18649091].
778 Singh-Ranger D, Ogadegbe A. Leucocyte count and oral temperature are a useful guide to selecting women with right iliac fossa pain for diagnostic laparoscopy. Annals of the Royal College of Surgeons of England. Jul. 2010;92(5):425-8. [pmid: 20626973].
779 Sitter H, Hoffmann S, Hassan I, et al. Diagnostic score in appendicitis. Validation of a diagnostic score (Eskelinen score) in patients in whom acute appendicitis is suspected. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Jun. 2004;389(3):213-8. [pmid: 14624293].
780 Sivit CJ, Applegate KE, Berlin SC, et al. Evaluation of suspected appendicitis in children and young adults: helical CT. Radiology. Aug. 2000;216(2):430-3. [pmid: 10924565].
781 Sivit CJ, Applegate KE, Stallion A, et al. Imaging evaluation of suspected appendicitis in a pediatric population: effectiveness of sonography versus CT. AJR American journal of roentgenology. Oct. 2000;175(4):977-80. [pmid: 11000147].
782 Sivit CJ, Newman KD, Boenning DA, et al. Appendicitis: usefulness of US in diagnosis in a pediatric population. Radiology. Nov. 1992;185(2):549-52. [pmid: 1410371].
783 Sivitz AB, Cohen SG, Tejani C. Evaluation of Acute Appendicitis by Pediatric Emergency Physician Sonography. [pmid: 24882665].
784 Skaane P, Amland PF, Nordshus T, et al. Ultrasonography in patients with suspected acute appendicitis: a prospective study. The British journal of radiology. Oct. 1990;63(754):787-93. [pmid: 2242476].
785 Skaane P, Schistad O, Amland PF, et al. Routine ultrasonography in the diagnosis of acute appendicitis: a valuable tool in daily practice?. The American surgeon. Nov. 1997;63(11):937-42. [pmid: 9358775].
786 Smink DS, Finkelstein JA, Garcia Pena BM, et al. Diagnosis of acute appendicitis in children using a clinical practice guideline. Journal of pediatric surgery. Mar. 2004;39(3):458-63. discussion -63. [pmid: 15017570].
787 Soda K, Nemoto K, Yoshizawa S, et al. Detection of pinpoint tenderness on the appendix under ultrasonography is useful to confirm acute appendicitis. Arch Surg. Oct. 2001;136(10):1136-40. [pmid: 11585505].
788 Sohail S, Siddiqui KJ. Doptaus--a simple criterion for improving sonographic diagnosis of acute appendicitis. JPMA The Journal of the Pakistan Medical Association. Feb. 2009;59(2):79-82. [pmid: 19260568].
789 Son CS, Jang BK, Seo ST, et al. A hybrid decision support model to discover informative knowledge in diagnosing acute appendicitis. BMC medical informatics and decision making. 2012;12:17. [pmid: 22410346].
790 Sondenaa K, Buan B, Soreide JA, et al. Rapid C-reactive protein (CRP) measurements in the diagnosis of acute appendicitis. Scandinavian journal of clinical and laboratory investigation. Nov. 1992;52(7):585-9. [pmid: 1455149].
791 Sood S, Katariya RN, Rao PG, et al. Significance of leucocyte count in the diagnosis of acute appendicitis. Journal of postgraduate medicine. Jan. 1977;23(1):25-7. [pmid: 615255].
792 Soomro AG, Siddiqui FG, Abro AH, et al. Diagnostic accuracy of Alvarado Scoring System in acute appendicitis. Journal of the Liaquat University of Medical and Health Sciences. 2008;7(2):93-6. PMID:.
793 Sozuer EM, Bedirli A, Ulusal M, et al. Laparoscopy for diagnosis and treatment of acute abdominal pain. Journal of laparoendoscopic & advanced surgical techniques Part A. Aug. 2000;10(4):203-7. [pmid: 10997843].
794 Spirtos NM, Eisenkop SM, Spirtos TW, et al. Laparoscopy--a diagnostic aid in cases of suspected appendicitis. Its use in women of reproductive age. American journal of obstetrics and gynecology. Jan. 1987;156(1):90-4. [pmid: 2948388].
795 Srinivasan A, Servaes S, Pena A, Darge K. Utility of CT after sonography for suspected appendicitis in children: integration of a clinical scoring system with a staged imaging protocol. [pmid: 24917390].
796 Staniland JR, Clamp SE, de Dombal FT, et al. Presentation and diagnosis of patients with acute abdominal pain: comparisons between Leeds, U.K. and Akershus county, Norway. Annales chirurgiae et gynaecologiae. 1980;69(6):245-50. [pmid: 7011161].
797 Steele RJ. Abdominal thermography in acute appendicitis. Scottish medical journal. Oct. 1986;31(4):229-30. [pmid: 3563460].
798 Stefanutti G, Ghirardo V, Gamba P. Inflammatory markers for acute appendicitis in children: are they helpful?. Journal of pediatric surgery. May. 2007;42(5):773-6. [pmid: 17502181].
799 Stephen AE, Segev DL, Ryan DP, et al. The diagnosis of acute appendicitis in a pediatric population: to CT or not to CT. Journal of pediatric surgery. Mar. 2003;38(3):367-71. discsussion -71. [pmid: 12632351].
800 Stephens PL, Mazzucco JJ. Comparison of ultrasound and the Alvarado score for the diagnosis of acute appendicitis. Connecticut medicine. Mar. 1999;63(3):137-40. [pmid: 10218289].
801 Stewart D, Grewal N, Choi R, et al. The use of tagged white blood cell scans to diagnose appendicitis in pregnant patients. The American surgeon. Oct. 2006;72(10):894-6. [pmid: 17058729].
802 Stewart JK, Olcott EW, Jeffrey BR. Sonography for appendicitis: nonvisualization of the appendix is an indication for active clinical observation rather than direct referral for computed tomography. Journal of clinical ultrasound : JCU. Oct. 2012;40(8):455-61. [pmid: 22638942].
803 Stewart RJ, Gupta RK, Purdie GL, et al. Fine-catheter aspiration cytology of peritoneal cavity improves decision-making about difficult cases of acute abdominal pain. Lancet. Dec. 20–27. 1986;2(8521-22):1414-5. [pmid: 2878273].
804 Stroman DL, Bayouth CV, Kuhn JA, et al. The role of computed tomography in the diagnosis of acute appendicitis. American journal of surgery. Dec. 1999;178(6):485-9. [pmid: 10670858].
805 Stromberg C, Johansson G, Adolfsson A. Acute abdominal pain: diagnostic impact of immediate CT scanning. World journal of surgery. Dec. 2007;31(12):2347-54. discussion 55–8. [pmid: 17896131].
806 Stunell H, Aremu M, Collins D, et al. Assessment of the value of pelvic ultrasonography in pre-menopausal women with right iliac fossa pain. Irish medical journal. Jul–Aug. 2008;101(7):216-7. [pmid: 18807813].
807 Styrud J, Eriksson S, Segelman J, et al. Diagnostic accuracy in 2,351 patients undergoing appendicectomy for suspected acute appendicitis: A retrospective study 1986–1993. Digestive surgery. 1999;16(1):39-44. [pmid: 9949266].
808 Styrud J, Josephson T, Eriksson S. Reducing negative appendectomy: evaluation of ultrasonography and computer tomography in acute appendicitis. International journal for quality in health care : journal of the International Society for Quality in Health Care/ISQua. Feb. 2000;12(1):65-8. [pmid: 10733085].
809 Summa M, Perrone F, Priora F, et al. Integrated clinical-ultrasonographic diagnosis in acute appendicitis. Journal of ultrasound. Dec. 2007;10(4):175-8. [pmid: 23396678].
810 Sun JS, Noh HW, Min YG, et al. Receiver operating characteristic analysis of the diagnostic performance of a computed tomographic examination and the Alvarado score for diagnosing acute appendicitis: emphasis on age and sex of the patients. Journal of computer assisted tomography. May–Jun. 2008;32(3):386-91. [pmid: 18520542].
811 Sun SS, Wu HS, Wang JJ, et al. Comparison between technetium 99m hexamethylpropyleneamine oxide labeled white blood cell abdominal scan and abdominal sonography to detect appendicitis in adult patients with atypical clinical presentation. Abdominal imaging. Nov–Dec. 2002;27(6):734-8. [pmid: 12395266].
812 Sutton GC. How accurate is computer-aided diagnosis?. Lancet. Oct. 14. 1989;2(8668):905-8. [pmid: 2571822].
813 Tabbara M, Evangelopoulos N, Raio L, et al. Transvaginal ultrasound in fertile patients with suspected appendicitis: an experience report of current practice. Emergency medicine international. 2012;2012:481797. [pmid: 22496979].
814 Tade AO. Evaluation of Alvarado score as an admission criterion in patients with suspected diagnosis of acute appendicitis. West African journal of medicine. Jul–Sep. 2007;26(3):210-2. [pmid: 18399336].
815 Tamanna MZ, Eram U, Al Harbi TM, et al. Clinical value of leukocyte counts in evaluation of patients with suspected appendicitis in emergency department. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Nov. 2012;18(6):474-8. [pmid: 23588904].
816 Tamburrini S, Brunetti A, Brown M, et al. Acute appendicitis: diagnostic value of nonenhanced CT with selective use of contrast in routine clinical settings. European radiology. Aug. 2007;17(8):2055-61. [pmid: 17180324].
817 Tamir IL, Bongard FS, Klein SR. Acute appendicitis in the pregnant patient. American journal of surgery. Dec. 1990;160(6):571-5. discussion 5–6. [pmid: 2252115].
818 Tan WJ, Pek W, Kabir T, et al. Alvarado score: a guide to computed tomography utilization in appendicitis. ANZ journal of surgery. Oct. 2013;83(10):748-52. [pmid: 23351046].
819 Teo AT, Lefter LP, Zarrouk AJ, Merrett ND. Institutional review of patients presenting with suspected appendicitis. [pmid: 24640953].
820 Teo EL, Tan KP, Lam SL, et al. Ultrasonography and computed tomography in a clinical algorithm for the evaluation of suspected acute appendicitis in children. Singapore medical journal. Aug. 2000;41(8):387-92. [pmid: 11256346].
821 Tepel J, Sommerfeld A, Klomp HJ, et al. Prospective evaluation of diagnostic modalities in suspected acute appendicitis. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Jun. 2004;389(3):219-24. [pmid: 14634825].
822 Terzi A, Yildiz F, Vural M, et al. A case series of 46 appendectomies during pregnancy. Wiener klinische Wochenschrift. Dec. 2010;122(23–24):686-90. [pmid: 21104201].
823 Thakur ML, Marcus CS, Kipper SL, et al. Imaging infection with LeuTech. Nuclear medicine communications. May. 2001;22(5):513-9. [pmid: 11388572].
824 Thieme ME, Leeuwenburgh MM, Valdehueza ZD, et al. Diagnostic accuracy and patient acceptance of MRI in children with suspected appendicitis. [pmid: 24135892].
825 Thimsen DA, Tong GK, Gruenberg JC. Prospective evaluation of C-reactive protein in patients suspected to have acute appendicitis. The American surgeon. Jul. 1989;55(7):466-8. [pmid: 2742230].
826 Thirumallai S, Wijesuriya SR, Mitchell A, Delriviere L. Predictive value of C-reactive protein with Alvarado score in acute appendicitis. [pmid: 24119072].
827 Thirumoorthi AS, Fefferman NR, Ginsburg HB, et al. Managing radiation exposure in children--reexamining the role of ultrasound in the diagnosis of appendicitis. Journal of pediatric surgery. Dec. 2012;47(12):2268-72. [pmid: 23217887].
828 Thompson MM, Underwood MJ, Dookeran KA, et al. Role of sequential leucocyte counts and C-reactive protein measurements in acute appendicitis. The British journal of surgery. Aug. 1992;79(8):822-4. [pmid: 1393485].
829 Thorell A, Grondal S, Schedvins K, et al. Value of diagnostic laparoscopy in fertile women with suspected appendicitis. The European journal of surgery. Acta chirurgica. Aug. 1999;165(8):751-4. [pmid: 10494640].
830 Ting HW, Wu JT, Chan CL, et al. Decision model for acute appendicitis treatment with decision tree technology--a modification of the Alvarado scoring system. Journal of the Chinese Medical Association : JCMA. Aug. 2010;73(8):401-6. [pmid: 20728850].
831 Tiu CM, Chou YH, Chen JD, Chiou YY, Wei CF, Chin TW, Chiou HJ, Chiou SY, Wang HK, Chen SP. Ultrasound diagnosis of acute appendicitis: impact on cost and outcome in pediatric patients (Structured abstract). Journal of Medical Ultrasound [serial on the Internet]. 2004;(3). Available from: http://onlinelibrary.wiley.com/o/cochrane/cleed/articles/NHSEED-22005001400/frame.html. Last accessed.
832 Togawa A, Kimura F, Chiku T, et al. Simple way to improve accuracy in diagnosis of quadrant inflammatory disease: how to avoid adverse laparotomy by using plain CT. Hepato-gastroenterology. Jan–Feb. 2005;52(61):135-8. [pmid: 15783013].
833 Tomizawa M, Shinozaki F, Sugiyama T, et al. Ultrasonography for leukocytosis or elevated C-reactive protein. Hepato-gastroenterology. Jul–Aug. 2011;58(109):1156-8. [pmid: 21937369].
834 Toorenvliet BR, Wiersma F, Bakker RF, et al. Routine ultrasound and limited computed tomography for the diagnosis of acute appendicitis. World journal of surgery. Oct. 2010;34(10):2278-85. [pmid: 20582544].
835 Toprak H, Kilincaslan H, Ahmad IC, Yildiz S, Bilgin M, Sharifov R, Acar M. Integration of ultrasound findings with Alvarado score in children with suspected appendicitis. [pmid: 23937630].
836 Torbati SS, Guss DA. Impact of helical computed tomography on the outcomes of emergency department patients with suspected appendicitis. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Aug. 2003;10(8):823-9. [pmid: 12896881].
837 Tracey M, Fletcher HS. Appendicitis in pregnancy. The American surgeon. Jun. 2000;66(6):555-9. discussion 9–60. [pmid: 10888131].
838 Tronin RJ, Burova VA, Grinberg AA. Laparoscopic diagnosis of acute appendicitis in women. The Journal of the American Association of Gynecologic Laparoscopists. Feb. 1996;3(2):257-61. [pmid: 9050636].
839 Trout AT, Sanchez R, Ladino-Torres MF, et al. A critical evaluation of US for the diagnosis of pediatric acute appendicitis in a real-life setting: how can we improve the diagnostic value of sonography?. Pediatric radiology. Jul. 2012;42(7):813-23. [pmid: 22402833].
840 Trout AT, Sanchez R, Ladino-Torres MF. Reevaluating the sonographic criteria for acute appendicitis in children: a review of the literature and a retrospective analysis of 246 cases. Academic radiology. Nov. 2012;19(11):1382-94. [pmid: 22947273].
841 Tsao K, St Peter SD, Valusek PA, et al. Management of pediatric acute appendicitis in the computed tomographic era. The Journal of surgical research. Jun. 15. 2008;147(2):221-4. [pmid: 18498874].
842 Tseng YC, Lee MS, Chang YJ, et al. Acute abdomen in pediatric patients admitted to the pediatric emergency department. Pediatrics and neonatology. Aug. 2008;49(4):126-34. [pmid: 19054918].
843 Tsushima Y, Yamada S, Aoki J, et al. Effect of contrast-enhanced computed tomography on diagnosis and management of acute abdomen in adults. Clinical radiology. Jun. 2002;57(6):507-13. [pmid: 12069469].
844 Turan C, Tutus A, Ozokutan BH, et al. The evaluation of technetium 99m-citrate scintigraphy in children with suspected appendicitis. Journal of pediatric surgery. Aug. 1999;34(8):1272-5. [pmid: 10466611].
845 Turkyilmaz Z, Sonmez K, Karabulut R, et al. Sequential cytokine levels in the diagnosis of appendicitis. Scandinavian journal of clinical and laboratory investigation. 2006;66(8):723-31. [pmid: 17101565].
846 Turkyilmaz Z, Sonmez K, Konus O, et al. Diagnostic value of plain abdominal radiographs in acute appendicitis in children. East African medical journal. Feb. 2004;81(2):104-7. [pmid: 15125095].
847 Tzanakis NE, Efstathiou SP, Danulidis K, et al. A new approach to accurate diagnosis of acute appendicitis. World journal of surgery. Sep. 2005;29(9):1151-6. discussion 7. [pmid: 16088420].
848 Tzovaras G, Liakou P, Baloyiannis I, et al. Laparoscopic appendectomy: differences between male and female patients with suspected acute appendicitis. World journal of surgery. Feb. 2007;31(2):409-13. [pmid: 17219281].
849 Ujiki MB, Murayama KM, Cribbins AJ, et al. CT scan in the management of acute appendicitis. The Journal of surgical research. Jun. 15. 2002;105(2):119-22. [pmid: 12121697].
850 Ulukaya Durakbasa C, Tasbasi I, Tosyali AN, et al. An evaluation of individual plain abdominal radiography findings in pediatric appendicitis: results from a series of 424 children. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Jan. 2006;12(1):51-8. [pmid: 16456751].
851 Unal A, Sayharman SE, Ozel L, et al. Acute abdomen in pregnancy requiring surgical management: a 20-case series. European journal of obstetrics, gynecology, and reproductive biology. Nov. 2011;159(1):87-90. [pmid: 21831513].
852 Unlu C, de Castro SM, Tuynman JB, et al. Evaluating routine diagnostic imaging in acute appendicitis. International journal of surgery (London, England). Oct. 2009;7(5):451-5. [pmid: 19559106].
853 van Breda Vriesman AC, Kole BJ, Puylaert JB. Effect of ultrasonography and optional computed tomography on the outcome of appendectomy. European radiology. Oct. 2003;13(10):2278-82. [pmid: 12845461].
854 van Dalen R, Bagshaw PF, Dobbs BR, et al. The utility of laparoscopy in the diagnosis of acute appendicitis in women of reproductive age. Surgical endoscopy. Aug. 2003;17(8):1311-3. [pmid: 12739123].
855 van den Broek WT, Bijnen BB, Rijbroek B, et al. Scoring and diagnostic laparoscopy for suspected appendicitis. The European journal of surgery. Acta chirurgica. 2002;168(6):349-54. [pmid: 12428873].
856 van den Broek WT, van der Ende ED, Bijnen AB, et al. Which children could benefit from additional diagnostic tools in case of suspected appendicitis?. Journal of pediatric surgery. Apr. 2004;39(4):570-4. [pmid: 15065030].
857 van Dieijen-Visser MP, Go PM, Brombacher PJ. The value of laboratory tests in patients suspected of acute appendicitis. European journal of clinical chemistry and clinical biochemistry : journal of the Forum of European Clinical Chemistry Societies. Nov. 1991;29(11):749-52. [pmid: 1782282].
858 van Randen A, Lameris W, van Es HW, et al. A comparison of the accuracy of ultrasound and computed tomography in common diagnoses causing acute abdominal pain. European radiology. Jul. 2011;21(7):1535-45. [pmid: 21365197].
859 van Randen A, Lameris W, van Es HW, et al. Profiles of US and CT imaging features with a high probability of appendicitis. European radiology. Jul. 2010;20(7):1657-66. [pmid: 20119730].
860 Van Way CW 3rd, Murphy JR, Dunn EL, et al. A feasibility study of computer aided diagnosis in appendicitis. Surgery, gynecology & obstetrics. Nov. 1982;155(5):685-8. [pmid: 6753199].
861 Vaughan-Shaw PG, Rees JR, Bell E, et al. Normal inflammatory markers in appendicitis: evidence from two independent cohort studies. JRSM short reports. May. 2011;2(5):43. [pmid: 21637404].
862 Vermeulen B, Morabia A, Unger PF, et al. Acute appendicitis: influence of early pain relief on the accuracy of clinical and US findings in the decision to operate--a randomized trial. Radiology. Mar. 1999;210(3):639-43. [pmid: 10207461].
863 Verroken R, Penninckx F, Van Hoe L, et al. Diagnostic accuracy of ultrasonography and surgical decision-making in patients referred for suspicion of appendicitis. Acta chirurgica Belgica. Jul–Aug. 1996;96(4):158-60. [pmid: 8830871].
864 Vignault F, Filiatrault D, Brandt ML, et al. Acute appendicitis in children: evaluation with US. Radiology. Aug. 1990;176(2):501-4. [pmid: 2195594].
865 Vu L, Ambrose D, Vos P, et al. Evaluation of MRI for the diagnosis of appendicitis during pregnancy when ultrasound is inconclusive. The Journal of surgical research. Sep. 2009;156(1):145-9. [pmid: 19560166].
866 Wade DS, Marrow SE, Balsara ZN, et al. Accuracy of ultrasound in the diagnosis of acute appendicitis compared with the surgeon’s clinical impression. Arch Surg. Sep. 1993;128(9):1039-44. discussion 44–6. [pmid: 8368922].
867 Wagner M, Aronsky D, Tschudi J, et al. Laparoscopic stapler appendectomy. A prospective study of 267 consecutive cases. Surgical endoscopy. Sep. 1996;10(9):895-9. [pmid: 8703146].
868 Wagner PL, Eachempati SR, Soe K, et al. Defining the current negative appendectomy rate: for whom is preoperative computed tomography making an impact?. Surgery. Aug. 2008;144(2):276-82. [pmid: 18656636].
869 Walker S, Haun W, Clark J, et al. The value of limited computed tomography with rectal contrast in the diagnosis of acute appendicitis. American journal of surgery. Dec. 2000;180(6):450-4. discussion 4–5. [pmid: 11182396].
870 Wallace CA, Petrov MS, Soybel DI, et al. Influence of imaging on the negative appendectomy rate in pregnancy. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Jan. 2008;12(1):46-50. [pmid: 17963012].
871 Wang HH, Shiau YC, Yang MD, et al. The usefulness of technetium-99m hexamethylpropyleneamineoxide labeled white blood cell abdomen scan to differentiate periappendiceal abscess from acute appendicitis--a preliminary report. Hepato-gastroenterology. Mar–Apr. 2003;50(50):416-8. [pmid: 12749236].
872 Wang LT, Prentiss KA, Simon JZ, et al. The use of white blood cell count and left shift in the diagnosis of appendicitis in children. Pediatric emergency care. Feb. 2007;23(2):69-76. [pmid: 17351404].
873 Wang SY, Fang JF, Liao CH, et al. Prospective study of computed tomography in patients with suspected acute appendicitis and low Alvarado score. The American journal of emergency medicine. Oct. 2012;30(8):1597-601. [pmid: 22205003].
874 Mehraj A, Naqvi MA, Din HU, Waqas. Importance of clinical assessment in diagnosis of acute appendicitis and its role in decreasing negative appendicectomy rate. [pmid: 24397040].
875 Webb EM, Nguyen A, Wang ZJ, et al. The negative appendectomy rate: who benefits from preoperative CT?. AJR American journal of roentgenology. Oct. 2011;197(4):861-6. [pmid: 21940573].
876 Wellwood J, Johannessen S, Spiegelhalter DJ. How does computer-aided diagnosis improve the management of acute abdominal pain?. Annals of the Royal College of Surgeons of England. Jan. 1992;74(1):40-6. [pmid: 1736794].
877 Wellwood JM, Spiegelhalter DJ. Computers and the diagnosis of acute abdominal pain. British journal of hospital medicine. Jun. 1989;41(6):564-7. [pmid: 2665898].
878 Weltman DI, Yu J, Krumenacker J Jr, et al. Diagnosis of acute appendicitis: comparison of 5- and 10-mm CT sections in the same patient. Radiology. Jul. 2000;216(1):172-7. [pmid: 10887244].
879 West WM, Brady-West DC, McDonald AH, et al. Ultrasound and white blood cell counts in suspected acute appendicitis. The West Indian medical journal. Mar. 2006;55(2):100-2. [pmid: 16921703].
880 Weyant MJ, Eachempati SR, Maluccio MA, et al. Interpretation of computed tomography does not correlate with laboratory or pathologic findings in surgically confirmed acute appendicitis. Surgery. Aug. 2000;128(2):145-52. [pmid: 10922984].
881 Weyant MJ, Eachempati SR, Maluccio MA, et al. The use of computed tomography for the diagnosis of acute appendicitis in children does not influence the overall rate of negative appendectomy or perforation. Surgical infections. Spring. 2001;2(1):19-23. [pmid: 12594877].
882 Whitney TM, Macho JR, Russell TR, et al. Appendicitis in acquired immunodeficiency syndrome. American journal of surgery. Nov. 1992;164(5):467-70. discussion 70–1. [pmid: 1332523].
883 Whitworth CM, Whitworth PW, Sanfillipo J, et al. Value of diagnostic laparoscopy in young women with possible appendicitis. Surgery, gynecology & obstetrics. Sep. 1988;167(3):187-90. [pmid: 2970682].
884 Wiersma F, Toorenvliet BR, Bloem JL, et al. US examination of the appendix in children with suspected appendicitis: the additional value of secondary signs. European radiology. Feb. 2009;19(2):455-61. [pmid: 18815791].
885 Wijetunga R, Tan BS, Rouse JC, et al. Diagnostic accuracy of focused appendiceal CT in clinically equivocal cases of acute appendicitis. Radiology. Dec. 2001;221(3):747-53. [pmid: 11719671].
886 Wild RE, Rutledge R, Herbst CA Jr. The use of barium enema in the evaluation of patients with possible appendicitis. The American surgeon. Aug. 1985;51(8):474-6. [pmid: 4026076].
887 Williams RF, Blakely ML, Fischer PE, et al. Diagnosing ruptured appendicitis preoperatively in pediatric patients. Journal of the American College of Surgeons. May. 2009;208(5):819-25. discussion 26–8. [pmid: 19476843].
888 Wilson D, Sinclair S, McCallion WA, et al. Acute appendicitis in young children in the Belfast urban area: 1985–1992. The Ulster medical journal. Apr. 1994;63(1):3-7. [pmid: 8658993].
889 Wilson EB, Cole JC, Nipper ML, et al. Computed tomography and ultrasonography in the diagnosis of appendicitis: when are they indicated?. Arch Surg. Jun. 2001;136(6):670-5. [pmid: 11387006].
890 Wilson PD, Horrocks JC, Lyndon PJ, et al. Simplified computer-aided diagnosis of acute abdominal pain. British medical journal. Apr. 12. 1975;2(5962):73-5. [pmid: 1093613].
891 Wise SW, Labuski MR, Kasales CJ, et al. Comparative assessment of CT and sonographic techniques for appendiceal imaging. AJR American journal of roentgenology. Apr. 2001;176(4):933-41. [pmid: 11264081].
892 Wong CS, Al-Ajami AK, Boshahri M, Naqvi SA. Diagnosis of acute surgical abdomen - The best diagnostic tool to reach a final diagnosiscin. Journal of Acute Disease. 2012;1(1):23-5. PMID:.
893 Wong DW, Vasinrapee P, Spieth ME, et al. Rapid detection of acute appendicitis with Tc-99m-labeled intact polyvalent human immune globulin. Journal of the American College of Surgeons. Dec. 1997;185(6):534-43. [pmid: 9404876].
894 Wong ML, Casey SO, Leonidas JC, et al. Sonographic diagnosis of acute appendicitis in children. Journal of pediatric surgery. Oct. 1994;29(10):1356-60. [pmid: 7807325].
895 Wong SK, Chan LP, Yeo A. Helical CT imaging of clinically suspected appendicitis: correlation of CT and histological findings. Clinical radiology. Aug. 2002;57(8):741-5. [pmid: 12169286].
896 Worrell JA, Drolshagen LF, Kelly TC, et al. Graded compression ultrasound in the diagnosis of appendicitis. A comparison of diagnostic criteria. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Mar. 1990;9(3):145-50. [pmid: 2407861].
897 Wu HP, Chang CF, Lin CY. Predictive inflammatory parameters in the diagnosis of acute appendicitis in children. Acta paediatrica Taiwanica = Taiwan er ke yi xue hui za zhi. Jul–Aug. 2003;44(4):227-31. [pmid: 14674227].
898 Wu HP, Chen CY, Kuo IT, et al. Diagnostic values of a single serum biomarker at different time points compared with Alvarado score and imaging examinations in pediatric appendicitis. The Journal of surgical research. May. 15. 2012;174(2):272-7. [pmid: 21529827].
899 Wu HP, Huang CY, Chang YJ, et al. Use of changes over time in serum inflammatory parameters in patients with equivocal appendicitis. Surgery. Jun. 2006;139(6):789-96. [pmid: 16782436].
900 Wu HP, Lin CY, Chang CF, et al. Predictive value of C-reactive protein at different cutoff levels in acute appendicitis. The American journal of emergency medicine. Jul. 2005;23(4):449-53. [pmid: 16032609].
901 Wu HP, Yang WC, Wu KH, et al. Diagnosing appendicitis at different time points in children with right lower quadrant pain: comparison between Pediatric Appendicitis Score and the Alvarado score. World journal of surgery. Jan. 2012;36(1):216-21. [pmid: 22009520].
902 Wu JY, Chen HC, Lee SH, et al. Diagnostic role of procalcitonin in patients with suspected appendicitis. World journal of surgery. Aug. 2012;36(8):1744-9. [pmid: 22491817].
903 Xharra S, Gashi-Luci L, Xharra K, et al. Correlation of serum C-reactive protein, white blood count and neutrophil percentage with histopathology findings in acute appendicitis. World journal of emergency surgery : WJES. 2012;7(1):27. [pmid: 22866907].
904 Yan DC, Shiau YC, Wang JJ, et al. Improving the diagnosis of acute appendicitis in children with atypical clinical findings using the technetium-99m hexamethylpropylene amine oxime-labelled white-blood-cell abdomen scan. Pediatric radiology. Sep. 2002;32(9):663-6. [pmid: 12195306].
905 Yang HR, Wang YC, Chung PK, et al. Laboratory tests in patients with acute appendicitis. ANZ journal of surgery. Jan–Feb. 2006;76(1–2):71-4. [pmid: 16483301].
906 Yang HR, Wang YC, Chung PK, et al. Role of leukocyte count, neutrophil percentage, and C-reactive protein in the diagnosis of acute appendicitis in the elderly. The American surgeon. Apr. 2005;71(4):344-7. [pmid: 15943411].
907 Yazici M, Ozkisacik S, Oztan MO, et al. Neutrophil/lymphocyte ratio in the diagnosis of childhood appendicitis. The Turkish journal of pediatrics. Jul–Aug. 2010;52(4):400-3. [pmid: 21043386].
908 Yetkin G, Basak M, Isgor A, et al. Can negative appendectomy rate be decreased by using spiral computed tomography without contrast material?. Acta chirurgica Belgica. Oct. 2002;102(5):334-7. [pmid: 12471766].
909 Yigiter M, Kantarci M, Yalcin O, et al. Does obesity limit the sonographic diagnosis of appendicitis in children?. Journal of clinical ultrasound : JCU. May. 2011;39(4):187-90. [pmid: 21480284].
910 Yildirim E, Karagulle E, Kirbas I, et al. Alvarado scores and pain onset in relation to multislice CT findings in acute appendicitis. Diagnostic and interventional radiology (Ankara, Turkey). Mar. 2008;14(1):14-8. [pmid: 18306139].
911 Yildirim O, Solak C, Kocer B, et al. The role of serum inflammatory markers in acute appendicitis and their success in preventing negative laparotomy. Journal of investigative surgery : the official journal of the Academy of Surgical Research. Nov–Dec. 2006;19(6):345-52. [pmid: 17101603].
912 Yoldas O, Karaca T, Tez M. External validation of Lintula score in Turkish acute appendicitis patients. International journal of surgery (London, England). 2012;10(1):25-7. [pmid: 22155381].
913 Yoldas O, Tez M, Karaca T. Artificial neural networks in the diagnosis of acute appendicitis. The American journal of emergency medicine. Sep. 2012;30(7):1245-7. [pmid: 21908136].
914 Yuksel Y, Dinc B, Yuksel D, Dinc SE, Mesci A. How reliable is the Alvarado score in acute appendicitis?. [pmid: 24639309].
915 Zakaria O, Sultan TA, Khalil TH, et al. Role of clinical judgment and tissue harmonic imaging ultrasonography in diagnosis of paediatric acute appendicitis. World journal of emergency surgery : WJES. 2011;6(1):39. [pmid: 22087573].
916 Zaki AM, MacMahon RA, Gray AR. Acute appendicitis in children: when does ultrasound help?. The Australian and New Zealand journal of surgery. Oct. 1994;64(10):695-8. [pmid: 7945068].
917 Zeidan BS, Wasser T, Nicholas GG. Ultrasonography in the diagnosis of acute appendicitis. Journal of the Royal College of Surgeons of Edinburgh. Feb. 1997;42(1):24-6. [pmid: 9046139].
918 Zhou H, Chen YC, Zhang JZ. Abdominal pain among children re-evaluation of a diagnostic algorithm. World journal of gastroenterology : WJG. Oct. 2002;8(5):947-51. [pmid: 12378648].
919 Zhu B, Zhang B, Li M, et al. An evaluation of a superfast MRI sequence in the diagnosis of suspected acute appendicitis. Quantitative imaging in medicine and surgery. Dec. 2012;2(4):280-7. [pmid: 23289088].
920 Zielke A, Hasse C, Sitter H, et al. “Surgical” ultrasound in suspected acute appendicitis. Surgical endoscopy. Apr. 1997;11(4):362-5. [pmid: 9094278].
921 Zielke A, Hasse C, Sitter H, et al. Influence of ultrasound on clinical decision making in acute appendicitis: a prospective study. The European journal of surgery. Acta chirurgica. Mar. 1998;164(3):201-9. [pmid: 9562281].
922 Zielke A, Sitter H, Rampp T, et al. Clinical decision-making, ultrasonography, and scores for evaluation of suspected acute appendicitis. World journal of surgery. May. 2001;25(5):578-84. [pmid: 11369983].
923 Zona JZ, Selke AC, Belin RP. Radiologic aids in the diagnosis of appendicitis in children. Southern medical journal. Nov. 1975;68(11):1373-6. [pmid: 1188426].
924 Zorman M, Eich HP, Kokol P, et al. Comparison of three databases with a decision tree approach in the medical field of acute appendicitis. Studies in health technology and informatics. 2001;84(Pt 2):1414-8. [pmid: 11604960].
925 Zuniga RV, Arribas JL, Montes SP, et al. Application of Pediatric Appendicitis Score on the emergency department of a secondary level hospital. Pediatric emergency care. Jun. 2012;28(6):489-92. [pmid: 22653450].

## B-2. Rejection Reason: Abstract Only

1 Clinical Rounds: Speed bumps may accelerate diagnosis. Nursing. 2013;43(3):28-9. Language: English. Entry Date: 20130405. Revision Date: 20140124. Publication Type: journal article.
2 Abbasi N, Bergman S, Patenaude V, Abenhaim H. Comparison of management and outcomes of acute appendicitis in pregnancy. American journal of obstetrics and gynecology. 2014;210(1):S271-S2. PMID:.
3 Adelgais KM, Kuppermann N, Kooistra J, Garcia M, Monroe D, Mahajan P, Menaker J, Erlich P, Atabaki S, Page K, Kwok M, Holmes J. Importance and performance of the abdominal examination to identify children with abdominal injuries. Academic Emergency Medicine. 2013;20(5):S299. PMID:.
4 Ahmed K, McLeod SL, Klingel M, Wu A, Theakston K. Imaging in the Diagnosis of Acute Appendicitis in Children: A retrospective chart review. Canadian Journal of Emergency Medicine. ((Ahmed K.; McLeod S. L.; Klingel M.; Wu A.; Theakston K.) University Western Ontario, London, Canada). 2014;16:S76. PMID:.
5 Akhavan M, Boccio E, Choi-Rosen J, Krief W. The utility and accuracy of skype in viewing computed tomography images from a remote facility for the diagnosis of appendicitis in pediatrics. Annals of emergency medicine. 2013;62(4):S111. PMID:.
6 Akhigbe T, Smith F, Adebowale A, et al. Acute appendicitis in children and Enterobius vermicularis: Surgical enigma. Irish journal of medical science. 2011;180:S280. PMID:.
7 Al-Brahim N, Al-Kandari I, Manahi M. Diverticular disease of the appendix: A clinico-pathological study of 25 cases. Histopathology. 2012;61:75-6. PMID:.
8 Al-sheikh M, Khout H, Toghyan H, Smith S, Fasih T. Diagnostic laparoscopy vs ultrasound scan: Which is better in the management of right iliac fossa pain?. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S237-S8. PMID:.
9 Al-sheikh M, Khout H, Toghyan H, et al. Diagnostic laparoscopy vs ultrasound scan: Which is better in the management of right iliac fossa pain?. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S237-S8. PMID:.
10 Al-sheikh M, Toghyan H, Smith S, et al. The role of laparoscopy in the management of acute abdomen. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S237. PMID:.
11 Altaf S, Warad D, Ishitani M, Rodriguez V, Khan S, Rao AN. Acute appendicitis in acute leukemias: A case series and literature review. Pediatric Blood and Cancer. 2012;58(7):1052. PMID:.
12 Altaf S, Warad D, Ishitani M, et al. Acute appendicitis in acute leukemias: A case series and literature review. Pediatric Blood and Cancer. 2012;58(7):1052. PMID:.
13 Alukal J, Antony J. Accuracy of alvarado score in the diagnosis of appendicitis. Australasian Medical Journal. 2012;5(1):56. PMID:.
14 Alukal J, Antony J. Accuracy of alvarado score in the diagnosis of appendicitis. Australasian Medical Journal. 2012;5(1):56. PMID:.
15 Alzahrani MA, Dennis H, Sussman J, Ahmad SA. Pre-operative imaging does not accurately stage patients with early stage appendiceal cancer. Gastroenterology. 2012;142(5):S1037. PMID:.
16 Ansaloni L, Catena F, Coccolini F, Gazzotti F, Pinna A. Multicentre randomized, double-blind, controlled trial of laparoscopic versus open surgery for suspected appendicitis in adults (the Leonardo study): preliminary results. European Journal of Trauma and Emergency Surgery [serial on the Internet]. 2007;(3 Suppl 2). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/411/CN-00614411/frame.html. Last accessed.
17 Arharov A, Glabai V, Keshishev A, Yunusov B, Aliev A. Surgical treatment of severe acute pancreatitis. HPB. ((Arharov A.; Glabai V.; Keshishev A.; Yunusov B.; Aliev A.) First Moscow State Medical University, Surgery, 11999, Moscow, Russian Federation). 2012;14:609. PMID:.
18 Armas ISD, Pimpalwar A. Laparoendoscopic single site appendectomy (LESS): Is it possible in children less than 8 years old?. Journal of Laparoendoscopic and Advanced Surgical Techniques. 2011;21(4):A63. PMID:.
19 Arminan JE, Roxin G, Stanger JD, MacLean AR, Buie WD. Right sided diverticulitis (RSD)-highly successful non-operative management and low recurrence rate. Gastroenterology. 2012;142(5):S1052. PMID:.
20 Asrani A, Tanaka I, Belfi L, Mennitt K. Finding the appendix: Pearls and pitfalls in mri of suspected appendicitis in pregnancy. Emergency radiology. 2012;19(5):371. PMID:.
21 Asrani A, Tanaka I, Belfi L, et al. Finding the appendix: Pearls and pitfalls in mri of suspected appendicitis in pregnancy. Emergency radiology. 2012;19(5):371. PMID:.
22 Aziz A, Healy DA, Wong M, et al. Prospective cost analysis study of cases of right iliac fossa pain. Irish journal of medical science. 2012;181:S29. PMID:.
23 Bai Y, Zhu Y, Zhou Q. The value of preoperative ultrasound exanimation in Appendix. Journal of gastroenterology and hepatology. ((Bai Y.; Zhu Y.; Zhou Q.) Ultrasound Department; Internal Medicine). 2013;28:467. PMID:.
24 Bailey B, Bergeron S, Gravel J, et al. Efficacy and impact of intravenous morphine before surgical consult in children with right lower quadrant pain suggestive of appendicitis: a randomized controlled trial... 2007 Society for Academic Emergency Medicine Annual Meeting. Academic Emergency Medicine. 2007;14(5):S90-S. Language: English. Entry Date: 20091211. Revision Date: 20091218. Publication Type: journal article.
25 Bakr AM. Laparoscopic appendectomy for the retrocecal subhepatic appendix: Tips and tricks. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S102. PMID:.
26 Bakr AM. Laparoscopic appendectomy for the retrocecal subhepatic appendix: Tips and tricks. Surgical Endoscopy and Other Interventional Techniques. ((Bakr A.M.) Cairo University, Cairo, Egypt). 2013;27:S102. PMID:.
27 Ball CG, Dixon E, MacLean AR, et al. The impact of a dedicated acute care surgery clinical care pathway for suspected appendicitis on diagnostic imaging and flow through the emergency department. Gastroenterology. 2012;142(5):S1051. PMID:.
28 Barksdale A, Gratton M, Hackman J, Bonham A. Diagnosis and disposition are changed when board certified emergency physicians use CT for non-traumatic abdominal pain. Annals of emergency medicine. 2012;60(4):S61. PMID:.
29 Barrett MJ, Pollock J, Harney T, Yeung SJ, Laffan K, Clarke E, Darcy S, Grant T, Melody L, Fitzpatrick P, Cashman S, Howard C, Iqbal Z, Taib F, McCoy S, Walsh S, O’Sullivan R. The correlation between c-reactive protein and serious bacterial infection in a tertiary paediatric emergency department: An observational case-controlled cohort study. Archives of disease in childhood. ((Barrett M.J.; Pollock J.; Harney T.; Yeung S.J.; Laffan K.; Clarke E.; Darcy S.; Melody L.; Fitzpatrick P.; Cashman S.; Howard C.; Iqbal Z.; Taib F.; McCoy S.; Walsh S.; O’Sullivan R.) Paediatric Emergency Research Unit, Department of Emergency Medicine, Our Lady’s Children’s Hospital Crumlin (OLCHC), Dublin, Ireland). 2012;97:A446-A7. PMID:.
30 Benkoe T, Baumann S, Angleitner P, et al. Immunphenotypical characterization of appendiceal and peripheral blood lymphocytes in children. European Surgery - Acta Chirurgica Austriaca. 2011;43:76. PMID:.
31 Bermudez GAA, Falla AR, Maldonado WS. Complicated acute appendicitis (peritonitis), laparoscopic management comparison of two techniques. Surgical Endoscopy and Other Interventional Techniques. ((Bermudez G.A.A.; Falla A.R.; Maldonado W.S.) Central Military Hospital, Bogota, Colombia). 2013;27:S480. PMID:.
32 Bernard K, Thorne F. Appendicitis: Histopathologial variations and the rate of negative appendectomies at the Eric Williams Medical Sciences Complex-2008 to 2010. West Indian Medical Journal. ((Bernard K., kanekajoy@yahoo.com; Thorne F.) Eric Williams Medical Sciences Complex, University of the West Indies, Mt Hope, Trinidad and Tobago). 2012;61:26. PMID:.
33 Bernard K, Thorne F. Appendicitis: Histopathologial variations and the rate of negative appendectomies at the Eric Williams Medical Sciences Complex-2008 to 2010. West Indian Medical Journal. 2012;61:26. PMID:.
34 Berselli M, Mangano A, Livraghi L, Latham L, Farassino L, Cotronea C, Bianchi V, Pagano G, Gambitta B, Cocozza E. Laparoscopic approach to abdominal emergencies: Results from a retrospective series of adult population according to eaes guidelines. Surgical Endoscopy and Other Interventional Techniques. ((Berselli M.; Mangano A.; Livraghi L.; Latham L.; Farassino L.; Cotronea C.; Bianchi V.; Pagano G.; Gambitta B.; Cocozza E.) Azienda Ospedaliera Ospedale di Circolo e Fondazione Macchi, Varese, Italy). 2014;28:S8. PMID:.
35 Bhullar JS, Chaudhary S, Gayagoy J, Adams J, Watson J, Lopez P, Mittal VK. Acute appendicitis in elderly: Diagnosis and management still a challenge. Surgical Endoscopy and Other Interventional Techniques. ((Bhullar J.S.; Chaudhary S.; Gayagoy J.; Adams J.; Watson J.; Lopez P.; Mittal V.K.) Department of Surgery, Providence Hospital, United States). 2013;27:S479. PMID:.
36 Bhullar JS, Chaudhary S, Gayagoy J, et al. Acute appendicitis in elderly: Diagnosis and management still a challenge. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S479. PMID:.
37 Birth M, Witten I, Gadzepko E, Weiser HF. Laparoscopic versus open appendectomy for acute appendicitis: a prospective randomized trial [abstract]. British Journal of Surgery [serial on the Internet]. 1998;(Suppl 2). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/479/CN-00594479/frame.html. Last accessed.
38 Blanco-Antona F, Sanchez J, Toledano M, Martin ML, Colao L, Blanco-Antona L, Bahamonde-Cabria S, Martin JC. Laparoscopic appendicectomy: 5 years experience in a community hospital. Colorectal Disease. ((Blanco-Antona F.; Sanchez J.; Toledano M.; Martin M.L.; Colao L.; Martin J.C.) Hospital de Medina del Campo, Medina del Campo, Valladolid, Spain). 2012;14:34. PMID:. [pmid: 23136823].
39 Blanco-Antona F, Sanchez J, Toledano M, et al. Laparoscopic appendicectomy: 5 years experience in a community hospital. Colorectal Disease. 2012;14:34. PMID:. [pmid: 23136823].
40 Boo Y, Kwak J, Lee E. Higher intra-abdominal surgical infection and readmission rates after laparoscopy in pediatric complicated appendicitis. Surgical infections. 2013;14(2):A9-A10. PMID:.
41 Bossotti M, Bona A, Revelli P, Borasi A, Barberis A, Bellomo P, De Paolis P. Laparoscopic approach to acute appendicitis: The last 5 years experience. Surgical Endoscopy and Other Interventional Techniques. ((Bossotti M.; Bona A.; Revelli P.; Borasi A.; Barberis A.; Bellomo P.; De Paolis P.) Presidio Sanitario Gradenigo, Turin, Italy). 2012;26:S73. PMID:.
42 Boutong S, Sheikh I, Howlader M, et al. The reasons behind conversion of laparoscopic appendicectomy to open. Colorectal Disease. 2011;13:29. PMID:.
43 Bowe CT, Trydestam C, Gregory W, et al. Computed tomography usage for emergency department patients with suspected appendicitis following implementation of a multidisciplinary scoring system-based protocol. Annals of emergency medicine. 2012;60(4):S85. PMID:.
44 Boyko NI, Havrysh Y, Khomyak V, Kemin R, Revura A. Carcinoid tumors of the appendix. Surgical Endoscopy and Other Interventional Techniques. ((Boyko N.I.; Havrysh Y.; Khomyak V.; Kemin R.; Revura A.) Lviv Medical University, Lviv, Ukraine). 2013;27:S92. PMID:.
45 Buescher E, Paka P, Paka C, et al. Frequency of appendiceal pathology encountered during surgery for pelvic pain. Journal of Minimally Invasive Gynecology. 2012;19(6):S27. PMID:.
46 Butt M, Connolly B, Durrani S, Harding B. Retrospective study of role of early vs late CT abdomen for acute abdomen. Irish journal of medical science. ((Butt M.; Connolly B.; Durrani S.; Harding B.) Surgical Department, Portiuncula Hospital Ballinasloe, Galway, Ireland). 2013;182:S172. PMID:.
47 Cabrera D, Bellolio MF, Vukov L. Mortality and acute renal failure after contrast enhanced computed tomography in octogenarians presenting to an emergency department with acute abdominal pain... 2007 Society for Academic Emergency Medicine Annual Meeting. Academic Emergency Medicine. 2007;14(5):S17-S. Language: English. Entry Date: 20091211. Revision Date: 20111230. Publication Type: journal article.
48 Castillo M, Bernal AJ, Fajardo R. Design of a bayesian network as a decision model for the diagnosis of appendicitis. Value in Health. 2012;15(4):A72-A3. PMID:.
49 Castillo M, Bernal AJ, Fajardo R. Design of a bayesian network as a decision model for the diagnosis of appendicitis. Value in Health. 2012;15(4):A72-A3. PMID:.
50 Celona G. Role of laparoscopic appendectomy in complicated appendicitis. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S18. PMID:.
51 Ceron M, Guerrero D, Bustos E, et al. Most frequent clinical manifestations of acute appendicitis in children under the age of three: Fifteen years of experience in the hospital infantil de mexico federico gomez emergency department. Acta Paediatrica, International Journal of Paediatrics. 2011;100:46. PMID:.
52 Chan V, Dorfman M, Chan SB. Sterile pyuria in acute appendicitis and diverticulitis. Academic Emergency Medicine. 2014;21(5):S206. PMID:.
53 Chapman S, Hakeem A, Smith N, Prasad KR. Does neutrophil-lymphocyte ratio predict outcome of appendicectomy?. International Journal of Surgery. 2013;11(8):654. PMID:.
54 Chaudhary V, Sharma R, Rana SS, Sharma V, Chhabra P, Bhasin DK. Comparative evaluation of abdominal ultrasound, endoscopic ultrasound and magnetic resonance imaging in detecting solid necrotic debris in walled off pancreatic necrosis. Gastroenterology. 2014;146(5):S623-S4. PMID:.
55 Chen EH, Baumann BM, Matsuura AC, et al. The impact of radiologic imaging on the management of ED patients with acute abdominal pain. Academic Emergency Medicine. 2011;18(5):S30. PMID:.
56 Chen PY, Chen JD, Tiu CM, et al. Ultrasound diagnosis of diverticulitis of right colon. Emergency radiology. 2011;18(6):456-7. PMID:.
57 Chiricolo G, Laudenbach A, Mooney T, et al. The effect on CT utilization in patients who have undergone appendectomy after emergency ultrasound of the appendix was introduced to an emergency department. Academic Emergency Medicine. 2012;19:S206-S7. PMID:.
58 Chiu YH, Chen JD, Tiu CM, et al. Is intravenous contrast intake necessary for CT diagnosis of acute appendicitis at ED?. Emergency radiology. 2011;18(6):456. PMID:.
59 Chowdhury M, Gillies M, Lakhoo K. A pitfall in the interpretation of plain abdominal radiographs in neonatal intestinal perforation. Journal of Medical Imaging and Radiation Oncology. ((Chowdhury M; Gillies M; Lakhoo K) Childrens Hospital, Oxford University Hospitals, Oxford, United Kingdom). 2012;56:174. PMID:.
60 Chumpitazi CE, Bendure EO, Valdez K, et al. Evaluation and treatment of children with abdominal pain and constipation in the emergency department. Gastroenterology. 2013;144(5):S607. PMID:.
61 Ciscar Belles A, Amillo Zaragueta M, Guirao Garriga X, Amador Gil S, Hernando Tavira R, Badia Perez J. Assessment of clinical risk factors in the perforated appendicitis. Surgical infections. 2013;14(2):A8. PMID:.
62 Cochon L, Pena M, Baez A. Comparative assessment of diagnostic accuracy of computed tomography and ultrasonography in the diagnosis of acute appendicitis after the application of the alvarado scoring system. Annals of emergency medicine. 2013;62(4):S35. PMID:.
63 Cotirlet A, Motoc I, Nedelcu MD. Laparoscopy for management of nontraumatic acute abdomen. Surgical Endoscopy and Other Interventional Techniques. ((Cotirlet A.; Motoc I.; Nedelcu M.D.) Moinesti Hospital, Moinesti, Romania). 2014;28:S57. PMID:.
64 Coyne SM, Trout AT, Zhang B. Does appendix diameter change with age? A sonographic study. Pediatric radiology. ((Coyne S.M.; Trout A.T.; Zhang B.) Cincinnati Children’s Hospital Medical Center, Cincinnati, United States). 2014;44:S328. PMID:.
65 Crain E, Kaufman I, Weinberg G, et al. Significance of Pseudomonas in perforated appendicitis in children. Emergency & Office Pediatrics. 1998;11(1):24-6. Language: English. Entry Date: 19981101. Revision Date: 20091218. Publication Type: journal article.
66 Cruttenden-Wood DR, Glaysher MA, Zeidan B, Saeed K, Miles AJ. Can procalcitonin levels tell us when to operate? A double blinded study to investigate the role of plasma procalcitonin (PCT) levels as an adjunct marker in clinically suspected appendicitis. International Journal of Surgery. 2013;11(8):651. PMID:.
67 Davenport K, Fairbanks T, Bickler S, Kling K, Hilfiker M, Saenz N, Grabowski J. Value of c-reactive protein in predicting abscess in pediatric appendicitis. Surgical infections. ((Davenport K; Fairbanks T; Bickler S; Kling K; Hilfiker M; Saenz N; Grabowski J) University of California, San Diego Rady Children’s Hospital, United States). 2014;15:S32-S3. PMID:.
68 De Armas IS, Pimpalwar A. Perforated appendicitis: Is single-incision laparoscopic appendectomy (SILS) a good idea?. Journal of Laparoendoscopic and Advanced Surgical Techniques. 2011;21(4):A20. PMID:.
69 Del Pin CA, Feinn RS, Train J. Right lower quadrant pain: Platelet count an indicator for laparoscopic appendectomy?. Surgical Endoscopy and Other Interventional Techniques. ((Del Pin C.A.; Feinn R.S.; Train J.) Quinnipiac University/Frank H.Netter MD SOM, United States). 2014;28:407. PMID:.
70 Del Pozo Garcia G, Carpio VM, Hilario A, et al. Should the abdominal radiograph be the initial imaging examination in the pediatric patient with abdominal pain?. Pediatric radiology. 2011;41:S272. PMID:.
71 Delgado J, Mahboubi S. Incidental findings atmultidetector computed tomography in children who referred emergency department to be evaluated for right lower quadrant pain. Pediatric radiology. ((Delgado J.; Mahboubi S.) Children’s Hospital of Philadelphia, Philadelphia, United States). 2013;43:S562. PMID:.
72 Delgado J, Mahboubi S. Incidental findings atmultidetector computed tomography in children who referred emergency department to be evaluated for right lower quadrant pain. Pediatric radiology. 2013;43:S562. PMID:.
73 Demir AY. Implementation of c-reactive protein (CRP) point of care testing in the primary care: A pilot study. Clinical Chemistry and Laboratory Medicine. ((Demir A.Y.) Meander Medical Center, Amersfoort, Netherlands). 2014;52:S1521. PMID:.
74 Doiron RJ, Hartin CW, Ozgediz DE, et al. Who’s guarding whom? The changing of the guard: A study of pediatric abdominal examinations. Journal of Surgical Research. 2012;172(2):294-5. PMID:.
75 D’Souza N, Karim D, Sunthareswaran R. Hyperbilirubinaemia predicting simple and perforated appendicitis. Diseases of the colon and rectum. 2013;56(4):e157-e8. PMID:.
76 D’Souza N, Karim D, Sunthareswaran R. Hyperbilirubinaemia predicting simple and perforated appendicitis. Diseases of the colon and rectum. 2013;56(4):e157-e8. PMID:.
77 Ekere C, Mehta C, Royston E, Arrowsmith C, Talbot R. Does ultrasound scanning RIF pain have a role in the investigation of suspected acute appendicitis. International Journal of Surgery. 2013;11(8):699. PMID:.
78 Elikashvili I, Tay ET, Tsung JW. The effect of operator experience on test performance characteristics for point-of-care ultrasound in diagnosing appendicitis in children: Implications for reducing misdiagnosis-related medical errors. Academic Emergency Medicine. 2013;20(5):S7. PMID:.
79 Elikashvili I, Tay ET, Tsung JW. The effect of operator experience on test performance characteristics for point-of-care ultrasound in diagnosing appendicitis in children: Implications for reducing misdiagnosis-related medical errors. Academic Emergency Medicine. 2013;20(5):S7. PMID:.
80 Ellemeir A, Swenson DW, Lourenco AP, Herliczek TW. Emergentmr imaging of right lower quadrant pain in children: Appendicitis and mimics. Emergency radiology. 2013;20(5):351. PMID:.
81 Emmanuel A, Murchan P, Wilson I, et al. Bilirubin is a specific marker for acute appendicitis. Irish journal of medical science. 2011;180:S95. PMID:.
82 Enholm B, Rabah S, Pirkka V, Maaret K, Marc B, Ari L. A comparison of the plasma proteome of patients with appendicitis, mesenterial ischemia, and secondary peritonitis. Surgical infections. 2012;13(3):A10. PMID:.
83 Ergun M, Tunc B, Ulker A, Sasmaz N. Clinical challenge for physicians: Abdominal tuberculosis review of 24 cases. Hepatology International. ((Ergun M.) Gastroenterology, Sisli Etfal Education and Research Hospital, Istanbul, Turkey). 2013;7:S700. PMID:.
84 Eroglu M, Ozdemir Y, Balta A, Osman Yildirim A, Emrah Eyi Y, Sucullu I, Akin M. Use of neutrophil/lymphocyte ratio in diagnosis of phlegmonous appendicitis. American Journal of Gastroenterology. ((Eroglu M.; Ozdemir Y.; Balta A.; Osman Yildirim A.; Sucullu I.; Akin M.) Emergency Medicine, GMMA Haydarpasa Training Hospital, Istanbul, Turkey). 2013;108:S182. PMID:.
85 Fahimi J, Herring A, Alter H. Trends in emergency department use of CT scan among children presenting with abdominal pain. Academic Emergency Medicine. 2011;18(5):S70-S1. PMID:.
86 Fahmy M, Pola S, Sandborn WJ, et al. Frequency and yield of computed tomography (CT) scan imaging in the emergency department in patients with inflammatory bowel disease (IBD). Gastroenterology. 2012;142(5):S536-S7. PMID:.
87 Farrell AE, Richardson D. Patients undergoing appendectomies: The effects of practice change. EMA - Emergency Medicine Australasia. ((Farrell A.E.; Richardson D.) Emergency Department, Canberra Hospital, Canberra, Australia). 2013;25:9. PMID:.
88 Farrell AE, Richardson D. Patients undergoing appendectomies: The effects of practice change. EMA - Emergency Medicine Australasia. 2013;25:9. PMID:.
89 Fedko MG, Bellamkonda Athmaram VR, Bellolio M, Campbell RL. The missing appendix. Annals of emergency medicine. 2012;60(4):S24. PMID:.
90 Ferlitsch A, Puspok A, Gasche C. Detection of appendix pathology by a novel endoscopic imaging procedure. Gastrointestinal endoscopy. 2012;75(4):AB173. PMID:.
91 Fernandes R, Williams S, Dhillion B, Roy P, Andrews B, Patel S, Rajwani K. An evaluation of the Alvarado scoring system in acute appendicitis and the effect of its modification. Colorectal Disease. ((Fernandes R.; Patel S.; Rajwani K.) QEQM Hospital, Margate, United Kingdom). 2012;14:35. PMID:. [pmid: 21114752].
92 Fernandes R, Dunstan M, Mukherjee D, et al. An assessment of the value of post appendicectomy colonoscopy in those over the age of 50 years. Colorectal Disease. 2012;14:21. PMID:.
93 Fernandes R, Williams S, Dhillion B, et al. An evaluation of the Alvarado scoring system in acute appendicitis and the effect of its modification. Colorectal Disease. 2012;14:35. PMID:. [pmid: 21114752].
94 Frizelle FA, Bagshaw RN, Dalen PF, Robertson GM. The utility of laparoscopy in the diagnosis of acute appendicitis in women of repoductive age: a prospective randomized study with long-term follow-up [abstract]. ANZ journal of surgery [serial on the Internet]. 2002. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/384/CN-00475384/frame.html. Last accessed.
95 Fung AKY, Ahmeidat H, McAteer D, Aly EH. Retrospective validation of a CT-grading system for acute complicated diverticulitis in the prediction of the need for operative or percutaneous intervention. Colorectal Disease. ((Ahmeidat H.) Aberdeen Medical School, Aberdeen, United Kingdom). 2012;14:46. PMID:.
96 Gafter-Gvili A, Paul M, Bernstine H, et al. The role of PET-CT for the diagnosis of infections in hemato-oncological patients with persistent febrile neutropenia. Blood. 2011;118(21). PMID:.
97 Galbreath T, Perez M, Tucker JJ, Bell T, Grim R, Martin J, Wesner V, Mueller M, Ahuja V. Appendicitis in the community center: Validation that ct scan is not indicated in adult males with suggestive clinical evaluation and leukocytosis. Journal of Surgical Research. 2014;186(2):552. PMID:.
98 Gans S, Atema J, Kiewiet J, Lameris W, Laurell H, Toorenvliet B, Boermeester M. The predictive value of CRP and WBC in the clinical diagnosis of acute abdominal pain. Surgical infections. 2013;14(2):A5. PMID:.
99 Garcia M, Drugas G, Babcock-Cimpello L, et al. CT scan with IV contrast alone for evaluation of pediatric appendicitis... 2007 Society for Academic Emergency Medicine Annual Meeting. Academic Emergency Medicine. 2007;14(5):S91-S. Language: English. Entry Date: 20091211. Revision Date: 20091218. Publication Type: journal article.
100 Garcia M, Taylor G, Cimpello LB, et al. CT scan with IV contrast alone: The role of Intra-abdominal Fat (IAF) on the ability to visualize the normal appendix. Academic Emergency Medicine. 2011;18(5):S232. PMID:.
101 Garel LA. Bowel sounds and music: Malrotation, intussusception, appendicitis, inflammatory bowel disease, imperforate anus. Pediatric radiology. 2012;42:S234. PMID:.
102 Gill J, Lalli P, Wang D, et al. The Calgary multifaceted intervention for suspected appendicitis reduces ED length of stay and time to surgery. Canadian Journal of Emergency Medicine. 2013;15:S54. PMID:.
103 Goldberg-Stein S, Liu B, Hahn PF, et al. Body computed tomography during pregnancy: Utilization trends, examination indications, and fetal radiation doses. Obstetrical and Gynecological Survey. 2011;66(5):271-3. PMID:.
104 Gray SH, Simard R, Lee JS. Which test leads to the shorter ED length of stay for patients with appendicitis: ultrasound or CT scan?. Canadian Journal of Emergency Medicine. ((Gray S. H.; Simard R.; Lee J. S.) St. Michaelnulls Hospital, Toronto, Canada). 2014;16:S89. PMID:.
105 Grechushkin V, Verma R, Barish M, Telem D. Utilityand accuracy of CT scan in distinguishing perforated from nonperforated acute appendicitis without evidence of abscess or phlegmon. Emergency radiology. 2013;20(5):350. PMID:.
106 Gregory J, Poonai N, Lim R, et al. Does pelvic ultrasound lead to a significant delay in management of acute pediatric appendicitis?. Canadian Journal of Emergency Medicine. 2012;14:S41-S2. PMID:.
107 Gupta M, Fasih N, Gupta R, et al. MRI of acute abdomen in pregnancy: A nightmare on call?. American Journal of Roentgenology. 2011;196(5):A134. PMID:.
108 Haider HH, Al-Aradi DF, Juma RT, Al-Herz W, Juma T. Appendiceal phlegmon; A laparoscopically defeated foe. Surgical Endoscopy and Other Interventional Techniques. ((Haider H.H.; Al-Aradi D.F.; Juma R.T.; Al-Herz W.; Juma T.) Department of Surgery, Amiri Hospital, Kuwait). 2012;26:S270. PMID:.
109 Hamid HA, Daneman A, Azzie G, et al. The role of delayed repeat ultrasound in children with right lower quadrant pain. Pediatric radiology. 2011;41:S272-S3. PMID:.
110 Harmon L, Chapa L, Jupiter D, Davis M, Frazee R, Smith R, Regner J. Computed tomography to operating room in less than 3 hours may become new standard in minimizing complications from appendicitis. Journal of the American College of Surgeons. 2013;217(3):S24-S5. PMID:.
111 Hatanaka M, Igarashi A, Suzuki M, et al. Substitution of conventional laparoscopic surgery with single-incision laparoscopic surgery for performing appendectomy: A single institution review. Journal of Laparoendoscopic and Advanced Surgical Techniques. 2011;21(4):A63-A4. PMID:.
112 Healy C, Hehir D. Influence of age and gender on application of the Alvarado score in diagnosis of acute appendicitis. Irish journal of medical science. 2011;180:S282. PMID:.
113 Healy DA, Aziz A, Mc Cartan D, et al. Increased use of laparoscopy reduces length of stay and the negative appendicectomy rate: A comparative analysis. Irish journal of medical science. 2012;181:S41. PMID:.
114 Henderson AA, Anupindi S, Servaes S, et al. Comparison of two-view abdominal radiographs to ultrasound in children with suspected intussusception. Pediatric emergency care. 2011;27(10):996. PMID:.
115 Hill ADK, Attwood SEA, Murphy PG, Stephens RB. Laparoscopic versus open appendicectomy - interim results of the randomised trial [abstract]. Irish journal of medical science [serial on the Internet]. 1992;(8). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/324/CN-00255324/frame.html. Last accessed.
116 Hotchkiss J, Roberge E, Graham J. The diagnostic accuracy of MRI in the evaluation of acute right lower quadrant pain during pregnancy. Emergency radiology. 2011;18(6):478. PMID:.
117 Hryhorczuk A, Melvin P, Taylor G. Imaging patterns for the evaluation of appendicitis among pediatric hospitals in the United States, 2005–2010. Pediatric radiology. 2011;41:S346. PMID:.
118 Huang WC, Chen JD, Tiu CM, et al. CT and ultrasound features of primary epiploic appendagitis in taiwaneses. Emergency radiology. 2011;18(6):479. PMID:.
119 Huber AW, Santi A, Muller MD. Clinical application of transvaginal Natural Orifice Translumenal Endoscopic Surgery (NOTES) in gynaecology. Gynecological Surgery. 2009;6:S57. PMID:.
120 Hussain T, Khan A. Suppressed leukocyte count among patients of acute appendicitis: An observational study. Journal of gastroenterology and hepatology. ((Hussain T.) Medicine/Gastroenterology, Isra University Teaching Hospital, Islamabad, Pakistan). 2012;27:158. PMID:. [pmid: 21871026].
121 Hussain T, Khan A. Suppressed leukocyte count among patients of acute appendicitis: An observational study. Journal of gastroenterology and hepatology. 2012;27:158. PMID:. [pmid: 21871026].
122 Ito K, Anderson C, Basson MD. Can serum lactate predict the outcome of patients who underwent emergent exploratory laparotomy for acute abdomen?. Gastroenterology. 2013;144(5):S1135-S6. PMID:.
123 Jain A, Kramullah E, Ahmad I, et al. Applications and limitations of ultrasound in imaging of acute abdomen: A pictorial essay. Journal of Medical Imaging and Radiation Oncology. 2012;56:165. PMID:.
124 Jesinger R, Baril R, Bleazard S, et al. Sonographic assessment of nontraumatic right upper quadrant abdominal pain in the emergency department: What if the diagnosis is not acute cholecystitis?. American Journal of Roentgenology. 2011;196(5):A134. PMID:.
125 Jhaj J, Sinha S, Patil S, Puckett M. The appropriateness of abdominal X-rays in surgical emergencies. European Surgical Research. 2014;52(3–4):175. PMID:.
126 Jude C, Zhang D, Patel M, Andrews-Tang D, Lee M, Poon C, Douek M, Doepke L. Unexpectedly low trade-offs in diagnostic accuracy and radiation dose in the performance of a clinical CT task. American Journal of Roentgenology. 2012;198(5). PMID:.
127 Kadam S, Mehta D, Clyde E, Ahmed I. Appendicectomy approach: Do we choose based on gender and time of day?. International Journal of Surgery. 2013;11(8):714. PMID:.
128 Kahmmanca S, Seker G, Azili C, et al. The role of fibrinogen, mean platelet volume and platelet distribution width in diagnosis of acute appendicitis. European Surgical Research. 2013;50:139. PMID:.
129 Kahramanca S, Seker G, Azili C, Guzel H, Kucukpinar T, Kulaconulllu IH. The role of fibrinogen, mean platelet volume and platelet distribution width in diagnosis of acute appendicitis. European Surgical Research. ((Kahramanca S.; Seker G.; Azili C.; Guzel H.; Kucukpinar T.; Kulaconulllu I.H.) Diskapi Yildirim Beyazit Research and Training Hospital, Turkey). 2013;50:139. PMID:.
130 Kaiser S, Gordon L, Andersson H. Patient dose reduction in pediatric abdominal CT using adaptive post processing filters: A prospective randomized study. Pediatric radiology. 2011;41:S422-S3. PMID:.
131 Kao LC, Yang PF, Fan WC. Comparing conventional and single-port laparoscopic appendectomies: A randomized prospective trail. Surgical endoscopy [serial on the Internet]. 2013. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/529/CN-00856529/frame.html. Last accessed.
132 Karasakalides A, Kapoutzis K, Michalopoulou E. Single incision laparoscopy for assessment and treatment of the acute abdomen. Surgical Endoscopy and Other Interventional Techniques. ((Karasakalides A.; Kapoutzis K.; Michalopoulou E.) Giannitsa General Hospital, Giannitsa, Greece). 2014;28:418. PMID:.
133 Katz D, Lu M, Daly B, et al. Acute complications of optical colonoscopy: CT diagnosis. Emergency radiology. 2011;18(6):477-8. PMID:.
134 Kelly ME, Heeney A, Winter DC. One year review of emergency CT scans performed in a university hospital. European Surgical Research. 2014;52(3–4):174-5. PMID:.
135 Kim Y, Cho Y, Jeong W. CT manifestations of variety appendiceal diseases; Pathologic correlation. Journal of Medical Imaging and Radiation Oncology. ((Kim Y.; Cho Y.; Jeong W.) Hanyang University, Guri Hospital, Guri city, South Korea). 2012;56:194. PMID:.
136 Kim Y, Cho Y, Jeong W. CT manifestations of variety appendiceal diseases; Pathologic correlation. Journal of Medical Imaging and Radiation Oncology. 2012;56:194. PMID:.
137 Klein SA, Budjan J, Heidenreich D, Attenberger U, Kreil S, Schonberg S, Hofmann WK, Michaely HJ. Identification of characteristic findings by abdominal magnetic resonance imaging in acute intestinal graft versus host disease. Blood. 2012;120(21). PMID:.
138 Kocher KE. National trends in use of computed tomography on the pediatric population in the emergency department. Academic Emergency Medicine. 2011;18(5):S60. PMID:.
139 Kokhanovsky N, Zeina AR, Reindorp N, Levit-Kantor A, Nachtigal A. Accuracy of ultrasonographic diagnosis of acute appendicitis in child population. Pediatric radiology. ((Kokhanovsky N.; Zeina A.-R.; Reindorp N.; Levit-Kantor A.; Nachtigal A.) Hillel Yaffe Medical Center, Hadera, Israel). 2013;43:S560. PMID:.
140 Kolbe N, Killu K, Coba V, Neri L, Bakey S, Louwers L, Blyden D, Horst H. Implementing point of care ultrasound (POCU) in rural nicaragua changes patient management. Critical Care Medicine. 2013;41(12):A31. PMID:.
141 Kollar D, McCartan D, Bourke M, Cross SK, Dowdall J. Predicting acute appendicitis? A prospective comparison of the alvarado score, the appendicitis inflammatory response score and clinical assessment. European Surgical Research. 2014;52(3–4):97. PMID:.
142 Konarski A, Sekhar H, Horsley A, Smart C, Darmas B. Rate and influencing factors of negative appendicectomy in the paediatric population. International Journal of Surgery. 2013;11(8):674. PMID:.
143 Kovanlikaya A, Rosenbaum D, Mazumdar M, Dunning A, Brill P. MR imaging of the normal appendix in children with suspected inflammatory bowel disease. Pediatric radiology. ((Kovanlikaya A.; Rosenbaum D.; Mazumdar M.; Dunning A.; Brill P.) NewYork Presbyterian Hospital, Weill Cornell Medical College, New York, United States). 2012;42:S488-S9. PMID:.
144 Kutovyy OB, Pelekh VA, Ruban NK, et al. Laparoscopic surgery for pregnancy. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S86. PMID:.
145 Kuzmichev KA, Khatkov IE, Chudnykh SM, Aliev ES. Laparoscopic versus open appendectomy in pregnancy: A comparative analysis. Surgical Endoscopy and Other Interventional Techniques. ((Kuzmichev K.A.; Khatkov I.E.; Chudnykh S.M.; Aliev E.S.) MSUMD, Moscow, Russian Federation). 2014;28:S27. PMID:.
146 Lalli P, Gill J, Wang D, Mercuur L, Lang E, McRae A. An expedited oral contrast protocol for suspected appendicitis does not lead to missed cases requiring surgery. Canadian Journal of Emergency Medicine. ((Lalli P; Gill J; Wang D; Mercuur L; Lang E.; McRae A.) University of Alberta, Canada). 2013;15:S68. PMID:.
147 Lalli P, Gill J, Wang D, et al. An expedited oral contrast protocol for suspected appendicitis does not lead to missed cases requiring surgery. Canadian Journal of Emergency Medicine. 2013;15:S68. PMID:.
148 Lam SHF, Grippo A, Konicki PJ, Strasburger D, Kerwin C. Bedside ultrasonography as an adjunct to routine workup to evaluate for possible acute appendicitis in the emergency department. Academic Emergency Medicine. 2013;20(5):S253. PMID:.
149 Lam SHF, Grippo A, Konicki PJ, et al. Bedside ultrasonography as an adjunct to routine workup to evaluate for possible acute appendicitis in the emergency department. Academic Emergency Medicine. 2013;20(5):S253. PMID:.
150 Lanitis S, Korotzi M, Sgourakis G, Karkoulias K, Konovounisios C, Zafeiriadou P, Karaliotas C. Has laparoscopic appendicectomy a role in the greek healthcare system? a comparative study. Surgical Endoscopy and Other Interventional Techniques. ((Lanitis S.) Korgialenio-Benakio’, Athens General Hospital, Athens, Greece). 2012;26:S10. PMID:.
151 Lanza C, Amici L, Bolli V, et al. Ultrasound in acute abdominal pain in pediatric emergency department: What use?. Pediatric radiology. 2011;41:S350. PMID:.
152 Leaper DJ, De Dombal FT, Horrocks JC, et al. Computer-assisted diagnosis of abdominal pain using estimates provided by clinicians. The British journal of surgery. Nov. 1972;59(11):897-8. [pmid: 4564750].
153 Lee HJ, Kang E, Shin JH. Effectiveness of noncontrast abdominal multidetector CT for evaluating the patient with renal insufficiency in the emergency department. Critical Care. 2014;18:S27-S8. PMID:.
154 Lee J, Rudge E, Boyes S. Pilot study: Evaluation of alvarado score in the diagnosis of acute appendicitis - A retrospective data analysis. International Journal of Surgery. 2013;11(8):709-10. PMID:.
155 Lengsu WC. The reliability of ultrasonography in the detection of pneumoperitoneum in acute abdomen with suspect hollow organ perforation. EMA - Emergency Medicine Australasia. 2012;24:25. PMID:.
156 Li D, Kang C, Liu J. Laparoendoscopic single-site surgery (LESS) abdominal exploration in acute abdomen: One unit experiences with 90 consecutive cases. Surgical Endoscopy and Other Interventional Techniques. ((Li D.; Kang C.; Liu J.) Dept. Surgery, Aerospace Center Hospital, Peking University, China). 2012;26:S424. PMID:.
157 Lin CM, Tseng LM, Chen KC, et al. A resident training program reduces the use of ct scans in the diagnosis of acute appendicitis in the emergency department. Emergency radiology. 2011;18(6):480. PMID:.
158 Liu B, Feng J, Ma S, et al. Endoscopic retrograde appendicitis treatment (ERAT): A multicenter retrospective study in china. Gastrointestinal endoscopy. 2013;77(5):AB146. PMID:.
159 Liu BR, Ma X, Song J. Endoscopic retrograde appendicography: An efficiency diagnostic method for acute appendicitis. Gastroenterology. 2014;146(5):S-768. PMID:.
160 Liu L, Khatri K, Murray M, Sayegh M. Appropriateness of abdominal X-rays in patients admitted with acute abdominal pain. Colorectal Disease. ((Liu L.; Khatri K.; Murray M.; Sayegh M.) Worthing Hospital, West Sussex, United Kingdom). 2012;14:37. PMID:.
161 Liu L, Khatri K, Murray M, et al. Appropriateness of abdominal X-rays in patients admitted with acute abdominal pain. Colorectal Disease. 2012;14:37. PMID:.
162 Lockwood SL, Zafar A, Dromey BP, Hartley JE. Diagnostic laparoscopy in the management of lower abdominal pain in female patients presenting on an acute surgical take. International Journal of Surgery. 2013;11(8):708. PMID:.
163 Longo S. Ultrasound evaluation for abdominal pain in the emergency setting. Clinical Chemistry and Laboratory Medicine. 2013;51(11):eA111. PMID:.
164 Love T, Wendel J, Allbery S, et al. Utilizing surgical specimen sonography to improve ultrasound detection of appendicitis and the normal appendix in patients with abdominal pain. American Journal of Roentgenology. 2011;196(5):A275. PMID:.
165 Love T, Wendel J, Allbery S, et al. Utilizing surgical specimen sonography to improve ultrasound detection of appendicitis and the normal appendix in patients with abdominal pain 2. American Journal of Roentgenology. 2011;196(5):A275. PMID:.
166 Luke D, Kidd A, Bloxham M. Appendicectomy in the 21st century: A retrospective study of practice and outcomes. Colorectal Disease. ((Luke D.; Kidd A.; Bloxham M.) Royal Wolverhampton Hospital NHS Trust, Wolverhampton, United Kingdom). 2012;14:37. PMID:.
167 Luke D, Kidd A, Bloxham M. Appendicectomy in the 21st century: A retrospective study of practice and outcomes. Colorectal Disease. 2012;14:37. PMID:.
168 Lukens EC, Monroe KW, Nichols MH. Chief complaint: Constipation-diagnosis, treatment, and complications. Journal of Investigative Medicine. 2012;60(1):437-8. PMID:.
169 Lukens EC, Monroe KW, Nichols MH. Chief complaint: Constipation-diagnosis, treatment, and complications. Journal of Investigative Medicine. 2012;60(1):437-8. PMID:.
170 Lunt JE, Castaneda JL, Sherman J, Lomibao A, Krief W. Assessing clinical and laboratory indicators in perforated appendicitis. Annals of emergency medicine. 2012;60(4):S100-S1. PMID:.
171 Lunt JE, Castaneda JL, Sherman J, et al. Assessing clinical and laboratory indicators in perforated appendicitis. Annals of emergency medicine. 2012;60(4):S100-S1. PMID:.
172 MacMahon P, Alkasab T, Singh A, Nazarian R, Avery L, Novelline R, Abujudeh H. Indeterminate CT appendicitis examinations: Correlating patient outcome with imaging findings. American Journal of Roentgenology. 2012;198(5). PMID:.
173 Maddu K, Coursey C, Mittal P. Utility of MRI in acute abdomen and pelvis in pregnancy: What the radiologist should know?. Emergency radiology. 2013;20(5):368. PMID:.
174 Maghiar AM, Ciurtin DH, Sfirlea M, Dejeu GE, Sookha PR, Macovei C, Maghiar T. Laparoscopic appendectomy: Our experience. Surgical Endoscopy and Other Interventional Techniques. ((Maghiar A.M.; Ciurtin D.H.; Sfirlea M.; Dejeu G.E.; Sookha P.R.; Macovei C.; Maghiar T.) Spitalul Pelican Oradea, Romania). 2013;27:S461. PMID:.
175 Mahajna A, Shalabna H, Shalabi A, Krausz MM. The value of ultrasonography and computed tomography in preoperative diagnosis to detect acute appendicitis. Surgical Endoscopy and Other Interventional Techniques. ((Mahajna A.; Shalabna H.; Shalabi A.; Krausz M.M.) Rambam Maimondes Health Care Campus, Haifa, Israel). 2012;26:S71. PMID:.
176 Makki AM, Merdad AA, Judeeba SS. Evaluation of diagnostic indices of acute appendicitis in kauh. Surgical Endoscopy and Other Interventional Techniques. ((Makki A.M.; Merdad A.A.; Judeeba S.S.) Department of Surgery, Medical College King Abdulaziz University, Jeddah, Saudi Arabia). 2013;27:S490. PMID:.
177 Makki AM, Merdad AA, Judeeba SS. Evaluation of diagnostic indices of acute appendicitis in kauh. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S490. PMID:.
178 Mallin M, Ockerse P, Craven P, Lipton M, Forbes B, Steenblik J, Youngquist S. Diagnosis of acute appendicitis by bedside ultrasound in the emergency department. Academic Emergency Medicine. 2014;21(5):S323-S4. PMID:.
179 Man E, Varga A, Lazar GY. Comparison of alvarado-score and clinical judgement in the diagnosis of acute appendicitis - Prospective, randomized trial. European Surgical Research. 2014;52(3–4):99. PMID:.
180 Mandavia R, Ament M, Worku D, Sheth H. Comparing the efficacy of clinical diagnosis and computed tomography in the diagnosis of acute appendicitis. International Journal of Surgery. 2013;11(8):652-3. PMID:.
181 Mandavia R, Li M, Sheth H. The efficacy of ultrasound scanning as a diagnostic tool in cases of suspected appendicitis. International Journal of Surgery. 2013;11(8):719. PMID:.
182 Mandavia R, Worku D, Lane N, Sheth H. C-reactive protein is a better predictor of perforated appendicitis than hyperbilirubinemia. International Journal of Surgery. 2013;11(8):718. PMID:.
183 Marshall M, Jefferson P, Smart N, Shaw A, Daniels I. Novel biomarkers in appendicitis: The complement cascade. Colorectal Disease. ((Marshall M.; Jefferson P.; Smart N.; Daniels I.) Royal Devon and Exeter Hospital, Exeter, Devon, United Kingdom). 2013;15:57. PMID:. [pmid: 22757637].
184 Marti J, Zurutuza A, Lasa B, Rodriguez Chinesta JM. Neuroendocrine tumours (NETs). Experience in the last 6 years in Goierri county. European journal of internal medicine. ((Marti J.; Zurutuza A.; Lasa B.; Rodriguez Chinesta J.M.) Internal Medicine, Osakidetza, Zumarraga, Spain). 2013;24:e103. PMID:.
185 Mathew Koshy R, Abusabeib A, Rizwan M, Khairat M. Solitary caecal diverticulitis: Multiple dilemmas in the rif. Surgical Endoscopy and Other Interventional Techniques. ((Mathew Koshy R.; Abusabeib A.; Rizwan M.; Khairat M.) Hamad General Hospital, Doha, Qatar). 2013;27:S313. PMID:.
186 Mayne JJ, Briggs-Malonson M. UCLA emergency department use of ultrasound in diagnosing pediatric appendicitis. Journal of Investigative Medicine. 2014;62(1):198-9. PMID:.
187 McCartan DP, Healy D, Fleming FJ, Clarke Moloney M, Walsh SR, Grace PA. Five year follow up of females admitted with acute right iliac fossa pain: Does initial intervention influence repeat admission?. Irish journal of medical science. ((McCartan D.P.; Healy D.; Clarke Moloney M.; Walsh S.R.; Grace P.A.) Department of Surgery, University Hospital Limerick, Limerick, Ireland). 2013;182:S46. PMID:.
188 McGowan DR, Sims HM, Zia K, Uheba M, Shaikh I. Predicting a perforation in acute appendicitis using total bilirubin levels, CRP, white cell count and neutrophils. Colorectal Disease. ((McGowan D.R.; Sims H.M.) Brighton and Sussex Medical School, Brighton, East Sussex, United Kingdom). 2012;14:28. PMID:.
189 McGowan DR, Howlader M, Zia K, et al. Management and outcome of appendicitis in octogenarians. Colorectal Disease. 2012;14:28. PMID:.
190 McGowan DR, Sims HM, Zia K, et al. Predicting a perforation in acute appendicitis using total bilirubin levels, CRP, white cell count and neutrophils. Colorectal Disease. 2012;14:28. PMID:.
191 McIlhenny J, Kirk M, Mailey J, Jabbar A, Rodger C. Ultrasound in appendicitis - A waste of time?. International Journal of Surgery. 2013;11(8):711. PMID:.
192 McLario DJ, Byyny RL, Liao M, Kendall JL. A prospective evaluation of emergency department bedside ultrasonography for the detection of acute pediatric appendicitis. Academic Emergency Medicine. ((McLario D.J.; Byyny R.L.; Liao M.; Kendall J.L.) Denver Health Medical Center, Denver, United States). 2012;19:S59. PMID:.
193 McLario DJ, Byyny RL, Liao M, et al. A prospective evaluation of emergency department bedside ultrasonography for the detection of acute pediatric appendicitis. Academic Emergency Medicine. 2012;19:S59. PMID:.
194 Meesa I, Mammen L. MRI of pregnant women with abdominal pain and suspected appendicitis: Diagnostic accuracy and outcomes. American Journal of Roentgenology. 2011;196(5):A176. PMID:.
195 Meltzer AC, Baumann BM, Chen EH, Shofer FS, Mills AM. Negative predictive value of a low modified alvarado score for adult ED patients with suspected appendicitis. Academic Emergency Medicine. ((Meltzer AC) George Washington University Washington, United States). 2012;19:S194. PMID:.
196 Menoch M, Simon H, Hirsh D, Baxter A, Sturm J. Imaging rates (CT and ultrasound) for suspected appendicitis: Variation between two different practice models within a single health care system. Academic Emergency Medicine. 2014;21(5):S100. PMID:.
197 Menoch M, Hirsh D, Baxter A, et al. Do abdominal CT utilization rates vary between academic and private practice pediatric emergency departments for suspected appendicitis?. Academic Emergency Medicine. 2012;19:S343. PMID:.
198 Merck LH, Heilpern K, Houry D, Holdsworth M, Ward LA, Applegate K, Lowery-North D. Predictors of positive findings in abdominal computed tomography in the emergency department. Annals of emergency medicine. 2012;60(4):S49. PMID:.
199 Merck LH, Heilpern K, Houry D, et al. Predictors of positive findings in abdominal computed tomography in the emergency department. Annals of emergency medicine. 2012;60(4):S49. PMID:.
200 Mersich T, Zarand A, Dede K, Faludi S, Besznyak I jr, Jakab F, Baranyai Zs. The effect of laparoscopic approach on the indication, outcome and benefit in acute appendicitis. Surgical Endoscopy and Other Interventional Techniques. ((Mersich T.; Zarand A.; Dede K.; Faludi S.; Besznyak jr. I.; Jakab F.; Baranyai Zs.) Uzsoki Teaching Hospital, Budapest, Hungary). 2012;26:S18. PMID:.
201 Miller E, Funtowicz L, De Petris G, Slack J, Leis J, Windgassen E, Hutt D, Crowell M, Leighton J. Graft versus host disease (GVHD) of the gastrointestinal (GI) tract: Diagnostic yield of upper versus lower endoscopic biopsies and their clinical application. American Journal of Gastroenterology. ((Miller E) Gastroenterology, Hepatology and Nutrition, MD Anderson Cancer Center, Houston, United States). 2012;107:S726. PMID:.
202 Miller N, Lyon M, Shiver SA. Use of point of care ultrasonography for new onset renal colic. Annals of emergency medicine. 2012;60(4):S111. PMID:.
203 Mills AM, Shofer FS, Soremekun OA, Datner EM, Hollander JE. The effect of suspected diagnosis on physician pretest probability for abdominal pain patients undergoing computed tomography in the emergency department. Academic Emergency Medicine. 2013;20(5):S147-S8. PMID:.
204 Mills AM, Shofer FS, Soremekun OA, et al. The effect of suspected diagnosis on physician pretest probability for abdominal pain patients undergoing computed tomography in the emergency department. Academic Emergency Medicine. 2013;20(5):S147-S8. PMID:.
205 Min SB, Abbas MI, Carter M, et al. Thickened gastrointestinal wall findings on computed tomography in children: How worried should we be?. Gastroenterology. 2012;142(5):S714-S5. PMID:.
206 Moon KT. CT imaging for appendicitis: Is less radiation just as good?. American family physician. 2012;86(10):964-6. PMID:.
207 Mooney D, Wiener E. Time of day affects radiographic study in the diagnosis of appendicitis in the pediatric emergency department. Annals of emergency medicine. 2012;60(4):S27. PMID:.
208 Mori S, Baba K, Yanagita S, Kita Y, Tetsuhiro N, Natsugoe S. Reduced port surgery for laparoscopic appendectomy. Surgical Endoscopy and Other Interventional Techniques. ((Mori S.; Baba K.; Yanagita S.; Kita Y.; Tetsuhiro N.; Natsugoe S.) Kagoshima University, Kagoshima, Japan). 2014;28:S121. PMID:.
209 Naeem S, Dwivedi R, Van Herwijinen I, Chadwick J, Sayer TR. Acute abdominal pain in emergency gynaecological setting: What have we learnt?. BJOG: An International Journal of Obstetrics and Gynaecology. ((Naeem S.; Dwivedi R.; Van Herwijinen I.; Chadwick J.; Sayer T.R.) Basingstoke and North Hampshire Hospital, United Kingdom). 2012;119:227-8. PMID:. [pmid: 21790950].
210 Naeem S, Dwivedi R, Van Herwijinen I, et al. Acute abdominal pain in emergency gynaecological setting: What have we learnt?. BJOG: An International Journal of Obstetrics and Gynaecology. 2012;119:227-8. PMID:. [pmid: 21790950].
211 Nager A, Kobylecka M, Pham P, Johnson L, Gold J. Effects of acupuncture on pain and inflammation in pediatric emergency department patients with acute appendicitis. Journal of Alternative and Complementary Medicine. 2014;20(5):A84. PMID:.
212 Nahon S, Lahmek P, Lesgourgues B, Poupardin C, Chaussade S, Peyrin-Biroulet L, Abitbol V. Factors associated with diagnostic delay in crohn’s disease. Gastroenterology. 2013;144(5):S426. PMID:.
213 Nair H, Skouras C, Leeman M, Paterson-Brown S. The diagnostic accuracy of ultrasound, white cell count, C-reactive protein, and laparoscopy in acute appendicitis. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S244-S5. PMID:.
214 Nair H, Skouras C, Leeman M, et al. The diagnostic accuracy of ultrasound, white cell count, C-reactive protein, and laparoscopy in acute appendicitis. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S244-S5. PMID:.
215 Newman N, Greenberg D, Cohen Z, et al. Community-acquired complicated intra-abdominal infection in hospitalized children. European Surgery - Acta Chirurgica Austriaca. 2011;43:6-7. PMID:.
216 Ngo J, Wong CH, Ho LC, et al. Critical reflection on the management of right iliac fossa pain in the UK hospital Set up: Is there a need for change?. Colorectal Disease. 2011;13:60. PMID:.
217 Nojkov B, Duffy M, Cappell M. Utility of repeated abdominal computed tomography (CT) in patients with an initially negative CT scan presenting to emergency room with non-traumatic abdominal pain. American Journal of Gastroenterology. 2011;106:S427-S8. PMID:.
218 Obinwa O, Motterlini N, Cassidy M, Fahey T, Flynn J. Risk factors associated with advanced appendicitis and complications after childhood appendectomy. Irish journal of medical science. ((Obinwa O.; Flynn J.) Department of Surgery, Portiuncula Hospital, Ballinasloe, County Galway, Ireland). 2012;181:S43. PMID:.
219 Oo T, Roy S. Acute gynaecology readmission rate has been rising in North Tees and Hartlepool NHS Trust since 2011: A register based study. BJOG: An International Journal of Obstetrics and Gynaecology. ((Oo T.; Roy S.) North Tees and Hartlepool NHS Trust, Hartlepool, United Kingdom). 2013;120:446-7. PMID:. [pmid: 23194279].
220 Oosthuizen P, Pearce N, Joubert G. Retrospective audit of appendectomy universitas hospital, Bloemfontein, South Africa 2005–2009. Journal of gastroenterology and hepatology. ((Oosthuizen P.; Pearce N.; Joubert G.) Department of Surgery, Division Gastroenterology, South Africa). 2013;28:541. PMID:.
221 Pace G, Bozzini G, Marenghi C, Picozzi S, Carmignani L. The pocket ultrasound: The phonendoscope of the urologist. European Urology, Supplements. 2012;11(1):e801-ea. PMID:.
222 Pace G, Bozzini G, Marenghi C, et al. The pocket ultrasound: The phonendoscope of the urologist. European Urology, Supplements. 2012;11(1):e801-ea. PMID:.
223 Pai D, Kaur G. Acute abdomen: Accuracy of ct scan in emergency laparotomy. European Surgical Research. 2013;50(2):245. PMID:.
224 Papandria DJ, Rhee D, Gorgy A, et al. Progression of acute appendicitis to perforation: Examination of a two-variant disease model in 683,590 patients. Journal of Surgical Research. 2012;172(2):281-2. PMID:.
225 Pappas A, Toutouni H, Lagoudianakis E, et al. Emergency department evaluation of abdominal pain in elderly patients. European journal of internal medicine. 2011;22:S72-S3. PMID:.
226 Pappas A, Toutouni H, Lagoudianakis E, et al. Admission characteristics of patients presented with acute abdorminal pain. European journal of internal medicine. 2011;22:S5-S6. PMID:.
227 Pare J, Saijwani S, Farooq L, Douriez C, Chiu H, Leo M, Carmody KA. Ultrasonography as a first-line imaging modality for appendicitis: Does it reduce health care costs, radiation exposure and length of stay in emergency department patients?. Annals of emergency medicine. 2012;60(4):S17-S8. PMID:.
228 Pare J, Saijwani S, Farooq L, et al. Ultrasonography as a first-line imaging modality for appendicitis: Does it reduce health care costs, radiation exposure and length of stay in emergency department patients?. Annals of emergency medicine. 2012;60(4):S17-S8. PMID:.
229 Park HC, Kim MJ, Lee BH. Right colonic disease with peritonitis may be treated successfully with laparoscopic surgery. Colorectal Disease. ((Park H.-C.; Kim M.J.; Lee B.H.) Hallym University, Sacred Heart Hospital, Seoul, South Korea). 2013;15:61. PMID:.
230 Park HC, Lee BH. Feasibility of laparoscopic treatment for perforated appendicitis: Analysis of consecutive 200 patients. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S71. PMID:.
231 Park J, Dayal S, Mukherjee A. Alvarado scoring: A positive impact on acute surgical services. Colorectal Disease. 2012;14:38. PMID:.
232 Parmet P, Johnston S, Davis H, Johnston J. Sonographic evaluation of acute appendicitis: A reviewof imaging technique, findings, and common mimics in pediatric RLQ ultrasound. Emergency radiology. 2013;20(5):356. PMID:.
233 Patel N, Williams A, Landes C. Does ultrasound (US) imaging for acute appendicitis in children influence surgical management and correlate with histological findings? Our experience in a tertiary paediatric radiology department. Pediatric radiology. 2011;41:S350. PMID:.
234 Patel S, Shipon C, Warner R, Burns JJ, Walck J. Does obesity contribute to missed diagnosis of appendicitis in children and adolescents? A retrospective review. Journal of Investigative Medicine. 2014;62(2):425. PMID:.
235 Patel S, Shipon C, Warner R, Burns JJ, Walck J. The relationship of mantrels score to appendiceal perforation in pediatric patients: A retrospective review. Journal of Investigative Medicine. 2014;62(2):425. PMID:.
236 Patil S, Chamberlain RS. The influence of age and other clinical factors on disease severity, treatment and outcomes of acute appendicitis: A united states population based outcomes study involving 485,203 patients. Journal of Surgical Research. 2013;179(2). PMID:.
237 Paul SP, Linney MJ. Significance of very high C-reactive protein (CRP) values in the paediatric practice: A retrospective study. Clinical biochemistry. 2011;44(7):540-1. PMID:.
238 Perez-Galaz F, Alvarez MM, Rea G, Rius R. SILS using conventional laparoscopic instruments, analysis of 50 cases in a developing country. Surgical Endoscopy and Other Interventional Techniques. ((Perez-Galaz F.; Alvarez M.M.; Rea G.; Rius R.) Hospital San Angel Inn Chapultepec, Hospital Angeles Lomas, Mexico, Mexico). 2014;28:410. PMID:.
239 Perry ZH, Atias A, Glazer Y, et al. Does time till surgery affect the outcome of lap appendectomy-A retrospective cohort study. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S47. PMID:.
240 Phatak UR, Lew DF, Escamilla R, Tapia NM, Alexandrovn Jordan Y, Suliburk JW, Morales Gonzalez A, Kao LS. Factors associated with perforated appendicitis among racial minority and underinsured patients: A multi-center study of three safety-net hospitals in texas. Surgical infections. ((Phatak U.R.; Lew D.F.; Escamilla R.; Tapia N.M.; Alexandrovn Jordan Y.; Suliburk J.W.; Morales Gonzalez A.; Kao L.S.) Departments of Surgery, University of Texas Health Science Center, Houston, TX USA; Baylor College of Medicine, Houston, TX USA; Texas Tech University Health Sciences Center, El Paso, TX USA). 2013;14:S31. PMID:.
241 Pinto F, Pinto A, Romano S, Romano L. Searching the missing hole in acute abdomen: Abdominal plain radiograph vs mdct in detectingfree extra-luminal air in patients with colonic perforation. experience in a large ed. Emergency radiology. 2012;19(5):368. PMID:.
242 Pontarelli E, Nosanov L, Ma I, et al. Appendicitis in children with cognitive deficits. Surgical infections. 2012;13:S26. PMID:.
243 Pontarelli EM, Nosonov L, Ma I, Pierce JR, Kwan KY, Mody A. Obesity in children does not increase complications of appendicitis. Journal of Surgical Research. 2014;186(2):570-1. PMID:.
244 Poulios E, Economopoulos KP, Tsakayannis D, Kiriakopoulos A, Tranoudakis D, Linos D. Needlescopic surgery in patients with acute abdomen. Surgical Endoscopy and Other Interventional Techniques. ((Poulios E.; Economopoulos K.P.; Tsakayannis D.; Kiriakopoulos A.; Tranoudakis D.; Linos D.) Department of Surgery, Hygeia Hospital, Athens, Greece). 2012;26:S399. PMID:.
245 Preston L, Adams C, Macdonald K. Are x-rays requested appropriately in acute abdominal pain?. Clinical radiology. ((Preston L.; Adams C.; Macdonald K.)). 2013;68:S9. PMID:.
246 Quezada N, Salinas J, Jones A, Passalacqua I, Pino P, Norero E, Funke R, Crovari F, Jarufe N, Boza C. Laparoscopic resolution of 30 cases of acute small bowel obstruction in an university center. Surgical Endoscopy and Other Interventional Techniques. ((Quezada N.; Salinas J.; Jones A.; Passalacqua I.; Pino P.; Norero E.; Funke R.; Crovari F.; Jarufe N.; Boza C.) Digestive Surgery Department, Hospital Clinico P. Universidad Catolica de Chile, Chile). 2012;26:S408. PMID:.
247 Quigley A, Stafrace S. Keeping it simple: Ultrasound for paediatric appendicitis. Overview of the spectrum of ultrasound findings. Pediatric radiology. 2013;43:S624. PMID:.
248 Radojicic V. Laparoscopic management of acute pelvic pain (APP). Gynecological Surgery. 2012;9(1):S64. PMID:.
249 Rafique H, Finkel J, Thornback D, Lyons C. Hyperbilirubinaemia as a marker of perforated appendix - A 5 years retrospective cohort study of 3001 cases. Colorectal Disease. ((Rafique H.; Finkel J.; Thornback D.; Lyons C.) St George’s Hospital, Tooting, London, United Kingdom). 2012;14:38. PMID:.
250 Rafique H, Finkel J, Thornback D, et al. Hyperbilirubinaemia as a marker of perforated appendix - A 5 years retrospective cohort study of 3001 cases. Colorectal Disease. 2012;14:38. PMID:.
251 Raina A, Conrad MA, Sahn B, Sedarat A, Ginsberg GG, Ahmad NA, Chandrasekhara V, Mamula P, Kochman ML. Endoscopic ultrasound with or without fine needle aspiration has a meaningful impact on clinical care in the pediatric population. Gastrointestinal endoscopy. 2013;77(5):AB246. PMID:.
252 Ratto EL, Noceti A, Rota A, et al. Laparoscopic appendectomy benefits. European Surgical Research. 2010;45(3–4):191. PMID:.
253 Redmond E, O’Callaghan A, Ni Eochagain A, et al. Paediatric laparoscopic appendicectomy in a regional general hospital. Irish journal of medical science. 2011;180:S97. PMID:.
254 Reiertsen O, Trondsen E, Færden AE, Edwin B, Rosseland AR, Larsen S. A randomized, controlled trial with sequential design of conventional versus laparoscopic appendectomy.abstract. Scandinavian journal of gastroenterology [serial on the Internet]. 1995;(Suppl 209). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/480/CN-00594480/frame.html. Last accessed.
255 Reiertsen O, Trondsen E, Færden AE, Edwin B, Rosseland AR, Larsen S. A randomized, controlled trial with sequential design of conventional versus laparoscopic appendectomy.abstract2. Scandinavian journal of gastroenterology [serial on the Internet]. 1995;(Suppl 209). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/480/CN-00594480/frame.html. Last accessed.
256 Rhee NG, Chung S. Assessing perforation of acute appendicitis using the delta neutrophil index reflecting the peripheral immature granulocyte count. Critical Care. ((Rhee N.G.; Chung S.) Yonsei University, College of Medicine, Seoul, South Korea). 2012;16:S23. PMID:.
257 Rhee NG, Chung S. Assessing perforation of acute appendicitis using the delta neutrophil index reflecting the peripheral immature granulocyte count. Critical Care. 2012;16:S23. PMID:.
258 Robert S, Le Sage N, Blanchet M, et al. INIMAPA: Investigation by medical imaging in patients with acute appendicitis. Canadian Journal of Emergency Medicine. 2010;12(3):276. PMID:.
259 Rodionova A. Hyposkillia as a cause of delayed diagnosis of acute appendicitis in the second half of pregnancy. BMC Proceedings. 2012;6. ((Rodionova A.) I.M. Sechenov First Moscow State Medical University, Moscow, Russian Federation). PMID:.
260 Rodrigues J, Reuther W, Fistein L. Acute appendicitis: Radiological or clinical diagnosis?. American Journal of Gastroenterology. 2011;106:S146. PMID:.
261 Romagnoli F, Catani M, De Milito R, Romeo V, Valperga R, Modini C. The laparoscopic approach in acute diffuse peritonitis. Surgical Endoscopy and Other Interventional Techniques. ((Romagnoli F.; De Milito R.; Romeo V.) Umberto I Policlinico di Roma, Rome, Italy). 2012;26:S18. PMID:.
262 Ross M, Thompson G. What happens to children with suspected appendicitis when the appendix cannot be visualized on ultrasound?. Canadian Journal of Emergency Medicine. ((Ross M.; Thompson G.) University of Calgary, Canada). 2013;15:S35. PMID:.
263 Roy H, Burbridge B. To CT, or not to CT? The utilization and diagnostic role of computed tomography amongst obese pediatric appendicitis patients. Canadian Journal of Emergency Medicine. ((Roy H.; Burbridge B.) University of Saskatchewan, College of Medicine, Saskatooon, Canada). 2014;16:S69. PMID:.
264 Royston E, Arrowsmith C, Ekere C, Mehta C, Talbot R. What impact has laparoscopy had on timing of appendicectomy and the rate of positive histology?. International Journal of Surgery. 2013;11(8):712. PMID:.
265 Ruffing RP, Trokel M, Weiner S. An interdisciplinary intervention to decrease abdominal CT use in children. Academic Emergency Medicine. 2012;19:S342-S3. PMID:.
266 Ruffing RP, Trokel M, Weiner S. An interdisciplinary intervention to decrease abdominal CT use in children. Academic Emergency Medicine. 2012;19:S342-S3. PMID:.
267 Rymeski B, Ying J, Dasgupta R. Impact of obesity on children with appendicitis. Journal of the American College of Surgeons. 2012;215(3):S76-S7. PMID:.
268 Saadat L, Mahvi DM, Helenowski I, Boller AM. Rare but significant problems associated with CT scans in the diagnosis of appendicitis. Gastroenterology. 2014;146(5):S-1039. PMID:.
269 Saavedra-Perez D, Ginesta C, Sampson J, Hidalgo NJ, Valentini M, Vidal O, Morales X, Martinez A, Benarroch G, Garcia-Valdecasas JC. Laparoscopic appendectomy in patients over 65 years old: Clinical and surgical characteristics. Surgical Endoscopy and Other Interventional Techniques. ((Saavedra-Perez D.; Ginesta C.; Sampson J.; Hidalgo N.J.; Valentini M.; Vidal O.; Morales X.; Martinez A.; Benarroch G.; Garcia-Valdecasas J.C.) Hospital Clinic of Barcelona, Barcelona, Spain). 2014;28:S83. PMID:.
270 Sahabi SM, Aliyu S, Usman B, et al. A review of the histopathological patterns of appendicitis in Sokoto, North Western Nigeria. Histopathology. 2012;61:94. PMID:.
271 Salama M, Zaidi A, Ahmed I. Negative appendicectomy in era of diagnostic laparoscopy. Irish journal of medical science. ((Salama M.; Zaidi A.; Ahmed I.) Department of General Surgery, Our Lady of Lourdes Hospital, Drogheda, Co. Louth, Ireland). 2012;181:S179. PMID:.
272 Salama M, Zaidi A, Taha T, et al. Has laparoscopy reduced the rate of negative appendicectoy in our institute?. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S85. PMID:.
273 Sampson J, Valentini M, Ginesta C, Soliva R, Morales X, Garcia-Valdecasas JC, Benarroch G. Acute appendicitis: Experience and results in an emergency room service of a specialized center. Surgical Endoscopy and Other Interventional Techniques. ((Sampson J.; Valentini M.; Ginesta C.; Soliva R.; Morales X.; Garcia-Valdecasas J.C.; Benarroch G.) Hospital Clinic of Barcelona, Barcelona, Spain). 2013;27:S84. PMID:.
274 Sampson J, Valentini M, Ginesta C, et al. Acute appendicitis: Experience and results in an emergency room service of a specialized center. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S84. PMID:.
275 Samuelson A, Agrawal D, Sreenarasimhaiah J. EUS-guided drainage of perirectal abscesses: Efficacy as a first-line intervention. Gastrointestinal endoscopy. 2014;79(5):AB305. PMID:.
276 Sarma V, Bowcock E, Moussa O, et al. The role of diagnostic laparoscopy in a district general hospital. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S82. PMID:.
277 Sazhin AV, Mosin SV, Kodjoglyan AA, Laypanov BK, Mirzoyan HT, Yuldoshev AR. Minimally invasive approach in the treatment of complicated appendicitis. Surgical Endoscopy and Other Interventional Techniques. ((Sazhin A.V.; Mosin S.V.; Kodjoglyan A.A.; Laypanov B.K.; Mirzoyan H.T.; Yuldoshev A.R.) Russian National Research Medical University named after NI Pirogov, Moscow, Russian Federation). 2013;27:S86. PMID:.
278 Sazhin AV, Mosin SV, Kodjoglyan AA, et al. Minimally invasive approach in the treatment of complicated appendicitis. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S86. PMID:.
279 Schok T, Simons P, Janssen M, Peters N, Konsten J. Prospective evaluation of the additive value of imaging within the diagnostic guideline appendicitis: Have we forgotten our clinical eye?. Colorectal Disease. ((Schok T.; Konsten J.) Maastricht University, Maastricht, Netherlands). 2012;14:18. PMID:. [pmid: 20955514].
280 Schok T, Simons P, Janssen M, et al. Prospective evaluation of the additive value of imaging within the diagnostic guideline appendicitis: Have we forgotten our clinical eye?. Colorectal Disease. 2012;14:18. PMID:. [pmid: 20955514].
281 Sekhar H, Konarski A, Horsley A, Smart C, Darmas B. Use of laparoscopic appendicectomy (LA) in a paediatric population in a DGH setting. International Journal of Surgery. 2013;11(8):673-4. PMID:.
282 Seol J, Adduci A. Diagnostic performance and clinical impact of ultrasound in suspected acute appendicitis. Emergency radiology. 2013;20(5):376. PMID:.
283 Sguinzi R, Boati S, Baticci F, et al. Comparison between a modified alvarado scoring system and clinical evaluation by an expert surgeon in diagnosis of acute appendicitis: A randomized prospective study. European Surgical Research. 2010;45(3–4):271. PMID:.
284 Shah D, Padnani A, Sharma G, Du L, Sharma S. Appendix mucocele: Case series and literature review. Surgical Endoscopy and Other Interventional Techniques. ((Shah D.; Padnani A.; Sharma G.; Du L.; Sharma S.) New York Hospital Queens, New York, United States). 2014;28:315. PMID:. [pmid: 23982652].
285 Shahzad M. Laparoscopic appendectomy is gold standard in female patients. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S463. PMID:.
286 Shahzad M. Laparoscopic appendectomy is gold standard in female patients. Surgical Endoscopy and Other Interventional Techniques. ((Shahzad M.) Holy Family Hospital, India). 2013;27:S463. PMID:.
287 Shapovalov VY, Geshelin SA, Kashtalyan MA, Yenin RV. Traditional and videoendoscopic appendectomy-results of performing first 1000 laparoscopic appendectomies. Surgical Endoscopy and Other Interventional Techniques. ((Shapovalov V.Yu.; Geshelin S.A.; Kashtalyan M.A.; Yenin R.V.) Odessa National Medical University, 411 Military Clinical Hospital, Odessa, Ukraine). 2014;28:S85. PMID:.
288 Sheel A, Baron R, Hartley M, Howes N. Appendicitis is still a clinical diagnosis. International Journal of Surgery. 2013;11(8):716. PMID:.
289 Shih J, Mennitt K. Dose matters: When can body MRI be used as an alternative to ct in the emergency setting. Emergency radiology. 2012;19(5):375-6. PMID:.
290 Shukur ZN, Hodgkinson JD, Tan E, et al. Are C-reactive protein levels necessary to diagnose acute appendicitis in adults?. Colorectal Disease. 2011;13:47. PMID:. [pmid: 22098518].
291 Siddiqui MA, Rizvi SWA, Ahmad I, Ullah E, Rizvi SAA. Pictorial review of ultrasonographic appearance of common abdominal and pelvic emergencies-are radiologists letting their most versatile weapon in the emergency room to slip from their hand. Emergency radiology. 2013;20(5):351-2. PMID:.
292 Simard R, Lee JS, Brooks SC, Gray SH. CT scan versus ultrasound for the diagnosis of appendicitis: What is the impact on emergency department length of stay?. Canadian Journal of Emergency Medicine. ((Simard R.; Lee J.S.; Brooks S.C.; Gray S.H.) University of Toronto, Canada). 2013;15:S27. PMID:.
293 Simard R, Lee JS, Brooks SC, et al. CT scan versus ultrasound for the diagnosis of appendicitis: What is the impact on emergency department length of stay?. Canadian Journal of Emergency Medicine. 2013;15:S27. PMID:.
294 Sisson C, Ehler B, Pham D, Minard J. Variation by sex and body mass index in anterior positioning of the acutely inflamed appendix in relation to the psoas muscle. Academic Emergency Medicine. 2013;20(5):S149. PMID:.
295 Sisson C, Ehler B, Minard J, et al. Determination of a body mass index upper limit in adults for the diagnosis of acute appendicitis using a high frequency linear ultrasound transducer. Academic Emergency Medicine. 2013;20(5):S251. PMID:.
296 Sisson C, Ehler B, Pham D, et al. Variation by sex and body mass index in anterior positioning of the acutely inflamed appendix in relation to the psoas muscle. Academic Emergency Medicine. 2013;20(5):S149. PMID:.
297 Smith ST, Lee J, Jangam B, et al. Single surgeon experience with single incision laparoscopic appendectomy. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S363. PMID:.
298 Snyder J, Thomas A, Keibel L, et al. Transumbilical laparoscopically-assisted appendectomy (TULAA): A cost-effective procedure for appendicitis in children. Surgical infections. 2012;13:S27. PMID:.
299 Spada A, Ulissi A, Marzano MA, Maida R. A multidisciplinary protocol for management of abdominal pain in emergency department. Italian Journal of Medicine. 2014;8:122-3. PMID:.
300 Spence JM, Gaunt K, Barratt L, Nathens A, Mourad O, Grover S, Kingsley S, Dias M, Touliopoulos S, Edgar C, Ng A. Abdominal pain protocols in the emergency department: A pilot project. Canadian Journal of Emergency Medicine. ((Spence J.M., jspence.engel@gmail.com; Gaunt K.; Barratt L.; Nathens A.; Mourad O.; Grover S.; Kingsley S.; Dias M.; Touliopoulos S.; Edgar C.; Ng A.) Keenan Research Centre, University of Toronto, St. Michael’s Hospital, Canada). 2012;14:S54. PMID:.
301 Spence JM, Gaunt K, Barratt L, et al. Abdominal pain protocols in the emergency department: A pilot project. Canadian Journal of Emergency Medicine. 2012;14:S54. PMID:.
302 Subedi S, Mallon S, Szpunar S, Lorenzana A, Lyons H. Pattern of CT scan use in the diagnosis of abdominal pain in children in a tertiary care center. American Journal of Gastroenterology. ((Subedi S.; Szpunar S.; Lorenzana A.) Pediatrics, SJHMC, Detroit, United States). 2013;108:S621. PMID:.
303 Suzuki R, Nakata K, Okamura S, Takeno A, Nakahira S, Miki H, Takeda Y, Tamura S. Factors associated with conversion in laparoscopic appendectomy. Surgical Endoscopy and Other Interventional Techniques. ((Suzuki R.; Nakata K.; Okamura S.; Takeno A.; Nakahira S.; Miki H.; Takeda Y.; Tamura S.) Kansai Rosai Hospital, Amagasaki, Japan). 2012;26:S94. PMID:.
304 Swischuk L, Chung D, Hawkins H, et al. Appendicitis of the appendiceal tip: Clinical observations and possible etiology. American Journal of Roentgenology. 2011;196(5):A275. PMID:.
305 Takehara K, Aoki J, Okazawa Y, et al. Study of single port laparoscopic appendectomy. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S457. PMID:.
306 Tanimizu T, Hinoki H, Kitagawa D, Matsumoto Y, Hatsuse K, Hase K, Yamamoto J. Laparoscopic repair in children with inguinal hernia-unexpected findings. Surgical Endoscopy and Other Interventional Techniques. ((Tanimizu T.; Hinoki H.; Kitagawa D.; Matsumoto Y.; Hatsuse K.; Hase K.; Yamamoto J.) National Defense Medical College, Tokorozawa, Japan). 2014;28:S159. PMID:.
307 Tashjian DB, Moriarty KP, Courtney RA, et al. Laparoscopic versus open appendectomy. Current surgery. Sep. 1. 2000;57(5):506. [pmid: 11064091].
308 Tavarez M, Chamberlain J, Brown K. Signs and symptoms associated with surgical intervention in children with abdominal pain. Academic Emergency Medicine. 2013;20(5):S8. PMID:.
309 Tavarez M, Chamberlain J, Brown K. Signs and symptoms associated with surgical intervention in children with abdominal pain. Academic Emergency Medicine. 2013;20(5):S8. PMID:.
310 Teh SH, Caslister DM. Single incision laparoscopic appendectomy using conventional non-articulate instruments: Is this the future to remove an appendix?. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S281. PMID:.
311 Thatigotla B, Vattipally V, Shah AK, et al. Diagnosing appendicitis in pregnancy: Is clinician the best armamentarium?. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S364. PMID:.
312 Theilen L, Mellnick V, Tuuli M, Odibo A, Macones G, Cahill A. Obstetric outcomes in women with acute appendicitis during pregnancy. American journal of obstetrics and gynecology. 2014;210(1):S298-S9. PMID:.
313 Theilen L, Mellnick V, Longman R, Macones G, Cahill A. Rate of and risk factors for non-visualization of the appendix with magnetic resonance imaging (MRI) in pregnant women with suspected appendicitis. American journal of obstetrics and gynecology. 2014;210(1):S105-S6. PMID:.
314 Thompson B, Ehrlich L, Eutsler E, Goodman T. Highly focused ct based on bony landmarks for dose reduction in the pediatric population for the diagnosis ofappendicitis. Emergency radiology. 2013;20(5):357-8. PMID:.
315 Thompson GC, Boag G, Stang AS, et al. Utilization of diagnostic imaging after implementation of a clinical pathway for suspected pediatric appendicitis. Paediatrics and Child Health. 2010;15:31A-2A. PMID:. [pmid: 21197168].
316 Thompson GC, Stang AS, DeForest EK, et al. Can pediatric emergency department nurses use a modified alvarado score to acurately predict appendicitis?. Paediatrics and Child Health. 2010;15:32A. PMID:.
317 Thomson J, Wilkinson G, Beattie TF. Ultrasound use in children presenting with atraumatic abdominal pain. Emergency Medicine Journal. 2009;26:12. Language: English. Entry Date: 20130315. Revision Date: 20130315. Publication Type: journal article.
318 Tobler JFT, Trout AT. Acute appendicitis mimic: Are there reliable imaging findings to suggest a diagnosis of lymphoid hyperplasia over acute appendicitis?. Pediatric radiology. ((Tobler J.F.T.; Trout A.T.) Cincinnati Children’s Hospital Medical Center, Cincinnati, United States). 2014;44:S351. PMID:.
319 Tokpanov S, Dosmagambetov S, Kotlobovskiy V. Laparoscopic treatment of liver hydatid disease in cases of cyst rupture. Surgical Endoscopy and Other Interventional Techniques. ((Tokpanov S.; Dosmagambetov S.; Kotlobovskiy V.)). 2014;28:364. PMID:.
320 Toma A, Bertini L, Casciani E, Gualdi G, Corazziari E. Colorectal transit during acute episodes of diverticulitis. Gastroenterology. 2013;144(5):S727. PMID:.
321 Tomoaki O, Yoshinori I, Yusuke N, Tatsuo Y, Tetsuya M, Michiko Y, Naoki I, Masaru M, Tarou N, Hidenori K, Kenzo O, Shinsuke K. Single incision laparoscopic appendectomy (sila) in our hospital. Surgical Endoscopy and Other Interventional Techniques. ((Tomoaki O.; Yoshinori I.; Yusuke N.; Tatsuo Y.; Tetsuya M.; Michiko Y.; Naoki I.; Masaru M.; Tarou N.; Hidenori K.; Kenzo O.; Shinsuke K.) Department of Surgery, Uwajima City Hospital, Japan). 2013;27:S449. PMID:.
322 Tompane T, Buehning L, Dansky T, et al. Gi radiology studies performed in a pediatric cohort over a nine-year period. Gastroenterology. 2012;142(5):S397. PMID:.
323 Tono C, Shimooki O, Abe T, Minakawa H, Tosha T, Takahashi M, Yusuke M. Clinical results of laparoscopic appendectomy in our institute. Surgical Endoscopy and Other Interventional Techniques. ((Tono C.; Shimooki O.; Abe T.; Minakawa H.; Tosha T.; Takahashi M.; Yusuke M.) Iwate prefectural Kuji Hospital, Iwate Prefecturee, Japan). 2013;27:S110. PMID:.
324 Tono C, Shimooki O, Abe T, et al. Clinical results of laparoscopic appendectomy in our institute. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S110. PMID:.
325 Tore H, Chalian H, Miller J, Hoff F, Hammond N, Nikolaidis P, Miller F, Yaghmai V. Iterative reconstruction to reduce radiation exposure in emergency department patients undergoing abdominopelvic MDCT. American Journal of Roentgenology. 2012;198(5). PMID:.
326 Torres-Grau J, Krysztopic R. The use of ultrasound for the acute abdomen in the surgical admissions unit (SAU). International Journal of Surgery. 2013;11(8):592. PMID:.
327 Treeprasertsuk S, Phaosawasdi K, Thepsuthammarat K, Chirawatkul A. Duration of hospital stay and mortality rate of the appendectomy as an indicator for quality of medical care: The 2010 nationwide study. Gastroenterology. 2014;146(5):S-255. PMID:.
328 Triantafyllidis I, Astreinidou A, Dimitriadou M, Demertzidis C. The role of diagnostic laparoscopy in a district general hospital. Surgical Endoscopy and Other Interventional Techniques. ((Triantafyllidis I.; Astreinidou A.; Dimitriadou M.; Demertzidis C.) Veria General Hospital, Veria, Greece). 2013;27:S63. PMID:.
329 Tsalis K, Patridas D, Antoniou N, Kyritsis D, Angelopoulos S, Lazaridis Ch. Routine use of open access technique to create pneumoperitoneum in laparoscopic surgery. Surgical Endoscopy and Other Interventional Techniques. ((Tsalis K.; Patridas D.; Antoniou N.; Kyritsis D.; Angelopoulos S.; Lazaridis Ch.) Aristotle University, Thessaloniki, Greece). 2014;28:S62. PMID:.
330 Tseng LM, Lin CM, Chen KC, et al. An emergency medicine resident training program in bedside ultrasonography helps the diagnosis of acute appendicitis. Emergency radiology. 2011;18(6):458. PMID:.
331 Tucker A, Sloan K, Garstin I, Dace S, Varghis R. White cell counts, C-Reactive protein and appendicitis e what is the role of pre-operative blood tests in assisting in the diagnosis?. International Journal of Surgery. 2013;11(8):707-8. PMID:.
332 Ukhanov AP, Dunaeva TV, Zakharov DV, Ignatjev A, Kovalev SV. Using of endovideosurgical technology in the diagnosis and treatment of patients with acute appendicitis with atypical location of the appendix. Surgical Endoscopy and Other Interventional Techniques. ((Ukhanov A.P.; Dunaeva T.V.; Zakharov D.V.; Ignatjev A.; Kovalev S.V.) Central Municipal Clinical Hospital, Velikiy Novgorod, Russian Federation). 2012;26:S68. PMID:.
333 Ukhanov AP, Zakharov DV, Ignatjev A, Kovalev SV, Dunaeva TV. Use of videolaparoscopy in the diagnostics and treatment of acute appendicitis and its complications. Surgical Endoscopy and Other Interventional Techniques. ((Ukhanov A.P.; Zakharov D.V.; Ignatjev A.; Kovalev S.V.; Dunaeva T.V.) First Municipal Clinical Hospital, Velikiy Novgorod, Russian Federation). 2012;26:S71. PMID:.
334 Ukhanov AP, Zakharov DV, Dementjev AP, Dunaeva TV, Ignatjev A, Smirnov VN, Bolshakov SV. The use of ultrasound scanning and videolaparoscopic appendectomy in patients with appendicular abscess. Surgical Endoscopy and Other Interventional Techniques. ((Ukhanov A.P.; Zakharov D.V.; Dementjev A.P.; Dunaeva T.V.; Ignatjev A.; Smirnov V.N.; Bolshakov S.V.) Central municipal hospital, Velikiy Novgorod, Russian Federation). 2014;28:S82. PMID:.
335 Ukhanov AP, Zakharov DV, Ignatjev A, et al. Use of endovideosurgical method in the diagnostics and treatment of acute appendicitis and its complications. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S84. PMID:.
336 Ul Haq MR, Kashif M, Hussain N. Alvarado score; a real guide for management of right iliac fossa pain in children. Medical Forum Monthly. 2009;20(2):26-32. PMID:.
337 Artiko V, Sobic-Saranovic D, Petrovic N, Krajnovic-Jaksic E, Pavlovic S, Obradovic V. Detection of abdominal infections using 99mtcantigranulocyte antibodies.
338 Vahedi A, Madhavan A, Phillips A, Macafee D. Ultrasound does not affect the negative appendicectomy rate in both adults and children. International Journal of Surgery. 2013;11(8):709.
339 Vajtai P, Hopkins K, Didier R. Accuracy in diagnosis of pediatric acute appendicitis: Weight-based CT protocols with traditional filtered back projection versus 60% CTDIvol-reduced protocols with iterative reconstruction technique. Pediatric radiology. ((Vajtai P; Hopkins K; Didier R) Oregon Health and Science University Portland, United States). 2013;43:S555.
340 Vajtai P, Hopkins K, Didier R. Accuracy in diagnosis of pediatric acute appendicitis: Weight-based CT protocols with traditional filtered back projection versus 60% CTDIvol-reduced protocols with iterative reconstruction technique. Pediatric radiology. 2013;43:S555.
341 Vieira A, Chen N, Leung A, Lim R, Joubert G, Poonai N. Is ultrasound associated with a lower negative appendectomy rate in children suspected of acute appendicitis?. Canadian Journal of Emergency Medicine. ((Vieira A.; Chen N.; Leung A.; Lim R.; Joubert G.; Poonai N.) Western University-Schulich School of Medicine and Dentistry, London, Canada). 2014;16:S70.
342 Vijayaraghavan G, Karam A, Smith A, Tefft C, Hussain S. The significance of ultrasound imaging in evaluating common gynecologic causes for acute pelvic pain. American Journal of Roentgenology. 2012;198(5).
343 Wandell M, Brown M, Simon H, Copeland K, Huckins D, Blumenstein B. Physician clinical impression compared to a novel clinical decision rule for use in sparing pediatric patients with signs and symptoms of acute appendicitis exposure to computed tomography. Academic Emergency Medicine. ((Wandell M.; Copeland K.) AspenBio Pharma, Castle Rock, United States). 2012;19:S194.
344 Wandell M, Brown M, Lewis R, Simon H, Huckins D, Copeland K, Blumenstein B, Spiro D. A novel biomarker panel to rule out acute appendicitis in pediatric patients with abdominal pain. Academic Emergency Medicine. ((Wandell M.; Copeland K.) AspenBio Pharma, Castle Rock, United States). 2012;19:S195.
345 Wandell M, Brown M, Simon H, et al. Physician clinical impression compared to a novel clinical decision rule for use in sparing pediatric patients with signs and symptoms of acute appendicitis exposure to computed tomography. Academic Emergency Medicine. 2012;19:S194.
346 Wei CH, Fu YW, Wang NL. Laparoscopic approach for enterocolitis-related acute intestinal perforation: Initial experience. Journal of Laparoendoscopic and Advanced Surgical Techniques. 2013;23(12):A-82.
347 Whiteman C, Folio L. Pilot study to assess clinical usefulness and radiation reduction of a proposed pediatric focused appendiceal CT. Emergency radiology. 2011;18(6):453.
348 Whitfield C, Amin S. nulleyes first and foremostnull - The accuracy of surgeon assessment of the appendix during emergency diagnostic laparoscopy. International Journal of Surgery. 2013;11(8):711.
349 Willimann M, Thompson GC. Influence of triage time on patient care in children presenting with suspected appendicitis to Canadian pediatric emergency departments. Canadian Journal of Emergency Medicine. 2013;15:S16.
350 Witherspoon J, Than M, Nicholls J, Appleton B. Surgeons may not be able to accurately assess the appendix intra-operatively. International Journal of Surgery. 2013;11(8):715.
351 Worku D, Mandavia R, Lane N, Sheth H. Hyperbilirubinemia as a marker for acute appendicitis. International Journal of Surgery. 2013;11(8):718.
352 Yan W, Shamdasani P, Shelton E, Boyapati R, Moore G. Endoscopic and surgical outcomes for CT-diagnosed ileal wall thickening. Journal of gastroenterology and hepatology. ((Yan W.; Shamdasani P.; Shelton E.; Boyapati R.; Moore G.) Department of Gastroenterology, Monash Medical Centre, Clayton, Australia). 2013;28:110.
353 Yangyihong, Liaowei, Zhongyiming, Xiedongming. Clinical analysis of 62 cases of aortic dissection misdiagnosed. Heart. ((Yangyihong; Liaowei; Zhongyiming; Xiedongming; Yangyihong) First Affiliated Hospital, Gannan Medical University, China). 2012;98:E257.
354 Yenidogen E, Ozsoy Z, Okan I, Kayaoglu HA, Tali S, Sahin M. Evaluation of the alvarado score as a diagnostic tool for appendicitis. European Surgical Research. ((Yenidogen E.; Ozsoy Z.; Okan I.; Kayaoglu H.A.; Tali S.; Sahin M.) Gaziosmanpasa University, Facelty of Medidne, Department of General Surgery, Tokat, Turkey). 2013;50:136.
355 Yenidogen E, Ozsoy Z, Okan I, et al. Evaluation of the alvarado score as a diagnostic tool for appendicitis. European Surgical Research. 2013;50:136.
356 Yilmaz M, Akbulut S, Kutluturk K, Sahin N, Arabaci E, Ara C, Yilmaz S. Unusual histopathological findings in appendectomy specimens from patients with suspected acute appendicitis. European Surgical Research. 2013;50:111-2.
357 Yilmaz Y, Kara F, Gumusdere M. The platelet indices in patients with acute appendicitis. Clinical Chemistry and Laboratory Medicine. ((Kara F.) Department of Biochemistry, Kars Government Hospital, Kars, Turkey). 2014;52:S991.
358 Yu J, Chandran S, Testro A. Overuse of computer tomography scanning in infectious gastroenteritis. Journal of gastroenterology and hepatology. 2012;27:138.
359 Zago M, Mariani D, Cirelli B, Pastori S, Pozzi R, Cortinovis M. Appendiceal abscess: Immediate or delayed laparoscopic appendectomy?. Surgical Endoscopy and Other Interventional Techniques. ((Zago M.) Policlinico San Pietro-BG, Milano, Italy). 2014;28:S86.
360 Zaki K, Ahern C, Kelly N, et al. An audit of paediatric appendectomies in a regional hospital. Irish journal of medical science. 2011;180:S113.
361 Zechner P, Campo Dell Orto M, Groesdonk HV, et al. Does the integration of personalized ultrasound change patient management in critical and acute care medicine?. Journal fur Kardiologie. 2012;19(5–6):147-8.
362 Zeise S, Sinha M, Connell M, Goettl C, Patel P. Clinical outcome of pediatric patients with acute abdominal pain and incidental finding of free fluid in the abdomen on diagnostic imaging. American Journal of Roentgenology. 2012;198(5).
363 Zhu Y, Bai Y, Xue L. Retrospective analysis of ultrasound diagnosis in children with acute mesenteric lymphadenitis. Journal of gastroenterology and hepatology. ((Zhu Y.; Bai Y.; Xue L.) Ultrasound Department; Clinican). 2013;28:246.
364 Zwank MD, Mayeux GP, MacDonald J. Repeat abdominal computed tomography influences emergency department patient diagnosis and disposition. Annals of emergency medicine. 2013;62(4):S40.

## B-3. Rejection Reason: Appendicitis Specific Test Results Not Reported

1 Agrusa A, Romano G, Di Buono G, Frazzetta G, Chianetta D, Sorce V, Billone V, Cucinella G, Gulotta G. Acute appendicitis and endometriosis: Retrospective analysis in emergency setting. Giornale Italiano di Ostetricia e Ginecologia. 2013;35(6):728-32. PMID:.
2 Akyildiz H, Akcan A, Ozturk A, et al. D-dimer as a predictor of the need for laparotomy in patients with unclear non-traumatic acute abdomen. A preliminary study. Scandinavian journal of clinical and laboratory investigation. 2008;68(7):612-7. [pmid: 19378433].
3 Alazzawi S, De Rover WS, Morris-Stiff G, et al. Erect chest radiography in the setting of the acute abdomen: essential tool or an unnecessary waste of resources?. Annals of the Royal College of Surgeons of England. Nov. 2010;92(8):697-9. [pmid: 20650038].
4 Ali N, Aliyu S. Appendicitis and its surgical management experience at the University of Maiduguri Teaching Hospital Nigeria. Nigerian journal of medicine : journal of the National Association of Resident Doctors of Nigeria. Apr–Jun. 2012;21(2):223-6. [pmid: 23311196].
5 Alioglu B, Avci Z, Ozcay F, et al. Neutropenic enterocolitis in children with acute leukemia or aplastic anemia. International journal of hematology. Nov. 2007;86(4):364-8. [pmid: 18055346].
6 Al-Mulhim AS, Nasser MA, Abdullah MM, et al. Emergency laparoscopy for acute abdominal conditions: a prospective study. Journal of laparoendoscopic & advanced surgical techniques Part A. Aug. 2008;18(4):599-602. [pmid: 18721012].
7 Du Bose, Lissauer M, Maung AA, Piper GL, O’Callaghan TA, Xian LO, Inaba K, Okoye O, Shestopalov A, Fielder WD, Ferrada P, Wilson A, Channel J, Moore FO, Paul DB, Johnson S. Pneumatosis Intestinalis Predictive Evaluation Study (PIPES): A multicenter epidemiologic study of the Eastern Association for the Surgery of Trauma. [pmid: 23778433].
8 Andersson RE, Hugander A, Thulin AJ. Diagnostic accuracy and perforation rate in appendicitis: association with age and sex of the patient and with appendicectomy rate. The European journal of surgery. Acta chirurgica. Jan. 1992;158(1):37-41. [pmid: 1348639].
9 Diagnosis unaffected by giving children narcotics for abdominal pain. Journal of Family Practice [serial on the Internet]. 2005;(7). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/608/CN-00569608/frame.html. Last accessed.
10 Augustin T, Bhende S, Chavda K, et al. CT scans and acute appendicitis: a five-year analysis from a rural teaching hospital. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Jul. 2009;13(7):1306-12. [pmid: 19381736].
11 Bairstow PJ, Persaud J, Mendelson R, et al. Reducing inappropriate diagnostic practice through education and decision support. International journal for quality in health care : journal of the International Society for Quality in Health Care/ISQua. Jun. 2010;22(3):194-200. [pmid: 20382660].
12 Banani SA, Amirghofran AA. The role and value of oral metronidazole in acute appendicitis. Pediatric Surgery International [serial on the Internet]. 1995:2-3. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/819/CN-00168819/frame.html. Last accessed.
13 Baron KT, Arleo EK, Robinson C, et al. Comparing the diagnostic performance of MRI versus CT in the evaluation of acute nontraumatic abdominal pain during pregnancy. Emergency radiology. Dec. 2012;19(6):519-25. [pmid: 22886287].
14 Bar-On Z, Ohry A. The acute abdomen in spinal cord injury individuals. Paraplegia. Dec. 1995;33(12):704-6. [pmid: 8927409].
15 Barreto SG, Travers E, Thomas T, et al. Acute perforated appendicitis: an analysis of risk factors to guide surgical decision making. Indian journal of medical sciences. Feb. 2010;64(2):58-65. [pmid: 22466494].
16 Barrett MJ, Pollock J, Harney T, et al. The correlation between c-reactive protein and serious bacterial infection in a tertiary paediatric emergency department: An observational case-controlled cohort study. Archives of disease in childhood. 2012;97:A446-A7. PMID:.
17 Bennion RS, Thompson JE Jr, Baron EJ, Schmit PJ, Finegold SM. The use of single-agent antibacterial regimens in the treatment of advanced appendicitis with peritonitis. Drug Invest [serial on the Internet]. 1992;(Suppl 1). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/273/CN-00196273/frame.html. Last accessed.
18 Bhangu A, Richardson C, Winter H, et al. Value of initial radiological investigations in patients admitted to hospital with appendicitis, acute gallbladder disease or acute pancreatitis. Emergency medicine journal : EMJ. Oct. 2010;27(10):754-7. [pmid: 20511636].
19 Bjerregaard B, Brynitz S, Holst-Christensen J, et al. The reliability of medical history and physical examination in patients with acute abdominal pain. Methods of information in medicine. Jan. 1983;22(1):15-8. [pmid: 6339868].
20 Blab E, Kohlhuber U, Tillawi S, et al. Advancements in the diagnosis of acute appendicitis in children and adolescents. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al]. Zeitschrift fur Kinderchirurgie. Dec. 2004;14(6):404-9. [pmid: 15630642].
21 Blisard D, Rosenfeld JC, Estrada F, et al. Institutioning a clinical practice guideline to decrease the rate of normal appendectomies. The American surgeon. Sep. 2003;69(9):796-8. [pmid: 14509330].
22 Brandt CP, Priebe PP, Eckhauser ML. Diagnostic laparoscopy in the intensive care patient. Avoiding the nontherapeutic laparotomy. Surgical endoscopy. May–Jun. 1993;7(3):168-72. [pmid: 8503073].
23 Brekke M, Eilertsen RK. Acute abdominal pain in general practice: tentative diagnoses and handling. A descriptive study. Scandinavian journal of primary health care. 2009;27(3):137-40. [pmid: 19731181].
24 Bresciani C, Perez RO, Habr-Gama A, Jacob CE, Ozaki A, Batagello C, Proscurshim I, Gama-Rodrigues J. Laparoscopic versus standard appendectomy outcomes and cost comparisons in the private sector (Structured abstract). Journal of Gastrointestinal Surgery [serial on the Internet]. 2005;(8). Available from: http://onlinelibrary.wiley.com/o/cochrane/cleed/articles/NHSEED-22006006265/frame.html. Last accessed.
25 Brockman SF, Scott S, Guest GD, et al. Does an Acute Surgical Model increase the rate of negative appendicectomy or perforated appendicitis?. ANZ journal of surgery. Oct. 2013;83(10):744-7. [pmid: 23692520].
26 Brown DF, Fischer RH, Novelline RA, et al. The role of abdominal computed tomography scanning in patients with non-traumatic abdominal symptoms. European journal of emergency medicine : official journal of the European Society for Emergency Medicine. Dec. 2002;9(4):330-3. [pmid: 12501032].
27 Burgos WF, Johnston DG. Appendicitis--a computer study. Postgraduate medicine. Aug. 1968;44(2):110-4. [pmid: 5663215].
28 Burr A, Renaud EJ, Manno M, et al. Glowing in the dark: time of day as a determinant of radiographic imaging in the evaluation of abdominal pain in children. Journal of pediatric surgery. Jan. 2011;46(1):188-91. [pmid: 21238664].
29 Butt M, Connolly B, Durrani S, et al. Retrospective study of role of early vs late CT abdomen for acute abdomen. Irish journal of medical science. 2013;182:S172. PMID:.
30 Chambers A, Halligan S, Goh V, et al. Therapeutic impact of abdominopelvic computed tomography in patients with acute abdominal symptoms. Acta radiologica (Stockholm, Sweden : 1987). May. 2004;45(3):248-53. [pmid: 15239417].
31 Chen EH, Shofer FS, Dean AJ, et al. Derivation of a clinical prediction rule for evaluating patients with abdominal pain and diarrhea. The American journal of emergency medicine. May. 2008;26(4):450-3. [pmid: 18410814].
32 Chen SC, Yen ZS, Wang HP, et al. Ultrasonography is superior to plain radiography in the diagnosis of pneumoperitoneum. The British journal of surgery. Mar. 2002;89(3):351-4. [pmid: 11872063].
33 Chhetri RK, Shrestha ML. A comparative study of pre-operative with operative diagnosis in acute abdomen. Kathmandu University medical journal (KUMJ). Apr–Jun. 2005;3(2):107-10. [pmid: 16415604].
34 Chiu CJ, Bratu I. The process of treating pediatric appendicitis. Clinical pediatrics. Sep. 2011;50(9):803-6. [pmid: 21885434].
35 Cothren CC, Moore EE, Johnson JL, et al. Can we afford to do laparoscopic appendectomy in an academic hospital?. American journal of surgery. Dec. 2005;190(6):950-4. [pmid: 16307952].
36 Curry RW. Value of the left lateral decubitus position in the roentgenologic diagnosis of acute abdominal disease. Surgery, gynecology & obstetrics. May. 1957;104(5):627-32. [pmid: 13433261].
37 Dalrymple NC, Verga M, Anderson KR, et al. The value of unenhanced helical computerized tomography in the management of acute flank pain. The Journal of urology. Mar. 1998;159(3):735-40. [pmid: 9474137].
38 Aghamohammadi Dawood, CG, Hosseinzadeh Hamzeh, Khajehee Mohammad Ali, Ghabili Kamyar, Golzari Samad EJ. An evaluation of the effect of morphine on abdominal pain and peritonealirritation signs in patients with acute surgical abdomen. PMID:.
39 DeArmond GM, Dent DL, Myers JG, et al. Appendicitis: selective use of abdominal CT reduces negative appendectomy rate. Surgical infections. Summer. 2003;4(2):213-8. [pmid: 12906722].
40 deForest EK, Thompson GC. Implementation of an advanced nursing directive for suspected appendicitis to empower pediatric emergency nurses. Journal of emergency nursing: JEN : official publication of the Emergency Department Nurses Association. May. 2010;36(3):277-81. [pmid: 20457332].
41 Delibegovic S, Granov M, Satrovic A, et al. Laparoscopic appendectomy in Bosnia and Herzegovina: the state of laparoscopic procedure in the treatment of acute appendicitis. Medicinski arhiv. 2009;63(1):13-5. [pmid: 19419119].
42 Dhillon S, Halligan S, Goh V, et al. The therapeutic impact of abdominal ultrasound in patients with acute abdominal symptoms. Clinical radiology. Apr. 2002;57(4):268-71. [pmid: 12014871].
43 Doria AS, Amernic H, Dick P, et al. Cost-effectiveness analysis of weekday and weeknight or weekend shifts for assessment of appendicitis. Pediatric radiology. Dec. 2005;35(12):1186-95. [pmid: 16163503].
44 Draghici I, Draghici L, Popescu M, et al. Exploratory laparoscopy--diagnosis method in pediatric surgery pathology. Journal of medicine and life. Jul–Sep. 2009;2(3):288-95. [pmid: 20112473].
45 Easter DW, Cuschieri A, Nathanson LK, et al. The utility of diagnostic laparoscopy for abdominal disorders. Audit of 120 patients. Archives of surgery (Chicago, Ill : 1960). Apr. 1992;127(4):379-83. [pmid: 1532708].
46 Eriksson S, Granstrom L. Randomized controlled trial of appendicectomy versus antibiotic therapy for acute appendicitis. The British journal of surgery. Feb. 1995;82(2):166-9. [pmid: 7749676].
47 Eskelinen M, Lipponen P. Usefulness index in nonspecific abdominal pain--an aid in the diagnosis?. Scandinavian journal of gastroenterology. Dec. 2012;47(12):1475-9. [pmid: 23094970].
48 Fahimi J, Herring A, Harries A, et al. Computed tomography use among children presenting to emergency departments with abdominal pain. Pediatrics. Nov. 2012;130(5):e1069-75. [pmid: 23045569].
49 Fang JF, Chen RJ, Lin BC, et al. Aggressive resection is indicated for cecal diverticulitis. American journal of surgery. Feb. 2003;185(2):135-40. [pmid: 12559443].
50 Firilas AM, Higginbotham PH, Johnson DD, Jackson RJ, Wagner CW, Smith SD. A new economic benchmark for surgical treatment of appendicitis (Structured abstract). American Surgeon [serial on the Internet]. 1999;(8). Available from: http://onlinelibrary.wiley.com/o/cochrane/cleed/articles/NHSEED-21999001491/frame.html. Last accessed.
51 Fleming F, Grace P. Irritable bowel syndrome and negative appendectomy. Gut. Oct. 2007;56(10):1479. [pmid: 17872582].
52 Foulds KA, Beasley SW, Maoate K. The effect of the availability of laparoscopic techniques on the treatment of appendicitis in children. Pediatric surgery international. 2000;16(7):490-2. [pmid: 11057549].
53 Freedman SB, Thull-Freedman J, Manson D, Rowe MF, Rumantir M, Eltorki M, Schuh S. Pediatric abdominal radiograph use, constipation, and significant misdiagnoses. [pmid: 24128647].
54 Frei SP, Bond WF, Bazuro RK, et al. Appendicitis outcomes with increasing computed tomographic scanning. The American journal of emergency medicine. Jan. 2008;26(1):39-44. [pmid: 18082779].
55 Gagne JP, Billard M, Gagnon R, et al. Province-wide population survey of acute appendicitis in Canada. New twists to an old disease. Surgical endoscopy. Aug. 2007;21(8):1383-7. [pmid: 17653814].
56 Gao Y, Lee K, Camacho M. Utility of pelvic ultrasound following negative abdominal and pelvic CT in the emergency room. [pmid: 23890572].
57 Garbarino S, Shimi SM. Routine diagnostic laparoscopy reduces the rate of unnecessary appendicectomies in young women. Surgical endoscopy. Mar. 2009;23(3):527-33. [pmid: 18365280].
58 Gardner RL, Almeida R, Maselli JH, et al. Does gender influence emergency department management and outcomes in geriatric abdominal pain?. The Journal of emergency medicine. Sep. 2010;39(3):275-81. [pmid: 18993017].
59 Garfield JL, Birkhahn RH, Gaeta TJ, et al. Diagnostic pathways and delays on route to operative intervention in acute appendicitis. The American surgeon. Nov. 2004;70(11):1010-3. [pmid: 15586517].
60 Gasior AC, St Peter SD, Knott EM, et al. National trends in approach and outcomes with appendicitis in children. Journal of pediatric surgery. Dec. 2012;47(12):2264-7. [pmid: 23217886].
61 Gorelick MH, Yen K. The kappa statistic was representative of empirically observed inter-rater agreement for physical findings. Journal of clinical epidemiology. Aug. 2006;59(8):859-61. [pmid: 16828681].
62 Gourtsoyianni S, Zamboni GA, Romero JY, et al. Routine use of modified CT Enterography in patients with acute abdominal pain. European journal of radiology. Mar. 2009;69(3):388-92. [pmid: 19108972].
63 Grabowski A, Korlacki W, Pasierbek M. Laparoscopy in elective and emergency management of ovarian pathology in children and adolescents. [pmid: 25097682].
64 Green R, Bulloch B, Kabani A, et al. Early analgesia for children with acute abdominal pain. Pediatrics. Oct. 2005;116(4):978-83. [pmid: 16199711].
65 Green SM. When do clinical decision rules improve patient care?. [pmid: 23548403].
66 Gruer R, Gunn AA, Ruxton AM. Medical audit in practice. British medical journal. Apr. 9. 1977;1(6066):957-8. [pmid: 856394].
67 Gupta SK, Gupta R, Singh G, et al. Perforation peritonitis: A two year experience. JK Science. 2010;12(3):141-4. PMID:.
68 Guss DA, Richards C. Normal Total WBC and Operative Delay in Appendicitis. The California journal of emergency medicine/California Chapter of the American Academy of Emergency Medicine. Oct. 2000;1(2):7-8. [pmid: 20852682].
69 Hayward MW, Hayward C, Ennis WP, et al. A pilot evaluation of radiography of the acute abdomen. Clinical radiology. Jul. 1984;35(4):289-91. [pmid: 6734062].
70 Healy DA, McCartan DP, Grace PA, Aziz A, Dermody F, Clarke Moloney M, Coffey JC, Walsh SR, Burke PE. The impact of regional reconfiguration on the management of appendicitis. [pmid: 24091613].
71 Hildebrand P, Kropp M, Stellmacher F, et al. Surgery for right-sided colonic diverticulitis: results of a 10-year-observation period. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Mar. 2007;392(2):143-7. [pmid: 17072664].
72 Hryhorczuk AL, Mannix RC, Taylor GA. Pediatric Abdominal Pain: Use of Imaging in the Emergency Department in the United States from 1999 to 2007. Radiology. 2012;263(3):778-85. [pmid: 22535565].
73 Ibis C, Altan A. The value of intra-abdominal pressure measurement in patients with acute abdomen. Asian journal of surgery/Asian Surgical Association. Jan. 2009;32(1):33-8. [pmid: 19321400].
74 Ignjatovic S, Majkic-Singh N, Mitrovic M, et al. Biochemical evaluation of patients with acute pancreatitis. Clinical chemistry and laboratory medicine : CCLM/FESCC. Nov. 2000;38(11):1141-4. [pmid: 11156345].
75 Jess P, Bjerregaard B, Brynitz S, et al. Acute appendicitis. Prospective trial concerning diagnostic accuracy and complications. American journal of surgery. Feb. 1981;141(2):232-4. [pmid: 7457743].
76 Jung A, Schlag C, Becker V, von Delius S, Lersch C, Jeliazkova P, Herner A, Bajbouj M, Schuster T, Meining A. Endosonography For Right-sided and Acute Upper Intestinal Misery: the EFRAIM study: A prospective, randomized, controlled, blinded study. [pmid: 24917980].
77 Jung SI, Kim YJ, Park HS, et al. Acute pelvic inflammatory disease: diagnostic performance of CT. The journal of obstetrics and gynaecology research. Mar. 2011;37(3):228-35. [pmid: 21114582].
78 Kanona H, Al Samaraee A, Nice C, Bhattacharya V. Stump appendicitis: A review. International Journal of Surgery. 2012;10(9):425-8. PMID:. [pmid: 22846617].
79 Kanterman RY, Siegel MJ, Rossiter JE. Pediatric barium enema examination: optimizing patient selection with univariate and multivariate analyses. Pediatric radiology. 1994;24(4):288-92. [pmid: 7800455].
80 Kapoor W, Hemmer K, Herbert D, et al. Abdominal computed tomography. Comparison of the usefulness of goal-directed v non-goal-directed studies. Archives of internal medicine. Feb. 1983;143(2):249-51. [pmid: 6824393].
81 Karahan OI, Kurt A, Yikilmaz A, et al. New method for the detection of intraperitoneal free air by sonography: scissors maneuver. Journal of clinical ultrasound : JCU. Oct. 2004;32(8):381-5. [pmid: 15372444].
82 Kellow ZS, MacInnes M, Kurzencwyg D, et al. The role of abdominal radiography in the evaluation of the nontrauma emergency patient. Radiology. Sep. 2008;248(3):887-93. [pmid: 18710981].
83 Khairy G. Acute appendicitis: is removal of a normal appendix still existing and can we reduce its rate?. Saudi journal of gastroenterology : official journal of the Saudi Gastroenterology Association. Jul–Sep. 2009;15(3):167-70. [pmid: 19636177].
84 Khalil J, Muqim R, Rafique M, et al. Laparoscopic versus open appendectomy: a comparison of primary outcome measures. Saudi journal of gastroenterology : official journal of the Saudi Gastroenterology Association. Jul–Aug. 2011;17(4):236-40. [pmid: 21727728].
85 Khan SA, Khokhar HA, Nasr ARH, et al. Incidence of right-sided colonic tumors (non-appendiceal) in patient’s (greater-than or equal to)40 years of age presenting with features of acute appendicitis. International Journal of Surgery. 2013;11(4):301-4. PMID:. [pmid: 23416535].
86 Kirby CP, Sparnon AL. Active observation of children with possible appendicitis does not increase morbidity. ANZ journal of surgery. Jul. 2001;71(7):412-3. [pmid: 11450916].
87 Kizer KW, Vassar MJ. Emergency department diagnosis of abdominal disorders in the elderly. The American journal of emergency medicine. Jul. 1998;16(4):357-62. [pmid: 9672450].
88 Kong VY, Van Der Linde S, Aldous C, Handley JJ, Clarke DL. The accuracy of the Alvarado score in predicting acute appendicitis in the black South African population needs to be validated. [pmid: 25078937].
89 Kwok SK, Seo SH, Ju JH, et al. Lupus enteritis: clinical characteristics, risk factor for relapse and association with anti-endothelial cell antibody. Lupus. 2007;16(10):803-9. [pmid: 17895303].
90 Ladd MR, Neff LP, Becher RD, et al. Computerized tomography in the workup of pediatric appendicitis: why are children scanned?. The American surgeon. Jun. 2012;78(6):716-21. [pmid: 22643271].
91 Laitinen R, Tahtinen J, Lantto T, et al. Tc-99m labeled leukocytes in imaging of patients with suspected acute abdominal inflammation. Clinical nuclear medicine. Sep. 1990;15(9):597-602. [pmid: 2208880].
92 Lameris W, van Randen A, van Es HW, et al. Imaging strategies for detection of urgent conditions in patients with acute abdominal pain: diagnostic accuracy study. BMJ (Clinical research ed). 2009;338:b2431. [pmid: 19561056].
93 Lanning DA, Thomas RL, Rood KD, et al. Using quantitative methods to improve the diagnostic workup for abdominal pain in children. Journal of pediatric surgery. Jun. 2005;40(6):949-53. discussion 53–4. [pmid: 15991176].
94 Laurell H, Hansson LE, Gunnarsson U. Diagnostic pitfalls and accuracy of diagnosis in acute abdominal pain. Scandinavian journal of gastroenterology. Oct. 2006;41(10):1126-31. [pmid: 16990196].
95 Lee J, Tashjian DB, Moriarty KP. Missed opportunities in the treatment of pediatric appendicitis. [pmid: 22622518].
96 Lee KS, Rofsky NM, Pedrosa I. Localization of the appendix at MR imaging during pregnancy: utility of the cecal tilt angle. Radiology. Oct. 2008;249(1):134-41. [pmid: 18710961].
97 Lee SL, Stark R, Yaghoubian A, et al. Does age affect the outcomes and management of pediatric appendicitis?. Journal of pediatric surgery. Dec. 2011;46(12):2342-5. [pmid: 22152878].
98 Legault Kingstone L, Kielar AZ, McInnes M, et al. The potential value of adding colonic sonography to routine abdominal protocol in patients with active pain. Journal of Diagnostic Medical Sonography. 2011;27(3):103-11. PMID:.
99 Levenson RB, Camacho MA, Horn E, Saghir A, McGillicuddy, Sanchez LD. Eliminating routine oral contrast use for CT in the emergency department: Impact on patient throughput and diagnosis. [pmid: 22744764].
100 Lewis LM, Klippel AP, Bavolek RA, et al. Quantifying the usefulness of CT in evaluating seniors with abdominal pain. European journal of radiology. Feb. 2007;61(2):290-6. [pmid: 17085004].
101 Lien WC, Wang HP, Liu KL, et al. Appendicolith delays resolution of appendicitis following nonoperative management. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Dec. 2012;16(12):2274-9. [pmid: 23007281].
102 Lindelius A, Sonden A, Torngren S, Pettersson H, Adami J. Surgeon-performed ultrasound for diagnosis and management of the acute abdomen. European Journal of Trauma and Emergency Surgery [serial on the Internet]. 2008;(Suppl 1). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/660/CN-00777660/frame.html. Last accessed.
103 Lintula H, Kokki H, Vanamo K, et al. The costs and effects of laparoscopic appendectomy in children. Archives of pediatrics & adolescent medicine. Jan. 2004;158(1):34-7. [pmid: 14706955].
104 Liu CC, Lu CL, Yen DH, et al. Diagnosis of appendicitis in the ED: comparison of surgical and nonsurgical residents. The American journal of emergency medicine. Mar. 2001;19(2):109-12. [pmid: 11239252].
105 Lo MC. Prevalence of Diagnosed Mental Disorders Among Florida Adult Appendectomy Patients: Implications for Medical Cost Offset with Mental Health Treatment. Internet Journal of Mental Health. 2012;8(1):1. Language: English. Entry Date: 20130816. Revision Date: 20130816. Publication Type: journal article.
106 Mallick MS, Al-Qahtani A, Al-Bassam A. Laparoscopic appendectomy is a favorable alternative for complicated appendicitis in children. Pediatric surgery international. Mar. 2007;23(3):257-9. [pmid: 17115229].
107 Martin AE, Vollman D, Adler B, et al. CT scans may not reduce the negative appendectomy rate in children. Journal of pediatric surgery. Jun. 2004;39(6):886-90. discussion -90. [pmid: 15185219].
108 Martin R, Plante F. Stomach content and ultrasound technology in appendicitis. Journal of clinical anesthesia. Sep. 2008;20(6):485. [pmid: 18929299].
109 Marzouk M, Khater M, Elsadek M, et al. Laparoscopic versus open appendectomy: a prospective comparative study of 227 patients. Surgical endoscopy. May. 2003;17(5):721-4. [pmid: 12616393].
110 McGowan DR, Sims HM, Zia K, et al. The value of biochemical markers in predicting a perforation in acute appendicitis. ANZ journal of surgery. Jan. 2013;83(1–2):79-83. [pmid: 23231057].
111 Mills AM, Baumann BM, Chen EH, et al. The impact of crowding on time until abdominal CT interpretation in emergency department patients with acute abdominal pain. Postgraduate medicine. Jan. 2010;122(1):75-81. [pmid: 20107291].
112 Mirza MR, Habib L, Jaleel F. Factors identified for negative appendicectomies. Mymensingh medical journal : MMJ. Jul. 2009;18(2):198-202. [pmid: 19623147].
113 Mollmann KM, Bonnevie O, Gudbrand Hoyer E, et al. A diagnostic study of patients with upper abdominal pain. Scandinavian journal of gastroenterology. 1975;10(8):805-9. [pmid: 1202611].
114 Mooney D, Wiener E. Time of day affects radiographic study in the diagnosis of appendicitis in the pediatric emergency department. Annals of emergency medicine. 2012;60(4):S27. PMID:.
115 Neff LP, Ladd MR, Becher RD, et al. Computerized tomography utilization in children with appendicitis-differences in referring and children’s hospitals. The American surgeon. Aug. 2011;77(8):1061-5. [pmid: 21944524].
116 Ng CS, Palmer CR. Analysis of diagnostic confidence: application to data from a prospective randomized controlled trial of CT for acute abdominal pain. Acta radiologica (Stockholm, Sweden : 1987). May. 2010;51(4):368-74. [pmid: 20350244].
117 Nozoe T, Matsumata T, Sugimachi K. Significance of SIRS score in therapeutic strategy for acute appendicitis. Hepato-gastroenterology. Mar–Apr. 2002;49(44):444-6. [pmid: 11995470].
118 Ohene-Yeboah M, Togbe B. An audit of appendicitis and appendicectomy in Kumasi, Ghana. West African journal of medicine. Apr–Jun. 2006;25(2):138-43. [pmid: 16918187].
119 Ohsawa I, Nagamachi S, Suzuki H, Honda D, Sato N, Ohi H, Horikoshi S, Tomino Y. Leukocytosis and high hematocrit levels during abdominal attacks of hereditary angioedema. [pmid: 23915279].
120 Oliak D, Sinow R, French S, et al. Computed tomography scanning for the diagnosis of perforated appendicitis. The American surgeon. Oct. 1999;65(10):959-64. [pmid: 10515543].
121 Ooi BC, Lim KW, Cheng HK, et al. Acute appendicitis in Singapore children--some clinical aspects. The Journal of the Singapore Paediatric Society. 1989;31(3–4):133-7. [pmid: 2638719].
122 Osada H, Ohno H, Watanabe W, et al. Multidetector computed tomography diagnosis of primary and secondary epiploic appendagitis. Radiation medicine. Dec. 2008;26(10):582-6. [pmid: 19132488].
123 Ou M-C, Chung-Chu P, Ou D, Su CH. The implications of abdominal palpation with manipulation for women with acute abdomen. [pmid: 21354746].
124 Panteghini M, Pagani F, Bonora R, et al. Diagnostic value of four assays for lipase determination in serum: a comparative reevaluation. Clinical biochemistry. Dec. 1991;24(6):497-503. [pmid: 1773490].
125 Parker JS, Vukov LF, Wollan PC. Abdominal pain in the elderly: use of temperature and laboratory testing to screen for surgical disease. Family medicine. Mar. 1996;28(3):193-7. [pmid: 8900552].
126 Paterson-Brown S, Vipond MN, Simms K, et al. Clinical decision making and laparoscopy versus computer prediction in the management of the acute abdomen. The British journal of surgery. Oct. 1989;76(10):1011-3. [pmid: 2532048].
127 Patrick GL, Stewart RJ, Isbister WH. Patients with acute abdominal pain: white cell and neutrophil counts as predictors of the surgical acute abdomen. The New Zealand medical journal. May. 8. 1985;98(778):324-6. [pmid: 3858715].
128 Peled Y, Ben-Haroush A, Eitan R, et al. The accuracy of the preoperative diagnosis in women undergoing emergent gynecological laparoscopy for acute abdominal pain. Archives of gynecology and obstetrics. Dec. 2011;284(6):1439-42. [pmid: 21234759].
129 Peng YS, Lee HC, Yeung CY, et al. Clinical criteria for diagnosing perforated appendix in pediatric patients. Pediatric emergency care. Jul. 2006;22(7):475-9. [pmid: 16871105].
130 Powers RD, Guertler AT. Abdominal pain in the ED: stability and change over 20 years. The American journal of emergency medicine. May. 1995;13(3):301-3. [pmid: 7755822].
131 Quaday, Salzman, Gordon. Magnetic resonance imaging and computed tomography utilization trends in an academic ED.
132 Raja AS, Wright C, Sodickson AD, et al. Negative appendectomy rate in the era of CT: an 18-year perspective. Radiology. Aug. 2010;256(2):460-5. [pmid: 20529988].
133 Raman SS, Osuagwu FC, Kadell B, et al. Effect of CT on false positive diagnosis of appendicitis and perforation. The New England journal of medicine. Feb. 28. 2008;358(9):972-3. [pmid: 18305278].
134 Rhea JT, Rao PM, Novelline RA, et al. A focused appendiceal CT technique to reduce the cost of caring for patients with clinically suspected appendicitis. AJR American journal of roentgenology. Jul. 1997;169(1):113-8. [pmid: 9207509].
135 Ringl H, Schernthaner R, Sala E, et al. Lossy 3D JPEG2000 compression of abdominal CT images in patients with acute abdominal complaints: effect of compression ratio on diagnostic confidence and accuracy. Radiology. Aug. 2008;248(2):476-84. [pmid: 18641251].
136 Risser WL, Pokorny SF, Maklad NF. Ultrasound examination of adolescent females with lower abdominal pain. Journal of adolescent health care : official publication of the Society for Adolescent Medicine. Sep. 1988;9(5):407-10. [pmid: 3049483].
137 Rosen MP, Siewert B, Sands DZ, et al. Value of abdominal CT in the emergency department for patients with abdominal pain. European radiology. Feb. 2003;13(2):418-24. [pmid: 12599010].
138 Sandler G. Do emergency tests help in the management of acute medical admissions?. British medical journal (Clinical research ed). Oct. 13. 1984;289(6450):973-7. [pmid: 6435748].
139 Sanna A, Adani GL, Anania G, et al. The role of laparoscopy in patients with suspected peritonitis: experience of a single institution. Journal of laparoendoscopic & advanced surgical techniques Part A. Feb. 2003;13(1):17-9. [pmid: 12676016].
140 Sarifakioglu B, Afsar SI, Yalbuzdag SA, Ustaomer K, Ayas S. Acute abdominal emergencies and spinal cord injury; our experiences: a retrospective clinical study. [pmid: 25000951].
141 Savioz D, Lironi A, Zurbuchen P, et al. Acute right iliac fossa pain in acquired immunodeficiency: a comparison between patients with and without acquired immune deficiency syndrome. The British journal of surgery. May. 1996;83(5):644-6. [pmid: 8689208].
142 Schneider PA, Hauser H. Diagnosis of alimentary tract perforation by CT. European journal of radiology. Aug. 1982;2(3):197-201. [pmid: 7128602].
143 Scholer SJ, Pituch K, Orr DP, et al. Clinical outcomes of children with acute abdominal pain. Pediatrics. Oct. 1996;98(4 Pt 1):680-5. [pmid: 8885946].
144 Shabbir B, Qadir H, Shafi F, Mahboob F. Acute abdominal pain in dengue fever. Pakistan Journal of Medical and Health Sciences. 2012;6(1):155-8. PMID:.
145 Siewert B, Raptopoulos V, Mueller MF, et al. Impact of CT on diagnosis and management of acute abdomen in patients initially treated without surgery. AJR American journal of roentgenology. Jan. 1997;168(1):173-8. [pmid: 8976942].
146 Simmen HP, Decurtins M, Rotzer A, et al. Emergency room patients with abdominal pain unrelated to trauma: prospective analysis in a surgical university hospital. Hepato-gastroenterology. Aug. 1991;38(4):279-82. [pmid: 1937370].
147 Stamper R, Todd BS, Macpherson P. Case-based explanation for medical diagnostic programs, with an example from gynaecology. Methods of information in medicine. May. 1994;33(2):205-13. [pmid: 8057948].
148 Stein GY, Rath-Wolfson L, Zeidman A, et al. Sex differences in the epidemiology, seasonal variation, and trends in the management of patients with acute appendicitis. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Oct. 2012;397(7):1087-92. [pmid: 22661078].
149 Tieng N, Grinberg D, Li SF. Discrepancies in interpretation of ED body computed tomographic scans by radiology residents. The American journal of emergency medicine. Jan. 2007;25(1):45-8. [pmid: 17157681].
150 Toorenvliet BR, Bakker RF, Flu HC, et al. Standard outpatient re-evaluation for patients not admitted to the hospital after emergency department evaluation for acute abdominal pain. World journal of surgery. Mar. 2010;34(3):480-6. [pmid: 20049441].
151 Tsai CC, Lee SY, Huang FC. Laparoscopic versus open appendectomy in the management of all stages of acute appendicitis in children: A retrospective study. [pmid: 23084720].
152 Tsushima Y, Aoki J, Endo K. Contribution of the diagnostic test to the physician’s diagnostic thinking: new method to evaluate the effect. Academic radiology. Jul. 2003;10(7):751-5. [pmid: 12862284].
153 Udwadia TE. Diagnostic laparoscopy. Surgical endoscopy. Jan. 2004;18(1):6-10. [pmid: 12958680].
154 Vadeboncoeur TF, Heister RR, Behling CA, et al. Impact of helical computed tomography on the rate of negative appendicitis. The American journal of emergency medicine. Jan. 2006;24(1):43-7. [pmid: 16338508].
155 Vainrib M, Buklan G, Gutermacher M, et al. The impact of early sonographic evaluation on hospital admissions of children with suspected acute appendicitis. Pediatric surgery international. Sep. 2011;27(9):981-4. [pmid: 21344218].
156 Verma I, Kaur S, Goyal S, Multani JS, Narang APS. Diagnostic value of lactate levels in acute abdomen disorders. [pmid: 24966491].
157 Vermeulen B, Morabia A, Unger PF. Influence of white cell count on surgical decision making in patients with abdominal pain in the right lower quadrant. The European journal of surgery. Acta chirurgica. Jul. 1995;161(7):483-6. [pmid: 7488661].
158 Vettoretto N, Montori G, Bartoli M, et al. Lesson learned from 10 years’ experience in laparoscopic appendectomy in a community hospital. Updates in surgery. Dec. 2012;64(4):285-8. [pmid: 22991328].
159 Wagner PL, Eachempati SR, Aronova A, et al. Contemporary predictors of conversion from laparoscopic to open appendectomy. Surgical infections. Aug. 2011;12(4):261-6. [pmid: 21790480].
160 Waldhausen JHT. Discussion. American journal of surgery. 2014;207(5):753. PMID:.
161 Wasson JH, Sox HC Jr, Sox CH. The diagnosis of abdominal pain in ambulatory male patients. Medical decision making : an international journal of the Society for Medical Decision Making. 1981;1(3):215-24. [pmid: 7052409].
162 Wen SW, Naylor CD. Diagnostic accuracy and short-term surgical outcomes in cases of suspected acute appendicitis. CMAJ : Canadian Medical Association journal. journal de l’Association medicale canadienne. May. 15. 1995;152(10):1617-26. [pmid: 7743448].
163 Whyte C, Levin T, Harris BH. Early decisions in perforated appendicitis in children: lessons from a study of nonoperative management. Journal of pediatric surgery. Aug. 2008;43(8):1459-63. [pmid: 18675635].
164 Yikilmaz A, Karahan OI, Senol S, et al. Value of multislice computed tomography in the diagnosis of acute mesenteric ischemia. European journal of radiology. Nov. 2011;80(2):297-302. [pmid: 20719444].
165 Yilmaz HG, Akgun Y, Bac B, et al. Acute appendicitis in pregnancy--risk factors associated with principal outcomes: a case control study. International journal of surgery (London, England). Jun. 2007;5(3):192-7. [pmid: 17509502].
166 Youssef MA, Elbarbary AA. The added value of coronal reformatted images using 16 slice multidetector computed tomography in non-traumatic-acute abdomen. Alexandria Journal of Medicine. 2014;50(2):179-88. PMID:.

## B-4. Rejection Reason: Case Report or Case Series

1 “Recurrent” appendicitis. AORN Journal. 2012;95(3):424. Language: English. Entry Date: 20120413. Revision Date: 20130607. Publication Type: journal article. [pmid: 22381561].
2 Abbasi M, Mahmood S, Fleming F, et al. Diagnostic dilemma--solved by appendicectomy. Irish medical journal. Jun. 2002;95(6):186-7. [pmid: 12171270].
3 Abdominal pain and fever. Virginia medical. Jun. 1988;115(6):280-6. [pmid: 3400304].
4 Antal A, Ezer P, Hideg G. Laparoscopic appendectomy (LA) with a new technique. Acta chirurgica Hungarica. 1995;35(3–4):225-8. [pmid: 9262718].
5 Arbatli MM, Kuscu L, Dorak AC, et al. Ultrasonic diagnosis of acute uncomplicated appendicitis located in the subhepatic space. Journal of clinical ultrasound : JCU. May. 1993;21(4):272-3. [pmid: 8478461].
6 Asad S, Bae K, Jeon KN, et al. Appendicitis caused by a foreign body of dental origin: diagnosis with ultrasonography. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Jul. 2007;26(7):967-70. [pmid: 17592060].
7 Babb RR, Trollope ML. Recurrent appendicitis. Uncommon, but it does occur. Postgraduate medicine. Jul. 1999;106(1):135-8. [pmid: 10418581].
8 Baerlocher MO, Asch MR. Interventional radiology in palliative care. CMAJ : Canadian Medical Association journal. journal de l’Association medicale canadienne. Mar. 13. 2007;176(6):762-3. [pmid: 17353527].
9 Baldisserotto M, Cavazzola S, Cavazzola LT, et al. Acute edematous stump appendicitis diagnosed preoperatively on sonography. AJR American journal of roentgenology. Aug. 2000;175(2):503-4. [pmid: 10915703].
10 Bao J, Lopez JA, Huerta S. Acute abdominal pain and abnormal CT findings. [pmid: 23982371].
11 Ben-Chetrit E, Putterman C. Clinical problem-solving. Still hazy after all these years. The New England journal of medicine. Oct. 6. 1994;331(14):934-8. [pmid: 7888006].
12 Blouhos K, Boulas KA, Salpigktidis I, Barettas N, Hatzigeorgiadis A. Ectopic spleen: An easily identifiable but commonly undiagnosed entity until manifestation of complications. [pmid: 24973525].
13 Boubalos A, Bret P. Diagnosis of epigastric appendicitis based on sonographic findings. AJR American journal of roentgenology. Jul. 1992;159(1):222. [pmid: 1609708].
14 Bravo Mata M, Martinon Torres F, Fernandez Cebrian S, et al. What is your diagnosis? Acute abdomen. Anales espanoles de pediatria. Sep. 1999;51(3):303-4. [pmid: 10575758].
15 Brockman J, Gibbs PM, Polenakovik H, et al. Acute appendicitis due to Malassezia restricta. Mycoses. Mar. 2012;55(2):e13-4. [pmid: 21797936].
16 Brook OR, Guralnik L, Engel A. CT scout view as an essential part of CT reading. Australasian radiology. Jun. 2007;51(3):211-7. [pmid: 17504310].
17 Brook OR, Slotzky M, Deutsch M, et al. The role of magnetic resonance imaging in the differential diagnosis of acute right lower quadrant pain during pregnancy. The Israel Medical Association journal : IMAJ. Dec. 2007;9(12):883-4. [pmid: 18210932].
18 Brown DF, Nadel ES. Acute intermittent abdominal pain. The Journal of emergency medicine. Sep–Oct. 1998;16(5):751-3. [pmid: 9752951].
19 Bruno MS, Ober WB. LEFT COSTOVERTEBRAL ANGLE PAIN AND ACUTE ABDOMINAL CONDITION. New York state journal of medicine. Sep. 1. 1964;64:2210-6. [pmid: 14180271].
20 Calvo Aguilar MJ, Sierra Sirvent JF, Bustillo Alonso M, et al. Fever, abdominal pain, and exanthema. Anales espanoles de pediatria. Sep. 2000;53(3):285-6. [pmid: 11083977].
21 Chang CW, Liao WS, Shih SC, et al. Vomiting and a target sign on abdominal CT. Gut. May. 2008;57(5):663. 94. [pmid: 18408103].
22 Chick JF, Chauhan NR, Mullen KM, Hanna JW, Bair RJ, Khurana B. Intestinal malrotation and acute left-sided appendicitis. [pmid: 23419212].
23 Chinchure D, Fortier MV. Role of radiology in diagnosis and treatment of an infant with acute abdomen. Annals of the Academy of Medicine, Singapore. Mar. 2011;40(3):154-5. [pmid: 21603739].
24 Chio UC, Tseng SH, Chen Y. Acute appendicitis associated with scarlet fever. The Pediatric infectious disease journal. Jun. 2012;31(6):662-3. [pmid: 22466330].
25 Cho J, Kwon OY, Cho B, Kim SW. Prevertebral paraspinal inflammation presenting with acute abdominal pain. [pmid: 23933857].
26 Chou AL, Lin CW, Tseng KC. Appearance of an inverted appendix on virtual colonoscopy. Endoscopy. Feb. Suppl 1. 2007;39:E139. [pmid: 17616919].
27 Chou JW, Feng CL, Lai HC. Appendiceal mucocele presenting with lower abdominal pain. Endoscopy. Suppl 2. 2009;41:E222-3. [pmid: 19757364].
28 Coady DJ, Snyder JR, Subramanyam B. Appendiceal abscess in pregnancy: diagnosis by ultrasound. Journal of clinical ultrasound : JCU. Jan. 1986;14(1):70-1. [pmid: 3080494].
29 Coughlin LM, Sparks DA, Chase DM. Scleroderma mimicking the acute abdomen. The American surgeon. Dec. 2012;78(12):E536-7. [pmid: 23265115].
30 da Freitas RS, Ascenco AS, Maluf I Junior, Nasser I, Balbinot P, Lopes MA, Forte AJ, Sadowski JA. Acute abdomen after abdominoplasty: differential diagnosis. [pmid: 23529759].
31 Danielson K, Chernin MM, Amberg JR, et al. Epiploic appendicitis: CT characteristics. Journal of computer assisted tomography. Jan–Feb. 1986;10(1):142-3. [pmid: 3944300].
32 de Dombal FT. Computer-aided diagnosis of acute abdominal pain. The British experience. Revue d’epidemiologie et de sante publique. 1984;32(1):50-6. [pmid: 6371951].
33 De la Cruz-Vigo F, Galvez-Valdovinos R, Sanchez-Bustos F, et al. Abdominal pain and acute hypotension. Postgraduate medical journal. Jun. 1995;71(836):363-4. [pmid: 7644399].
34 Deceuninck A, Danse E. Primary epiploic appendagitis: US and CT findings. JBR-BTR : organe de la Societe royale belge de radiologie (SRBR) = orgaan van de Koninklijke Belgische Vereniging voor Radiologie (KBVR). Jul–Aug. 2006;89(4):225. [pmid: 16999328].
35 Devuyst O, Maldague P, Francois P, et al. Time-course of lymphopenia in gangrenous appendicitis. Lancet. Oct. 26. 1991;338(8774):1074. [pmid: 1681371].
36 Diabetes mellitus and alcoholism complicated by an acute abdomen. The American journal of medicine. Mar. 1972;52(3):379-90. [pmid: 5011395].
37 Donkervoort SC, Boerma D. Suspicion of acute appendicitis in the third trimester of pregnancy: pros and cons of a laparoscopic procedure. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Jul–Sep. 2011;15(3):379-83. [pmid: 21985728].
38 Duckler L. Foreign body producing appendicitis. Clinical pediatrics. Apr. 1976;15(4):383. [pmid: 1253520].
39 Edmiston J. Abdominal pain is not always appendicitis. [pmid: 24201925].
40 Ellis H. A mass in the right iliac fossa. British Journal of Hospital Medicine (17508460). 2012;73(12):C188-9. Language: English. Entry Date: 20130118. Revision Date: 20140620. Publication Type: journal article.
41 Estevao-Costa J, Soares-Oliveira M, Lopes JM, et al. Idiopathic perforation of the gallbladder: a novel differential diagnosis of acute abdomen. Journal of pediatric gastroenterology and nutrition. Jul. 2002;35(1):88-9. [pmid: 12142817].
42 Etkin Y, Chao E. Rare presentation of perforated diverticulitis. The American surgeon. Dec. 2012;78(12):E527-8. [pmid: 23265110].
43 Evans RH, Colbert RF. Acute perforated appendicitis--an unusual variant simulating acute acalculous cholecystitis. Journal of clinical ultrasound : JCU. Sep. 1988;16(7):513-5. [pmid: 3152450].
44 Fedyshin P, Kelvin FM, Rice RP. Nonspecificity of barium enema findings in acute appendicitis. AJR American journal of roentgenology. Jul. 1984;143(1):99-102. [pmid: 6610341].
45 Fee HJ Jr, Jones PC, Kadell B, et al. Radiologic diagnosis of appendicitis. Archives of surgery (Chicago, Ill : 1960). Jun. 1977;112(6):742-4. [pmid: 860923].
46 Feldberg MA, Hendriks MJ, van Waes PF. Computed tomography in complicated acute appendicitis. Gastrointestinal radiology. 1985;10(3):289-95. [pmid: 4029546].
47 Fernandez-Rey CL, Alvarez-Gonzalez SA, Diaz-Solis P, et al. Small bowel obstruction secondary to ileal endometriosis: multisection computer tomography evaluation. Revista espanola de enfermedades digestivas : organo oficial de la Sociedad Espanola de Patologia Digestiva. Dec. 2009;101(12):872-4. [pmid: 20082549].
48 Fields RC, DeMatteo RP. Incidentally discovered, intra-abdominal metallic foreign object on preoperative imaging. The American surgeon. Sep. 2010;76(9):E180-1. [pmid: 21396280].
49 Filatov J, Ilibitzki A, Davidovitch S, et al. Appendicitis within a femoral hernia: sonographic appearance. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Sep. 2006;25(9):1233-5. [pmid: 16929028].
50 Fink S. Rectal examinations and appendicitis malpractice claims. Southern medical journal. Dec. 1995;88(12):1279. [pmid: 7502127].
51 Fishman EK. Spiral CT: applications in the emergency patient. Radiographics : a review publication of the Radiological Society of North America, Inc. Jul. 1996;16(4):943-8. [pmid: 8835983].
52 Fisk DT, Saint S, Tierney LM Jr. Clinical problem-solving. Back to the basics. The New England journal of medicine. Sep. 2. 1999;341(10):747-50. [pmid: 10471462].
53 Fraley EE, Reinberg Y, Holt T, et al. Computerized tomography in the diagnosis of appendicovesical fistula. The Journal of urology. Apr. 1993;149(4):830-2. [pmid: 8455252].
54 Freitas GP, Bacellar R, Nunes V, et al. Cutaneous fistula and abdominal pain. Acute appendicitis. Acta gastroenterologica Latinoamericana. Sep. 2010;40(3):196. 300. [pmid: 21049769].
55 Friedlich MS, Papadatos D. Acute appendagitis as a cause of right lower quadrant pain. Canadian journal of surgery Journal canadien de chirurgie. Jun. 2006;49(3):215-6. [pmid: 16749985].
56 Garg PK, Jain BK, Rathi V, et al. Giant appendicolith. Indian journal of gastroenterology : official journal of the Indian Society of Gastroenterology. Sep. 2011;30(5):243. [pmid: 21922301].
57 Gayer G. Appendicitis in an elderly women: CT diagnosis. The Israel Medical Association journal : IMAJ. May. 2001;3(5):386-7. [pmid: 11411210].
58 Gifford SM, Bowman J, Perry WB, et al. Right lower quadrant pain in a young adult male. Current surgery. Sep–Oct. 2006;63(5):318-21. [pmid: 16971201].
59 Gockel I, Jager F, Shah S, et al. Appendicitis necessitatis: appendicitis perforating the abdominal wall. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Sep. 2007;78(9):840-2. [pmid: 17342350].
60 Goldman JA, Peleg D, Feldberg D, et al. IUD appendicitis. European journal of obstetrics, gynecology, and reproductive biology. Jul. 1983;15(3):181-3. [pmid: 6684597].
61 Goodwin AT, Ghilchik M. Acute strangulation of the appendix within a laparoscopic port-site hernia. The European journal of surgery. Acta chirurgica. Feb. 1998;164(2):151-2. [pmid: 9537725].
62 Gopal K, Kumar S, Grewal H. Torsion of the vermiform appendix. Journal of pediatric surgery. Feb. 2005;40(2):446-7. [pmid: 15750946].
63 Guptill P. Differential Diagnosis of Abdominal Manifestations of Acute Rheumatic Fever from Acute Appendicitis. Annals of surgery. Apr. 1934;99(4):650-60. [pmid: 17867175].
64 Haider Z, Condous G, Ahmed S, et al. Transvaginal sonographic diagnosis of appendicitis in acute pelvic pain. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Sep. 2006;25(9):1243-4. [pmid: 16929030].
65 Hair MJ, Carlton DM. FOREIGN BODIES IN THE APPENDIX. The Journal of the Louisiana State Medical Society : official organ of the Louisiana State Medical Society. Mar. 1965;117:90-1. [pmid: 14257681].
66 Hamcan S, Akgun V, Battal B, Karaman B. Acute perforated appendicitis in femoral hernia sac: CT imaging findings. [pmid: 23955983].
67 Harell GS, Uddo JF Jr. Radiology corner. Appendicitis. The Journal of the Louisiana State Medical Society : official organ of the Louisiana State Medical Society. Jun. 1990;142(6):13-5. [pmid: 2193995].
68 Hart PA, Sweetser S, Baron TH. A diagnosis that’s up in the air. [pmid: 24680968].
69 Healy D, Dunne M, Duignan J, et al. The use of ultrasonography in the diagnosis of retroperitoneal abscess caused by perforation of the appendix. Irish journal of medical science. Dec. 1980;149(12):479. [pmid: 7228594].
70 Hermanides RS, Coenen JL, Groeneveld PH. Acute left-sided abdominal pain. [pmid: 23462057].
71 Holden DM, Einstein DM. Which imaging test for right lower quadrant pain?. Cleveland Clinic journal of medicine. Jan. 2007;74(1):37-40. [pmid: 17373345].
72 Hollander SC, Springer SA. The diagnosis of acute left-sided appendicitis with computed tomography. Pediatric radiology. Jan. 2003;33(1):70-1. [pmid: 12497246].
73 Hsiao TF, Chou YH. Stercoral perforation of colon: a rare but important mimicker of acute appendicitis. The American journal of emergency medicine. Jan. 2010;28(1):112.e1-2. [pmid: 20006219].
74 Hughes JH, Durtz RG. Appendicitis--still a potentially lethal disease. The Ohio State medical journal. Jun. 1975;71(6):387-9. [pmid: 1134698].
75 Iki K, Echigo M, Nogami A, et al. Preoperative diagnosis of acute appendiceal diverticulitis by ultrasonography. Surgery. Jul. 2001;130(1):87-9. [pmid: 11436018].
76 Image interpretation session. Perforated appendix. Radiographics : a review publication of the Radiological Society of North America, Inc. Jan. 1990;10(1):142-3. [pmid: 2296690].
77 Jackson JG, Gammill SL. Right lower quadrant pain and tenderness: appendiceal abscess with appendicolith. Journal of the Tennessee Medical Association. Jul. 1986;79(7):433-4. [pmid: 3747506].
78 Jacombs A, Webb G, Leibman S. Right iliac fossa pain 10 years after appendicectomy and the diagnosis of stump appendicitis. ANZ journal of surgery. Aug. 2008;78(8):711-2. [pmid: 18796035].
79 Johnston G. PNEUMOPERITONEUM IN ACUTE APPENDICITIS. The British journal of radiology. Jan. 1964;37:76-7. [pmid: 14111629].
80 Jones WL. A nearly fatal illness presenting under the guise of virus flu syndrome. South Dakota journal of medicine. Jul. 1982;35(7):5-7. [pmid: 6958064].
81 Jopson JH. IX. Acute Gangrenous Appendicitis in Typhoid Fever Simulating Perforation. Annals of surgery. Nov. 1905;42(5):738-43. [pmid: 17861707].
82 Jores AP, Joeris A, Stranzinger E. Impressive sonogram of appendicitis. Der Radiologe. Nov. 2012;52(11):1042-6. [pmid: 23108495].
83 Kaplan L, Young M, Krilov L. Acute abdominal pain and an abnormal chest X-ray. Hospital practice (Hospital ed). Apr. 9. 1982;17(4):65-70. [pmid: 7200078].
84 Kaushik N, Krasinskas A, Slivka A, et al. Acute appendicitis. Gastrointestinal endoscopy. Jul. 2004;60(1):102-3. [pmid: 15229439].
85 Kim RW, Marcus CS. Periodontal disease detected by Tc-99m albumin colloid leukocyte imaging. Clinical nuclear medicine. Mar. 1993;18(3):241-2. [pmid: 8462219].
86 Kirbas I, Yildirim E, Harman A, et al. Perforated ileal diverticulitis: CT findings. Diagnostic and interventional radiology (Ankara, Turkey). Dec. 2007;13(4):188-9. [pmid: 18092289].
87 Kirshenbaum KJ, Warner JJ, Nadimpalli SR, et al. Endometriosis of the right fallopian tube mimicking appendicitis on sonography. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Jan. 1990;9(1):57-9. [pmid: 2404135].
88 Matkowskyj KA, Rao MS, Raparia K. Transcription Factor E3 Protein-Positive Perivascular Epithelioid Cell Tumor of the Appendix Presenting as Acute Appendicitis. [pmid: 23451753].
89 Kokhanovsky N, Nachtigal A, Reindorp N, Zeina AR. Ultrasonography diagnosis of acute appendicitis in a 6-month-old infant coexisting with ileal obstruction caused by an omental band. [pmid: 23393720].
90 Kolisch PR. APPENDICITIS: MORTALITY AND ACCURACY OF DIAGNOSIS. New York state journal of medicine. Jun. 15. 1965;65:1676-8. [pmid: 14302203].
91 Konicki PJ, Kulstad EB. Diagnosis of appendicitis with ultrasound: case example. The Journal of emergency medicine. Aug. 2004;27(2):187-9. [pmid: 15261364].
92 Kopilnick M, Mansberger AR Jr. Ammonia determinations on peritoneal fluid value in differntial diagnosis of acute abdominal disease. Maryland state medical journal. Apr. 1963;12:154-60. [pmid: 14034690].
93 Lauretta A, Almoudaris AM, Jiao LR. Septic thrombophlebitis of portal vein: unusual presentation of appendicitis. The American surgeon. Sep. 2011;77(9):E206-7. [pmid: 21944612].
94 Lee SY, Lee KH, Hwang HS, et al. Septic encephalopathy complicating acute appendicitis. Pediatric critical care medicine : a journal of the Society of Critical Care Medicine and the World Federation of Pediatric Intensive and Critical Care Societies. Jan. 2009;10(1):e11-3. [pmid: 19131864].
95 Leonardi NR, Lutfi RE. Postoperative acute appendicitis after laparoscopic gastric band placement. Surgery for obesity and related diseases : official journal of the American Society for Bariatric Surgery. Jul–Aug. 2012;8(4):e49-51. [pmid: 21676656].
96 Lewis SRR, Mahony PJ, Simpson J. Appendicitis. BMJ (Online). 2011;343(7827).
97 Liu YP, Shih SL, Yang FS. Sudden onset of right lower quadrant pain after heavy exercise. American family physician. Aug. 1. 2008;78(3):379-80. 84. [pmid: 18711954].
98 Lucenti MJ, Nadel ES, Brown DF. Right lower quadrant pain. The Journal of emergency medicine. Nov. 2001;21(4):431-4. [pmid: 11728774].
99 Lyne PJ. Acute appendicitis in the young soldier. Guy’s Hospital reports. 1955;104(3):268-74. [pmid: 13294591].
100 Mahajan PS, Abdalla MF, Purayil NK. First Report of Preoperative Imaging Diagnosis of a Surgically Confirmed Case of Valentino’s Syndrome. [pmid: 24991479].
101 Mansberger AR Jr. Value of peritoneal fluid ammonia levels in the differential diagnosis of the acute abdomen. Annals of surgery. Jun. 1962;155:998-1010. [pmid: 14469419].
102 Marchiole P, Di Capua E, Costantini S. A right latero-pelvic mass: an uncommon diagnosis by endovaginal ultrasonography. Mucocele of the appendix. Acta obstetricia et gynecologica Scandinavica. 2006;85(8):1014-5. [pmid: 16862486].
103 Marn CS, Bree RL. Advances in pelvic ultrasound: endovaginal scanning for ectopic gestation and graded compression sonography for appendicitis. Annals of emergency medicine. Dec. 1989;18(12):1304-9. [pmid: 2686501].
104 Martin KL, Weir M, Engbers PB, et al. Recurrent appendicitis after appendectomy. CMAJ : Canadian Medical Association journal. journal de l’Association medicale canadienne. Jan. 10. 2012;184(1):E83. [pmid: 22083683].
105 Martínez-Criado YM-LA, Galán N, De-Agustín-Asensio JC. Acute appendicitis by Enterobius vermicularis, an unusual etiology in children. [Spanish]. [pmid: 22849508].
106 McGahan JP. Perinephric abscess secondary to ruptured retrocecal appendix diagnosed by computerized tomography. Urology. Feb. 1982;19(2):217-9. [pmid: 7058618].
107 Melnick ER, Melnick JR, Nelson BP. Pelvic ultrasound in acute appendicitis. The Journal of emergency medicine. Feb. 2010;38(2):240-2. [pmid: 18571366].
108 Modgil G, Cooke DI, Newbury L. Appendiceal appearances: the great imitator. Archives of disease in childhood. Apr. 2006;91(4):333. [pmid: 16551787].
109 Mowrey K. The challenge of assessing and diagnosing acute abdomen in tetraplegics: a case study. The Journal of neuroscience nursing : journal of the American Association of Neuroscience Nurses. Feb. 2007;39(1):5-8. [pmid: 17396531].
110 Mull AC, Hurtado TR. Right lower quadrant pain in an adult woman. The American journal of emergency medicine. Jan. 2011;29(1):132.e1-2. [pmid: 20825869].
111 Mullins TK, Barnett SJ, Biro FM. Bilateral scrotal pain. [pmid: 23162935].
112 Munoz M, Usatine RP. Abdominal pain in a pregnant woman. The Journal of family practice. Aug. 2005;54(8):665-8. [pmid: 16061051].
113 Nath UK, Ray SS, Chattopadhyay A, Chakrabarti P, Chaudhuri U. Acute abdomen due to splenic infarction as the initial presentation of pediatric acute lymphoblastic leukemia. [pmid: 23386231].
114 Newman J, Arhi C. Negative laparoscopic appendicectomy: the value of diagnostic laparoscopy. [pmid: 24521810].
115 Nguyen H, Le K, Le C, et al. Concurrent ruptured ectopic pregnancy and appendicitis. The Journal of the American Board of Family Practice/American Board of Family Practice. Jan–Feb. 2005;18(1):63-6. [pmid: 15709066].
116 Nur E, Arntzenius AB, Bokani N, et al. Acute abdomen and liver enzyme abnormalities. The Netherlands journal of medicine. Jun. 2010;68(6):268-71. [pmid: 20558858].
117 Oakenful C, Lambrianides AL, Brown J. Subhepatic appendicitis. The American surgeon. Nov. 2011;77(11):E258-9. [pmid: 22196645].
118 Ocana S, Arredondo J, Martinez P, et al. Value of laparoscopy in the treatment of cecal perforation by a foreign body; differential diagnosis of appendicitis. Revista espanola de enfermedades digestivas : organo oficial de la Sociedad Espanola de Patologia Digestiva. Apr. 2013;105(4):241-3. [pmid: 23859460].
119 Oerskov LH, Jansen T, Mynster T. Left-sided tubular colonic duplication presenting as an acute abdomen with compartment syndrome. The American surgeon. Dec. 2012;78(12):E525-6. [pmid: 23265109].
120 Otto R. Radiological diagnosis of abdominal disease. Journal belge de radiologie. 1987;70(6):562-3. [pmid: 3329193].
121 Packer JM. RADIOLOGIC SEMINAR XXII: APPENDICEAL CALCULI. Journal of the Mississippi State Medical Association. Feb. 1964;5(2):52-3. [pmid: 14123913].
122 Pai K. Granulomatous appendicitis in children: a single institutional experience. [pmid: 24647289].
123 Panda N, Bansal NK, Narasimhan M, Ardhanari R. Laparoscopic correction of intestinal malrotation in adult. [pmid: 24761085].
124 Parr G, Leyland N. The hockey stick sign in appendiceal endometriosis. Journal of obstetrics and gynaecology Canada : JOGC. Journal d’obstetrique et gynecologie du Canada : JOGC. May. 2010;32(5):421. 2. [pmid: 20500946].
125 Patel RP, Kan JH. Stump appendicitis. Pediatric radiology. Mar. 2009;39(3):306. [pmid: 19002452].
126 Patel RV, Brown LM, More B, Stewart R. Neonatal-perforated appendix forming antibioma masquerading as duodenal duplication. [pmid: 23897387].
127 Patterson EJ, Buckley AR. Ultrasound diagnosis of acute appendicitis. Canadian journal of surgery Journal canadien de chirurgie. Aug. 1997;40(4):251-2. [pmid: 9267290].
128 Pauker SG, Kopelman RI. Clinical problem-solving. A masked marauder. The New England journal of medicine. Jun. 2. 1994;330(22):1596-8. [pmid: 8177250].
129 Paul SP, Paulie N, Hawes D. Appendicitis presenting as gastroenteritis: the importance of making a correct diagnosis. Nursing times. Aug. 3–9. 2010;106(30):20. [pmid: 20836477].
130 Petersen RW. An unusual roentgen sign in--gangrenous appendicitis. California medicine. Oct. 1965;103(4):285-6. [pmid: 5828178].
131 Pfefferkorn MD. Appendiceal orifice inflammation and ulcerative proctitis. Clinical gastroenterology and hepatology : the official clinical practice journal of the American Gastroenterological Association. Aug. 2008;6(8):e31-2. [pmid: 18674731].
132 Powers AM. The expected and unexpected: incidental discovery of an ovarian mass with acute appendicitis. [pmid: 23975051].
133 Rajendran N, Ameen S, Rohatgi A. Laparoscopic management of a torted appendix. Annals of the Royal College of Surgeons of England. Oct. 2006;88(6):W6-7. [pmid: 17059706].
134 Rao PM, Sagarin MJ, McCabe CJ. Stump appendicitis diagnosed preoperatively by computed tomography. The American journal of emergency medicine. May. 1998;16(3):309-11. [pmid: 9596441].
135 Tong K, Merchant R. Nonacute Acute Abdomen in Older Adults. [pmid: 22332680].
136 Rhoades T, Lohr J, Jennings M. Symptoms of acute appendicitis caused by primary neuroma of the appendix. The American surgeon. Aug. 2007;73(8):841. [pmid: 17879700].
137 Richardson CG, DeMuro JP. Primary repair of cecal perforation from acute appendicitis: an operative dilemma. The American surgeon. Dec. 2012;78(12):E508-9. [pmid: 23265102].
138 Roic G, Bahtijarevic Z, Cvitkovic A. Acute appendicitis perforated into the bladder. Pediatric radiology. Feb. 2003;33(2):147. [pmid: 12645539].
139 Rosing MA, Amory S. Perforated ileal diverticulitis. An atypical presentation with definitive diagnosis by laparoscopy. Surgical endoscopy. May. 1995;9(5):522-4. [pmid: 7676377].
140 Rutten MJ, Jager GJ. Epiploic appendicitis: ultrasound and CT characteristics. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Mar. 1996;164(3):264-5. [pmid: 8672785].
141 Sadiq A, Hershman M, Luke D, Durrans D, Wells D. Abdominal pain. BMJ (Online). 2011;343(7827). PMID:.
142 Saleem A, Ganey M, Maxwell D, et al. Chain appendicitis. The American surgeon. Sep. 2012;78(9):E432-4. [pmid: 22964190].
143 Salih AK, Insall RL. Retained gall-stone as a differential diagnosis of acute appendicitis. Hospital medicine (London, England : 1998). Oct. 2000;61(10):742. [pmid: 11103292].
144 Schwartz JH, Manco LG. Left-sided appendicitis. Journal of the American College of Surgeons. Mar. 2008;206(3):590. [pmid: 18308231].
145 Schwimer SR, Joseph BJ, Lebovic J. Unusual presentation of a mucocele of the appendix. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Feb. 1987;6(2):85-7. [pmid: 2435924].
146 Scott KJ, Sacks AJ, Goldschmidt RP. Subhepatic appendicitis. The American journal of gastroenterology. Oct. 1993;88(10):1773-4. [pmid: 8213723].
147 Serra I. Appendicitis caused by an intrauterine contraceptive device. The British journal of surgery. Nov. 1986;73(11):927-8. [pmid: 3790929].
148 Sherer DM, Abramowicz JS, Allen T, et al. Transient perinephric accumulation of fluid associated with acute appendicitis in pregnancy. Journal of clinical ultrasound : JCU. Jun. 1992;20(5):356-9. [pmid: 1316381].
149 Shuster J. Interferon beta-induced panniculitis mimicking acute appendicitis; Acute methotrexate neurotoxicity with associated choreiform movements; Chorea associated with gabapentin use; Acute interstitial nephritis associated with linezolid; Atypical neuroleptic malignant syndrome with quetiapine; Hypersensitivity reactions to generic drugs with soybean oil. Hospital Pharmacy. 2009;44(12):1066-71. PMID:.
150 Sinha S, Salter MC. Atypical acute appendicitis. Emergency medicine journal : EMJ. Dec. 2009;26(12):856. [pmid: 19934126].
151 Siu WT, Tang CN, Law BK, et al. Spontaneous rectus sheath hematoma. Canadian journal of surgery Journal canadien de chirurgie. Oct. 2003;46(5):390. [pmid: 14577716].
152 Snyder BK, Hayden SR. Accuracy of leukocyte count in the diagnosis of acute appendicitis. Annals of emergency medicine. May. 1999;33(5):565-74. [pmid: 10216334].
153 Soliman MO, Ayyash EH, Al Mosawi AA, Asfar S. Right iliac fossa pain. [pmid: 24089296].
154 Song YS, Covarrubias DA, Nardi PM. Foreign body appendicitis. AJR American journal of roentgenology. Aug. 2009;193(2):W154-5. [pmid: 19620419].
155 Spalluto LB, Grand DJ. MRI of acute appendicitis in the pregnant patient. Medicine and health, Rhode Island. Feb. 2012;95(2):39-40. [pmid: 22474870].
156 Kollia P, Kounoudes C, Veloudis G, Giannakou N, Gourgiotis S. True ectopic ovary in the right iliac fossa mimicking acute appendicitis and associated with ipsilateral renal agenesis. [pmid: 24320118].
157 Steinkeler JA, Woodfield CA. MR imaging of acute appendicitis in pregnancy. Medicine and health, Rhode Island. Jun. 2008;91(6):196. [pmid: 18610808].
158 Stone MB, Chao J. Emergency ultrasound diagnosis of acute appendicitis. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Jan. 2010;17(1):E5. [pmid: 19891673].
159 Stuber JL, Leonidas JC, Holder TM. Abdominal ultrasonography in pediatrics. American journal of diseases of children (1960). Sep. 1975;129(9):1096-101. [pmid: 171943].
160 Swischuk LE. Abdominal pain and anorexia. Pediatric emergency care. Feb. 1992;8(1):45-6. [pmid: 1603691].
161 Swischuk LE. Acute abdomen with right lower quadrant pain. Pediatric emergency care. Aug. 1992;8(4):241-2. [pmid: 1513740].
162 Swischuk LE. Acute abdomen: suspected appendicitis: computed tomography: surprise. Pediatric emergency care. Jul. 2010;26(7):536-7. [pmid: 20622638].
163 Swischuk LE. Fever, chest radiograph, then reevaluation. Pediatric emergency care. May. 2010;26(5):394-5. [pmid: 20453799].
164 Swischuk LE. I woke up, “my whole stomach hurts”. Pediatric emergency care. Oct. 2004;20(10):687-9. [pmid: 15454746].
165 Swischuk LE. Periumbilical pain and fever. Pediatric emergency care. Apr. 1998;14(2):159-60. [pmid: 9583403].
166 Taheri MS, Haghighatkhah HR, Birang S, et al. Spiral CT findings in complicated appendicitis: Pictorial essay. Iranian Journal of Radiology. 2009;6(1):1-6. PMID:.
167 Takada T, Yasuda H, Uchiyama K, et al. Ultrasonic diagnosis of acute appendicitis complicated by paralytic ileus and generalized peritonitis. Journal of clinical ultrasound : JCU. Feb. 1988;16(2):123-6. [pmid: 3130404].
168 Talluri J, Besur S, Talluri SK. Abdominal pain and milky white serum. [pmid: 22753667].
169 Tammelleo AD. Failure to diagnose & treat acute abdomen. Regan Report on Nursing Law. 1998;39(7):2. Language: English. Entry Date: 19990301. Revision Date: 20091218. Publication Type: journal article. [pmid: 10067612].
170 Thorpe JA. The plain abdominal radiograph in acute appendicitis. Annals of the Royal College of Surgeons of England. Jan. 1979;61(1):45-7. [pmid: 420493].
171 Thorpe Marin, Jennifer R. Identification of unanticipated pelvic pathology on renal bedside ultrasound. [pmid: 23558277].
172 Tirumani H, Tirumani SH. Distal intestinal obstruction syndrome: a mimic of acute appendicitis. [pmid: 23345312].
173 Toprak H, Bilgin M, Atay M, et al. Diagnosis of Appendicitis in Patients with Abnormal Position of the Appendix due to Mobile Caecum. Case reports in surgery. 2012;2012:921382. [pmid: 23227414].
174 Torbati SS, Chan TC. Classic helical CT scan findings of acute appendicitis. The Journal of emergency medicine. Jan. 2000;18(1):101. [pmid: 10645847].
175 Townsend RR, Jeffrey RB Jr, Laing FC. Cecal diverticulitis differentiated from appendicitis using graded-compression sonography. AJR American journal of roentgenology. Jun. 1989;152(6):1229-30. [pmid: 2655389].
176 Ungprasert P, Leeaphorn N, Cheungpasitporn W. A catastrophic acute abdomen. [pmid: 24269564].
177 Unsal E, Uguz A, Cevik N. An acute vasculitis resembling polyarteritis nodosa. The Turkish journal of pediatrics. Apr–Jun. 1998;40(2):261-5. [pmid: 9677733].
178 Van Hoe L, Baert AL, Marchal G, et al. Thrombosed ovarian vein collateral mimicking acute appendicitis on CT. Journal of computer assisted tomography. Jul–Aug. 1994;18(4):643-6. [pmid: 8040454].
179 Wang, Basnet Samjhana, Du Xiao Qin, Shou Song Tao. Acute appendicitis presenting as acute diarrhea accompanying hypokalemia. [pmid: 24332249].
180 Williams R, Mackway-Jones K. Towards evidence based emergency medicine: best BETs from the Manchester Royal Infirmary. Abdominal ultrasound in the diagnosis of childhood appendicitis. Emergency medicine journal : EMJ. May. 2001;18(3):211-2. [pmid: 11354218].
181 Wright TE, Diaco JF. Recurrent appendicitis after laparoscopic appendectomy. International surgery. Jul–Sep. 1994;79(3):251-2. [pmid: 7883507].
182 Yagnik VD. Amyand hernia with appendicitis. [pmid: 24765286].
183 Yan J, Sabbagh R, Adu A, et al. MRI of early appendicitis during pregnancy. BMJ case reports. 2012;2012. [pmid: 23076695].
184 Yan SL, Liu YT, Chou DA. Appendicitis with a palpable mass. Endoscopy. Feb. Suppl 1. 2007;39:E20. [pmid: 17285483].
185 Yucel AF, Pergel A, Aydin I, Sahin DA. An unexpected complication of acute appendicitis: Internal herniation. [pmid: 21752738].
186 Zajdowicz TR. Amebic liver abscess: the unconsidered and undiagnosed mimic. Military medicine. Sep. 1986;151(9):481-4. [pmid: 3095703].
187 Zhou WX, Abeysinghe JD, Chua TC. Mimicry of appendicitis. [pmid: 23465216].
188 Zimmer V, Juengling B, Lammert F. Colonoscopy in acute appendicitis. Internal medicine (Tokyo, Japan). 2010;49(20):2273. [pmid: 20962450].

## B-5. Rejection Reason: Case-Control Study Design

1 Albayrak Y, Albayrak A, Albayrak F, et al. Mean platelet volume: a new predictor in confirming acute appendicitis diagnosis. Clinical and applied thrombosis/hemostasis : official journal of the International Academy of Clinical and Applied Thrombosis/Hemostasis. Aug. 2011;17(4):362-6. [pmid: 20460349].
2 Albayrak Y, Albayrak A, Celik M, et al. High mobility group box protein-1 (HMGB-1) as a new diagnostic marker in patients with acute appendicitis. Scandinavian journal of trauma, resuscitation and emergency medicine. 2011;19:27. [pmid: 21507210].
3 Al-Brahim N, Al-Kandari I, Munahai M, Sharma P. Clinicopathological study of 25 cases of diverticular disease of the appendix: experience from farwaniya hospital. [pmid: 24224113].
4 Bilici S, Sekmenli T, Goksu M, et al. Mean platelet volume in diagnosis of acute appendicitis in children. African health sciences. Sep. 2011;11(3):427-32. [pmid: 22275934].
5 Bolandparvaz S, Vasei M, Owji AA, et al. Urinary 5-hydroxy indole acetic acid as a test for early diagnosis of acute appendicitis. Clinical biochemistry. Nov. 2004;37(11):985-9. [pmid: 15498526].
6 Cabarrus M, Sun YL, Courtier JL, et al. The prevalence and patterns of intraluminal air in acute appendicitis at CT. Emergency radiology. Jan. 2013;20(1):51-6. [pmid: 22996072].
7 Caglayan F, Cakmak M, Caglayan O, et al. Plasma D-lactate levels in diagnosis of appendicitis. Journal of investigative surgery : the official journal of the Academy of Surgical Research. Jul–Aug. 2003;16(4):233-7. [pmid: 12893500].
8 Chandel V, Batt SH, Bhat MY, et al. Procalcitonin as the biomarker of inflammation in diagnosis of appendicitis in pediatric patients and prevention of unnecessary appendectomies. The Indian journal of surgery. Apr. 2011;73(2):136-41. [pmid: 22468064].
9 Constantinides C, Tryfonas G, Pappis C. Acute appendicitis in infancy and childhood: the leukocytic picture. Panminerva medica. Apr–Jun. 1978;20(2):133-40. [pmid: 704134].
10 Demircan M, Cetin S, Uguralp S, et al. Plasma D-lactic acid level: a useful marker to distinguish perforated from acute simple appendicitis. Asian journal of surgery/Asian Surgical Association. Oct. 2004;27(4):303-5. [pmid: 15564184].
11 Doraiswamy NV. The neutrophil count in childhood acute appendicitis. The British journal of surgery. May. 1977;64(5):342-4. [pmid: 861473].
12 Drescher MJ, Marcotte S, Grant R, et al. Family history is a predictor for appendicitis in adults in the emergency department. The western journal of emergency medicine. Dec. 2012;13(6):468-71. [pmid: 23359540].
13 Durup-Dickenson M, Christensen MK, Gade J. Abdominal auscultation does not provide clear clinical diagnoses. Danish medical journal. May. 2013;60(5):A4620. [pmid: 23673260].
14 Eshed I, Halshtok O, Erlich Z, et al. Differentiation between right tubo-ovarian abscess and appendicitis using CT--a diagnostic challenge. Clinical radiology. Nov. 2011;66(11):1030-5. [pmid: 21718977].
15 Fagerstrom A, Miettinen P, Valtola J, Juvonen P, Tarvainen R, Ilves I, Paajanen H. Long-term outcome of patients with acute non-specific abdominal pain compared to acute appendicitis: prospective symptom audit after two decades. [pmid: 24720138].
16 Friedland JA, Siegel MJ. CT appearance of acute appendicitis in childhood. AJR American journal of roentgenology. Feb. 1997;168(2):439-42. [pmid: 9016223].
17 Gade J, Kruse P, Andersen OT, et al. Physicians’ abdominal auscultation. A multi-rater agreement study. Scandinavian journal of gastroenterology. Jul. 1998;33(7):773-7. [pmid: 9712245].
18 Graham AD, Johnson HF. The incidence of radiographic findings in acute appendicitis compared to 200 normal abdomens. Military medicine. Mar. 1966;131(3):272-6. [pmid: 4955756].
19 Grebeldinger, Radojcic B, Meljnikov I, Mocko-Kacanski M. Neurogenic appendicopathy in pediatric patients: A clinical and histopathological entity. PMID:.
20 Gronroos JM, Gronroos P. Leucocyte count and C-reactive protein in the diagnosis of acute appendicitis. The British journal of surgery. Apr. 1999;86(4):501-4. [pmid: 10215824].
21 Gronroos JM. Do normal leucocyte count and C-reactive protein value exclude acute appendicitis in children?. Acta paediatrica (Oslo, Norway : 1992). Jun. 2001;90(6):649-51. [pmid: 11440098].
22 Hachim MY, Ahmed AH. The role of the cytokines and cell-adhesion molecules on the immunopathology of acute appendicitis. Saudi medical journal. Dec. 2006;27(12):1815-21. [pmid: 17143355].
23 Harlak A, Gulec M, Mentes O, et al. Atopy is a risk factor for acute appendicitis? A prospective clinical study. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Jul. 2008;12(7):1251-6. [pmid: 18350341].
24 Hobson MJ, Carney DE, Molik KA, et al. Appendicitis in childhood hematologic malignancies: analysis and comparison with typhilitis. Journal of pediatric surgery. Jan. 2005;40(1):214-9. discussion 9–20. [pmid: 15871157].
25 Hoffmann J, Kurgan A, Abramowitz HB. Rectal temperature in the diagnosis of acute lower abdominal pain. Israel journal of medical sciences. Jun. 1983;19(6):505-7. [pmid: 6862854].
26 Hsiao KH, Lin LH, Chen DF. Application of the MANTRELS scoring system in the diagnosis of acute appendicitis in children. Acta paediatrica Taiwanica = Taiwan er ke yi xue hui za zhi. May–Jun. 2005;46(3):128-31. [pmid: 16231558].
27 Ilkhanizadeh B, Owji AA, Tavangar SM, et al. Spot urine 5-hydroxy indole acetic acid and acute appendicitis. Hepato-gastroenterology. May–Jun. 2001;48(39):609-13. [pmid: 11462886].
28 Iosub S, Naik M, Bhalani K, et al. Leukocyte and neutrophil counts in healthy Puerto Rican children and children with acute appendicitis. Clinical pediatrics. Jul. 1986;25(7):366-8. [pmid: 3709022].
29 Jacobs DO, Settle RG, Clarke JR, et al. Identification of human appendicitis by in vitro nuclear magnetic resonance. The Journal of surgical research. Feb. 1990;48(2):107-10. [pmid: 2304337].
30 Jhobta RS, Attri AK, Kaushik R, et al. Spectrum of perforation peritonitis in India--review of 504 consecutive cases. World journal of emergency surgery : WJES. 2006;1:26. [pmid: 16953884].
31 Kalra U, Chitkara N, Dadoo RC, et al. Evaluation of plasma serotonin concentration in acute appendicitis. Indian journal of gastroenterology : official journal of the Indian Society of Gastroenterology. Jan. 1997;16(1):18-9. [pmid: 9167375].
32 Kamer E, Unalp HR, Derici H, Tansug T, Onal MA. Early diagnosis and prediction of severity in acute pancreatitis using the urine trypsinogen-2 dipstick test: a prospective study. World journal of gastroenterology : WJG [serial on the Internet]. 2007;(46). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/808/CN-00700808/frame.html. Last accessed.
33 Konan A, Hayran M, Kilic YA, et al. Scoring systems in the diagnosis of acute appendicitis in the elderly. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Sep. 2011;17(5):396-400. [pmid: 22090323].
34 Kuhlman JE, Fishman EK. Acute abdomen in AIDS: CT diagnosis and triage. Radiographics : a review publication of the Radiological Society of North America, Inc. Jul. 1990;10(4):621-34. [pmid: 2198633].
35 Lee KH, Lee HS, Park SH, et al. Appendiceal diverticulitis: diagnosis and differentiation from usual acute appendicitis using computed tomography. Journal of computer assisted tomography. Sep–Oct. 2007;31(5):763-9. [pmid: 17895789].
36 Lee WS, Kim TY. Is mean platelet volume a new predictor in confirming a diagnosis of acute appendicitis?. Clinical and applied thrombosis/hemostasis : official journal of the International Academy of Clinical and Applied Thrombosis/Hemostasis. Nov–Dec. 2011;17(6):E125-6. [pmid: 21159703].
37 Leeuwenburgh M, Wiarda B, Wiezer M, Vrouenraets B, Gratama J, Spilt A, Richir M, Bossuyt P, Stoker J, Boermeester M. Can MRI replace CT in adults with suspected appendicitis?. Surgical infections. 2012;13(3):A3. PMID:.
38 Lien WC, Huang SP, Chi CL, et al. Appendiceal outer diameter as an indicator for differentiating appendiceal mucocele from appendicitis. The American journal of emergency medicine. Nov. 2006;24(7):801-5. [pmid: 17098100].
39 Lim HK, Lee WJ, Kim TH, et al. Appendicitis: usefulness of color Doppler US. Radiology. Oct. 1996;201(1):221-5. [pmid: 8816547].
40 Matsuno WC, Anaya R, Tay ET, et al. Computed tomographic scan diagnosis of appendicitis in children by pediatric and adult radiologists. Pediatric emergency care. Mar. 2012;28(3):265-7. [pmid: 22344218].
41 Megibow AJ, Rusinek H, Lisi V, et al. Computed tomography diagnosis utilizing compressed image data: an ROC analysis using acute appendicitis as a model. Journal of digital imaging. Jun. 2002;15(2):84-90. [pmid: 12297974].
42 Meljnikov I, Grebeldinger S, Radojcic B, Cigic T. Evaluation of Neurogenic appendicopathy in negative appendectomy in pediatric patients. HealthMED. 2012;6(2):428-37. PMID:.
43 Miki T, Ogata S, Uto M, et al. Enhanced multidetector-row computed tomography (MDCT) in the diagnosis of acute appendicitis and its severity. Radiation medicine. Jun. 2005;23(4):242-55. [pmid: 16012400].
44 Morishita K, Gushimiyagi M, Hashiguchi M, et al. Clinical prediction rule to distinguish pelvic inflammatory disease from acute appendicitis in women of childbearing age. The American journal of emergency medicine. Feb. 2007;25(2):152-7. [pmid: 17276803].
45 Muenzer JT, Jaffe DM, Schwulst SJ, et al. Evidence for a novel blood RNA diagnostic for pediatric appendicitis: the riboleukogram. Pediatric emergency care. May. 2010;26(5):333-8. [pmid: 20404783].
46 Naeger DM, Chang SD, Kolli P, et al. Neutral vs positive oral contrast in diagnosing acute appendicitis with contrast-enhanced CT: sensitivity, specificity, reader confidence and interpretation time. The British journal of radiology. May. 2011;84(1001):418-26. [pmid: 20959365].
47 Narci H, Turk E, Karagulle E, Togan T, Karabulut K. The role of mean platelet volume in the diagnosis of acute appendicitis: a retrospective case-controlled study. [pmid: 24693387].
48 Narci H, Turk E, Karagulle E, Togan T, Karabulut K. The role of red cell distribution width in the diagnosis of acute appendicitis: a retrospective case-controlled study. [pmid: 24216220].
49 Nitta N, Takahashi M, Furukawa A, et al. MR imaging of the normal appendix and acute appendicitis. Journal of magnetic resonance imaging : JMRI. Feb. 2005;21(2):156-65. [pmid: 15666398].
50 Oruc MT, Kulah B, Ozozan O, et al. The value of 5-hydroxy indole acetic acid measurement in spot urine in diagnosis of acute appendicitis. East African medical journal. Jan. 2004;81(1):40-1. [pmid: 15080514].
51 Paajanen H, Tainio H, Laato M. A chance of misdiagnosis between acute appendicitis and renal colic. Scandinavian journal of urology and nephrology. Oct. 1996;30(5):363-6. [pmid: 8936624].
52 Patriquin HB, Garcier JM, Lafortune M, et al. Appendicitis in children and young adults: Doppler sonographic-pathologic correlation. AJR American journal of roentgenology. Mar. 1996;166(3):629-33. [pmid: 8623640].
53 Petroianu A, Alberti LR, Zac RI. Fecal loading in the cecum as a new radiological sign of acute appendicitis. World journal of gastroenterology : WJG. Jul. 21. 2005;11(27):4230-2. [pmid: 16015695].
54 Petroianu A, Alberti LR. Importance of the new radiographic sign of fecal loading in the cecum in the presence of acute appendicitis in comparison with other inflammatory diseases of the right abdomen. European journal of internal medicine. Jan. 2008;19(1):22-6. [pmid: 18206597].
55 Pickhardt PJ, Suhonen J, Lawrence EM, et al. Appendiceal length as an independent risk factor for acute appendicitis. European radiology. Dec. 2013;23(12):3311-7. [pmid: 23821021].
56 Rao PM, Rhea JT, Novelline RA. Appendiceal and peri-appendiceal air at CT: prevalence, appearance and clinical significance. Clinical radiology. Oct. 1997;52(10):750-4. [pmid: 9366533].
57 Rao PM. Presence or absence of gas in the appendix: additional criteria to rule out or confirm acute appendicitis-evaluation with US. Radiology. Nov. 2000;217(2):599-600. [pmid: 11058669].
58 Ruber M, Berg A, Ekerfelt C, et al. Different cytokine profiles in patients with a history of gangrenous or phlegmonous appendicitis. Clinical and experimental immunology. Jan. 2006;143(1):117-24. [pmid: 16367942].
59 Rusnak RA, Borer JM, Fastow JS. Misdiagnosis of acute appendicitis: common features discovered in cases after litigation. The American journal of emergency medicine. Jul. 1994;12(4):397-402. [pmid: 8031420].
60 Sasso RD, Hanna EA, Moore DL. Leukocytic and neutrophilic counts in acute appendicitis. American journal of surgery. Nov. 1970;120(5):563-6. [pmid: 5489703].
61 Sivit CJ. Significance of peritoneal fluid identified by ultrasonographic examination in children with acute abdominal pain. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Dec. 1993;12(12):743-6. [pmid: 8301714].
62 Sohn TJ, Chang YS, Kang JH, et al. Clinical characteristics of acute appendiceal diverticulitis. Journal of the Korean Surgical Society. Jan. 2013;84(1):33-7. [pmid: 23323233].
63 Stabile Ianora AA, Moschetta M, Lorusso V, et al. Atypical appendicitis: diagnostic value of volume-rendered reconstructions obtained with 16-slice multidetector-row CT. La Radiologia medica. Feb. 2010;115(1):93-104. [pmid: 19774442].
64 Stawowy M, Rossel P, Bluhme C, et al. Somatosensory changes in the referred pain area following acute inflammation of the appendix. European journal of gastroenterology & hepatology. Oct. 2002;14(10):1079-84. [pmid: 12362098].
65 Taha AS, Grant V, Kelly RW. Urinalysis for interleukin-8 in the non-invasive diagnosis of acute and chronic inflammatory diseases. Postgraduate medical journal. Mar. 2003;79(929):159-63. [pmid: 12697917].
66 Tanrikulu CS, Tanrikulu Y, Sabuncuoglu MZ, Karamercan MA, Akkapulu N, Coskun F. Mean platelet volume and red cell distribution width as a diagnostic marker in acute appendicitis.
67 Teicher I, Landa B, Cohen M, et al. Scoring system to aid in diagnoses of appendicitis. Annals of surgery. Dec. 1983;198(6):753-9. [pmid: 6639177].
68 Thuijls G, Derikx JP, Prakken FJ, et al. A pilot study on potential new plasma markers for diagnosis of acute appendicitis. The American journal of emergency medicine. Mar. 2011;29(3):256-60. [pmid: 20825793].
69 Uyanik B, Kavalci C, Arslan ED, et al. Role of mean platelet volume in diagnosis of childhood acute appendicitis. Emergency medicine international. 2012;2012:823095. [pmid: 22970376].
70 Wattanasirichaigoon S. Leukocytic count in the diagnosis of acute appendicitis. Journal of the Medical Association of Thailand. Chotmaihet thangphaet. Feb. 1994;77(2):87-91. [pmid: 7798841].
71 Webster DP, Schneider CN, Cheche S, et al. Differentiating acute appendicitis from pelvic inflammatory disease in women of childbearing age. The American journal of emergency medicine. Nov. 1993;11(6):569-72. [pmid: 8240553].
72 Wu HC, Yan MT, Lu KC, et al. Clinical manifestations of acute appendicitis in hemodialysis patients. Surgery today. Sep. 2013;43(9):977-83. [pmid: 23052740].
73 Yabunaka K, Katsuda T, Sanada S, et al. Sonographic examination of the appendix in acute infectious enteritis and acute appendicitis. Journal of clinical ultrasound : JCU. Feb. 2008;36(2):63-6. [pmid: 17661385].
74 Yaghmai V, Brandwein WM, Hammond N, et al. MDCT diagnosis of appendicitis using only coronal reformations. Emergency radiology. Jul. 2007;14(3):167-72. [pmid: 17457625].
75 Yamana I, Kawamoto S, Inada K, et al. Clinical characteristics of 12 cases of appendiceal diverticulitis: a comparison with 378 cases of acute appendicitis. Surgery today. Apr. 2012;42(4):363-7. [pmid: 22358430].
76 Yang YL, Huang YH, Tiao MM, et al. Comparison of clinical characteristics and neutrophil values in omental infarction and acute appendicitis in children. Pediatrics and neonatology. Jun. 2010;51(3):155-9. [pmid: 20675239].
77 Yilmaz FM, Yilmaz G, Erol MF, et al. Nitric oxide, lipid peroxidation and total thiol levels in acute appendicitis. Journal of clinical laboratory analysis. 2010;24(2):63-6. [pmid: 20333767].
78 Zakrzewska I, Gajda R. The activity of granulocyte alpha-amylase in acute appendicitis. Roczniki Akademii Medycznej w Bialymstoku (1995). 1994;39:81-5. [pmid: 7497089].

## B-6. Rejection Reason: Data Not Extractable

1 Abougabal AM, Afifi AH, Kasem MI. Role of multidetector computed tomography (MDCT) in diagnosis of subhepatic appendicitis. Egyptian Journal of Radiology and Nuclear Medicine. 2012;43(3):347-52. PMID:.
2 Abu-Eshy SA, Ibn Ouf MA, Malatani TS, et al. Acute appendicitis in females--a clinical study of 366 cases. African journal of medicine and medical sciences. Sep. 1995;24(3):227-30. [pmid: 8798956].
3 Adibe OO, Amin SR, Hansen EN, et al. An evidence-based clinical protocol for diagnosis of acute appendicitis decreased the use of computed tomography in children. Journal of pediatric surgery. Jan. 2011;46(1):192-6. [pmid: 21238665].
4 Adibe OO, Muensterer OJ, Georgeson KE, et al. Severity of appendicitis correlates with the pediatric appendicitis score. Pediatric surgery international. Jun. 2011;27(6):655-8. [pmid: 20936475].
5 Agresta F, Mazzarolo G, Ciardo LF, et al. The laparoscopic approach in abdominal emergencies: has the attitude changed? : A single-center review of a 15-year experience. Surgical endoscopy. May. 2008;22(5):1255-62. [pmid: 17943358].
6 Ahmed J. Presentation of acute appendicitis in children. Pakistan Journal of Medical and Health Sciences. 2010;4(4). PMID:.
7 Aljefri A, Al-Nakshabandi N. The stranded stone: relationship between acute appendicitis and appendicolith. Saudi journal of gastroenterology : official journal of the Saudi Gastroenterology Association. Oct–Dec. 2009;15(4):258-60. [pmid: 19794272].
8 Al-Mulhim AR, Al-Sultan AI. Modified Alvarado score for acute appendicitis in overweight patients. Saudi medical journal. Aug. 2008;29(8):1184-7. [pmid: 18690316].
9 Anderson SW, Rhea -JT, Milch HN, et al. Influence of body habitus and use of oral contrast on reader confidence in patients with suspected acute appendicitis using 64 MDCT. Emergency radiology. Nov. 2010;17(6):445-53. [pmid: 20496094].
10 Aspelund G, Fingeret A, Gross E, Kessler D, Keung C, Thirumoorthi A, Oh PS, Behr G, Chen S, Lampl B, Middlesworth W, Kandel J, Ruzal-Shapiro C. Ultrasonography/MRI versus CT for diagnosing appendicitis. [pmid: 24590746].
11 Attia MW. The Paediatric Appendicitis Score (PAS) was useful in children with acute abdominal pain. Evidence-based medicine. Feb. 2009;14(1):26. [pmid: 19181958].
12 Barker PA, Jutley RS, Youngson GG. Hospital re-admission in children with non-specific abdominal pain. Pediatric surgery international. Sep. 2002;18(5–6):341-3. [pmid: 12415351].
13 Berger-Achituv S, Zissin R, Shenkman Z, et al. Gastric emptying time of oral contrast material in children and adolescents undergoing abdominal computed tomography. Journal of pediatric gastroenterology and nutrition. Jul. 2010;51(1):31-4. [pmid: 20410846].
14 Broder JS, Hollingsworth CL, Miller CM, et al. Prospective double-blinded study of abdominal-pelvic computed tomography guided by the region of tenderness: estimation of detection of acute pathology and radiation exposure reduction. Annals of emergency medicine. Aug. 2010;56(2):126-34. [pmid: 20074835].
15 Bullapur HM, Deshpande AV, Phin SJ, Cohen RC. Adjunct ultrasonography in children with suspected acute appendicitis: identifying the optimal target group. [pmid: 24754725].
16 Butala P, Greenstein AJ, Sur MD, et al. Surgical management of acute right lower-quadrant pain in pregnancy: a prospective cohort study. Journal of the American College of Surgeons. Oct. 2010;211(4):490-4. [pmid: 20822740].
17 Butler M, Servaes S, Srinivasan A, et al. US depiction of the appendix: role of abdominal wall thickness and appendiceal location. Emergency radiology. Dec. 2011;18(6):525-31. [pmid: 21826465].
18 Cano Alonso R, Borruel Nacenta S, Diez Martinez P, et al. Role of multidetector CT in the management of acute female pelvic disease. Emergency radiology. Nov. 2009;16(6):453-72. [pmid: 19326153].
19 Cheong LH, Emil S. Outcomes of pediatric appendicitis: an international comparison of the United States and Canada. [pmid: 24257904].
20 Chiang DT, Tan EI, Birks D. ‘To have...or not to have’. Should computed tomography and ultrasonography be implemented as a routine work-up for patients with suspected acute appendicitis in a regional hospital?. Annals of the Royal College of Surgeons of England. Jan. 2008;90(1):17-21. [pmid: 18201492].
21 Chooi WK, Brown JA, Zetler P, et al. Imaging of acute appendicitis and its impact on negative appendectomy and perforation rates: the St. Paul’s experience. Canadian Association of Radiologists journal. Journal l’Association canadienne des radiologistes. Oct. 2007;58(4):220-4. [pmid: 18186433].
22 Collins GB, Tan TJ, Gifford J, Tan A. The accuracy of pre-appendectomy computed tomography with histopathological correlation: a clinical audit, case discussion and evaluation of the literature. [pmid: 24879063].
23 Deleger L, Brodzinski H, Zhai H, Li Q, Lingren T, Kirkendall ES, Alessandrini E, Solti I. Developing and evaluating an automated appendicitis risk stratification algorithm for pediatric patients in the emergency department. [pmid: 24130231].
24 Di Saverio S, Sibilio A, Giorgini E, Biscardi A, Villani S, Coccolini F, Smerieri N, Pisano M, Ansaloni L, Sartelli M, Catena F, Tugnoli G. The NOTA Study (Non Operative Treatment for Acute Appendicitis): prospective study on the efficacy and safety of antibiotics (amoxicillin and clavulanic acid) for treating patients with right lower quadrant abdominal pain and long-term follow-up of conservatively treated suspected appendicitis. [pmid: 24646528].
25 Eko FN, Ryb GE, Drager L, Goldwater E, Wu JJ, Counihan TC. Ideal timing of surgery for acute uncomplicated appendicitis. [pmid: 23378951].
26 El Kheshen AMM. Role of MSCT (multi-slice computed tomography) in acute abdomen using 64-slice technology. Egyptian Journal of Radiology and Nuclear Medicine. 2012;43(1):41-51. PMID:.
27 Eryigit V, Mahsanlar Y, Demirtas Y, Parlak I. The value of ultrasonography, leukocyte count and clinical results in diagnosis of acute appendicitis and the duration of stay of the patients in emergency department. Turkiye Acil Tip Dergisi. 2014;14(1):20-4. PMID:.
28 Finkelstone, Wolf E, Stein MW. Etiology of small bowel thickening on computed tomography. [pmid: 23248791].
29 Gibney EJ, Ajayi N, Leader M, et al. Emergency appendicectomy: a one year audit. Irish journal of medical science. Apr. 1992;161(4):101-4. [pmid: 1428756].
30 Giuliano V, Giuliano C, Pinto F, et al. Rapid CT scan visualization of the appendix and early acute non-perforated appendicitis using an improved oral contrast method. Emergency radiology. Apr. 2004;10(5):235-7. [pmid: 15290466].
31 Graff L, Radford MJ, Werne C. Probability of appendicitis before and after observation. Annals of emergency medicine. May. 1991;20(5):503-7. [pmid: 2024789].
32 Grim PF 3rd. Emergency medicine physicians’ and pediatricians’ use of computed tomography in the evaluation of pediatric patients with abdominal pain without trauma in a community hospital. [pmid: 24391124].
33 Juvonen P, Lehtimaki T, Eskelinen M, Ilves I, Vanninen R, Miettinen P, Paajanen H. The need for surgery in acute abdominal pain: a randomized study of abdominal computed tomography. [pmid: 25004681].
34 Hahn B, Dima J, Hirschorn D, et al. Incidence and pathology of repeat computed tomography of the abdomen and pelvis in a pediatric emergency department population. Pediatric emergency care. Jul. 2013;29(7):822-5. [pmid: 23823261].
35 Hatipoglu S, Hatipoglu F, Abdullayev R. Acute right lower abdominal pain in women of reproductive age: clinical clues. [pmid: 24744594].
36 Hopkins CL, Madsen T, Foy Z, et al. Does limiting oral contrast decrease emergency department length of stay?. The western journal of emergency medicine. Nov. 2012;13(5):383-7. [pmid: 23359477].
37 Hotic N, Hasukic S, Cickusic E, Rifatbegovic Z, Husaric E. Diagnostic value of serum inflammatory markers (leucocyte count, C-reactive protein and neutrophil count) for detection of acute appendicitis in children. Acta Medica Saliniana [serial on the Internet]. 2012;(1). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/279/CN-00917279/frame.html. Last accessed.
38 Im AL, Lee YH, Bang DH, et al. Dual energy CT in patients with acute abdomen; is it possible for virtual non-enhanced images to replace true non-enhanced images?. Emergency radiology. Dec. 2013;20(6):475-83. [pmid: 23821015].
39 Jo YH, Kim K, Rhee JE, et al. The accuracy of emergency medicine and surgical residents in the diagnosis of acute appendicitis. The American journal of emergency medicine. Sep. 2010;28(7):766-70. [pmid: 20837252].
40 Juvonen P, Lehtimaki T, Eskelinen M, Ilves I, Vanninen R, Miettinen P, Paajanen H. Differentiation of early perforated from nonperforated appendicitis: MDCT findings, MDCT diagnostic performance, and clinical outcome. [pmid: 24633221].
41 Kahn SA, Sleem R, Schiralli M, Stassen NA, Sangosanya A, Cheng JD, Gestring ML, Bankey PE. Assessment of surgical residents’ ability to predict appendicitis with computed tomography. [pmid: 24351363].
42 Khalid M, Redhu N, Nazir B, et al. Diagnostic value of ultrasonography in evaluation and management of acute abdominal conditions in the paediatric age group. African journal of paediatric surgery : AJPS. Sep–Dec. 2012;9(3):198-201. [pmid: 23250239].
43 Khalid R, Yousaf SA. Emergency based ultrasound of clinically suspected acute appendicitis with low frequency curvilinear transducer and its association with surgical outcome. PMID:.
44 Kirshtein B, Perry ZH, Mizrahi S, et al. Value of laparoscopic appendectomy in the elderly patient. World journal of surgery. May. 2009;33(5):918-22. [pmid: 19172345].
45 Koike Y, Uchida K, Matsushita K, Otake K, Nakazawa M, Inoue M, Kusunoki M, Tsukamoto Y. Intraluminal appendiceal fluid is a predictive factor for recurrent appendicitis after initial successful non-operative management of uncomplicated appendicitis in pediatric patients. [pmid: 24952800].
46 Korner H, Sondenaa K, Soreide JA, et al. Structured data collection improves the diagnosis of acute appendicitis. The British journal of surgery. Mar. 1998;85(3):341-4. [pmid: 9529488].
47 Lanitis, Korontzi M, Sgourakis G, Karkoulias K, Kontovounisios C, Karaliotas C. Laparoscopic versus open appendicectomy in Greek reality. [pmid: 23047396].
48 Lee SC, Kim KY, Yoon SN, Kim BC, Kim JW. Feasibility of gasless laparoscopy-assisted transumbilical appendectomy: early experience. [pmid: 24960173].
49 Lee SL, Ho HS. Acute appendicitis: is there a difference between children and adults?. The American surgeon. May. 2006;72(5):409-13. [pmid: 16719195].
50 Li Y, Guo A, Tang J, Wang L, Wang J, Yu D. Role of preoperative sonography in the diagnosis and pathologic staging of pseudomyxoma peritonei. [pmid: 23980216].
51 Linz DN, Hrabovsky EE, Franceschi D, et al. Does the current health care environment contribute to increased morbidity and mortality of acute appendicitis in children?. Journal of pediatric surgery. Mar. 1993;28(3):321-6. discussion 6–8. [pmid: 8468640].
52 MacKersie AB, Lane MJ, Gerhardt RT, et al. Nontraumatic acute abdominal pain: unenhanced helical CT compared with three-view acute abdominal series. Radiology. Oct. 2005;237(1):114-22. [pmid: 16183928].
53 Mathews EK, Griffin RL, Mortellaro V, Beierle EA, Harmon CM, Chen MK, Russell RT. Utility of immature granulocyte percentage in pediatric appendicitis. J Surg Res. Jul. 2014;190(1):230-4. [pmid: 24793450].
54 Mathis RD, Chiumento AB, Yeh B, et al. An outcome study of the use of computed tomography for the diagnosis of appendicitis in a community-based emergency department. Southern medical journal. Dec. 2005;98(12):1169-72. [pmid: 16440916].
55 Matz S, Connell M, Sinha M, Goettl CS, Patel PC, Drachman D. Clinical outcomes of pediatric patients with acute abdominal pain and incidental findings of free intraperitoneal fluid on diagnostic imaging. [pmid: 23980214].
56 McGrath FP, Keeling F. The role of early sonography in the management of the acute abdomen. Clinical radiology. Sep. 1991;44(3):172-4. [pmid: 1914392].
57 Menes TS, Aufses AH Jr, Rojas M, et al. Increased use of computed tomography does not harm patients with acute appendicitis. The American surgeon. Apr. 2006;72(4):326-9. [pmid: 16676857].
58 Mirza MR, Habib L. Negative appendicectomy rate in current surgical practice. JPMI - Journal of Postgraduate Medical Institute. 2009;23(3):241-4. PMID:.
59 Morse BC, Roettger RH, Kalbaugh CA, et al. Abdominal CT scanning in reproductive-age women with right lower quadrant abdominal pain: does its use reduce negative appendectomy rates and healthcare costs?. The American surgeon. Jun. 2007;73(6):580-4. discussion 4. [pmid: 17658095].
60 Multicentre observational study of performance variation in provision and outcome of emergency appendicectomy. [pmid: 23842836].
61 Nauta RJ, Magnant C. Observation versus operation for abdominal pain in the right lower quadrant. Roles of the clinical examination and the leukocyte count. American journal of surgery. Jun. 1986;151(6):746-8. [pmid: 3717506].
62 Nojkov B, Duffy MC, Cappell MS. Utility of repeated abdominal CT scans after prior negative CT scans in patients presenting to ER with nontraumatic abdominal pain. Digestive diseases and sciences. Apr. 2013;58(4):1074-83. [pmid: 23179149].
63 Ohmann C, Yang Q, Franke C. Diagnostic scores for acute appendicitis. Abdominal Pain Study Group. The European journal of surgery. Acta chirurgica. Apr. 1995;161(4):273-81. [pmid: 7612771].
64 Omari AH, Khammash MR, Qasaimeh GR, Shammari AK, Yaseen MK, Hammori SK. Acute appendicitis in the elderly: risk factors for perforation. [pmid: 24428909].
65 Pinheiro RN, Sousa RC, Castro FM, Almeida RO, de Gouveia GC, Oliveira VR. Single-incision videolaparoscopic appendectomy with conventional videolaparoscopy equipment. [pmid: 24676296].
66 Poonai N, Gregory J, Thompson G, Lim R, Van Osch S, Andrusiak T, Mekhaiel S, Sangha G, Seabrook J, Joubert G. Is pelvic ultrasound associated with an increased time to appendectomy in pediatric appendicitis?. [pmid: 24680102].
67 Priola AM, Priola SM, Volpicelli G, Giraudo MT, Martino V, Fava C, Veltri A. Accuracy of 64-row multidetector CT in the diagnosis of surgically treated acute abdomen. [pmid: 23764231].
68 Raptopoulos V, Katsou G, Rosen MP, et al. Acute appendicitis: effect of increased use of CT on selecting patients earlier. Radiology. Feb. 2003;226(2):521-6. [pmid: 12563149].
69 Riddell AM, Khalili K. Assessment of acute abdominal pain: utility of a second cross-sectional imaging examination. Radiology. Feb. 2006;238(2):570-7. [pmid: 16436818].
70 Rosen MP, Sands DZ, Longmaid HE 3rd, et al. Impact of abdominal CT on the management of patients presenting to the emergency department with acute abdominal pain. AJR American journal of roentgenology. May. 2000;174(5):1391-6. [pmid: 10789801].
71 Russo A, Cappabianca S, Iaselli F, Reginelli A, D’Andrea A, Mazzei G, Martiniello C, Grassi R, Rotondo A. Acute abdominal pain in childhood and adolescence: assessing the impact of sonography on diagnosis and treatment. [pmid: 24432175].
72 Saito JM, Yan Y, Evashwick TW, et al. Use and accuracy of diagnostic imaging by hospital type in pediatric appendicitis. Pediatrics. Jan. 2013;131(1):e37-44. [pmid: 23266930].
73 Sangrasi AK, Talpu KA, Kella N, Laghari AA, Rehman Abbasi M, Naeem Qureshi J. Role of laparoscopy in peritonitis. [pmid: 24353681].
74 Scheinfeld MH, Mahadevia S, Stein EG, et al. Can lab data be used to reduce abdominal computed tomography (CT) usage in young adults presenting to the emergency department with nontraumatic abdominal pain?. Emergency radiology. Sep. 2010;17(5):353-60. [pmid: 20306104].
75 Schisgall RM. Use of the barium swallow in the diagnosis of acute appendicitis. American journal of surgery. Nov. 1983;146(5):663-7. [pmid: 6638274].
76 Slusher J, Bates CA, Johnson C, Williams C, Dasgupta R, von Allmen D. Standardization and improvement of care for pediatric patients with perforated appendicitis. [pmid: 24888855].
77 Sreedharan S, Fiorentino M, Sinha S. Plain abdominal radiography in acute abdominal pain-is it really necessary?. [pmid: 24880255].
78 Sulowski C, Doria AS, Langer JC, et al. Clinical outcomes in obese and normal-weight children undergoing ultrasound for suspected appendicitis. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Feb. 2011;18(2):167-73. [pmid: 21314776].
79 Systermans BJ, Devitt PG. Computed tomography in acute abdominal pain: an overused investigation?. [pmid: 23937360].
80 Taylor GA, Callahan MJ, Rodriguez D, et al. CT for suspected appendicitis in children: an analysis of diagnostic errors. Pediatric radiology. Apr. 2006;36(4):331-7. [pmid: 16463152].
81 Tompane T, Leong CW, Bush R, Chuang NA, Dansky T, Huang JS. Appropriateness of radiology procedures performed in children with gastrointestinal symptoms and conditions. [pmid: 24035771].
82 van Randen A, Lameris W, Luitse JS, et al. The role of plain radiographs in patients with acute abdominal pain at the ED. The American journal of emergency medicine. Jul. 2011;29(6):582-9.e2. [pmid: 20825832].
83 Vargas HI, Tolmos J, Klein SR, et al. Laparoscopic appendectomy in the 1990’s. International surgery. Jul–Sep. 1994;79(3):242-6. [pmid: 7883505].
84 Velanovich V, Harkabus MA, Tapia FV, et al. When it’s not appendicitis. The American surgeon. Jan. 1998;64(1):7-11. [pmid: 9457030].
85 Wu HP, Fu YC. Application with repeated serum biomarkers in pediatric appendicitis in clinical surgery. Pediatric surgery international. Feb. 2010;26(2):161-6. [pmid: 20128109].
86 Yajima H, Fujita T, Yanaga K. Profile of signs and symptoms in mild and advanced acute appendicitis. International surgery. Jan–Mar. 2010;95(1):63-6. [pmid: 20480844].
87 Yakan S, Caliskan C, Uguz A, et al. A retrospective study on mucocele of the appendix presented with acute abdomen or acute appendicitis. Hong Kong Journal of Emergency Medicine. 2011;18(3):144-9. PMID:.
88 Yegane R, Peyvandi H, Hajinasrollah E, et al. Evaluation of the modified alvarado score in acute appendicitis among iranian patients. Acta Medica Iranica. 2008;46(6):501-6. PMID:.
89 York D, Smith A, Phillips JD, et al. The influence of advanced radiographic imaging on the treatment of pediatric appendicitis. Journal of pediatric surgery. Dec. 2005;40(12):1908-11. [pmid: 16338316].
90 Yuan S, Lian F, Chen D, Li H, Qiu Q, Zhan Z, Ye Y, Xu H, Liang L, Yang X. Clinical features and associated factors of abdominal pain in systemic lupus erythematosus. [pmid: 24187097].
91 Zampieri N, Corroppolo M, El Dalati G, et al. Correlation between high-resolution ultrasound and surgical/pathological findings in patients with suspected appendicitis. Minerva chirurgica. Dec. 2008;63(6):469-74. [pmid: 19078879].
92 Zoarets I, Poluksht N, Halevy A. Does selective use of computed tomography scan reduce the rate of ‘white’ (negative) appendectomy?. [pmid: 25058992].

## B-7. Rejection Reason: Duplicate Publication

1 Akhator A. Appendicitis in the elderly-experience from Nigeria. Biosciences Biotechnology Research Asia. 2012;9(2):717-9. PMID:.
2 Al-Brahim N, Al-Kandari I, Manahi M, editors. Diverticular disease of the appendix: a clinico-pathological study of 25 cases. HISTOPATHOLOGY. 2012. WILEY-BLACKWELL. 111 RIVER ST, HOBOKEN 07030-5774, NJ USA.
3 Aliyev ES. The diagnosis and tactics of surgical management of acute appendicitis in pregnant women. Azerbaijan Medical Journal. 2012;(1):109-13. PMID:.
4 Bowe C, Trydestam C, Gregory W, et al. 234 Computed Tomography Usage for Emergency Department Patients With Suspected Appendicitis Following Implementation of a Multidisciplinary Scoring System-Based Protocol. Annals of emergency medicine. 2012;60(4):S85. PMID:.
5 Chiricolo G, Laudenbach A, Mooney T, et al. The effect on CT utilization in patients who have undergone appendectomy after emergency ultrasound of the appendix was introduced to an emergency department. Academic Emergency Medicine. 2012;19:S206-S7. PMID:.
6 Chumpitazi CE, Bendure EO, Valdez K, et al. Mo1210 Evaluation and Treatment of Children With Abdominal Pain and Constipation in the Emergency Department. Gastroenterology. 2013;144(5):S-607. PMID:.
7 Daneshmandi S, Ghasemi A, Pourfathollah AA. IL-6-174G/C promoter polymorphism in acute appendicitis. Lab Medicine. 2009;40(10):600-3. PMID:.
8 Doiron R, Hartin C, Ozgediz D, et al. Who’s Guarding Whom? the Changing of the Guard: A Study of Pediatric Abdominal Examinations. Journal of Surgical Research. 2012;172(2):294. PMID:.
9 El Kheshen AM. Role of MSCT (multi-slice computed tomography) in acute abdomen using 64-slice technology. The Egyptian Journal of Radiology and Nuclear Medicine. 2012;43(1):41-51. PMID:.
10 Elikashvili I, Tay ET, Tsung JW. The Effect of Point-of-care Ultrasonography on Emergency Department Length of Stay and Computed Tomography Utilization in Children With Suspected Appendicitis. Academic Emergency Medicine. 2014;21(2):163-70. [pmid: 24673672].
11 Erkasap S, Ates E, Ustuner Z, et al. Diagnostic value of interleukin-6 and C-reactive protein in acute appendicitis. Swiss surgery. Schweizer Chirurgie = Chirurgie suisse =Chirurgia svizzera. 2000;6(4):169-72. [pmid: 10967943].
12 Ferlitsch A, Puspok A, Gasche C. 918 Detection of Appendix Pathology by a Novel Endoscopic Imaging Procedure. Gastrointestinal endoscopy. 2012;75(4):AB173.
13 Garel LA. Bowel sounds and music: Malrotation, intussusception, appendicitis, inflammatory bowel disease, imperforate anus. Pediatric radiology. 2012;42:S234.
14 Gill J, Lalli P, Wang D, et al. The Calgary multifaceted intervention for suspected appendicitis reduces ED length of stay and time to surgery. Canadian Journal of Emergency Medicine. 2013;15:S54.
15 Grebeldinger S, Radojcic B, Meljnikov I, et al. Neurogenic appendicopathy in pediatric patients: A clinical and histopathological entity. HealthMED. 2012;6(3):950-62.
16 Healy D, Aziz A, McCartan D, et al., editors. Increased use of laparoscopy reduces length of stay and the negative appendicectomy rate: A comparative analysis. Irish journal of medical science. 2012. SPRINGER LONDON LTD. 236 GRAYS INN RD, 6TH FLOOR, LONDON WC1X 8HL, ENGLAND.
17 Jeong Kim W, Kang K, Kim K, et al. Effect of pain control in suspected acute appendicitis on the diagnostic accuracy of surgical residents. Cjem. Feb. 1. 2014;16(2):1-8. [pmid: 24423989].
18 LeBedis CA, Penn DR, Broder JC, et al. Current applications of MRI in emergent gastrointestinal diseases. Applied Radiology. 2012;41(11):9. PMID:.
19 Leeuwenburgh MM, Wiarda BM, Wiezer MJ, et al. Comparison of imaging strategies with conditional contrast-enhanced CT and unenhanced MR imaging in patients suspected of having appendicitis: a multicenter diagnostic performance study. Radiology. 2013;268(1):135-43. PMID:. [pmid: 23481162].
20 McGowan D, Howlader M, Patel R, et al. Management and outcome of appendicitis among octogenarians in an English hospital over a five year period. International Journal of Surgery. 2011;9(8):669-71. PMID:. [pmid: 22057007].
21 Meljnikov I, Grebeldinger S, Radojcic B, et al. Evaluation of Neurogenic Appendicopathy in negative appendectomy in pediatric patients. HealthMed. 2012;6(2). PMID:.
22 Meltzer AC, Baumann BM, Chen EH, Shofer FS, Mills AM. Negative predictive value of a low modified alvarado score for adult ED patients with suspected appendicitis. Academic Emergency Medicin. ((Meltzer AC) George Washington University, Washington, United States). 2012;19:S194. PMID:.
23 Menoch M, Hirsh D, Baxter A, et al. Do abdominal CT utilization rates vary between academic and private practice pediatric emergency departments for suspected appendicitis?. Academic Emergency Medicine. 2012;19:S343. PMID:.
24 Min SB, Abbas MI, Carter M, et al. Mo1988 Thickened Gastrointestinal Wall Findings on Computed Tomography in Children: How Worried Should We Be?. Gastroenterology. 2012;142(5):S-714-S-5. PMID:.
25 Moon KT. CT imaging for appendicitis: Is less radiation just as good?. American family physician. 2012;86(10):964-6. PMID:.
26 Morrison I. Interpreting a radiograph of the abdomen. Surgery. 2008;26(6):250-4. PMID:.
27 Papandria D, Rhee D, Gorgy A, et al. Progression of Acute Appendicitis to Perforation: Examination of a Two-Variant Disease Model in 683,590 Patients. Journal of Surgical Research. 2012;172(2):281-2. PMID:.
28 Pérez EM, Castroagudín JF, Muñoz JED. Protocolo diagnóstico del paciente con fiebre y dolor en hipocondrio derecho. Medicine. 2012;11(8):510-3. PMID:.
29 Pontarelli E, Nosanov L, Ma I, et al. Appendicitis in children with cognitive deficits. Surgical infections. 2012;13:S26. PMID:.
30 Salama M, Zaidi A, Taha T, et al. Has laparoscopy reduced the rate of negative appendicectoy in our institute?. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S85. PMID:.
31 Schimpl G. Appendicitis. Diagnosis and therapy. Padiatrische Praxis. 2012;78(2):241-7. PMID:.
32 Shah NA, Islam M, Sabir IA, et al. DIAGNOSTIC ACCURACY OF CLINICAL EXAMINATION VERSUS COMBINATION OF ABDOMINAL ULTRASOUND AND ALVARADO SCORE, IN PATIENTS WITH ACUTE APPENDICITIS. Journal of Postgraduate Medical Institute (Peshawar-Pakistan). 2011;22(1). PMID:.
33 Shah NA, Islam M, Sabir IA, et al. DIAGNOSTIC ACCURACY OF CLINICAL EXAMINATION VERSUS COMBINATION OF ABDOMINAL ULTRASOUND AND ALVARADO SCORE, IN PATIENTS WITH ACUTE APPENDICITIS 2. Journal of Postgraduate Medical Institute (Peshawar-Pakistan). 2011;22(1). PMID:.
34 Sisson C, Ehler B, Minard J, et al. Determination of a body mass index upper limit in adults for the diagnosis of acute appendicitis using a high frequency linear ultrasound transducer. Academic Emergency Medicine. 2013;20(5):S251. PMID:.
35 Ukhanov AP, Zakharov DV, Ignatjev A, et al. Use of endovideosurgical method in the diagnostics and treatment of acute appendicitis and its complications. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S84. PMID:.
36 Van Dalen R, Bagshaw P, Dobbs B, et al. The utility of laparoscopy in the diagnosis of acute appendicitis in women of reproductive age. Surgical Endoscopy And Other Interventional Techniques. 2003;17(8):1311-3. PMID:. [pmid: 12739123].
37 Wu HP, Fu YC. Application with repeated serum biomarkers in pediatric appendicitis in clinical surgery. Pediatric surgery international. Feb. 2010;26(2):161-6. [pmid: 19921211].
38 Yu J, Chandran S, Testro A, editors. Overuse of computer tomography scanning in infectious gastroenteritis. Journal of gastroenterology and hepatology. 2012. WILEY-BLACKWELL. 111 RIVER ST, HOBOKEN 07030-5774, NJ USA.

## B-8. Rejection Reason: Index Test Confounded by Antibiotics

1 Winn RD, Laura S, Douglas C, et al. Protocol-based approach to suspected appendicitis, incorporating the Alvarado score and outpatient antibiotics. ANZ journal of surgery. May. 2004;74(5):324-9. [pmid: 15144250].

## B-9. Rejection Reason: Index Test Results Not Reported

2 Ahn S. LOCAT (low-dose computed tomography for appendicitis trial) comparing clinical outcomes following low- vs standard-dose computed tomography as the first-line imaging test in adolescents and young adults with suspected acute appendicitis: study protocol for a randomized controlled trial. [pmid: 24438500].
3 Andersson RE. Short-term complications and long-term morbidity of laparoscopic and open appendicectomy in a national cohort. [pmid: 24979720].
4 Anyanwu AC, Moalypour SM. Are abdominal radiographs still overutilized in the assessment of acute abdominal pain? A district general hospital audit. Journal of the Royal College of Surgeons of Edinburgh. Aug. 1998;43(4):267-70. [pmid: 9735654].
5 Arnbjornsson E. Bacteriuria in appendicitis. American journal of surgery. Feb. 1988;155(2):356-8. [pmid: 3341560].
6 Asefa Z. Pattern of acute abdomen in Yirgalem Hospital, southern Ethiopia. Ethiopian medical journal. Oct. 2000;38(4):227-35. [pmid: 11125497].
7 Baglaj M, Rysiakiewicz J, Rysiakiewicz K. Acute appendicitis in children under 3 years of age. Diagnostic and therapeutic problems. Medycyna wieku rozwojowego. Apr–Jun. 2012;16(2):154-61. [pmid: 22971661].
8 Barnett WO, Yelverton RL. INTESTINAL OBSTRUCTION RESULTING FROM LOCALIZED PERITONITIS. Journal of the Mississippi State Medical Association. Jun. 1964;5(6):217-21. [pmid: 14157706].
9 Beardsley CJ, Sandhu T, Gubicak S, Srikanth SV, Galketiya KP, Piscioneri F. A model-based evaluation of the Canberra Hospital Acute Care Surgical Unit : acute care surgery: a case of one size fits all?. [pmid: 24178132].
10 Bentancur AG, Naveh N, Lancri J, et al. Urine leukotriene B4 in familial Mediterranean fever and other forms of right lower abdominal pain. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Jul. 2005;12(7):671-4. [pmid: 15995103].
11 Bergeron E. Clinical judgment remains of great value in the diagnosis of acute appendicitis. Canadian journal of surgery Journal canadien de chirurgie. Apr. 2006;49(2):96-100. [pmid: 16630419].
12 Bingol-Kologlu M, Tanyel FC, Ocal T, et al. Intraabdominal pressure: a parameter helpful for diagnosing and predicting a complicated course in children with appendicitis. Journal of pediatric surgery. Apr. 2000;35(4):559-63. [pmid: 10770381].
13 Blennerhassett L, Hall JL, Hall JC. White blood cell counts in patients undergoing abdominal surgery. The Australian and New Zealand journal of surgery. Jun. 1996;66(6):369-71. [pmid: 8678855].
14 Bugliosi TF, Meloy TD, Vukov LF. Acute abdominal pain in the elderly. Annals of emergency medicine. Dec. 1990;19(12):1383-6. [pmid: 2240749].
15 Carrico CW, Fenton LZ, Taylor GA, et al. Impact of sonography on the diagnosis and treatment of acute lower abdominal pain in children and young adults. AJR American journal of roentgenology. Feb. 1999;172(2):513-6. [pmid: 9930815].
16 Carter JF, Soper DE. Operative laparoscopy in pregnancy. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Jan–Mar. 2004;8(1):57-60. [pmid: 14974665].
17 Chi CH, Shiesh SC, Lin XZ. Total antioxidant capacity and malondialdehyde in acute abdominal pain. The American journal of emergency medicine. Mar. 2002;20(2):79-82. [pmid: 11880867].
18 Cobben LP, de Van Otterloo AM, Puylaert JB. Spontaneously resolving appendicitis: frequency and natural history in 60 patients. Radiology. May. 2000;215(2):349-52. [pmid: 10796906].
19 Dalal I, Somekh E, Bilker-Reich A, et al. Serum and peritoneal inflammatory mediators in children with suspected acute appendicitis. Archives of surgery (Chicago, Ill : 1960). Feb. 2005;140(2):169-73. [pmid: 15723999].
20 Daneshmandi S, Ghasemi A, Pourfathollah AA. IL-6-174G/C promoter polymorphism in acute appendicitis. Laboratory Medicine. 2009;40(10):600-3. PMID:.
21 de Dombal FT, Horrocks JC, Staniland JR, et al. Construction and uses of a ‘data-base’ of clinical information concerning 600 patients with acute abdominal pain. Proceedings of the Royal Society of Medicine. Sep. 1971;64(9):978. [pmid: 4939896].
22 de Dombal FT. Computers and the surgeon--a matter of decision. Surgery annual. 1979;11:33-57. [pmid: 388693].
23 De Dombal FT. The diagnosis of acute abdominal pain with computer assistance: worldwide perspective. Annales de chirurgie. 1991;45(4):273-7. [pmid: 2064288].
24 Doberneck RC. Appendectomy during pregnancy. The American surgeon. May. 1985;51(5):265-8. [pmid: 3994167].
25 Engin O, Muratli A, Ucar AD, et al. The importance of fecaliths in the aetiology of acute appendicitis. Chirurgia (Bucharest, Romania : 1990). Nov–Dec. 2012;107(6):756-60. [pmid: 23294954].
26 Ergun T, Lakadamyal H. The CT frequencies of various non-traumatic acute abdominal emergencies in hemodialysis, peritoneal dialysis patients and the general population. European journal of radiology. Jan. 2012;81(1):13-20. [pmid: 21067883].
27 Eskelinen M, Lipponen P. Usefulness of history-taking in non-specific abdominal pain: a prospective study of 1333 patients with acute abdominal pain in Finland. In vivo (Athens, Greece). Mar–Apr. 2012;26(2):335-9. [pmid: 22351680].
28 Esses D, Birnbaum A, Bijur P, et al. Ability of CT to alter decision making in elderly patients with acute abdominal pain. The American journal of emergency medicine. Jul. 2004;22(4):270-2. [pmid: 15258866].
29 Fahel E, Amaral PC, Filho EM, et al. Non-traumatic acute abdomen: videolaparoscopic approach. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Jul–Sep. 1999;3(3):187-92. [pmid: 10527329].
30 Flum DR, Morris A, Koepsell T, et al. Has misdiagnosis of appendicitis decreased over time? A population-based analysis. JAMA : the journal of the American Medical Association. Oct. 10. 2001;286(14):1748-53. [pmid: 11594900].
31 Flum DR, Steinberg SD, Sarkis AY, et al. Appendicitis in patients with acquired immunodeficiency syndrome. Journal of the American College of Surgeons. May. 1997;184(5):481-6. [pmid: 9145068].
32 Fulton J, Lazarus C. Acute appendicitis among black South Africans. South African journal of surgery Suid-Afrikaanse tydskrif vir chirurgie. Dec. 1995;33(4):165-6. [pmid: 8677468].
33 Gaitan HG, Eslava-Schmalbach J, Gomez PI. Cost effectiveness of diagnostic laparoscopy in reproductive aged females suffering from non-specific acute low abdominal pain. Revista de salud publica (Bogota, Colombia). May–Aug. 2005;7(2):166-79. [pmid: 16149276].
34 Geis WP, Kim HC. Use of laparoscopy in the diagnosis and treatment of patients with surgical abdominal sepsis. Surgical endoscopy. Feb. 1995;9(2):178-82. [pmid: 7597589].
35 Gerhardt RT, Nelson BK, Keenan S, et al. Derivation of a clinical guideline for the assessment of nonspecific abdominal pain: the Guideline for Abdominal Pain in the ED Setting (GAPEDS) Phase 1 Study. The American journal of emergency medicine. Oct. 2005;23(6):709-17. [pmid: 16182976].
36 Goodwin AT, Swift RI, Bartlett MJ, et al. Can serum interleukin-6 levels predict the outcome of patients with right iliac fossa pain?. Annals of the Royal College of Surgeons of England. Mar. 1997;79(2):130-3. [pmid: 9135242].
37 Goulart RN, de Silverio GS, Moreira MB, et al. Main findings in laboratory tests diagnosis of acute appendicitis: a prospective evaluation. Arquivos brasileiros de cirurgia digestiva : ABCD. Brazilian archives of digestive surgery. Apr–Jun. 2012;25(2):88-90. [pmid: 23381749].
38 Grayson DE, Wettlaufer JR, Dalrymple NC, et al. Appendiceal CT in pediatric patients: relationship of visualization to amount of peritoneal fat. AJR American journal of roentgenology. Feb. 2001;176(2):497-500. [pmid: 11159103].
39 Hallan S, Lange C, Asberg A. Abdominal skin temperature in acute appendicitis. The British journal of surgery. Feb. 1995;82(2):177. [pmid: 7749680].
40 Hannan MJ, Hoque MM, Begum LN. Laparoscopic appendectomy in pregnant women: experience in Chittagong, Bangladesh. World journal of surgery. Apr. 2012;36(4):767-70. [pmid: 22311138].
41 Harvey AC, Moodie PF, Reda JE, et al. The acute abdomen in emergency with Hypercard. Proceedings/the Annual Symposium on Computer Application [sic] in Medical Care Symposium on Computer Applications in Medical Care. 1991:156-9. [pmid: 1807577].
42 Hawthorn IE. Abdominal pain as a cause of acute admission to hospital. Journal of the Royal College of Surgeons of Edinburgh. Dec. 1992;37(6):389-93. [pmid: 1283410].
43 Helmrath MA, Dorfman SR, Minifee PK, et al. Right lower quadrant pain in children caused by omental infarction. American journal of surgery. Dec. 2001;182(6):729-32. [pmid: 11839348].
44 Hill BC, Johnson SC, Owens EK, et al. CT scan for suspected acute abdominal process: impact of combinations of IV, oral, and rectal contrast. World journal of surgery. Apr. 2010;34(4):699-703. [pmid: 20054539].
45 Horattas MC, Guyton DP, Wu D. A reappraisal of appendicitis in the elderly. American journal of surgery. Sep. 1990;160(3):291-3. [pmid: 2393058].
46 Hoshino T, Ihara Y, Suzuki T. Appendicitis during pregnancy. International journal of gynaecology and obstetrics: the official organ of the International Federation of Gynaecology and Obstetrics. Jun. 2000;69(3):271-3. [pmid: 10854871].
47 Hui TT, Major KM, Avital I, et al. Outcome of elderly patients with appendicitis: effect of computed tomography and laparoscopy. Archives of surgery (Chicago, Ill : 1960). Sep. 2002;137(9):995-8. discussion 9–1000. [pmid: 12215147].
48 Hustey FM, Meldon SW, Banet GA, et al. The use of abdominal computed tomography in older ED patients with acute abdominal pain. The American journal of emergency medicine. May. 2005;23(3):259-65. [pmid: 15915395].
49 Hyman P, Westring DW. Leukocytosis in acute appendicitis. Observed racial difference. JAMA : the journal of the American Medical Association. Sep. 16. 1974;229(12):1630-1. [pmid: 4408297].
50 Impellizzeri P, Centonze A, Antonuccio P, et al. Utility of a scoring system in the diagnosis of acute appendicitis in pediatric age. A retrospective study. Minerva chirurgica. Jun. 2002;57(3):341-6. [pmid: 12029229].
51 Jahangiri M, Wyllie JH. Peripheral blood lymphopenia in gangrenous appendicitis. BMJ (Clinical research ed). Jul. 28. 1990;301(6745):215. [pmid: 2393731].
52 Jan YT, Yang FS, Huang JK. Visualization rate and pattern of normal appendix on multidetector computed tomography by using multiplanar reformation display. Journal of computer assisted tomography. Jul–Aug. 2005;29(4):446-51. [pmid: 16012298].
53 Johnson KA, Dewbury KC. Ultrasound imaging of the appendix testis and appendix epididymis. Clinical radiology. May. 1996;51(5):335-7. [pmid: 8641095].
54 Kaiser S, Mesas-Burgos C, Soderman E, et al. Appendicitis in children--impact of US and CT on the negative appendectomy rate. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al]. Zeitschrift fur Kinderchirurgie. Aug. 2004;14(4):260-4. [pmid: 15343467].
55 Kalliakmanis V, Pikoulis E, Karavokyros IG, et al. Acute appendicitis: the reliability of diagnosis by clinical assessment alone. Scandinavian journal of surgery : SJS : official organ for the Finnish Surgical Society and the Scandinavian Surgical Society. 2005;94(3):201-6. [pmid: 16259168].
56 Karamanakos SN, Sdralis E, Panagiotopoulos S, et al. Laparoscopy in the emergency setting: a retrospective review of 540 patients with acute abdominal pain. Surgical laparoscopy, endoscopy & percutaneous techniques. Apr. 2010;20(2):119-24. [pmid: 20393340].
57 Killen DA, Brooks DW Jr. APPENDICOLITH IN PATIENTS SUSPECTED OF HAVING ACUTE APPENDICITIS. The American surgeon. Jun. 1964;30:397-400. [pmid: 14173789].
58 Kim HJ, Lee JI, Lee YS, et al. Single-port transumbilical laparoscopic appendectomy: 43 consecutive cases. Surgical endoscopy. Nov. 2010;24(11):2765-9. [pmid: 20396909].
59 Kim MK, Strait RT, Sato TT, et al. A randomized clinical trial of analgesia in children with acute abdominal pain. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Apr. 2002;9(4):281-7. [pmid: 11927450].
60 Kim Y, Kim B. A report on twenty-one cases of nonspecific ulcerative terminal ileitis. Western journal of surgery, obstetrics, and gynecology. Dec. 1952;60(12):606-8. [pmid: 13015855].
61 Konoplitsky VS. Endogenous intoxication syndrome when acute process in abdominal cavity. Acta chirurgica Hungarica. 1997;36(1–4):170-1. [pmid: 9408333].
62 Kuan WS, Mahadevan M. Emergency unscheduled returns: can we do better?. Singapore medical journal. Nov. 2009;50(11):1068-71. [pmid: 19960161].
63 Kumar S. Right-sided low inguinal pain in young women. Journal of the Royal College of Surgeons of Edinburgh. Apr. 1996;41(2):93-4. [pmid: 8632398].
64 Kutasy B, Puri P. Appendicitis in obese children. Pediatric surgery international. Jun. 2013;29(6):537-44. [pmid: 23475429].
65 Kuuliala IK, Niemi LK. Sonography as an adjunct to plain film in the evaluation of acute abdominal pain. Annals of clinical research. 1987;19(5):355-8. [pmid: 3327444].
66 Latifi SQ, O’Riordan MA, Levine AD, et al. Persistent elevation of serum interleukin-6 in intraabdominal sepsis identifies those with prolonged length of stay. Journal of pediatric surgery. Oct. 2004;39(10):1548-52. [pmid: 15486902].
67 Laurell H, Hansson LE, Gunnarsson U. Acute abdominal pain among elderly patients. Gerontology. 2006;52(6):339-44. [pmid: 16905885].
68 Leape LL, Ramenofsky ML. Laparoscopy for questionable appendicitis: can it reduce the negative appendectomy rate?. Annals of surgery. Apr. 1980;191(4):410-3. [pmid: 6445178].
69 Leaper DJ, Gill PW, Staniland JR, et al. Clinical diagnostic process: an analysis. British medical journal. Sep. 15. 1973;3(5880):569-74. [pmid: 4580218].
70 Lee JH, Park YS, Choi JS. The epidemiology of appendicitis and appendectomy in South Korea: national registry data. Journal of epidemiology/Japan Epidemiological Association. 2010;20(2):97-105. [pmid: 20023368].
71 Lee PW. The leucocyte count in acute appendicitis. The British journal of surgery. Aug. 1973;60(8):618. [pmid: 4724201].
72 Lee PW. The plain X-ray in the acute abdomen: a surgeon’s evaluation. The British journal of surgery. Oct. 1976;63(10):763-6. [pmid: 990697].
73 Leigh PG. Appendicitis--still a considerable problem. South African medical journal. Suid-Afrikaanse tydskrif vir geneeskunde. May. 31. 1969;43(22):700-5. [pmid: 5786237].
74 Lelli JL Jr, Drongowski RA, Raviz S, et al. Historical changes in the postoperative treatment of appendicitis in children: impact on medical outcome. Journal of pediatric surgery. Feb. 2000;35(2):239-44. discussion 44–5. [pmid: 10693673].
75 Levy JH, Texidor MS. The lack of importance of Lanwei point in the diagnosis of acute appendicitis. Pain. Apr. 1988;33(1):79-80. [pmid: 3380555].
76 Lewis FR, Holcroft JW, Boey J, et al. Appendicitis. A critical review of diagnosis and treatment in 1,000 cases. Archives of surgery (Chicago, Ill : 1960). May. 1975;110(5):677-84. [pmid: 16566087].
77 Liddington MI, Thomson WH. Rebound tenderness test. The British journal of surgery. Jul. 1991;78(7):795-6. [pmid: 1873703].
78 Nabulsi, Hani, Karam M. Impact of C-reactive protein test results on evidence-based decision-making in cases of bacterial infection. [pmid: 22943554].
79 Ma KW, Chia NH, Yeung HW, et al. If not appendicitis, then what else can it be? A retrospective review of 1492 appendectomies. Hong Kong medical journal/Hong Kong Academy of Medicine. Xianggang yi xue za zhi. Feb. 2010;16(1):12-7. [pmid: 20124568].
80 Macari M, Hines J, Balthazar E, et al. Mesenteric adenitis: CT diagnosis of primary versus secondary causes, incidence, and clinical significance in pediatric and adult patients. AJR American journal of roentgenology. Apr. 2002;178(4):853-8. [pmid: 11906862].
81 Machado NO, Grant CS. Laparoscopic appendicectomy in all trimesters of pregnancy. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Jul–Sep. 2009;13(3):384-90. [pmid: 19793481].
82 Malik AA, Bari SU. Conservative management of acute appendicitis. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. May. 2009;13(5):966-70. [pmid: 19277796].
83 Manimaran N, Galland RB. Significance of routine digital rectal examination in adults presenting with abdominal pain. Annals of the Royal College of Surgeons of England. Jul. 2004;86(4):292-5. [pmid: 15239875].
84 Maslovitz S, Gutman G, Lessing JB, et al. The significance of clinical signs and blood indices for the diagnosis of appendicitis during pregnancy. Gynecologic and obstetric investigation. 2003;56(4):188-91. [pmid: 14576469].
85 McCallion J, Canning GP, Knight PV, et al. Acute appendicitis in the elderly: a 5-year retrospective study. Age and ageing. Jul. 1987;16(4):256-60. [pmid: 3630850].
86 Meeson S, Alvey CM, Golding SJ. Justifying multidetector CT in abdominal sepsis: time for review?. The British journal of radiology. Mar. 2009;82(975):190-7. [pmid: 18955415].
87 Menten R, Lebecque P, Saint-Martin C, et al. Outer diameter of the vermiform appendix: not a valid sonographic criterion for acute appendicitis in patients with cystic fibrosis. AJR American journal of roentgenology. Jun. 2005;184(6):1901-3. [pmid: 15908550].
88 Middleton SB, Whitbread T, Morgans BT, et al. Combination of skin temperature and a single white cell count does not improve diagnostic accuracy in acute appendicitis. The British journal of surgery. Apr. 1996;83(4):499. [pmid: 8665239].
89 Mills AM, Dean AJ, Hollander JE, et al. Abdominal pain: a survey of clinically important outcomes for future research. Cjem. Nov. 2010;12(6):485-90. [pmid: 21073774].
90 Min SB, Nylund CM, Abbas MI, et al. Thickened gastrointestinal wall findings on computed tomography in children: a reason for endoscopy?. Journal of pediatric gastroenterology and nutrition. Sep. 2013;57(3):305-10. [pmid: 23575298].
91 Mirvis SE, Young JW, Keramati B, et al. Plain film evaluation of patients with abdominal pain: are three radiographs necessary?. AJR American journal of roentgenology. Sep. 1986;147(3):501-3. [pmid: 3488654].
92 Mohebbi HA, Panahi F, Kabir A. Comparing presentation and diagnostic accuracy for conscripts and nonconscripts who have already been selected for appendectomy. Military medicine. Nov. 2006;171(11):1110-2. [pmid: 17153551].
93 Mollitt DL, Mitchum D, Tepas JJ 3rd. Pediatric appendicitis: efficacy of laboratory and radiologic evaluation. Southern medical journal. Dec. 1988;81(12):1477-9. [pmid: 3201295].
94 Nance ML, Adamson WT, Hedrick HL. Appendicitis in the young child: a continuing diagnostic challenge. Pediatric emergency care. Jun. 2000;16(3):160-2. [pmid: 10888451].
95 Natesha R, Barnwell S, Weaver WL, et al. Is there evidence for a racial difference in misdiagnosis in patients explored for appendicitis?. Journal of the National Medical Association. Mar. 1989;81(3):269-71. [pmid: 2709430].
96 Nega B. Pattern of acute abdomen and variables associated with adverse outcome in a rural primary hospital setting. Ethiopian medical journal. Jan. 2009;47(2):143-51. [pmid: 19743794].
97 Nmadu PT, Dawam D. Childhood appendicitis in Zaria: a retrospective study. East African medical journal. Aug. 1993;70(8):496-8. [pmid: 8261969].
98 Ogbonna BC, Obekpa PO, Momoh JT, et al. Another look at acute appendicitis in tropical Africa: and the value of laparoscopy in diagnosis. Tropical doctor. Apr. 1993;23(2):82-4. [pmid: 8488583].
99 Ohmann C, Belenky G, Platen C. Integration of a data dictionary and a clinical database in an expert system for acute abdominal pain. Medinfo MEDINFO. 1995;8(Pt 2):943-6. [pmid: 8591593].
100 Olivas VJ Jr, Palladino H, De Las Casas LE, et al. Cecal diverticulitis after laparoscopic resection of appendiceal diverticulitis with perforation. The American surgeon. Jan. 2013;79(1):114-6. [pmid: 23317626].
101 Olutola PS. Plain film radiographic diagnosis of acute appendicitis: an evaluation of the signs. Canadian Association of Radiologists journal. Journal l’Association canadienne des radiologistes. Dec. 1988;39(4):254-6. [pmid: 3203217].
102 Orient JM, Kettel LJ, Lim J. A test of a linear discriminant for identifying low-risk abdominal pain. Medical decision making : an international journal of the Society for Medical Decision Making. 1985;5(1):77-87. [pmid: 4068935].
103 Orji EO, Fasubaa OB, Adeyemi B, et al. Mortality and morbidity associated with misdiagnosis of ectopic pregnancy in a defined Nigerian population. Journal of obstetrics and gynaecology : the journal of the Institute of Obstetrics and Gynaecology. Sep. 2002;22(5):548-50. [pmid: 12521428].
104 Ou CS, Rowbotham R. Laparoscopic diagnosis and treatment of nontraumatic acute abdominal pain in women. Journal of laparoendoscopic & advanced surgical techniques Part A. Feb. 2000;10(1):41-5. [pmid: 10706302].
105 Ozdogan M, Devay AO, Gurer A, et al. Plasma total anti-oxidant capacity correlates inversely with the extent of acute appendicitis: a case control study. World journal of emergency surgery : WJES. 2006;1:6. [pmid: 16759345].
106 Park NH, Park CS, Lee EJ, et al. Ultrasonographic findings identifying the faecal-impacted appendix: differential findings with acute appendicitis. The British journal of radiology. Nov. 2007;80(959):872-7. [pmid: 17875592].
107 Paudel RK, Jain BK, Rani S, et al. Acute appendicitis: a quality assurance study. Tropical gastroenterology : official journal of the Digestive Diseases Foundation. Apr–Jun. 2003;24(2):83-6. [pmid: 14603829].
108 Peltokallio P, Svinhufvud U, Rantakaulio M, et al. The significance of thermography in the diagnosis of acute abdominal disease. The American journal of roentgenology, radium therapy, and nuclear medicine. Sep. 1975;125(1):164-71. [pmid: 1200209].
109 Pena BM, Taylor GA, Fishman SJ, et al. Costs and effectiveness of ultrasonography and limited computed tomography for diagnosing appendicitis in children. Pediatrics. Oct. 2000;106(4):672-6. [pmid: 11015507].
110 Perez J, Barone JE, Wilbanks TO, et al. Liberal use of computed tomography scanning does not improve diagnostic accuracy in appendicitis. American journal of surgery. Mar. 2003;185(3):194-7. [pmid: 12620554].
111 Pines JM, Hollander JE, Isserman JA, et al. The association between physician risk tolerance and imaging use in abdominal pain. The American journal of emergency medicine. Jun. 2009;27(5):552-7. [pmid: 19497460].
112 Poh BR, Cashin P, Dubrava Z, Blamey S, Yong WW, Croagh DG. Impact of an acute care surgery model on appendicectomy outcomes. [pmid: 24099125].
113 Polites SF, Mohamed MI, Habermann EB, Homme JL, Anderson JL, Moir CR, Ishitani MB, Zarroug AE. A simple algorithm reduces computed tomography use in the diagnosis of appendicitis in children. [pmid: 24953265].
114 Poljak A, Jeffrey RB Jr, Kernberg ME. The gas-containing appendix: potential sonographic pitfall in the diagnosis of acute appendicitis. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Nov. 1991;10(11):625-8. [pmid: 1811080].
115 Ponsky TA, Huang ZJ, Kittle K, et al. Hospital- and patient-level characteristics and the risk of appendiceal rupture and negative appendectomy in children. JAMA : the journal of the American Medical Association. Oct. 27. 2004;292(16):1977-82. [pmid: 15507583].
116 Potts FEt, Vukov LF. Utility of fever and leukocytosis in acute surgical abdomens in octogenarians and beyond. The journals of gerontology Series A, Biological sciences and medical sciences. Feb. 1999;54(2):M55-8. [pmid: 10051855].
117 Pranesh N, Sathya V, Mainprize KS. Serosal appendicitis: incidence, causes and clinical significance. Postgraduate medical journal. Dec. 2006;82(974):830-2. [pmid: 17148708].
118 Punnonen R, Aho AJ, Gronroos M, et al. Appendicectomy during pregnancy. Acta chirurgica Scandinavica. 1979;145(8):555-8. [pmid: 539341].
119 Quillin SP, Siegel MJ. Appendicitis in children: color Doppler sonography. Radiology. Sep. 1992;184(3):745-7. [pmid: 1509060].
120 Ramraje SN, Pawar VI. Routine histopathologic examination of two common surgical specimens-appendix and gallbladder: is it a waste of expertise and hospital resources?. [pmid: 24891777].
121 Rao PM, Rhea JT, Novelline RA. CT diagnosis of mesenteric adenitis. Radiology. Jan. 1997;202(1):145-9. [pmid: 8988204].
122 Reed JL, Strait RT, Kachelmeyer AM, et al. Biomarkers to distinguish surgical etiologies in females with lower quadrant abdominal pain. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Jul. 2011;18(7):686-91. [pmid: 21762231].
123 Rennie AT, Tytherleigh MG, Theodoroupolou K, et al. A prospective audit of 300 consecutive young women with an acute presentation of right iliac fossa pain. Annals of the Royal College of Surgeons of England. Mar. 2006;88(2):140-3. [pmid: 16551402].
124 Reynolds SL, Jaffe DM. Children with abdominal pain: evaluation in the pediatric emergency department. Pediatric emergency care. Mar. 1990;6(1):8-12. [pmid: 2320493].
125 Rollins MD, Andolsek W, Scaife ER, et al. Prophylactic appendectomy: unnecessary in children with incidental appendicoliths detected by computed tomographic scan. Journal of pediatric surgery. Dec. 2010;45(12):2377-80. [pmid: 21129549].
126 Roth C, Tello R, Sutherland K, et al. Prediction rule for etiology of vague abdominal pain in the emergency room: utility for imaging triage. Investigative radiology. Oct. 2002;37(10):552-6. [pmid: 12352163].
127 Rothrock SG, Green SM, Hummel CB. Plain abdominal radiography in the detection of major disease in children: a prospective analysis. Annals of emergency medicine. Dec. 1992;21(12):1423-9. [pmid: 1443835].
128 Rowe MI, Buckner DM, Newmark S. The early diagnosis of gram negative septicemia in the pediatric surgical patient. Annals of surgery. Sep. 1975;182(3):280-6. [pmid: 126047].
129 Sakai S, Kobayashi K, Nakamura J, et al. Accuracy in the diagnostic prediction of acute appendicitis based on the Bayesian network model. Methods of information in medicine. 2007;46(6):723-6. [pmid: 18066425].
130 Sakellaris G, Tilemis S, Charissis G. Acute appendicitis in preschool-age children. European journal of pediatrics. Feb. 2005;164(2):80-3. [pmid: 15703977].
131 Salem TA, Molloy RG, O’Dwyer PJ. Prospective study on the role of C-reactive protein (CRP) in patients with an acute abdomen. Annals of the Royal College of Surgeons of England. Apr. 2007;89(3):233-7. [pmid: 17394705].
132 Salky BA, Edye MB. The role of laparoscopy in the diagnosis and treatment of abdominal pain syndromes. Surgical endoscopy. Jul. 1998;12(7):911-4. [pmid: 9632858].
133 Sarfati MR, Hunter GC, Witzke DB, et al. Impact of adjunctive testing on the diagnosis and clinical course of patients with acute appendicitis. American journal of surgery. Dec. 1993;166(6):660-4. discussion 4–5. [pmid: 8273845].
134 Saunders P, Milton PJ. Laparotomy during pregnancy: an assessment of diagnostic accuracy and fetal wastage. British medical journal. Jul. 21. 1973;3(5872):165-7. [pmid: 4720768].
135 Scatarige JC, DiSantis DJ, Allen HA 3rd, et al. CT demonstration of the appendix in asymptomatic adults. Gastrointestinal radiology. Summer. 1989;14(3):271-3. [pmid: 2731702].
136 Schrenk P, Rieger R, Shamiyeh A, et al. Diagnostic laparoscopy through the right lower abdominal incision following open appendectomy. Surgical endoscopy. Feb. 1999;13(2):133-5. [pmid: 9918613].
137 Sebastian S, Kalra MK, Mittal P, et al. Can independent coronal multiplanar reformatted images obtained using state-of-the-art MDCT scanners be used for primary interpretation of MDCT of the abdomen and pelvis? A feasibility study. European journal of radiology. Dec. 2007;64(3):439-46. [pmid: 17408899].
138 Sgourakis G, Sotiropoulos GC, Molmenti EP, et al. Are acute exacerbations of chronic inflammatory appendicitis triggered by coprostasis and/or coproliths?. World journal of gastroenterology : WJG. May. 28. 2008;14(20):3179-82. [pmid: 18506922].
139 Simon HK, Muehlberg A, Linakis JG. Serum amylase determinations in pediatric patients presenting to the ED with acute abdominal pain or trauma. The American journal of emergency medicine. May. 1994;12(3):292-5. [pmid: 7513997].
140 Singh SM, Dean HG, de Dombal FT, et al. Concentrations of serotonin in plasma--a test for appendicitis?. Clinical chemistry. Dec. 1988;34(12):2572-4. [pmid: 3197305].
141 Sivit CJ, Newman KD, Chandra RS. Visualization of enlarged mesenteric lymph nodes at US examination. Clinical significance. Pediatric radiology. 1993;23(6):471-5. [pmid: 8255656].
142 Slater PE, Ben-Dom R, Rosenbluth MS. The price of better diagnostic accuracy in suspected appendicitis in Jerusalem. European journal of epidemiology. Jun. 1987;3(2):181-6. [pmid: 3609248].
143 Smink DS, Fishman SJ, Kleinman K, et al. Effects of race, insurance status, and hospital volume on perforated appendicitis in children. Pediatrics. Apr. 2005;115(4):920-5. [pmid: 15805365].
144 Smith RC, Verga M, McCarthy S, et al. Diagnosis of acute flank pain: value of unenhanced helical CT. AJR American journal of roentgenology. Jan. 1996;166(1):97-101. [pmid: 8571915].
145 Soo KS, Michie CA, Baker SR, et al. Selective recruitment of lymphocyte subsets to the inflamed appendix. Clinical and experimental immunology. Apr. 1995;100(1):133-8. [pmid: 7697912].
146 Staniland JR, Ditchburn J, De Dombal FT. Clinical presentation of acute abdomen: study of 600 patients. British medical journal. Aug. 12. 1972;3(5823):393-8. [pmid: 4506871].
147 Stewart RJ, Gupta RK, Purdie GL, et al. Fine catheter peritoneal cytology for the acute abdomen: a randomized, controlled trial. The Australian and New Zealand journal of surgery. Dec. 1988;58(12):965-70. [pmid: 3060065].
148 Stower MJ, Amar SS, Mikulin T, et al. Evaluation of the plain abdominal X-ray in the acute abdomen. Journal of the Royal Society of Medicine. Aug. 1985;78(8):630-3. [pmid: 4020796].
149 Sturman MF, Perez M. Computer-assisted diagnosis of acute abdominal pain. Comprehensive therapy. Feb. 1989;15(2):26-35. [pmid: 2647383].
150 Sugrue M, Redfern M. Computerized phonoenterography: the clinical investigation of a new system. Journal of clinical gastroenterology. Mar. 1994;18(2):139-44. [pmid: 8189010].
151 Sundal E, Gyr K, Fahrlaender H. Peritoneoscopy in abdominal emergencies--a valuable diagnostic tool. Endoscopy. May. 1982;14(3):97-9. [pmid: 6210524].
152 Tait IS, Ionescu MV, Cuschieri A. Do patients with acute abdominal pain wait unduly long for analgesia?. Journal of the Royal College of Surgeons of Edinburgh. Jun. 1999;44(3):181-4. [pmid: 10372490].
153 Tarantino L, Giorgio A, de Stefano G, et al. Acute appendicitis mimicking infectious enteritis: diagnostic value of sonography. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Sep. 2003;22(9):945-50. [pmid: 14510266].
154 Tayal VS, Bullard M, Swanson DR, et al. ED endovaginal pelvic ultrasound in nonpregnant women with right lower quadrant pain. The American journal of emergency medicine. Jan. 2008;26(1):81-5. [pmid: 18082786].
155 Tehrani HY, Petros JG, Kumar RR, et al. Markers of severe appendicitis. The American surgeon. May. 1999;65(5):453-5. [pmid: 10231216].
156 Tiboni S, Bhangu A, Hall NJ. Outcome of appendicectomy in children performed in paediatric surgery units compared with general surgery units. [pmid: 24700440].
157 Todd BS, Stamper R. The relative accuracy of a variety of medical diagnostic programs. Methods of information in medicine. Oct. 1994;33(4):402-16. [pmid: 7799817].
158 Turhan AN, Kapan S, Kutukcu E, et al. Comparison of operative and non operative management of acute appendicitis. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Sep. 2009;15(5):459-62. [pmid: 19779986].
159 Tytgat SH, Bakker XR, Butzelaar RM. Laparoscopic evaluation of patients with suspected acute appendicitis. Surgical endoscopy. Jul. 1998;12(7):918-20. [pmid: 9632860].
160 Udayasankar UK, Li J, Baumgarten DA, et al. Acute abdominal pain: value of non-contrast enhanced ultra-low-dose multi-detector row CT as a substitute for abdominal radiographs. Emergency radiology. Jan. 2009;16(1):61-70. [pmid: 18597128].
161 Ueberrueck T, Koch A, Meyer L, et al. Ninety-four appendectomies for suspected acute appendicitis during pregnancy. World journal of surgery. May. 2004;28(5):508-11. [pmid: 15085399].
162 Ustek D, Ekmekci CG, Selcukbiricik F, et al. Association between reduced levels of MEFV messenger RNA in peripheral blood leukocytes and acute inflammation. Arthritis and rheumatism. Jan. 2007;56(1):345-50. [pmid: 17195238].
163 Vaid NB, Mukherjee S, Gupta A. Acute abdominal pain in gynaecology. Journal of the Indian Medical Association. Oct. 1990;88(10):285-7. [pmid: 2090685].
164 van den Broek WT, Bijnen AB, de Ruiter P, et al. A normal appendix found during diagnostic laparoscopy should not be removed. The British journal of surgery. Feb. 2001;88(2):251-4. [pmid: 11167876].
165 van den Broek WT, Bijnen AB, van Eerten PV, et al. Selective use of diagnostic laparoscopy in patients with suspected appendicitis. Surgical endoscopy. Oct. 2000;14(10):938-41. [pmid: 11080407].
166 van Geloven AA, Biesheuvel TH, Luitse JS, et al. Hospital admissions of patients aged over 80 with acute abdominal complaints. The European journal of surgery. Acta chirurgica. Nov. 2000;166(11):866-71. [pmid: 11097153].
167 Van Lente F, Galen RS. Acute-phase proteins in acute appendicitis. Clinical chemistry. Jan. 1984;30(1):160. [pmid: 6690135].
168 Vander Velpen GC, Shimi SM, Cuschieri A. Diagnostic yield and management benefit of laparoscopy: a prospective audit. Gut. Nov. 1994;35(11):1617-21. [pmid: 7828984].
169 Vergara-Fernandez O, Zeron-Medina J, Mendez-Probst C, et al. Acute abdominal pain in patients with systemic lupus erythematosus. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Jul. 2009;13(7):1351-7. [pmid: 19415401].
170 Wai S, Ma L, Kim E, et al. The utility of the emergency department observation unit for children with abdominal pain. Pediatric emergency care. May. 2013;29(5):574-8. [pmid: 23603645].
171 Walker SJ, West CR, Colmer MR. Acute appendicitis: does removal of a normal appendix matter, what is the value of diagnostic accuracy and is surgical delay important?. Annals of the Royal College of Surgeons of England. Sep. 1995;77(5):358-63. [pmid: 7486763].
172 Wang CL, Guo XJ, Yuan ZD, et al. Radiologic diagnosis of Fitz-Hugh-Curtis syndrome. Chinese medical journal. Mar. 20. 2009;122(6):741-4. [pmid: 19323945].
173 Ward ST, Strong S, Goodchild RL, et al. Delays to appendicectomy within a split-site hospital. Clinical Governance. 2010;15(4):283-91. PMID:.
174 Webb EM, Joe BN, Coakley FV, et al. Appendiceal wall thickening at CT in asymptomatic patients with extraintestinal malignancy may mimic appendicitis. Clinical imaging. May–Jun. 2009;33(3):200-3. [pmid: 19411025].
175 Weinstein EC, Roscher A. Fecaliths of the appendix. International surgery. Mar. 1974;59(3):162-3. [pmid: 4824646].
176 Weinstein EC. ACUTE APPENDICITIS. California medicine. Jun. 1965;102:416-9. [pmid: 14298868].
177 Weir-McCall J, Shaw A, Arya A, et al. The use of pre-operative computed tomography in the assessment of the acute abdomen. Annals of the Royal College of Surgeons of England. Mar. 2012;94(2):102-7. [pmid: 22391377].
178 Wereszczynska-Siemiatkowska U, Dabrowski A, Siemiatkowski A, et al. Serum profiles of E-selectin, interleukin-10, and interleukin-6 and oxidative stress parameters in patients with acute pancreatitis and nonpancreatic acute abdominal pain. Pancreas. Mar. 2003;26(2):144-52. [pmid: 12604912].
179 Wiersma F, Toorenvliet BR, Ruige M, et al. Increased echogenicity of renal cortex: a transient feature in acutely ill children. AJR American journal of roentgenology. Jan. 2008;190(1):240-3. [pmid: 18094318].
180 Wilkinson RH, Bartlett RH, Eraklis AJ. Diagnosis of appendicitis in infancy. The value of abdominal radiographs. American journal of diseases of children (1960). Nov. 1969;118(5):687-90. [pmid: 5348366].
181 Williams NM, Johnstone JM, Everson NW. The diagnostic value of symptoms and signs in childhood abdominal pain. Journal of the Royal College of Surgeons of Edinburgh. Dec. 1998;43(6):390-2. [pmid: 9990785].
182 Williams RJ, Windsor AC, Rosin RD, et al. Ultrasound scanning of the acute abdomen by surgeons in training. Annals of the Royal College of Surgeons of England. Jul. 1994;76(4):228-33. [pmid: 8074382].
183 Wilson DH, Wilson PD, Walmsley RG, et al. Diagnosis of acute abdominal pain in the accident and emergency department. The British journal of surgery. Apr. 1977;64(4):250-4. [pmid: 322788].
184 Wolkomir AF, Barone JE, Moser RL. Selective microscopic examination of gallbladders, hernia sacs, and appendices. The American surgeon. May. 1991;57(5):289-92. [pmid: 2039125].
185 Wright JE. The polymorphonuclear leucocyte count as an aid to the diagnosis of acute appendicitis. The Medical journal of Australia. Nov. 8. 1969;2(19):956-8. [pmid: 5359690].
186 Wu C, Sun H, Wang H, et al. Evaluation of high mobility group box 1 protein as a presurgical diagnostic marker reflecting the severity of acute appendicitis. Scandinavian journal of trauma, resuscitation and emergency medicine. 2012;20:61. [pmid: 22947457].
187 Yang HR, Huang HH, Wang YC, et al. Management of right colon diverticulitis: a 10-year experience. World journal of surgery. Oct. 2006;30(10):1929-34. [pmid: 16983473].
188 Yip WC, Ho TF, Yip YY, et al. Value of abdominal sonography in the assessment of children with abdominal pain. Journal of clinical ultrasound : JCU. Oct. 1998;26(8):397-400. [pmid: 9783246].
189 Yitta S, Mausner EV, Kim A, et al. Pelvic ultrasound immediately following MDCT in female patients with abdominal/pelvic pain: is it always necessary?. Emergency radiology. Oct. 2011;18(5):371-80. [pmid: 21638034].
190 You JJ, Chen HC, Huang TM, et al. Missed cancerous lesions in emergency laparoscopic surgery: retrospective study of 2074 cases. Minimally invasive therapy & allied technologies : MITAT : official journal of the Society for Minimally Invasive Therapy. Jul. 2011;20(4):253-6. [pmid: 21082897].
191 Young YR, Chiu TF, Chen JC, et al. Acute appendicitis in the octogenarians and beyond: a comparison with younger geriatric patients. The American journal of the medical sciences. Oct. 2007;334(4):255-9. [pmid: 18030181].

## B-10. Rejection Reason: Less Than Sample Size CutOff

1 Ames Castro M, Shipp TD, Castro EE, et al. The use of helical computed tomography in pregnancy for the diagnosis of acute appendicitis. American journal of obstetrics and gynecology. Apr. 2001;184(5):954-7. [pmid: 11303204].
2 Aronsky D, Z’Graggen K, Banz M, et al. Abdominal fat tissue necrosis as a cause of acute abdominal pain. Laparoscopic diagnosis and therapy. Surgical endoscopy. Jul. 1997;11(7):737-40. [pmid: 9214322].
3 Aydin F, Kin Cengiz A, Gungor F. Tc-99m Labeled HMPAO white Blood Cell Scintigraphy in Pediatric Patients. Molecular imaging and radionuclide therapy. Apr. 2012;21(1):13-8. [pmid: 23487346].
4 Bentley JF, Dennison WM. THE ECTOPIC KIDNEY AS A DIAGNOSTIC PROBLEM. Clinical pediatrics. Feb. 1964;3:116-9. [pmid: 14119397].
5 Binderow SR, Shaked AA. Acute appendicitis in patients with AIDS/HIV infection. American journal of surgery. Jul. 1991;162(1):9-12. [pmid: 1829589].
6 Blane CE, White SJ, Wesley JR, et al. Sonography of ruptured appendicitis. Gastrointestinal radiology. 1986;11(4):357-60. [pmid: 3770346].
7 Cranston PE, Gray RE. Radiological seminar CCXLIII: CT examination in acute and complicated appendicitis. Journal of the Mississippi State Medical Association. Oct. 1985;26(10):285-8. [pmid: 4057244].
8 Davey WW. Rovsing’s sign. British medical journal. Jul. 7. 1956;2(4983):28-30. [pmid: 13329371].
9 Erian M, McLaren G. Unexpected causes of gynecological pelvic pain. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Oct–Dec. 2004;8(4):380-3. [pmid: 15554286].
10 Fish B, Smulewicz JJ, Barek L. Role of computed tomography in diagnosis of appendiceal disorders. New York state journal of medicine. May. 1981;81(6):900-4. [pmid: 6940006].
11 Harswick C, Uyenishi AA, Kordick MF, et al. Clinical guidelines, computed tomography scan, and negative appendectomies: a case series. The American journal of emergency medicine. Jan. 2006;24(1):68-72. [pmid: 16338513].
12 Healy DA, Aziz A, Wong M, et al. A descriptive cost analysis study of cases of right iliac fossa pain. International journal of surgery (London, England). 2013;11(7):524-8. [pmid: 23681149].
13 Hiller N, Berelowitz D, Hadas-Halpern I. Primary epiploic appendagitis: clinical and radiological manifestations. The Israel Medical Association journal : IMAJ. Dec. 2000;2(12):896-8. [pmid: 11344769].
14 Hornez E, Gellie G, Entine F, et al. Is there still a benefit to operate appendiceal abscess on board French nuclear submarines?. Military medicine. Aug. 2009;174(8):874-7. [pmid: 19743747].
15 Huynh LN, Coughlin BF, Wolfe J, et al. Patient encounter time intervals in the evaluation of emergency department patients requiring abdominopelvic CT: oral contrast versus no contrast. Emergency radiology. Jul. 2004;10(6):310-3. [pmid: 15278712].
16 Index of suspicion. Pediatrics in review/American Academy of Pediatrics. Dec. 2002;23(12):433-8. [pmid: 12456896].
17 Kosehan D, Akin K, Topcu A, et al. Spontaneous urinary extravasation: detection rate with 64-row multidetector computed tomography in patients presenting with acute abdomen. Emergency radiology. Aug. 2013;20(4):273-7. [pmid: 23515650].
18 Kulkarni, Sergi. Appendix carcinoids in childhood: Long-term experience at a single institution in Western Canada and systematic review. [pmid: 23279208].
19 Liese J, Halbinger TM, Ulrich F, Bechstein WO, Strey CW. Appendicitis-the balance between cost effectiveness and safety remains challenging. [pmid: 24633534].
20 Liu KY, Shyu JF, Uen YH, et al. Acute appendicitis in patients with acquired immunodeficiency syndrome. Journal of the Chinese Medical Association : JCMA. May. 2005;68(5):226-9. [pmid: 15909728].
21 Mangini M, Carrafiello G, Lagana D, et al. Non-traumatic acute bowel disease: differential diagnosis with 64-row MDCT. Emergency radiology. May. 2008;15(3):171-8. [pmid: 18247070].
22 McGreevy JM, Finlayson SR, Alvarado R, et al. Laparoscopy may be lowering the threshold to operate on patients with suspected appendicitis. Surgical endoscopy. Jul. 2002;16(7):1046-9. [pmid: 12165820].
23 Munck A, Belbari N, de Lagausie P, et al. Ultrasonography detects appendicular mucocele in cystic fibrosis patients suffering recurrent abdominal pain. Pediatrics. Apr. 2000;105(4 Pt 1):921. [pmid: 10819672].
24 Myslenski M, Effron, David. Acute Dx: What is the Cause of Sudden Illness?. Consultant (00107069). 2014;54(1):45-7. Language: English. Entry Date: 20140221. Revision Date: 20140221. Publication Type: journal article.
25 Nagpal, Udgiri, Sharma, Curras, Cosgrove, Farkas. Delaying an appendectomy: Is it safe?. [pmid: 22856499].
26 Parulekar SG. Ultrasonographic findings in diseases of the appendix. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Feb. 1983;2(2):59-64. [pmid: 6842659].
27 Paterson-Brown S, Thompson JN, Eckersley JR, et al. Which patients with suspected appendicitis should undergo laparoscopy?. British medical journal (Clinical research ed). May. 14. 1988;296(6633):1363-4. [pmid: 2969270].
28 Pelsang RE, Warnock NG, Abu-Yousef M. Diagnosis of acute appendicitis on transvaginal ultrasonography. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Sep. 1994;13(9):723-5. [pmid: 7933051].
29 Piper HG, Rusnak C, Orrom W, et al. Current management of appendicitis at a community center--how can we improve?. American journal of surgery. May. 2008;195(5):585-8. discussion 8–9. [pmid: 18367143].
30 Polese, Sarzo, Cadrobbi, Merigliano. Diagnostic flexible laparoscopy: A single incision procedure. [pmid: 24300933].
31 Poole GV. Appendicitis. The diagnostic challenge continues. The American surgeon. Oct. 1988;54(10):609-12. [pmid: 3052200].
32 Puylaert JB, van der Werf SD, Ulrich C, et al. Crohn disease of the ileocecal region: US visualization of the appendix. Radiology. Mar. 1988;166(3):741-3. [pmid: 3277243].
33 Reynolds M, Sherman JO, McLone DG. Ventriculoperitoneal shunt infection masquerading as an acute surgical abdomen. Journal of pediatric surgery. Dec. 1983;18(6):951-4. [pmid: 6663427].
34 Ross JA, Mc NT, Isaac A, et al. Excretion urography in the acute abdomen. Journal of the Royal College of Surgeons of Edinburgh. Oct. 1962;8:70-5. [pmid: 13975100].
35 Sandler MA, Pearlberg JL, Madrazo BL. Ultrasonic and computed tomographic features of mucocele of the appendix. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Mar. 1984;3(3):97-100. [pmid: 6726864].
36 Schreiber JH. Laparoscopic appendectomy in pregnancy. Surgical endoscopy. 1990;4(2):100-2. [pmid: 2142826].
37 Scott WW Jr, Fishman EK, Siegelman SS. Anticoagulants and abdominal pain. The role of computed tomography. JAMA : the journal of the American Medical Association. Oct. 19. 1984;252(15):2053-6. [pmid: 6481913].
38 Shetty MK, Garrett NM, Carpenter WS, et al. Abdominal computed tomography during pregnancy for suspected appendicitis: a 5-year experience at a maternity hospital. Seminars in ultrasound, CT, and MR. Feb. 2010;31(1):8-13. [pmid: 20102691].
39 Smith DE, Kirchmer NA, Stewart DR. Use of the barium enema in the diagnosis of acute appendicitis and its complications. American journal of surgery. Dec. 1979;138(6):829-34. [pmid: 507300].
40 Stoney RJ, Wylie EJ. Recognition and surgical management of visceral ischemic syndromes. Annals of surgery. Oct. 1966;164(4):714-22. [pmid: 5924791].
41 Sugarbaker PH, Sanders JH, Bloom BS, et al. Preoperative laparoscopy in diagnosis of acute abdominal pain. Lancet. Feb. 22. 1975;1(7904):442-5. [pmid: 48625].
42 Varoglu E, Polat KY, Tastekin G, et al. Diagnostic value of Tc-99m HIG scintigraphy in the detection of acute appendicitis. Clinical nuclear medicine. Aug. 1996;21(8):645-7. [pmid: 8853921].
43 Williams HJ. COPROLITHS IN CHILDREN: RECOGNITION AND SIGNIFICANCE. Pediatrics. Sep. 1964;34:372-7. [pmid: 14211103].
44 Winslow R. THE DIAGNOSIS OF APPENDICITIS IN EARLY TYPHOID FEVER. Annals of surgery. Nov. 1915;62(5):534-8. [pmid: 17863448].
45 Worley G, Wiener JS, George TM, et al. Acute abdominal symptoms and signs in children and young adults with spina bifida: ten years’ experience. Journal of pediatric surgery. Sep. 2001;36(9):1381-6. [pmid: 11528610].
46 Yoshida H, Onda M, Tajiri T, et al. Ultrasonography of non-perforated appendicitis in young children. Hepato-gastroenterology. Sep–Oct. 2002;49(47):1293-5. [pmid: 12239928].
47 Yu SY, Chiu JH, Loong CC, et al. Diagnostic laparoscopy: indication and benefit. Zhonghua yi xue za zhi. Chinese medical journal; Free China ed. Mar. 1997;59(3):158-63. [pmid: 9198290].
48 Zissin R, Gayer G, Bernheim J, et al. Granulomatous appendicitis presenting as right lower quadrant pain: CT findings. Abdominal imaging. Mar–Apr. 2003;28(2):280-3. [pmid: 12592479].

## B-11. Rejection Reason: No Human Subjects

1 de Souza AC, Lange RR, Guerios SD, Froes TR. Ultrasonographic examination in non-human primates with acute abdomen signs. [pmid: 23931624].
2 Karaman U, Turkmen E, Iraz M, et al. Parasitosis in appendectomy cases. European Journal of General Medicine. 2010;7(3):317-20. PMID:.
3 Seroussi B. Computer-aided diagnosis of acute abdominal pain when taking into account interactions. Methods of information in medicine. Oct. 1986;25(4):194-8. [pmid: 3534522].
4 Waraich T, Sarsfield P, Wright DH. The accessory cell populations in ulcerative colitis: a comparison between the colon and appendix in colitis and acute appendicitis. Human pathology. Mar. 1997;28(3):297-303. [pmid: 9042793].

## B-12. Rejection Reason: No Primary Data

1 A feasibility study of computer aided diagnosis in appendicitis. Surgery, gynecology & obstetrics. Nov. 1983;157(5):471-3. [pmid: 6356424].
2 a safer appendix test. Parents. 2014;89(6):55. Language: English. Entry Date: 20140530. Revision Date: 20140613. Publication Type: journal article.
3 A sound approach to the diagnosis of acute appendicitis. Lancet. Jan. 24. 1987;1(8526):198-200. [pmid: 2880022].
4 Abdullah M, Firmansyah MA. Diagnostic approach and management of acute abdominal pain. Acta medica Indonesiana. Oct. 2012;44(4):344-50. [pmid: 23314978].
5 Abu-Yousef MM, Franken EA Jr. An overview of graded compression sonography in the diagnosis of acute appendicitis. Seminars in ultrasound, CT, and MR. Aug. 1989;10(4):352-63. [pmid: 2697348].
6 Abu-Yousef MM. Ultrasonography of the right lower quadrant. Ultrasound quarterly. Dec. 2001;17(4):211-25. [pmid: 12973062].
7 Abu-Zidan FM, Windsor JA. Laparoscopic versus open appendicectomy. The Australian and New Zealand journal of surgery. Dec. 1996;66(12):838-40. [pmid: 8996067].
8 Abu-Zidan FM. Scoring systems for diagnosing acute appendicitis. Saudi medical journal. Apr. 2005;26(4):692. author reply 3. [pmid: 15900394].
9 Abu-Zidan FM. The role of ultrasonography in acute appendicitis. World journal of surgery. Apr. 2000;24(4):496-7. [pmid: 10706926].
10 Acheson J, Banerjee J. Management of suspected appendicitis in children. Archives of disease in childhood Education and practice edition. Feb. 2010;95(1):9-13. [pmid: 20145013].
11 Ackerman SJ, Irshad A, Anis M. Ultrasound for pelvic pain II: nongynecologic causes. Obstetrics and gynecology clinics of North America. Mar. 2011;38(1):69-83. viii. [pmid: 21419328].
12 Adametz WB. Failure to make diagnostic tests. JAMA : the journal of the American Medical Association. Oct. 6. 1969;210(1):213-4. [pmid: 5820382].
13 Adedeji OA. Alvarado score and acute appendicitis. Journal of the Royal Society of Medicine. Aug. 1992;85(8):508-9. [pmid: 1404214].
14 Akisik FM, Sandrasegaran K, Aisen AM, et al. Abdominal MR imaging at 3.0 T. Radiographics : a review publication of the Radiological Society of North America, Inc. Sep–Oct. 2007;27(5):1433-44. discussion 62–4. [pmid: 17848701].
15 Akle CA. Laparoscopic appendicectomy. The British journal of surgery. Sep. 1992;79(9):973. [pmid: 1294111].
16 Akpinar MY, Namdaroglu O. Mucosele of the appendix. Journal of Clinical and Analytical Medicine. 2014;5(1):88. PMID:.
17 Albiston E. The role of radiological imaging in the diagnosis of acute appendicitis. Canadian journal of gastroenterology. Journal canadien de gastroenterologie. Jul. 2002;16(7):451-63. [pmid: 12177724].
18 Alexander RJ, Lee-Elliott C, Nash GF. Magnetic resonance imaging and the acute abdomen (Br J Surg 2008; 95: 1193–1194). The British journal of surgery. Jan. 2009;96(1):119. author reply. [pmid: 19109806].
19 Alford BA, McIlhenny J. The child with acute abdominal pain and vomiting. Radiologic clinics of North America. Mar. 1992;30(2):441-53. [pmid: 1535866].
20 Al-Fozan H, Tulandi T. Safety and risks of laparoscopy in pregnancy. Current opinion in obstetrics & gynecology. Aug. 2002;14(4):375-9. [pmid: 12151826].
21 Ali SM, Hassanain M. Laparoscopic versus open appendectomy. Saudi journal of gastroenterology : official journal of the Saudi Gastroenterology Association. Jul–Aug. 2011;17(4):225-6. [pmid: 21727725].
22 Allescher H. Appendicitis: Can immediate antibiotic treatment still be withheld?. [pmid: 22281274].
23 Alonzo TA, Pepe MS. Development and evaluation of classifiers. Methods in molecular biology (Clifton, NJ). 2007;404:89-116. [pmid: 18450047].
24 Al-Rawashdeh F, Hadad S. Perforated appendicitis in children. Journal of the American College of Surgeons. 2012;215(3):442-3. PMID:. [pmid: 22901516].
25 Amesquita M, McGillicuddy D. Recurrent appendicitis. Internal and emergency medicine. Sep. 2008;3(3):251-3. [pmid: 18415029].
26 Ammori BJ. The clinical and economic correlates of nonspecific abdominal pain mismanaged by appendectomy. Archives of surgery (Chicago, Ill : 1960). Jan. 2003;138(1):111. author reply. [pmid: 12511164].
27 Amundson GM. Pediatric ultrasound cost-effective in ER. Diagnostic imaging. Oct. 1994;16(10):68-71. [pmid: 10150896].
28 Anderson M, Collins E. Analgesia for children with acute abdominal pain and diagnostic accuracy. Archives of disease in childhood. Nov. 2008;93(11):995-7. [pmid: 18305071].
29 Anderson SW, Soto JA. Multi-detector row CT of acute non-traumatic abdominal pain: contrast and protocol considerations. Radiologic clinics of North America. Jan. 2012;50(1):137-47. [pmid: 22099492].
30 Andersson R, Nystrom PO, Olaison G. Computed tomography of the appendix. The New England journal of medicine. Jun. 18. 1998;338(25):1847. author reply 8. [pmid: 9634362].
31 Andersson RE. Evaluation of the appendicitis inflammatory response score for patients with acute appendicitis. World journal of surgery. Jul. 2012;36(7):1546-7. [pmid: 22392357].
32 Andersson RE. Resolving appendicitis is common: further evidence. Annals of surgery. Mar. 2008;247(3):553. author reply. [pmid: 18376205].
33 Andersson RE. Routine ultrasound and limited computed tomography for the diagnosis of acute appendicitis: a surgeon’s perspective. World journal of surgery. Feb. 2011;35(2):295-6. [pmid: 21125273].
34 Andersson RE. Surgery: Laparoscopy for suspected appendicitis. Nature reviews Gastroenterology & hepatology. Jul. 2009;6(7):390-1. [pmid: 19575024].
35 Ansaloni L, Catena F, Coccolini F, et al. Letter to the editor. Re: Conservative management of acute appendicitis. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. May. 2010;14(5):931-2. author reply 3. [pmid: 20127199].
36 Antonson DL. Abdominal pain. Gastrointestinal endoscopy clinics of North America. Jan. 1994;4(1):1-21. [pmid: 8137010].
37 Anupindi SA, Janitz E, Darge K. Bowel Imaging in Children: A Comprehensive Look Using US and MRI. Semin Roentgenol. Apr. 2012;47(2):118-26. [pmid: 22370190].
38 Anupindi SA, Terreblanche O, Courtier J. MR Enterography. Inflammatory Bowel Disease and Beyond. Magnetic resonance imaging clinics of North America. 2013. PMID:.
39 Appendicitis in infancy. British medical journal. Sep. 12. 1970;3(5723):599. [pmid: 5470082].
40 Appendicitis. Seminars in ultrasound, CT, and MR. Aug. 1989;10(4):303-63. [pmid: 2627506].
41 Appendicitis. The Journal of practical nursing. Fall. 2008;58(3):10-2. [pmid: 19180843].
42 Applegate KE, Sivit CJ, Myers MT, et al. Using helical CT to diagnosis acute appendicitis in children: spectrum of findings. AJR American journal of roentgenology. Feb. 2001;176(2):501-5. [pmid: 11159104].
43 Arnot RS. Letter: Diagnosis of appendicitis. South African medical journal. Suid-Afrikaanse tydskrif vir geneeskunde. Mar. 22. 1975;49(13):458. [pmid: 1145364].
44 Arys B, Mandelstam S, Rao P, Kernick S, Kumbla S. Sonography of the pediatric gastrointestinal system. [pmid: 24850026].
45 Aschoff AJ. MDCT of the abdomen. European radiology. Nov. Suppl 7. 2006;16:M54-7. [pmid: 18655267].
46 Ashley SW. Foreword. [pmid: 25155148].
47 Assifi MM, Hines OJ. Appendicitis equals diverticulitis: a challenge to traditional dogma. Archives of surgery (Chicago, Ill : 1960). Mar. 2011;146(3):315. [pmid: 21542190].
48 Atassi KA. Action stat. Appendicitis. Nursing. Aug. 2002;32(8):96. [pmid: 12352857].
49 Attwood S. Ultrasonography in diagnosis of acute appendicitis. Diagnostic laparoscopy is often more useful than ultrasonography. BMJ (Clinical research ed). Mar. 10. 2001;322(7286):615. [pmid: 11269259].
50 Atwell JD. The incidence and value of rectal examination in children with suspected appendicitis: Assessor’s comment. Annals of the Royal College of Surgeons of England. Jul. 1991;73(4):234. [pmid: 19311346].
51 Augustin G, Majerovic M. Non-obstetrical acute abdomen during pregnancy. European journal of obstetrics, gynecology, and reproductive biology. Mar. 2007;131(1):4-12. [pmid: 16982130].
52 Avery JK. Old questions, new playing field. Tennessee medicine : journal of the Tennessee Medical Association. Feb. 2005;98(2):79-80. [pmid: 15779194].
53 Avila NA, Dwyer AJ, Moss J. Imaging features of lymphangioleiomyomatosis: diagnostic pitfalls. AJR American journal of roentgenology. Apr. 2011;196(4):982-6. [pmid: 21427352].
54 Avni FE. Imaging acute abdomen in the pediatric population. JBR-BTR : organe de la Societe royale belge de radiologie (SRBR) = orgaan van de Koninklijke Belgische Vereniging voor Radiologie (KBVR). 2012;95(6):394. PMID:.
55 Avni FE. Imaging acute abdomen in the pediatric population. JBR-BTR : organe de la Societe royale belge de radiologie (SRBR) = orgaan van de Koninklijke Belgische Vereniging voor Radiologie (KBVR). 2012;95(6):394. PMID:.
56 Axelrod DA, Sonnad SS, Hirschl RB. An economic evaluation of sonographic examination of children with suspected appendicitis (Structured abstract). Journal of pediatric surgery [serial on the Internet]. 2000;(8). Available from: http://onlinelibrary.wiley.com/o/cochrane/cleed/articles/NHSEED-22000001479/frame.html. Last accessed.
57 Babu ED. Would measurement of C-reactive protein reduce the rate of negative exploration for acute appendicitis?. Journal of the Royal College of Surgeons of Edinburgh. Jun. 2000;45(3):202-3. [pmid: 10881494].
58 Badruddoja M. Delayed appendectomy for acute appendicitis. Archives of surgery (Chicago, Ill : 1960). Jan. 2007;142(1):99. author reply 100. [pmid: 17224511].
59 Baevsky R. Leukocyte count in diagnosis of acute appendicitis. Annals of emergency medicine. Nov. 1999;34(5):688. [pmid: 10577292].
60 Bailey AA, Pedrosa I, Twickler DM, et al. MR imaging of abdominal and pelvic pain in pregnancy. Applied Radiology. 2012;41(9):16-24. PMID:.
61 Bailey AA, Pedrosa I, Twickler DM, Rofsky NM. MR imaging of abdominal and pelvic pain in pregnancy. Applied Radiology. 2012;41(9):16-24. PMID:.
62 Baillie J. Rapid measurement of urinary trypsinogen-2 as a screening test for acute pancreatitis. Gastrointestinal endoscopy. Oct. 1997;46(4):385-6. [pmid: 9351056].
63 Bain HW. Abdominal pain in children. Primary care. Mar. 1975;2(1):121-33. [pmid: 1046683].
64 Baker SR. Plain films and cross-sectional imaging for acute abdominal pain: unresolved issues. Seminars in ultrasound, CT, and MR. Apr. 1999;20(2):142-7. [pmid: 10222521].
65 Baker SR. Unenhanced helical CT versus plain abdominal radiography: a dissenting opinion. Radiology. Oct. 1997;205(1):45-7. [pmid: 9314960].
66 Balachandran B, Singhi S, Lal S. Emergency management of acute abdomen in children. Indian journal of pediatrics. Mar. 2013;80(3):226-34. [pmid: 23456644].
67 Baldassarre E, Ferrero C, Da Costa Duarte D, et al. Amyand’s hernia in infancy: why laparoscopy?. Journal of pediatric surgery. Aug. 2009;44(8):1673-4. [pmid: 19635331].
68 Baltarowich OH, Scoutt LM, Hamper UM. Nongynecologic findings on pelvic ultrasound: focus on gastrointestinal diseases. Ultrasound Q. Jun. 2012;28(2):65-85. [pmid: 22634768].
69 Balthazar EJ, Gordon RB. CT of appendicitis. Seminars in ultrasound, CT, and MR. Aug. 1989;10(4):326-40. [pmid: 2697345].
70 Banerjee D. Randomized clinical trial of laparoscopic versus open appendicectomy (Br J Surg 2001; 88: 200–5). The British journal of surgery. Aug. 2001;88(8):1132. discusssion 3. [pmid: 11488808].
71 Banerjee S, Farrell RJ, Lembo T. Gastroenterological causes of pelvic pain. World journal of urology. Jun. 2001;19(3):166-72. [pmid: 11469603].
72 Banez AV. Peritoneoscopy (also known as laparoscopy). American journal of proctology, gastroenterology & colon & rectal surgery. Oct. 1980;31(10):7-8. 20. [pmid: 6448551].
73 Barton E, Dixon AK. Is the appendix where you think it is?. Clinical radiology. Nov. 1993;48(5):365. [pmid: 8258227].
74 Bassiouny RH, El Maati A. Acute right lower quadrant pain beyond acute appendicitis: MDCT in evaluation of benign and malignant gastrointestinal causes. Egyptian Journal of Radiology and Nuclear Medicine. 2014. ((Bassiouny R.H.; El Maati A, amalamin74@yahoo.com) Department of Radio Diagnosis, Ain Shams University, Egypt). PMID:.
75 Bates CM, Plevris JN. Clinical evaluation of abdominal pain in adults. Medicine (United Kingdom). 2013;41(2):81-6. PMID:.
76 Bates CM, Plevris JN. Clinical evaluation of abdominal pain in adults. Medicine (United Kingdom). 2013;41(2):81-6. PMID:.
77 Bau A, Atri M. Acute female pelvic pain: ultrasound evaluation. Seminars in ultrasound, CT, and MR. Feb. 2000;21(1):78-93. [pmid: 10688069].
78 Baumeister CF. Practical everyday uses for the computer in medicine: the role of the computer as a diagnostic aid in the surgical abdomen. Section A--pain in the RLQ of the abdomen. Medical times. Jan. 1970;98(1):182-93. [pmid: 4904261].
79 Beasly SW. Can we improve diagnosis of acute appendicitis?. BMJ (Clinical research ed). Oct. 14. 2000;321(7266):907-8. [pmid: 11030658].
80 Bell DJ, Woo EK. Re: AC Anyanwu, SM Moalypour. Are abdominal radiographs still overutilised in the assessment of acute abdominal pain? A district general hospital audit. J R Coll Surg Edinb Irel 1998;43(4): 267–70. The surgeon : journal of the Royal Colleges of Surgeons of Edinburgh and Ireland. Feb. 2006;4(1):61. [pmid: 16459505].
81 Beltran MA, Almonacid J, Vicencio A, Gutierrez J, Cruces KS, Cumsille MA. Response to the Letter to the Editor of Dr Martin Brand. Journal of pediatric surgery. 2008;43(1):256-7. PMID:. [pmid: 18206493].
82 Beneventano TC, Schein CJ, Jacobson HG. The roentgen aspects of some appendiceal abnormalities. The American journal of roentgenology, radium therapy, and nuclear medicine. Feb. 1966;96(2):344-60. [pmid: 5907129].
83 Bentley SA. Alternatives to the neutrophil band count. Archives of pathology & laboratory medicine. Sep. 1988;112(9):883-4. [pmid: 3415439].
84 Berci G, Sackier JM, Paz-Partlow M. Emergency laparoscopy. American journal of surgery. Mar. 1991;161(3):332-5. [pmid: 1825752].
85 Berk MS. A RADIOLOGIC CONSULTATION : ACUTE ABDOMINAL PAIN. The Journal of the Florida Medical Association. Jan. 1965;52:40-1. [pmid: 14222826].
86 Berk RN. Barium enema examination in acute appendicitis. JAMA : the journal of the American Medical Association. Jul. 26. 1976;236(4):394-5. [pmid: 947060].
87 Berlin L. To order or not to order a CT examination because of radiation exposure: that is the question. AJR American journal of roentgenology. Feb. 2011;196(2):W216. [pmid: 21257867].
88 Berney C. Negative appendicectomy and perforation rates in patients undergoing laparoscopic surgery for suspected appendicitis (Br J Surg 2011; 98: 589–595). The British journal of surgery. Sep. 2011;98(9):1335. author reply. [pmid: 21792854].
89 Bhattacharya K, Cathrine AN. Re: Alvarado score: an admission criterion in patients with right iliac fossa pain. Surg J R Coll Surg Edinb Irel 2003; 1: 39–41. The surgeon : journal of the Royal Colleges of Surgeons of Edinburgh and Ireland. Oct. 2003;1(5):308. author reply. [pmid: 15570787].
90 Billington P, Khan SH, Lapsia S. Radiology of the acute abdomen. British journal of hospital medicine (London, England : 2005). Aug. 2011;72(8):M124-7. [pmid: 21841582].
91 Birnbaum BA, Jeffrey RB Jr. CT and sonographic evaluation of acute right lower quadrant abdominal pain. AJR American journal of roentgenology. Feb. 1998;170(2):361-71. [pmid: 9456947].
92 Birnbaum S. CT dose optimization: The general radiologist’s perspective. [pmid: 23763877].
93 Blackmore CC, Terasawa T. Optimizing the interpretation of CT for appendicitis: modeling health utilities for clinical practice. Journal of the American College of Radiology : JACR. Feb. 2006;3(2):115-21. [pmid: 17412021].
94 Blanc B, Pocard M. Surgical techniques of appendectomy for acute appendicitis. Journal de chirurgie. Oct. 2009;146(Spec 1):22-31. [pmid: 19846093].
95 Blebea JS, Meilstrup JW, Wise SW. Appendiceal imaging: which test is best?. Seminars in ultrasound, CT, and MR. Apr. 2003;24(2):91-5. [pmid: 12744501].
96 Blucher D, Lobe TE. Minimal access surgery in children: the state of the art. International surgery. Oct–Dec. 1994;79(4):317-21. [pmid: 7713699].
97 Boddy AP. Increased use of pre-operative imaging and laparoscopy has no impact on clinical outcomes in patients undergoing appendicectomy. Annals of the Royal College of Surgeons of England. May. 2012;94(4):287. [pmid: 22613323].
98 Bodenstein L. CT risks dwarfed by diagnostic benefits. Science (New York, NY). May. 27. 2011;332(6033):1032-3. [pmid: 21617056].
99 Bolog N, Popiel A, Oancea I, et al. Multi-detector row spiral CT (MDCT) in bowel related non-traumatic abdominal emergencies. Romanian journal of gastroenterology. Dec. 2003;12(4):319-24. [pmid: 14726979].
100 Bonn D. Rapid diagnosis of equivocal appendicitis. Molecular medicine today. Sep. 1998;4(9):367. [pmid: 9791857].
101 Borst AR. Acute appendicitis: pregnancy complicates this diagnosis. JAAPA : official journal of the American Academy of Physician Assistants. Dec. 2007;20(12):36-8. 41. [pmid: 18181368].
102 Bowen ME, Poehling KA, Gunn VL, et al. Does the use of oxycodone affect diagnostic accuracy in children with acute abdominal pain?. Archives of pediatrics & adolescent medicine. Apr. 2005;159(4):326-8. [pmid: 15809383].
103 Boyd CA, Riall TS. In Brief. Current problems in surgery. 2012;49(4):190-3. PMID:.
104 Brake D, Holtz J. The role of imaging in diagnosis of acute appendicitis. Kansas medicine : the journal of the Kansas Medical Society. Fall. 1995;96(3):130-2. 29. [pmid: 8583739].
105 Brand M. Re: Predictive value of white cell count and C-reactive protein in children with appendicitis. Journal of pediatric surgery. Jan. 2008;43(1):256. author reply -7. [pmid: 18206493].
106 Branicki FJ. Abdominal emergencies: diagnostic and therapeutic laparoscopy. Surgical infections. Fall. 2002;3(3):269-82. [pmid: 12542928].
107 Brazaitis MP, Dachman AH. The radiologic evaluation of acute abdominal pain of intestinal origin. A clinical approach. The Medical clinics of North America. Sep. 1993;77(5):939-61. [pmid: 8371622].
108 Brenner DJ. Slowing the increase in the population dose resulting from CT scans. Radiation research. Dec. 2010;174(6):809-15. [pmid: 20731591].
109 Brewster GS, Herbert ME, Hoffman JR. Medical myth: Analgesia should not be given to patients with an acute abdomen because it obscures the diagnosis. The Western journal of medicine. Mar. 2000;172(3):209-10. [pmid: 10734818].
110 Brewster GS, Herbert ME. Medical myth: a digital rectal examination should be performed on all individuals with possible appendicitis. The Western journal of medicine. Sep. 2000;173(3):207-8. [pmid: 10986194].
111 Brice J. What should CT’s role be in pediatric appendicitis?. Diagnostic imaging. Jan. Suppl. 2000:21-3. [pmid: 10848420].
112 Brisbois D, Magotteaux P, Bouali K, et al. Acute abdomen. Is ultrasonography useful, essential or unnecessary?. Acta gastro-enterologica Belgica. Apr–Jun. 1996;59(2):134-6. [pmid: 8903058].
113 Bromberg R, Goldman RD. Does analgesia mask diagnosis of appendicitis among children?. Canadian family physician Medecin de famille canadien. Jan. 2007;53(1):39-41. [pmid: 17872606].
114 Brooks SL. Laparoscopic appendectomy. Journal of visual communication in medicine. Dec. 2012;35(4):177. [pmid: 23397641].
115 Brown JJ. Acute appendicitis: the radiologist’s role. Radiology. Jul. 1991;180(1):13-4. [pmid: 2052679].
116 Brown MA. Imaging Acute Appendicitis. Seminars in Ultrasound, CT and MRI. 2008;29(5):293-307. PMID:.
117 Brown MA. Imaging acute appendicitis. Seminars in ultrasound, CT, and MR. Oct. 2008;29(5):293-307. [pmid: 18853837].
118 Brown T, Herbert ME. Medical myth: Bimanual pelvic examination is a reliable decision aid in the investigation of acute abdominal pain or vaginal bleeding. Cjem. Mar. 2003;5(2):120-2. [pmid: 17475104].
119 Brownell TRB, Wolpert Michael L, Jarmakani Marwan F, Mohebbi Mohammad R. Acute Appendicitis Presenting With Right Upper Quadrant Pain. Consultant (00107069). 2012;52(12):824. Language: English. Entry Date: 20130118. Revision Date: 20130208. Publication Type: journal article.
120 Buckley O, Geoghegan T, Ridgeway P, et al. Imaging of appendicoliths dropped at laparoscopic appendectomy and their complications. Canadian Association of Radiologists journal. Journal l’Association canadienne des radiologistes. Jun. 2007;58(3):146-51. [pmid: 17718298].
121 Buls N, Nieboer K, de Mey J. Comment on article of K. Udayasankar, J. Li, D.A. Baumgarten, W.C. Small, M.K. Kalra: acute abdominal pain:value of non-contrast enhanced ultra-low-dose multi-detector row CT as a substitute for abdominal radiographs (2009). Emergency radiology. Mar. 2010;17(2):165-6. author reply 7–8. [pmid: 19885690].
122 Bundy DG, Byerley JS, Liles EA, Perrin EM, Katznelson J, Rice HE. Does this child have appendicitis? (Structured abstract). JAMA : the journal of the American Medical Association [serial on the Internet]. 2007;(4). Available from: http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-12007008178/frame.html. Last accessed.
123 Bundy DG. Clinical prediction rule identifies children at low risk for appendicitis. The Journal of pediatrics. Mar. 2013;162(3):654-5. [pmid: 23438925].
124 Bundy DG. Diagnostic accuracy in pediatric appendicitis. Pediatrics. Aug. 2004;114(2):514-5. author reply -5. [pmid: 15286249].
125 Buppert C. How to Avoid Missing Appendicitis. Journal for Nurse Practitioners. 2012;8(3):237-8. Language: English. Entry Date: 20120413. Revision Date: 20120413. Publication Type: journal article. Journal Subset: Blind Peer Reviewed.
126 Burd RS, Whalen TV. Evaluation of the child with suspected appendicitis. Pediatric annals. Dec. 2001;30(12):720-5. [pmid: 11766200].
127 Burke M. Study explores imaging trends for diagnosing appendicitis. Contemporary Pediatrics. 2012;29(8):21. Language: English. Entry Date: 20120907. Revision Date: 20120914. Publication Type: journal article.
128 Burkhart C. Guidelines for rapid assessment of abdominal pain indicative of acute surgical abdomen. The Nurse practitioner. Jun. 43. 1992;17(6):39-6. 9. [pmid: 1608569].
129 Burton-Shepherd A. Diagnosing appendicitis. Independent Nurse. 2014;2. Language: English. Entry Date: 20140425. Revision Date: 20140530. Publication Type: journal article.
130 Buxbaum JL, Eloubeidi MA. Endoscopic ultrasound, the one-stop shop for abdominal pain?. United European Gastroenterol J. Oct. 2013;1(5):326-8. [pmid: 24917979].
131 Cabell R. Differential indications for sonography, 1. Ultrasound examination: general abdomen. MMW, Munchener medizinische Wochenschrift. Jul. 22. 1983;125(32–33):63-4. [pmid: 6415406].
132 Cadth. Ultrasound versus computed tomography for children with suspected appendicitis: clinical evidence, cost-effectiveness, and guidelines (Structured abstract). Health Technology Assessment Database [serial on the Internet]. 2013;(3). Available from: http://onlinelibrary.wiley.com/o/cochrane/clhta/articles/HTA-32014000896/frame.html. Last accessed.
133 Callahan MJ, Rodriguez DP, Taylor GA. CT of appendicitis in children. Radiology. Aug. 2002;224(2):325-32. [pmid: 12147823].
134 Cameron CT. Rectal examination in acute abdominal pain. The Medical journal of Australia. May. 13. 1967;1(19):992. [pmid: 6025016].
135 Cappell MS, Friedel D. Abdominal pain during pregnancy. Gastroenterology clinics of North America. Mar. 2003;32(1):1-58. [pmid: 12635413].
136 Cariati A, Piromalli E. Conservative or operative management (open or laparoscopic) of acute appendicitis. Canadian journal of surgery Journal canadien de chirurgie. Jun. 2012;55(3):E6. author reply E-7. [pmid: 22630066].
137 Cariati A, Piromalli E. Conservative or operative management (open or laproscopic) of actue appendicitis. Canadian Journal of Surgery. 2012;55(3):E6-E. Language: English. Entry Date: 20120720. Revision Date: 20120720. Publication Type: journal article.
138 Carr NJ. The pathology of acute appendicitis. Annals of diagnostic pathology. Feb. 2000;4(1):46-58. [pmid: 10684382].
139 Carreras Aja M, Arrieta Artieda I, Borruel Nacenta S. Multidetector computed tomography in acute abdomen. Radiologia. Oct. Suppl 1. 2011;53:60-9. [pmid: 21742357].
140 Carroll BJ. Management of appendicitis and cholecystitis. Journal of the American College of Surgeons. 2013;216(5):1026. PMID:. [pmid: 23618001].
141 Cartwright SL, Knudson MP. Evaluation of acute abdominal pain in adults. American family physician. Apr. 1. 2008;77(7):971-8. [pmid: 18441863].
142 Carvalho C. Acute appendicitis. Acta medica portuguesa. Jun. 1994;7(6):393-4. [pmid: 7942146].
143 Catanzano, O’Connor. Letter From the Guest Editors: Multimodality Imaging of the Pregnant Patient. [pmid: 22264897].
144 Chalazonitis AN, Tzovara I, Sammouti E, et al. CT in appendicitis. Diagnostic and interventional radiology (Ankara, Turkey). Mar. 2008;14(1):19-25. [pmid: 18306140].
145 Chalazonitis AN, Tzovara I, Sammouti E, et al. CT in appendicitis. Diagnostic and Interventional Radiology. 2008;14(1):19-25. PMID:. [pmid: 18306140].
146 Chandraharan E, Arulkumaran S. Acute abdomen and abdominal pain in pregnancy. Poloznictwo Ginekologia i Medycyna Rozrodu. 2009;3(1):12-21. PMID:.
147 Chao TB. Appendiceal diverticular disease. Formosan Journal of Surgery. 2013;46(1):33.
148 Charron M. Inflammatory bowel disease in pediatric patients. The quarterly journal of nuclear medicine : official publication of the Italian Association of Nuclear Medicine (AIMN) [and] the International Association of Radiopharmacology (IAR). Dec. 1997;41(4):309-20. [pmid: 9542422].
149 Chaudhuri A. Re: Chan MYP, Tan C, Chiu MT, Ng YY. Alvarado score: an admission criterion in patients with right iliac fossa pain. Surg J R Coll Surg Edinb Irel 2003; 1 (1): 39–41. The surgeon : journal of the Royal Colleges of Surgeons of Edinburgh and Ireland. Aug. 2003;1(4):243-4. author reply 4. [pmid: 15570771].
150 Chaudhuri TK, Fink S, Mahon CB, et al. Current status of imaging in the diagnosis of acute appendicitis. American journal of physiologic imaging. 1990;5(2):89-96. [pmid: 2252610].
151 Chaudhuri TK, Fink S. Therapeutic impact of CT of the appendix in a community hospital. AJR American journal of roentgenology. Sep. 2009;193(3):W255. author reply W6. [pmid: 19696269].
152 Chiu K, Baskerville JR. Bet 4 is magnetic resonance imaging useful for suspected appendicitis in pregnant patients?. Emergency Medicine Journal. 2009;26(6):437. PMID:. [pmid: 19465620].
153 Chong WK, Shah MS. Sonography of Right Upper Quadrant Pain. Ultrasound Clinics. 2008;3(1):121-38. PMID:.
154 Choudhary RK, Choudhary M. A useful diagnostic and prognostic tool for acute appendicitis and acute pancreatitis. BMJ (Clinical research ed). 2012;344:e1404. author reply e9. [pmid: 22374894].
155 Choudhary RK, Choudhary, Manaswini. Markers in acute appendicitis and acute pancreatitis... Watson J, Round A, Hamilton W. Raised inflammatory markers. BMJ 2012;344:e454. (3 February.). BMJ: British Medical Journal (Overseas & Retired Doctors Edition). 2012;344(7846):28. Language: English. Entry Date: 20120413. Revision Date: 20140321. Publication Type: journal article.
156 Chow LW, Loh TK, Ong CL. Role of sequential leucocyte counts and C-reactive protein measurements in acute appendicitis. The British journal of surgery. May. 1993;80(5):673. [pmid: 8518915].
157 Chow RD. A perspective from within the white coat. Yale journal of health policy, law, and ethics. Spring. 2001;1:171-5. [pmid: 12669326].
158 Choy A, McGuinness C, Gajraj H. Laparoscopic versus open appendicectomy: a prospective evaluation. The British journal of surgery. Mar. 1993;80(3):399. [pmid: 8329029].
159 Christensen AM. Randomized Prospective Study to Compare Laparoscopic Appendectomy Versus Umbilical Single-Incision Appendectomy. [pmid: 24374528].
160 Christina AL, Penn DR, Broder JC, et al. Current applications of MRI in emergent gastrointestinal diseases. Applied Radiology. 2012;41(11):9-15. PMID:.
161 Chung R, Hatrick A. Imaging and radiological interventions for the acute abdomen. Surgery (United Kingdom). 2013;31(11):588-96. PMID:.
162 Churney OL. Acute appendicitis; complications and their management. Medical bulletin of the U S Army, Europe United States Army, Europe Medical Division. Sep. 1952;9(9):386-96. [pmid: 12982143].
163 Ciarrocchi A, Amicucci G. Laparoscopic versus open appendectomy in obese patients: A meta-analysis of prospective and retrospective studies. [pmid: 24501501].
164 Clark CG, Boulos PB. Abdominal pain in the overseas visitor or immigrant. The Practitioner. Apr. 1979;222(1330):487-96. [pmid: 471907].
165 Clarke JR, Badawy SB. Acute pain over the appendix. A model of the surgical decision. Annales de chirurgie. 1991;45(4):279-83. [pmid: 2064289].
166 Clarke JR. A concise model for the management of possible appendicitis. Medical decision making : an international journal of the Society for Medical Decision Making. 1984;4(3):331-8. [pmid: 6521621].
167 Clarke JR. Appendicitis. The computer as a diagnostic tool. International journal of technology assessment in health care. 1989;5(3):371-9. [pmid: 10303908].
168 Clement DJ. Evaluation of the acute abdomen with CT: is image everything?. The American journal of gastroenterology. Aug. 1993;88(8):1282-3. [pmid: 8338105].
169 Clinical digest. Speed bump experience is a helpful diagnostic tool for acute appendicitis. Nursing Standard. 2013;27(20):17. Language: English. Entry Date: 20130208. Revision Date: 20140627. Publication Type: journal article.
170 Clinicopathologic conference: Appendiceal abscess. The American journal of medicine. Jan. 1974;56(1):92-102. [pmid: 4809574].
171 Clyne B, Olshaker JS. The C-reactive protein. The Journal of emergency medicine. Nov–Dec. 1999;17(6):1019-25. [pmid: 10595891].
172 Mellnick VM, Menias CO. Computed tomography of colonic and appendiceal emergencies. [pmid: 24836494].
173 Coburg AJ, Carus T, Kempf U, et al. Surgical laparoscopy in acute abdomen. Langenbecks Archiv fur Chirurgie Supplement Kongressband Deutsche Gesellschaft fur Chirurgie Kongress. 1998;115:985-7. [pmid: 9931767].
174 Cohen HL, Smith WL, Kushner DC, et al. Imaging evaluation of acute right lower quadrant and pelvic pain in adolescent girls. American College of Radiology. ACR Appropriateness Criteria. Radiology. Jun. Suppl. 2000;215:833-40. [pmid: 11037507].
175 Cohen MD. Radiation risks of medical imaging. [pmid: 23431231].
176 Cole MA, Maldonado N. Evidence-based management of suspected appendicitis in the emergency department. Emergency medicine practice. Oct. 2011;13(10):1-29. quiz. [pmid: 22164515].
177 Coley B. Appendicitis in children: one radiologist’s perspective. Pediatric radiology. Jan. 2007;37(1):1-3. [pmid: 17072610].
178 Computer aided diagnosis of acute abdominal pain. British medical journal (Clinical research ed). Nov. 15. 1986;293(6557):1305-6. [pmid: 3096475].
179 Computer aided diagnosis of acute abdominal pain. British medical journal (Clinical research ed). Oct. 18. 1986;293(6553):1025-6. [pmid: 3094746].
180 Computer-assisted diagnosis in acute abdominal pain. Lancet. Nov. 4. 1989;2(8671):1102-3. [pmid: 2572827].
181 Connally HE. Cytology and fluid analysis of the acute abdomen. Clinical techniques in small animal practice. Feb. 2003;18(1):39-44. [pmid: 12772868].
182 Conners GP, Schroeder LL. Assessing the accuracy of diagnostic imaging for pediatric appendicitis during the course of illness. Annals of emergency medicine. Nov. 2012;60(5):603-4. [pmid: 22841179].
183 Coppolino F, Gatta G, Di Grezia G, Reginelli A, Iacobellis F, Vallone G, Giganti M, Genovese E. Nontraumatic Abdominal Pain in Pregnancy: Imaging Considerations for a Multiorgan System Problem. Crit Ultrasound J. Jul. 15. Suppl 1. 2013;5:S4. [pmid: 23902744].
184 Corrigan D, Taweel A, Fahey T, et al. An ontological treatment of clinical prediction rules implementing the Alvarado score. Studies in health technology and informatics. 2013;186:103-7. [pmid: 23542977].
185 Coulthard MG. A clinical appendicitis score may assist with the diagnosis of appendicitis. Archives of disease in childhood Education and practice edition. Jun. 2010;95(3):95. [pmid: 20501535].
186 Crichton NJ, Hinde JP. Correspondence analysis as a screening method for indicants for clinical diagnosis. Statistics in medicine. Nov. 1989;8(11):1351-62. [pmid: 2609046].
187 Cromer DW. Preoperative evaluation of young woman with an acute abdomen. JAMA : the journal of the American Medical Association. Oct. 24–31. 1990;264(16):2140. [pmid: 2214086].
188 Crownover BK, Bepko JL. Appropriate and safe use of diagnostic imaging. American family physician. Apr. 1. 2013;87(7):494-501. [pmid: 23547591].
189 Cruz-Arambulo R, Wrigley R. Ultrasonography of the acute abdomen. Clinical techniques in small animal practice. Feb. 2003;18(1):20-31. [pmid: 12772866].
190 Cudmore RE. Rectal examinations and acute appendicitis. Archives of disease in childhood. Oct. 1985;60(10):993-4. [pmid: 4062356].
191 Cura JL, Oleaga L, Grande D, Vela AC, Ibanez AM. Reliability of diagnostic imaging techniques in suspected acute appendicitis: proposed diagnostic protocol (Structured abstract). Radiologia [serial on the Internet]. 2001;(10). Available from: http://onlinelibrary.wiley.com/o/cochrane/cleed/articles/NHSEED-22002009105/frame.html. Last accessed.
192 Curtin KR, Fitzgerald SW, Nemcek AA Jr, et al. CT diagnosis of acute appendicitis: imaging findings. AJR American journal of roentgenology. Apr. 1995;164(4):905-9. [pmid: 7726046].
193 Cuschieri RJ, Barker J. Acute appendicitis: does removal of a normal appendix matter, what is the value of diagnostic accuracy and is surgical delay important?. Annals of the Royal College of Surgeons of England. Jan. 1996;78(1):73. [pmid: 8659988].
194 Dabir D, Furst G, Blondin D. MRI in acute appendicitis in pregnancy. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Nov. 2010;182(11):1010-1. [pmid: 20563964].
195 Dachman AH. Improving the role of CT in diagnosing perforated appendicitis: can appendiceal air help?. Academic radiology. Oct. 2012;19(10):1173-4. [pmid: 22958716].
196 Dadswell JV. Acute appendicitis and Salmonella infections. British medical journal. Mar. 24. 1973;1(5855):740. [pmid: 4694704].
197 Dagiely S. An algorithm for triaging commonly missed causes of acute abdominal pain. Journal of emergency nursing: JEN : official publication of the Emergency Department Nurses Association. Feb. 2006;32(1):91-3. [pmid: 16439300].
198 Damani N, Wilson SR. Nongynecologic applications of transvaginal US. Radiographics : a review publication of the Radiological Society of North America, Inc. Oct. 1999;19(Spec No):S179-200. quiz S65–6. [pmid: 10517454].
199 Dang C, Aguilera P, Dang A, et al. Acute abdominal pain. Four classifications can guide assessment and management. Geriatrics. Mar. 2002;57(3):30-2. 5. 6. 41. 2. [pmid: 11899547].
200 Daniels IR, Chisholm EM. Suspected acute appendicitis: is ultrasonography or computed tomography the preferred imaging technique?. The European journal of surgery. Acta chirurgica. Nov. 2000;166(11):910. [pmid: 11097162].
201 Darge K, Anupindi SA, Jaramillo D. MR imaging of the bowel: pediatric applications. Magnetic resonance imaging clinics of North America. Aug. 2008;16(3):467-78. vi. [pmid: 18585599].
202 Das DN. Prospective evaluation of modified Alvarado score for diagnosis of acute appendicitis. Journal of the Indian Medical Association. Dec. 2002;100(12):718. author reply. [pmid: 12793641].
203 Dassinger MS, Smith SD. Reply to letter to the editor. Journal of pediatric surgery. 2012;47(12):2358. PMID:.
204 Davenport M. A useful sign for the diagnosis of peritoneal irritation in the right iliac fossa and Can serum interleukin-6 levels predict the outcome of patients with right iliac fossa pain?. Annals of the Royal College of Surgeons of England. Jul. 1997;79(4):310-1. [pmid: 9244086].
205 Davis EA, Werman HA, Rund DA. Journal club: Use of leukocyte count and differential in the evaluation of abdominal pain. The American journal of emergency medicine. Sep. 1986;4(5):482-6. [pmid: 3741566].
206 Dawson JW, Tate JJ, Robertson CS. The missing appendix. The British journal of surgery. Sep. 1992;79(9):973. [pmid: 1422772].
207 De Arzua Zulaica E. Ultrasonics in the diagnosis of acute appendicitis. Revista espanola de las enfermedades del aparato digestivo. Jul. 1988;74(1):57-8. [pmid: 3051193].
208 de Dombal FT. Acute abdominal pain in the elderly. Journal of clinical gastroenterology. Dec. 1994;19(4):331-5. [pmid: 7876517].
209 de Dombal FT. Analysis of symptoms in the acute abdomen. Clinics in gastroenterology. Jul. 1985;14(3):531-43. [pmid: 3905087].
210 de Dombal FT. Comment and reply. A study of diagnostic accuracy in suspected acute appendicitis. The Australian and New Zealand journal of surgery. May. 1989;59(5):409-10. [pmid: 2658940].
211 De Dombal FT. Computer-aided decision support in acute abdominal pain, with special reference to the EC concerted action. International journal of bio-medical computing. Sep. 1990;26(3):183-8. [pmid: 2242936].
212 de Dombal FT. Computer-aided decision support: in praise of level playing fields. Methods of information in medicine. May. 1994;33(2):161-3. [pmid: 8057941].
213 De Dombal FT. Computer-aided decision support--glittering prospects, practical problems, and Pandora’s box. Bailliere’s clinical obstetrics and gynaecology. Dec. 1990;4(4):841-9. [pmid: 2289369].
214 de Dombal FT. Computers, diagnoses and patients with acute abdominal pain. Archives of emergency medicine. Sep. 1992;9(3):267-70. [pmid: 1449572].
215 De Dombal FT. Computer-unaided diagnosis of acute abdominal pain in an accident and emergency department. Archives of emergency medicine. Mar. 1989;6(1):77-8. [pmid: 2712994].
216 de Dombal FT. Diagnosis of acute abdominal pain. What the computer teaches us. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Nov. 10. 1980;100(31):1852-5. [pmid: 7006145].
217 de Dombal FT. Picking the best tests in acute abdominal pain. Journal of the Royal College of Physicians of London. Oct. 1979;13(4):203-8. [pmid: 529208].
218 de Dombal FT. The O.M.G.E. Acute Abdominal Pain Survey--progress report, 1982. Scandinavian journal of gastroenterology Supplement. 1984;95:28-40. [pmid: 6379850].
219 de Dombal FT. The OMGE acute abdominal pain survey. Progress report, 1986. Scandinavian journal of gastroenterology Supplement. 1988;144:35-42. [pmid: 3043646].
220 de Dombol FT, Clamp SE, Chan M. Aids to the diagnosis of acute appendicitis. The British journal of surgery. Dec. 1989;76(12):1353. [pmid: 2691016].
221 de Kok HJ. Is laparoscopy of value in acute appendicitis?. Nederlands tijdschrift voor geneeskunde. Oct. 30. 1993;137(44):2271-2. author reply 2–3. [pmid: 7639834].
222 Deballon PO, Chalumeau C, Facy O. CT scan and appendicitis: inadequate population. Journal of surgical education. Mar–Apr. 2007;64(2):64. author reply 5. [pmid: 17462204].
223 Debnath J, Chatterjee S, Sharma V. Artificial neural networks in the diagnosis of acute appendicitis: should imaging be a part of it?. The American journal of emergency medicine. Jan. 2013;31(1):258-9. [pmid: 23122420].
224 Debnath J, Chatterjee S, Sharma V. Re: Surgeon-performed ultrasound as a diagnostic tool in appendicitis. Journal of pediatric surgery. Dec. 2012;47(12):2357. author reply 8. [pmid: 23217906].
225 Debnath J, Chatterjee S, Sharma V. Letter to the editor. Journal of pediatric surgery. 2012;47(12):2357. PMID:. [pmid: 23217906].
226 Debnath J, Sharma V, Chatterjee S. Diagnosing acute appendicitis: is there any role of ultrasonography?. [pmid: 24055143].
227 Debnath J. Acute appendicitis: Is removal of a normal appendix still existing and can we reduce its rate?. Saudi journal of gastroenterology : official journal of the Saudi Gastroenterology Association. Apr–Jun. 2010;16(2):122. [pmid: 20339186].
228 Debnath J. Glowing in the dark: Should the time of day determine radiographic imaging in the evaluation of abdominal pain in children?. [pmid: 22325410].
229 Delaney CP, O’Connell PR. Towards consensus on the fate of the normal appendix at laparoscopy for suspected appendicitis. Irish journal of medical science. Apr–Jun. 1999;168(2):109-10. [pmid: 10422390].
230 Demircan M. Plasma d-lactate level: a useful marker to distinguish a perforated appendix from acute simple appendicitis. Journal of investigative surgery : the official journal of the Academy of Surgical Research. May–Jun. 2004;17(3):173-4. discussion 5. [pmid: 15204961].
231 Denouement. Pediatr Infect Dis J. Jun. 2014;33(6):672-3. [pmid: 24830522].
232 Desai AU, Pienaar WE, Howlett DC, et al. Imaging of the gastrointestinal tract. Foundation Years. 2008;4(7):287-92. PMID:.
233 Devarajan S, Chandraharan E. Abdominal pain in pregnancy: A rational approach to management. Obstetrics, Gynaecology and Reproductive Medicine. 2011;21(7):198-206. PMID:.
234 Devey L, Henderson J, Wakefied C. Diagnosis of acute appendicitis. Appendicitis is a separate clinical entity in men and women. BMJ (Clinical research ed). Jul. 7. 2001;323(7303):50. [pmid: 11464830].
235 Dewhurst C, Beddy P, Pedrosa I. MRI evaluation of acute appendicitis in pregnancy. Journal of magnetic resonance imaging : JMRI. Mar. 2013;37(3):566-75. [pmid: 23423797].
236 Deysine M. The preoperative diagnosis of acute appendicitis: are we approaching 100% accuracy. Journal of investigative surgery : the official journal of the Academy of Surgical Research. May–Jun. 2004;17(3):175-6. [pmid: 15224692].
237 Dholakia, Khalid. Correspondence to: Bilirubin; a diagnostic marker for appendicitis. [pmid: 24296156].
238 Di Saverio, Tugnoli G, Sofia S, Masetti M, Catena F, Ansaloni L, Jovine E. Re: Appendectomy in pregnancy: Evaluation of the risks of a negative appendectomy. [pmid: 22153084].
239 Dickson MJ. The acute abdomen. Hospital medicine (London, England : 1998). Mar. 2001;62(3):182. [pmid: 11291473].
240 Dietz KR, Merrow AC, Podberesky DJ, Towbin AJ. Beyond acute appendicitis: imaging of additional pathologies of the pediatric appendix. [pmid: 23179488].
241 Dietz KR, Merrow AC, Podberesky DJ, Towbin AJ. Reply to Dr. Meyers et al regarding ‘Beyond acute appendicitis: imaging of additional pathologies of the pediatric appendix’. [pmid: 23703227].
242 Dingemann J, Ure B. Imaging and the use of scores for the diagnosis of appendicitis in children. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al]. Zeitschrift fur Kinderchirurgie. Jun. 2012;22(3):195-200. [pmid: 22767172].
243 Dixon JM, Elton RA. Rectal examination in patients with abdominal pain. BMJ (Clinical research ed). May. 25. 1991;302(6787):1274. [pmid: 2043861].
244 Dohan A, Soyer P. Low-dose abdominal CT for diagnosing appendicitis. The New England journal of medicine. Aug. 2. 2012;367(5):477. author reply 8–9. [pmid: 22853026].
245 Dominguez EP, Sweeney JF, Choi YU. Diagnosis and management of diverticulitis and appendicitis. Gastroenterology clinics of North America. Jun. 2006;35(2):367-91. [pmid: 16880071].
246 Donnelly LF. CT imaging of immunocompromised children with acute abdominal symptoms. AJR American journal of roentgenology. Oct. 1996;167(4):909-13. [pmid: 8819381].
247 Donner MW, Weiner S. DIAGNOSTIC EVALUATION OF ABDOMINAL CALCIFICATIONS IN ACUTE ABDOMINAL DISORDERS. Radiologic clinics of North America. Apr. 1964;2:145-59. [pmid: 14115286].
248 Donohue JH. Laparoscopic surgical procedures. Mayo Clinic proceedings. Aug. 1994;69(8):758-62. [pmid: 8035632].
249 Doria AS. Abdominal pain duration impacts the accuracy of ultrasound for diagnosing paediatric appendicitis. Evidence-based medicine. Dec. 2013;18(6):224-5. [pmid: 23454874].
250 Doria AS. Optimizing the role of imaging in appendicitis. Pediatric radiology. Apr. Suppl 2. 2009;39:S144-8. [pmid: 19308374].
251 Drake DP, Knott JG. Prediction of gangrenous and perforating appendicitis in children. British medical journal. Apr. 22. 1978;1(6119):1052. [pmid: 638597].
252 Drake DP. Rectal examination and acute appendicitis. Archives of disease in childhood. Jan. 1986;61(1):95-6. [pmid: 3082296].
253 Drake FT, Flum DR. Improvement in the diagnosis of appendicitis. [pmid: 24298858].
254 Dubinsky TJ, Sadro CT. Acute onset flank pain-suspicion of stone disease. [pmid: 22902853].
255 Dudley HA. Pay-off, heuristics, and pattern recognition in the diagnostic process. Lancet. Sep. 28. 1968;2(7570):723-6. [pmid: 4175101].
256 Dupuis O, Audra P, Mellier G. Is helical computed tomography 100% sensitive to diagnose acute appendicitis during pregnancy?. American journal of obstetrics and gynecology. Feb. 2002;186(2):336. [pmid: 11854661].
257 Duran JC, Beidle TR, Perret R, et al. CT Imaging of acute right lower quadrant disease. AJR American journal of roentgenology. Feb. 1997;168(2):411-6. [pmid: 9016217].
258 Dyall, Chan Thomas, Meyer Alastair, Asadpour Ali, Au Allan, Sfakiotaki Anastasia, Gondal Bashir, Campain Gary, Crompton Daniel, Simatos Dimi, Aljamal Hani, Summers Ian, Karro Jonty, Walker Katie, Bushby Nathan, Rosler Rachel, Ch’ng Wei. Authors of appendicitis transfer study reach wrong conclusion... Loke P, Tantoco J, Ferguson P et al. Accuracy of inter-hospital paediatric appendicitis referrals. Emerg Med Australas. 2012;24. [pmid: 23379464].
259 Easter DW, Cohen JS. Laparoscopy for Acute Diseases of the Lower Abdomen and Pelvis. Seminars in laparoscopic surgery. Sep. 1996;3(3):135-9. [pmid: 10401115].
260 Ehrlich L. THE ACUTE ABDOMEN, A VIEW FROM THE X-RAY DEPARTMENT. Boletin de la Asociacion Medica de Puerto Rico. Nov. 1964;56:492-3. [pmid: 14245155].
261 Eisenberg RL. The role of abdominal radiography in the evaluation of the nontrauma emergency patient: new thoughts on an old problem. Radiology. Sep. 2008;248(3):715-6. [pmid: 18710969].
262 Ek WL, MacDonald G, Johnson V, Rudralingham. Seeing past the appendix: the role of ultrasound in right iliac fossa pain. Ultrasound. 2014;22(2):104-12. Language: English. Entry Date: 20140523. Revision Date: 20140523. Publication Type: journal article.
263 El Sherif A, McPherson SJ, Dixon AK. Spiral CT of the abdomen: increased diagnostic potential. European journal of radiology. Jul. 1999;31(1):43-52. [pmid: 10477098].
264 Ellis H. Acute appendicitis. [pmid: 22411604].
265 Ellis H. Charles McBurney: pioneer in the diagnosis and treatment of appendicitis. [pmid: 24105313].
266 Ellis H. The acute abdomen and laboratory diagnosis. Contemporary issues in clinical biochemistry. 1985;2:33-7. [pmid: 3842348].
267 Emby DJ. Appropriate use of CT scanning in acute appendicitis. AJR American journal of roentgenology. Jun. 2006;186(6):E23. [pmid: 16714632].
268 Emil S. Appendicitis, is it an emergency?. [pmid: 22524781].
269 Eriksson S. Acute appendicitis--ways to improve diagnostic accuracy. The European journal of surgery. Acta chirurgica. Jun. 1996;162(6):435-42. [pmid: 8817219].
270 Errors in Text and Conversion Factors in: Validation and Refinement of a Prediction Rule to Identify Children at Low Risk for Acute Appendicitis. Archives of pediatrics & adolescent medicine. Oct. 1. 2012;166(10):901. [pmid: 23753870].
271 Estrada Rodriguez M, Leon Martinez R, Izquierdo de la Rosa H, et al. Is the diagnosis of acute appendicitis more efficient with emergency laparoscopy than with echography?. Revista espanola de las enfermedades del aparato digestivo. Aug. 1989;76(2):196-7. [pmid: 2530608].
272 Evans, Sarani, Bhanot, Feldman. In Brief.
273 Eyvazzadeh AD, Levine D. Imaging of pelvic pain in the first trimester of pregnancy. Radiologic clinics of North America. Nov. 2006;44(6):863-77. [pmid: 17147990].
274 Eyvazzadeh AD, Pedrosa I, Rofsky NM, et al. MRI of right-sided abdominal pain in pregnancy. AJR American journal of roentgenology. Oct. 2004;183(4):907-14. [pmid: 15385280].
275 Fahrlaender H. LAPAROSCOPY IN ABDOMINAL EMERGENCIES. Helvetica chirurgica acta. Jan. 1965;32:54-9. [pmid: 14292160].
276 Faiz O, Aylin P, Bottle A. Changing trends in surgery for acute appendicitis (Br J Surg 2008; 95: 363–368). The British journal of surgery. Jun. 2008;95(6):801. author reply. [pmid: 18446765].
277 Faro S, Maccato M. Pelvic pain and infections. Obstetrics and gynecology clinics of North America. Jun. 1990;17(2):441-55. [pmid: 2234753].
278 Fathi-Torbaghan M, Meyer D. MEDUSA: a fuzzy expert system for medical diagnosis of acute abdominal pain. Methods of information in medicine. Dec. 1994;33(5):522-9. [pmid: 7869951].
279 Federle MP. CT of the acute (emergency) abdomen. European radiology. Nov. Suppl 4. 2005;15:D100-4. [pmid: 16479657].
280 Fenyo G. Computer-aided diagnosis and decision-making in acute abdominal pain. Digestive diseases (Basel, Switzerland). 1990;8(3):125-37. [pmid: 2186880].
281 Ferrante D. Laparoscopic vs conventional appendectomy for suspected acute appendicitis (Structured abstract). Health Technology Assessment Database [serial on the Internet]. 2003;(3). Available from: http://onlinelibrary.wiley.com/o/cochrane/clhta/articles/HTA-32005000617/frame.html. Last accessed.
282 Fielding JR, Washburn D. Imaging the pregnant patient: A uniform approach. Journal of Women’s Imaging. 2005;7(1):16-21. PMID:.
283 Fingerhut A, Millat B, Borrie F. Laparoscopic versus open appendectomy: time to decide. World journal of surgery. Aug. 1999;23(8):835-45. [pmid: 10415210].
284 FitzGerald PA. Deep-seated mischief. Who can help the clinician?. Proceedings of the Royal Society of Medicine. Dec. 1970;63(12):1289-90. [pmid: 5490787].
285 Fleshner P. Introduction. Seminars in Colon and Rectal Surgery. 2012;23(2):43. PMID:.
286 Floyd MS. Evaluation of the plain roentgenogram of the abdomen in diagnosis of abdominal disease. The Journal of the Indiana State Medical Association. Oct. 1971;64(10):1099-105. [pmid: 5121876].
287 Forcier M. Emergency Department Evaluation of Acute Pelvic Pain in the Adolescent Female. Clinical Pediatric Emergency Medicine. 2009;10(1):20-30. PMID:.
288 Forsted DH, Kalbhen CL. CT of pregnant women for urinary tract calculi, pulmonary thromboembolism, and acute appendicitis. AJR American journal of roentgenology. May. 2002;178(5):1285. [pmid: 11959748].
289 Franken EH Jr, Abu-Yousef M. The usefulness of diagnostic tests. AJR American journal of roentgenology. Nov. 1988;151(5):1053-4. [pmid: 3051958].
290 Fraser GC. Children with acute abdominal pain. Taking a reasonable approach. Canadian family physician Medecin de famille canadien. Jun. 1993;39:1461-2. 5. 7. [pmid: 8324414].
291 Fraser GC. The incidence and value of rectal examination in children with suspected appendicitis. Annals of the Royal College of Surgeons of England. Nov. 1991;73(6):400. [pmid: 19311375].
292 Freeman AH. CT and bowel disease. The British journal of radiology. Jan. 2001;74(877):4-14. [pmid: 11227775].
293 Freeman NV. Rectal examination in appendicitis. Archives of disease in childhood. Sep. 1985;60(9):891. [pmid: 4051550].
294 Freimanis AK, Nelson SW. THE CHEST ROENTGENOGRAM IN THE DIAGNOSIS OF ACUTE ABDOMINAL DISEASE. Radiologic clinics of North America. Apr. 1964;2:3-20. [pmid: 14115291].
295 Frenn KA, Hendrickson M, Kharbanda AB. Reducing pediatric CT usage through web-based education. Radiol Manage. May–Jun. 2014;36(3):12-6. [pmid: 25004681].
296 Friday JH. Update on appendicitis: diagnosis and presurgical management. Current opinion in pediatrics. Jun. 2006;18(3):234-8. [pmid: 16721141].
297 Froggatt P, Harmston C. Acute appendicitis. Surgery. 2011;29(8):372-6. PMID:.
298 Frothingham EP, Newman TB. Computed tomography of the appendix. The New England journal of medicine. Jun. 18. 1998;338(25):1848. [pmid: 9634364].
299 Frush D, Beam C, Effmann EL. Acute appendicitis in children: an evaluation with ultrasound. Investigative radiology. Jun. 1992;27(6):489-90. [pmid: 1607265].
300 Frush DP, Frush KS, Oldham KT. Imaging of acute appendicitis in children: EU versus U.S. ... or US versus CT? A North American perspective. Pediatric radiology. May. 2009;39(5):500-5. [pmid: 19221730].
301 Fujita T, Yanaga K. Appendectomy: negative appendectomy no longer ignored. Archives of surgery (Chicago, Ill : 1960). Nov. 2007;142(11):1023-5. [pmid: 18025327].
302 Fujita T. Is Crohn’s disease associated with appendectomy or appendicitis?. The American journal of gastroenterology. May. 2009;104(5):1324. [pmid: 19319122].
303 Funaki B. Nonenhanced CT for suspected appendicitis. Radiology. Sep. 2000;216(3):916-8. [pmid: 10966732].
304 Gage H. ACUTE APPENDICITIS OCCURRING IN THE COURSE OF TYPHOID FEVER. Annals of surgery. Aug. 1915;62(2):146-51. [pmid: 17863397].
305 Gaitan HG, Reveiz L, Farquhar C, Elias VM. Laparoscopy for the management of acute lower abdominal pain in women of childbearing age. [pmid: 24848893].
306 Gaitan HG, Reveiz L, Malagon NR, et al. Early laparoscopy versus clinical observation for the management of nonspecific acute abdominal pain in women of childbearing age. Cochrane Database of Systematic Reviews. 2009;(2). PMID:.
307 Gakhal MS. Epiploic appendagitis: a clinically valuable imaging diagnosis. Delaware medical journal. Jul. 2010;82(7):237-40. [pmid: 20718377].
308 Ganeshan DM. Interpreting CT of the abdomen. AJR American journal of roentgenology. Jan. 2012;198(1):W104. [pmid: 22194507].
309 Gani JS. 21st century appendicitis: selecting non-operative winners. ANZ journal of surgery. Jan. 2013;83(1–2):6-7. [pmid: 23472252].
310 Gans SL, Stoker J, Boermeester MA. Plain abdominal radiography in acute abdominal pain; past, present, and future. Int J Gen Med. 2012;5:525-33. [pmid: 22807640].
311 Garcia Pena BM, Taylor GA, Lund DP. Appendicitis in children. New insights into an age-old problem. JAAPA : official journal of the American Academy of Physician Assistants. Jan. 2000;13(1):65-7. 70. 3-6 passim. [pmid: 11503225].
312 Garg AG, Singh AK. Inflammatory fatty masses of the abdomen. Seminars in ultrasound, CT, and MR. Oct. 2008;29(5):378-85. [pmid: 18853843].
313 Garg PK, Jain BK. Combined Use of Modified Alvarado Score and USG in Decreasing Negative Appendicectomy Rate: Critical Appraisal of Data. [pmid: 24426433].
314 Gayer G. Acute abdominal pain is one of the most common presenting complaints in the emergency department. Seminars in ultrasound, CT, and MR. Oct. 2008;29(5):291-2. [pmid: 18853836].
315 Geis WP, Miller CE, Teresi M, et al. Laparoscopic approach ideal for acute appendicitis. Clinical laser monthly. Jun. 1991;9(6):87-90. [pmid: 10150034].
316 Gelford GJ, Robb PL, Theros EG. An exercise in radiologic-pathologic correlation. Radiology. Dec. 1967;89(6):1107-12. [pmid: 6059638].
317 Gemellus. [pmid: 25116070].
318 Gerstle RK. Postpartum appendicitis presenting as RUQ pain. American family physician. Feb. 1. 2008;77(3):282. [pmid: 18297953].
319 Ghiatas AA, Chopra S, Chintapalli KN, et al. Computed tomography of the normal appendix and acute appendicitis. European radiology. 1997;7(7):1043-7. [pmid: 9265671].
320 Girotti MJ, Holliday RL. Nothing new on appendicitis. CMAJ : Canadian Medical Association journal. journal de l’Association medicale canadienne. Oct. 1. 1995;153(7):888. 90. [pmid: 7553489].
321 Gjelsteen AC, Ching BH, Meyermann MW, et al. CT, MRI, PET, PET/CT, and ultrasound in the evaluation of obstetric and gynecologic patients. The Surgical clinics of North America. Apr. 2008;88(2):361-90. vii. [pmid: 18381118].
322 Glanc P, Maxwell C. Acute abdomen in pregnancy: role of sonography. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Oct. 2010;29(10):1457-68. [pmid: 20876900].
323 Glasziou P. Threshold analysis via the Bayes’ nomogram. Medical decision making : an international journal of the Society for Medical Decision Making. Jan–Mar. 1991;11(1):61-2. [pmid: 2034077].
324 Goldberg HI, Mulvihill SJ. The radiologist’s role in the new era of laparoscopic general surgery. AJR American journal of roentgenology. Dec. 1994;163(6):1302-3. [pmid: 7992717].
325 Gollub MJ. Inverted appendiceal orifice masquerading as a cecal polyp on virtual colonoscopy. Gastrointestinal endoscopy. Feb. 2006;63(2):358. [pmid: 16427964].
326 Gomez N, Garberoglio CA. Reply. [pmid: 23618000].
327 Gonzalez de Dios J, Ochoa Sangrador C. Yield of abdominal ultrasonography in the diagnosis of acute appendicitis. Importance of the likelihood ratio. Anales de pediatria (Barcelona, Spain : 2003). Dec. 2003;59(6):603-5. [pmid: 14636531].
328 Gore RM, Miller FH, Pereles FS, et al. Helical CT in the evaluation of the acute abdomen. AJR American journal of roentgenology. Apr. 2000;174(4):901-13. [pmid: 10749221].
329 Gorter RR, van der Lee JH, Go PM, Wijnen MH, Meijer RW, Cense HA, Kneepkens CM, Heij HA. Appendicitis in children: An ongoing debate. [pmid: 23456287].
330 Goto M. Computed tomography and ultrasonography to detect appendicitis. Annals of internal medicine. May. 3. 2005;142(9):799-800. author reply. [pmid: 15867416].
331 Gough IR. Computer assisted diagnosis of the acute abdomen. The Australian and New Zealand journal of surgery. Sep. 1993;63(9):699-702. [pmid: 8363479].
332 Gough IR. Visualisation of the normal appendix at laparoscopy. Journal of the Royal College of Surgeons of Edinburgh. Feb. 1987;32(1):65. [pmid: 2951519].
333 Gouma DJ. Is laparoscopy helpful in acute appendicitis?. Nederlands tijdschrift voor geneeskunde. Jul. 24. 1993;137(30):1486-7. [pmid: 7639828].
334 Graff L. The MANTRELS score. Annals of emergency medicine. Jun. 1991;20(6):712-3. [pmid: 2039119].
335 Graffeo CS, Counselman FL. Appendicitis. Emergency medicine clinics of North America. Nov. 1996;14(4):653-71. [pmid: 8921763].
336 Graham DF. Prediction of gangrenous and perforating appendicitis in children. British medical journal. Jun. 10. 1978;1(6126):1550. [pmid: 656794].
337 Grassi R, Di Mizio R, Pinto A, et al. Serial plain abdominal film findings in the assessment of acute abdomen: spastic ileus, hypotonic ileus, mechanical ileus and paralytic ileus. La Radiologia medica. Jul–Aug. 2004;108(1–2):56-70. [pmid: 15269690].
338 Greenhalgh R, Punwani S, Taylor SA. Is MRI routinely indicated in pregnant patients with suspected appendicitis after equivocal ultrasound examination?. Abdominal imaging. Jan–Feb. 2008;33(1):21-5. [pmid: 17874265].
339 Greydanus DE, Rowlett JD. Perspectives on acute abdominal pain in the college student: A clinically challenging conundrum. International Journal on Disability and Human Development. 2012;11(3):199-210. PMID:.
340 Griffen WO Jr, Dilts PV Jr, Roddick JW Jr. Non-obstetric surgery during pregnancy. Current problems in surgery. Nov. 1969:1-56. [pmid: 4904941].
341 Griffin LP. Use of laparoscopy in the treatment of acute and chronic right lower quadrant pain. The Journal of the Kentucky Medical Association. Apr. 1996;94(4):160. [pmid: 8636658].
342 Grogono JL. A simple scoring system to reduce the negative appendicectomy rate rate: Invited comment. Annals of the Royal College of Surgeons of England. Jul. 1992;74(4):285. [pmid: 19311407].
343 Gronroos JM, Gronroos P. Diagnosis of acute appendicitis. Radiology. Apr. 2001;219(1):297-8. [pmid: 11274576].
344 Gronroos JM. Clinical suspicion of acute appendicitis - is the time ripe for more conservative treatment?. Minimally invasive therapy & allied technologies : MITAT : official journal of the Society for Minimally Invasive Therapy. Jan. 2011;20(1):42-5. [pmid: 20662630].
345 Gronroos P, Huhtinen H, Gronroos JM. Normal leukocyte count and C-reactive protein value do not effectively exclude acute appendicitis in children. Diseases of the colon and rectum. May. 2009;52(5):1028-9. author reply 9. [pmid: 19502880].
346 Grosskreutz S, Funaki B, Funaki C. Distal appendicitis: a possible anatomic source of error. Radiology. Dec. 1998;209(3):882-3. [pmid: 9844693].
347 Grover CA, Sternbach G. Charles McBurney: McBurney’s point. The Journal of emergency medicine. May. 2012;42(5):578-81. [pmid: 21982626].
348 Gruber H, Loizides A, Galiano K, Obernauer J. What is new?. Regional Anesthesia and Pain Medicine. 2012;37(4):460. PMID:. [pmid: 22722569].
349 Grzybowski M, Younger JG. Statistical methodology: III. Receiver operating characteristic (ROC) curves. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Aug. 1997;4(8):818-26. [pmid: 9262704].
350 Guillerman RP, Brody AS, Kraus SJ. Evidence-based guidelines for pediatric imaging: the example of the child with possible appendicitis. Pediatric annals. Oct. 2002;31(10):629-40. [pmid: 12389367].
351 Gupta H, Dupuy DE. Advances in imaging of the acute abdomen. The Surgical clinics of North America. Dec. 1997;77(6):1245-63. [pmid: 9431338].
352 Gupta S. Laboratory approach to the management of clinical emergencies: a diagnostic series. Journal of laboratory physicians. Jan. 2009;1(1):27-30. [pmid: 21938247].
353 Guy R, Dewar EP. Practical score to aid decision making in doubtful cases of appendicitis. The British journal of surgery. Dec. 1994;81(12):1829-30. [pmid: 7827952].
354 Haddad MC, Azzi MC, Hourani MH. Current diagnosis of acute appendicitis. Le Journal medical libanais The Lebanese medical journal. Oct–Dec. 2003;51(4):211-5. [pmid: 15623136].
355 Hainaux B, Borens-Fefer B. Radiology of acute abdominal pain in adult patients. Revue medicale de Bruxelles. Sep. 2010;31(4):298-303. [pmid: 21089407].
356 Bhattacharyya SK, Bhattacharya S, Alam H. Lesson learnt following diagnostic failure of a case of acute abdomen in pregnancy. [pmid: 22612067].
357 Hallan S, Asberg A. The accuracy of C-reactive protein in diagnosing acute appendicitis (Structured abstract). Scandinavian journal of clinical and laboratory investigation [serial on the Internet]. 1997;(5). Available from: http://onlinelibrary.wiley.com/o/cochrane/cldare/articles/DARE-11997001078/frame.html. Last accessed.
358 Hamminga JT, Haveman JW. The feasibility score for the Laparoscopic Appendicitis Score. Surgical endoscopy. Oct. 2013;27(10):3953. [pmid: 23644841].
359 Harris A, Bolus NE. Appendicitis imaging. Radiologic technology. Nov–Dec. 2005;77(2):111-7. quiz 8–20. [pmid: 16335340].
360 Harris JL. Radiography of abdominal emergencies. Radiography. Oct. 1967;33(394):207-17. [pmid: 6064498].
361 Harvey C, Hart JL, Lloyd CR. Ultrasound in the acute abdomen. British journal of hospital medicine (London, England : 2005). Aug. 2008;69(8):M116-9. [pmid: 18783095].
362 Hatcher-Ross K. Sensitivity and specificity of the Pediatric Appendicitis Score. The Journal of pediatrics. Feb. 2009;154(2):308. [pmid: 19150684].
363 Hattoum A, Heller M. Imaging of right lower quadrant pain: Beyond appendicitis. Emergency radiology. 2011;18(6):476. PMID:.
364 Hauk L. AAP releases guideline on diagnosis and management of acute bacterial sinusitis in children one to 18 years of age. [pmid: 24784128].
365 Hayden CK Jr. Ultrasonography of the gastrointestinal tract in infants and children. Abdominal imaging. Jan–Feb. 1996;21(1):9-20. [pmid: 8672983].
366 Hayes R. Abdominal pain: general imaging strategies. European radiology. Mar. Suppl 4. 2004;14:L123-37. [pmid: 14752577].
367 Heath W. Computer systems. Saving money--saving lives. The Health service journal. Nov. 6. 1986;96(5024):1458. [pmid: 10301126].
368 Hefny AF, Corr P, Abu-Zidan FM. The role of ultrasound in the management of intestinal obstruction. J Emerg Trauma Shock. Jan. 2012;5(1):84-6. [pmid: 22416163].
369 Heij HA, Offringa M. Effect of an imaging protocol on clinical outcomes among pediatric patients with appendicitis. Pediatrics. Mar. 2004;113(3 Pt 1):626. [pmid: 14993563].
370 Helbig D. Proceedings: Appendicitis in childhood (author’s transl). Langenbecks Archiv fur Chirurgie. 1973;334:867-70. [pmid: 4776173].
371 Heller, Hattoum A. Imaging of acute right lower quadrant abdominal pain: Differential diagnoses beyond appendicitis. [pmid: 22072087].
372 Heller MT, Khanna V. Cross-sectional imaging of acute abdominal conditions in the oncologic patient. Emergency radiology. Oct. 2011;18(5):417-28. [pmid: 21701881].
373 Hemphill P. Acute abdomen. British medical journal. Mar. 9. 1968;1(5592):638. [pmid: 5637581].
374 Herbert R, White RG. Ultrasound of the acute abdomen--Part II. Radiography today. Jun. 1990;56(637):23-30. [pmid: 2194491].
375 Herbert R, White RG. Ultrasound of the acute abdomen--Part III. Radiography today. Jul. 1990;56(638):16-24. [pmid: 2222794].
376 Herbert R, White RG. Ultrasound of the acute abdomen--Part IV. Radiography today. Aug. 1990;56(639):21-4. [pmid: 2242224].
377 Hernanz-Schulman M. CT and US in the diagnosis of appendicitis: an argument for CT. Radiology. Apr. 2010;255(1):3-7. [pmid: 20308436].
378 Hertzberg BS, Kliewer MA. Sonography of benign cystic teratoma of the ovary: pitfalls in diagnosis. AJR American journal of roentgenology. Nov. 1996;167(5):1127-33. [pmid: 8911163].
379 Heverhagen JT, Klose KJ. MR imaging for acute lower abdominal and pelvic pain. Radiographics : a review publication of the Radiological Society of North America, Inc. Oct. 2009;29(6):1781-96. [pmid: 19959521].
380 Higginbotham P, Gottlieb A. Improving care with a pediatric appendicitis pathway. Nursing case management : managing the process of patient care. Jan–Feb. 1998;3(1):26-35. [pmid: 9526393].
381 Hilger DJ. Radiology of appendicitis impact of newer modalities. The Nebraska medical journal. Jul. 1990;75(7):179-82. [pmid: 2204836].
382 Hinson FL. Role of sequential leucocyte counts and C-reactive protein measurements in acute appendicitis. The British journal of surgery. May. 1993;80(5):673. [pmid: 8518916].
383 Hinton D. Appendicitis: the worm still turns. The Journal of the Arkansas Medical Society. Jul. 2012;109(1):4. [pmid: 22866473].
384 Hlongwane NT. How sick is your appendectomy?. South African Family Practice. 2014;56(2):S28-S32. PMID:.
385 Hodgson WJ. Laparoscopic appendectomy for perforated appendicitis with peritonitis. Surgical endoscopy. Mar. 2007;21(3):497. [pmid: 17054005].
386 Hoeffel C, Crema MD, Belkacem A, et al. Multi-detector row CT: spectrum of diseases involving the ileocecal area. Radiographics : a review publication of the Radiological Society of North America, Inc. Sep–Oct. 2006;26(5):1373-90. [pmid: 16973770].
387 Hoffer FA. Interventional radiology in the acute pediatric abdomen. Radiologic clinics of North America. Jul. 1997;35(4):977-87. [pmid: 9216634].
388 Hoffmann B, Nurnberg D, Westergaard MC. Focus on abnormal air: diagnostic ultrasonography for the acute abdomen. European journal of emergency medicine : official journal of the European Society for Emergency Medicine. Oct. 2012;19(5):284-91. [pmid: 22668809].
389 Hoffmann J, Rasmussen OO. Aids in the diagnosis of acute appendicitis. The British journal of surgery. Aug. 1989;76(8):774-9. [pmid: 2527580].
390 Hogan MJ. Appendiceal abscess drainage. Techniques in vascular and interventional radiology. Dec. 2003;6(4):205-14. [pmid: 14767853].
391 Holcomb GW. What’s new in appendicitis. [pmid: 22767170].
392 Hollerweger A, Macheiner P, Rettenbacher T, et al. Primary epiploic appendagitis: sonographic findings with CT correlation. Journal of clinical ultrasound : JCU. Oct. 2002;30(8):481-95. [pmid: 12242737].
393 Hollerweger A. Acute appendicitis: sonographic evaluation. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Oct. 2006;27(5):412-26. quiz 27–32. [pmid: 17033943].
394 Holm HH, Kristensen JK, Rasmussen SN, et al. Indications for ultrasonic scanning in abdominal diagnostics. Journal of clinical ultrasound : JCU. Mar. 1974;2(1):5-15. [pmid: 4220231].
395 Hookman P, Barkin JS. Diagnosis of acute right lower quadrant pain and appendicitis by CT scan: do we still need the clinician?. The American journal of gastroenterology. May. 2000;95(5):1355-7. [pmid: 10811354].
396 Horng A, Reiser MF, Clevert DA. Modern sonography in the diagnosis of acute abdomen. Der Radiologe. Mar. 2010;50(3):214-25. [pmid: 20165940].
397 Horton KM. Acute appendicitis. Critical reviews in computed tomography. 2003;44(1):1-19. [pmid: 12627780].
398 Hotz TK. Laparoscopic versus open appendectomy. American journal of surgery. Feb. 1997;173(2):150. [pmid: 9074389].
399 Hudson PA, Promes SB. Abdominal ultrasonography. Emergency medicine clinics of North America. Nov. 1997;15(4):825-48. [pmid: 9391495].
400 Hulett R. Imaging of appendicitis. The Western journal of medicine. Jul–Aug. 1996;165(1–2):54-5. [pmid: 8855688].
401 Huprich JE, Fletcher JG, Fidler J, et al. The routine use of CT enterography with positive enteric contrast in patients with non-traumatic acute abdominal pain. European journal of radiology. Jan. 2011;77(1):189-90. [pmid: 19766419].
402 Hussain A, El-Hasani S. Transumbilical laparoscopically assisted appendectomy in children. Surgical endoscopy. Apr. 2009;23(4):912. [pmid: 19118428].
403 Hwang U. A clinical prediction rule to identify children at low risk for appendicitis. Journal of Clinical Outcomes Management. 2012;19(10):442-4. PMID:.
404 J IA. Alternative guide to utilization of computed tomography in appendicitis. [pmid: 24593758].
405 Identifying optimal diagnostic strategies algorithms with multiple tests. Ancillary study of Optimisation of diagnostic imaging use in patients with acute abdominal pain: cost-effectiveness analysis of imaging strategies (OPTIMA study) (Project record). Health Technology Assessment Database [serial on the Internet]. 2005;(3). Available from: http://onlinelibrary.wiley.com/o/cochrane/clhta/articles/HTA-32005001087/frame.html. Last accessed.
406 Ikard RW, Federspiel CF. Laparoscopic versus open appendectomy. The New England journal of medicine. Sep. 28. 1995;333(13):881-2. [pmid: 7651496].
407 Ikehata A, Nakano Y, Sakuma T. Acute appendicitis after barium enema examination. Journal of clinical gastroenterology. Apr. 1999;28(3):280-1. [pmid: 10192627].
408 Incesu L. Diagnosis of acute appendicitis in children. AJR American journal of roentgenology. Oct. 1995;165(4):1014. [pmid: 7676957].
409 Ingberg HO, Prust FW. The diagnosis of abdominal emergencies in patients with spinal cord lesions. Archives of physical medicine and rehabilitation. Jun. 1968;49(6):343-8. [pmid: 5667248].
410 in’t Hof KH, Kazemier G. Videolaparoscopic appendectomy: the current outlook. Surgical endoscopy. Oct. 2007;21(10):1901. author reply 2–3. [pmid: 17704861].
411 Kessler, Bauer. Utility of the digital rectal examination in the emergency department: A review. [pmid: 22883714].
412 Jackson PG, Raiji MT. Evaluation and management of intestinal obstruction. American family physician. Jan. 15. 2011;83(2):159-65. [pmid: 21243991].
413 Jacobs JE, Birnbaum BA. CT imaging in acute appendicitis: techniques and controversies. Seminars in ultrasound, CT, and MR. Apr. 2003;24(2):96-100. [pmid: 12744502].
414 Jacobs JE. CT and sonography for suspected acute appendicitis: a commentary. AJR American journal of roentgenology. Apr. 2006;186(4):1094-6. [pmid: 16554585].
415 Jaffe V, Mathie RT, Alexander B. Use of skin thermometer to diagnose acute appendicitis. BMJ (Clinical research ed). Apr. 14. 1990;300(6730):1017. [pmid: 2344499].
416 Jahangir T, Roy MK. Evaluation of negative appendicectomy rate in cases of suspected acute appendicitis and to study the usefulness of ultrasonography in improving the diagnostic accuracy. The Indian journal of surgery. Apr. 2009;71(2):109-10. [pmid: 23133130].
417 Jain A, Kramullah E, Ahmad I, et al. Applications and limitations of ultrasound in imaging of acute abdomen: A pictorial essay 2. Journal of Medical Imaging and Radiation Oncology. 2012;56:165. PMID:.
418 James, Kelly. The abdominal radiograph. [pmid: 24505155].
419 Jaye DL, Waites KB. Clinical applications of C-reactive protein in pediatrics. The Pediatric infectious disease journal. Aug. 1997;16(8):735-46. quiz 46–7. [pmid: 9271034].
420 Jeffrey RB Jr. In patients with right lower quadrant pain, is sonography or CT the preferred imaging technique for initial evaluation?. AJR American journal of roentgenology. Jun. 1995;164(6):1547-8. [pmid: 7754913].
421 Jin Ong S, Whitley S, Safar-Aly H, et al. Imaging the patient with suspected appendicitis. British journal of hospital medicine (London, England : 2005). Dec. 2012;73(12):C178-82. [pmid: 23519064].
422 Joffe MD, Lavelle J. Appendicitis in childhood. Comprehensive therapy. Jun–Jul. 1999;25(6–7):370-5. [pmid: 10470522].
423 Johari HG, Mohseni GR, Eskandari S. Acute appendicitis: emergency medicine physician and surgeon clinical judgment vs abdominal computed tomography scan. The American journal of emergency medicine. Nov. 2011;29(9):1230-1. [pmid: 21855264].
424 John SD. Imaging of acute abdominal emergencies in infants and children. Current problems in diagnostic radiology. Sep–Oct. 2000;29(5):141-79. [pmid: 11027076].
425 Johnson A. Laparoscopic surgery. Lancet. Mar. 1. 1997;349(9052):631-5. [pmid: 9057744].
426 Johnson GL, Fishman EK. Using CT to evaluate the acute abdomen: spectrum of urinary pathology. AJR American journal of roentgenology. Jan. 1997;168(1):273-6. [pmid: 8976959].
427 Johnson JF, Coughlin WF. Plain film diagnosis of appendiceal perforation in children. Seminars in ultrasound, CT, and MR. Aug. 1989;10(4):306-13. [pmid: 2697343].
428 Jones A, Akhtar MZ. Problem with right iliac fossa pain. ANZ J Surg. May. 2012;82(5):379. [pmid: 23305057].
429 Jones EE. Ectopic pregnancy: common and some uncommon misdiagnoses. Obstetrics and gynecology clinics of North America. Mar. 1991;18(1):55-72. [pmid: 1717911].
430 Jones PF, Krukowski ZH, Youngson GG. Randomized clinical trial of early laparoscopy in the management of acute non-specific abdominal pain. The British journal of surgery. Apr. 2000;87(4):523-4. [pmid: 10809578].
431 Jones PF. Computed tomography in suspected acute appendicitis. Surgery. Apr. 2001;129(4):514-5. [pmid: 11283550].
432 Jones PF. Ultrasonography in diagnosis of acute appendicitis. Active observation is often sufficient to make diagnosis. BMJ (Clinical research ed). Mar. 10. 2001;322(7286):615-6. [pmid: 11269260].
433 Julia, Gomez, Codina-Cazador. Antibiotic treatment for uncomplicated acute appendicitis. [pmid: 22464388].
434 Kaiser AM, Katkhouda N. Laparoscopic management of the perforated viscus. Seminars in laparoscopic surgery. Mar. 2002;9(1):46-53. [pmid: 11979410].
435 Kao SC, Smith WL, Abu-Yousef MM, et al. Acute appendicitis in children: sonographic findings. AJR American journal of roentgenology. Aug. 1989;153(2):375-9. [pmid: 2665455].
436 Karam AR, Birjawi GA, Sidani CA, et al. Alternative diagnoses of acute appendicitis on helical CT with intravenous and rectal contrast. Clinical imaging. Mar–Apr. 2007;31(2):77-86. [pmid: 17320773].
437 Karnam US, Reddy KR. Diagnostic laparoscopy: an update. Endoscopy. Feb. 2002;34(2):146-53. [pmid: 11822010].
438 Karnath BM, Luh JY. Suspected appendicitis. The New England journal of medicine. Jul. 17. 2003;349(3):305-6. author reply -6. [pmid: 12867617].
439 Kasimov RR, Mukhin AS. Current state of acute appendicitis diagnosis. Sovremennye Tehnologii v Medicine. 2013;5(4):112-6. PMID:.
440 Kaste SC. Imaging gently: a call for awareness. The Journal of the American Osteopathic Association. Mar. 2012;112(3):119-20. [pmid: 22411965].
441 Kastenberg ZJ, Hurley MP, Luan A, Vasu-Devan V, Spain DA, Owens DK, Goldhaber-Fiebert JD. Cost-effectiveness of preoperative imaging for appendicitis after indeterminate ultrasonography in the second or third trimester of pregnancy. [pmid: 24084540].
442 Kelly ME, Winter DC. Stumped; the Achilles of laparoscopic appendectomy. [pmid: 24796315].
443 Kelso LA, Kugelmas M. Nontraumatic abdominal pain. AACN clinical issues. Aug. 1997;8(3):437-48. [pmid: 9313379].
444 Kendall JL, Blaivas M, Hoffenberg S, et al. History of emergency ultrasound. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Aug. 2004;23(8):1130-3. author reply 3–5. [pmid: 15284475].
445 Kennedy A. Assessment of acute abdominal pain in the pregnant patient. Seminars in ultrasound, CT, and MR. Feb. 2000;21(1):64-77. [pmid: 10688068].
446 Kennedy EK. Lower rates of unnecessary appendectomies. Hospital peer review. Aug. 1998;23(8):151. [pmid: 10181315].
447 Kennedy JS, Hanly EJ, Mittendorf EA. Asymptomatic appendicolithiasis: principles of evaluation and management. Current surgery. Jan–Feb. 2005;62(1):87-90. [pmid: 15708156].
448 Kerwat RM, Hardwick R. Randomized clinical trial of early laparoscopy in the management of acute non-specific abdominal pain. The British journal of surgery. Apr. 2000;87(4):523. [pmid: 10809577].
449 Khanzada Z, Lagatolla N. Comment on: The use of pre-operative computed tomography in the assessment of the acute abdomen. Annals of the Royal College of Surgeons of England. Sep. 2012;94(6):449-50. author reply 50. [pmid: 22943352].
450 Kharbanda AB. Appendicitis: Do Clinical Scores Matter?. [pmid: 24882663].
451 Kiatpongsan S, Meng L, Eisenberg JD, Herring M, Avery LL, Kong CY, Pandharipande PV. Imaging for Appendicitis: Should Radiation-induced Cancer Risks Affect Modality Selection?. Radiology. Nov. 2014;273(2):472-82. [pmid: 24988435].
452 Kiely N, Williams N. Evaluation of the modified Alvarado score in the diagnosis of acute appendicitis: a prospective study. Annals of the Royal College of Surgeons of England. Mar. 1995;77(2):157. [pmid: 7661968].
453 Kim HC, Yang DM, Jin W, et al. Added diagnostic value of multiplanar reformation of multidetector CT data in patients with suspected appendicitis. Radiographics : a review publication of the Radiological Society of North America, Inc. Mar–Apr. 2008;28(2):393-405. discussion -6. [pmid: 18349447].
454 Kim YS, Kim Y, Cho OK, et al. Sonography for right lower quadrant pain. Journal of clinical ultrasound : JCU. Mar–Apr. 2001;29(3):157-85. [pmid: 11329159].
455 Kipper SL. The role of radiolabeled leukocyte imaging in the management of patients with acute appendicitis. The quarterly journal of nuclear medicine : official publication of the Italian Association of Nuclear Medicine (AIMN) [and] the International Association of Radiopharmacology (IAR). Mar. 1999;43(1):83-92. [pmid: 10230284].
456 Kirchner SG, Horev G. Diagnostic imaging in children with acute chest and abdominal disorders. Pediatric clinics of North America. Dec. 1985;32(6):1363-82. [pmid: 3906530].
457 Kirkham SJ. Letter 2: Moving from open to laparoscopic appendicectomy (Br J Surg 2003; 90: 257–258). The British journal of surgery. Jun. 2003;90(6):760. [pmid: 12808633].
458 Kittisupamongkol W. Digital rectal examination and incision line. The American journal of emergency medicine. Feb. 2009;27(2):247. [pmid: 19371543].
459 Kittisupamongkol W. Modified Alvarado score for acute appendicitis. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Sep. 2009;11(7):788. [pmid: 19508544].
460 Kiyak G, Ozgun Y, Sarikaya SM, et al. Isolated cecal necrosis mimicking acute appendicitis. The Turkish journal of gastroenterology : the official journal of Turkish Society of Gastroenterology. Mar. 2008;19(1):71-2. [pmid: 18386246].
461 Klufio CA, Amoa AB, Rageau O. Abdominal pain in pregnancy. Papua and New Guinea medical journal. Dec. 1993;36(4):342-52. [pmid: 7941766].
462 Kocher KE, Meurer WJ, Fazel R, et al. National trends in use of computed tomography in the emergency department. Annals of emergency medicine. Nov. 2011;58(5):452-62.e3. [pmid: 21835499].
463 Kodi SR. Laparoscopic cholecystectomy and appendicectomy in situs inversus totalis. Journal of minimal access surgery. Oct. 2012;8(4):164-5. [pmid: 23248451].
464 Kohn MA. White blood cell count intervals and likelihood ratios for appendicitis. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. May. 2005;12(5):480. author reply -1. [pmid: 15860704].
465 Korner M. Preoperative abdominal CT reduces negative appendectomies. Der Radiologe. Dec. 2010;50(12):1071. [pmid: 21052619].
466 Koruda MJ. Appendicitis: laparoscopic strategy in diagnosis and treatment. North Carolina medical journal. May. 1992;53(5):196-8. [pmid: 1385645].
467 Kory LA. More on CT for suspected appendicitis. AJR American journal of roentgenology. May. 1999;172(5):1449. [pmid: 10227538].
468 Kosaka N, Sagoh T, Uematsu H, et al. Difficulties in the diagnosis of appendicitis: review of CT and US images. Emergency radiology. Oct. 2007;14(5):289-95. [pmid: 17674062].
469 Kraemer M, Ohmann C, Leppert R, et al. Macroscopic assessment of the appendix at diagnostic laparoscopy is reliable. Surgical endoscopy. Jul. 2000;14(7):625-33. [pmid: 10948298].
470 Kramer IR. Computers in clinical and laboratory diagnosis. International dental journal. Sep. 1980;30(3):214-25. [pmid: 7002806].
471 Kruis W, Morgenstern J, Schanz S. Appendicitis/diverticulitis: diagnostics and conservative treatment. Digestive diseases (Basel, Switzerland). 2013;31(1):69-75. [pmid: 23797126].
472 Kruszka PS, Kruszka SJ. Evaluation of acute pelvic pain in women. American family physician. Jul. 15. 2010;82(2):141-7. [pmid: 20642266].
473 Kuhlman JE, Fishman EK. Acute abdominal disorders in AIDS: CT evaluation. Critical reviews in diagnostic imaging. 1991;32(3):229-70. [pmid: 1930687].
474 Kumar R, Erian M, Sinnot S, et al. Laparoscopic appendectomy in modern gynecology. The Journal of the American Association of Gynecologic Laparoscopists. Aug. 2002;9(3):252-63. [pmid: 12101318].
475 Kundra V, Silverman PM. Impact of multislice CT on imaging of acute abdominal disease. Radiologic clinics of North America. Nov. 2003;41(6):1083-93. [pmid: 14661659].
476 Kupesic S, Aksamija A, Vucic N, Trepalo A, Kurjak A. Ultrasonic testing in acute pelvic pain. Acta Medica Croatica. 2002;56(4–5):171-80. PMID:. [pmid: 12768897].
477 Kwok MY, Kim MK, Gorelick MH. Evidence-based approach to the diagnosis of appendicitis in children. Pediatric emergency care. Oct. 2004;20(10):690-8. quiz 9–701. [pmid: 15454747].
478 Lai CW, Yue CT, Chen JH. Mucinous cystadenocarcinoma of the appendix mimics acute appendicitis. Clinical gastroenterology and hepatology : the official clinical practice journal of the American Gastroenterological Association. Feb. 2013;11(2):e11. [pmid: 22677573].
479 Laing FC. Ultrasonography of the acute abdomen. Radiologic clinics of North America. Mar. 1992;30(2):389-404. [pmid: 1535863].
480 Lally J. Radiograph of the month. Appendiceal perforation with appendicolith. Delaware medical journal. Oct. 1993;65(10):657-8. [pmid: 8253254].
481 Lalwani N, Dubinsky TJ. Preface. Radiologic clinics of North America. 2013;51(6):13. PMID:.
482 Lameris W, van Randen A, Dijkgraaf MG, et al. Optimization of diagnostic imaging use in patients with acute abdominal pain (OPTIMA): Design and rationale. BMC emergency medicine. 2007;7:9. [pmid: 17683592].
483 Lansdown M, Kraly Z, Milkins R, et al. Conventional versus laparoscopic surgery for acute appendicitis. The British journal of surgery. Oct. 1993;80(10):1349-50. [pmid: 8242323].
484 Lantto E. Investigation of suspected intra-abdominal sepsis: the contribution of nuclear medicine. Scandinavian journal of gastroenterology Supplement. 1994;203:11-4. [pmid: 7973441].
485 Larsson G, Weibull H, Larsson BW. Analysis of the decision-making process leading to appendectomy: a grounded theory study. Scandinavian journal of psychology. Nov. 2004;45(5):449-54. [pmid: 15535813].
486 Lassrich MA. RADIOLOGICAL EXAMINATION IN CHRONIC APPENDICITIS IN CHILDREN. Annales de radiologie. 1964;7:395-9. [pmid: 14140689].
487 Lavers GD. Observation versus operation for abdominal pain in the right lower quadrant. Roles of the clinical examination and the leukocyte count. American journal of surgery. May. 1987;153(5):448. [pmid: 3578665].
488 Lawler F. Sonography in the diagnosis of acute appendicitis. American family physician. Jun. 1992;45(6):2482. 5. [pmid: 1595503].
489 Lawrence J. Computed tomography in diagnosing suspected appendicitis. Pediatrics. May. 2001;107(5):1231. [pmid: 11388319].
490 Lazzaron AR, Marques de Souza R. Re: Chen, SC et al.: Abdominal sonography screening of clinically diagnosed or suspected appendicitis before surgery. World J. Surg. 22:449, 1998. World journal of surgery. Apr. 1999;23(4):425-6. [pmid: 10030868].
491 LeBedis CA, Penn, David R, Broder Jennifer C, Gupta Avneesh, Tkacz Jaroslaw N, Soto Jorge A. Current applications of MRI in emergent gastrointestinal diseases. Applied Radiology. 2012;41(11):9-15. Language: English. Entry Date: 20130104. Publication Type: journal article.
492 Lee DW, Chan AC. Visualisation of the peritoneum during endoscopic retrograde cholangiopancreatography. Hong Kong medical journal/Hong Kong Academy of Medicine. Xianggang yi xue za zhi. Dec. 2001;7(4):445-6. [pmid: 11773684].
493 Lee SL, Ho HS. Ultrasonography and computed tomography in suspected acute appendicitis. Seminars in ultrasound, CT, and MR. Apr. 2003;24(2):69-73. [pmid: 12744498].
494 Leeuwenburgh MM, Lameris W, van Randen A, et al. Optimizing imaging in suspected appendicitis (OPTIMAP-study): a multicenter diagnostic accuracy study of MRI in patients with suspected acute appendicitis. Study Protocol. BMC emergency medicine. 2010;10:19. [pmid: 20961412].
495 Leppaniemi A. Acute appendicitis--we thought we knew it all?. [pmid: 24667394].
496 Letter: Acute abdomen in childhood. Lancet. Feb. 7. 1976;1(7954):299-300. [pmid: 55605].
497 LeuTech. BioDrugs : clinical immunotherapeutics, biopharmaceuticals and gene therapy. 2002;16(4):319-20. [pmid: 12196046].
498 LeuTech. Drugs in R&D. 2002;3(2):130-1. [pmid: 12001817].
499 Levine D. Obstetric MRI. Journal of magnetic resonance imaging : JMRI. Jul. 2006;24(1):1-15. [pmid: 16736491].
500 Levine G. Indium 111 imaging in appendicitis. Seminars in ultrasound, CT, and MR. Feb. 1990;11(1):1. [pmid: 2331393].
501 Levine MS. Plain film diagnosis of the acute abdomen. Emergency medicine clinics of North America. Aug. 1985;3(3):541-62. [pmid: 3893981].
502 Leyendecker JR, Gorengaut V, Brown JJ. MR imaging of maternal diseases of the abdomen and pelvis during pregnancy and the immediate postpartum period. Radiographics : a review publication of the Radiological Society of North America, Inc. Sep–Oct. 2004;24(5):1301-16. [pmid: 15371610].
503 Liang MK. The art and science of diagnosing acute appendicitis. Southern medical journal. Dec. 2005;98(12):1159-60. [pmid: 16440911].
504 Linam LE, Munden M. Sonography as the first line of evaluation in children with suspected acute appendicitis. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Aug. 2012;31(8):1153-7. [pmid: 22837278].
505 Liu Z, Lu Y. Feasibility of the laparoscopic appendicitis score. [pmid: 23982643].
506 Lobe TE. Acute abdomen. The role of laparoscopy. Seminars in pediatric surgery. May. 1997;6(2):81-7. [pmid: 9159858].
507 Locey M. Ultrasonography in the diagnosis of appendicitis. Southern medical journal. Aug. 1988;81(8):1071-2. [pmid: 3043689].
508 Loefler IJ. Laparoscopic appendicectomy. East African medical journal. Sep. 2003;80(9):445-6. [pmid: 14640163].
509 Lomax D. Laparoscopic appendicectomy. Lancet. Nov. 13. 1993;342(8881):1247. [pmid: 7901571].
510 Long SS, Long C, Lai H, et al. Imaging strategies for right lower quadrant pain in pregnancy. AJR American journal of roentgenology. Jan. 2011;196(1):4-12. [pmid: 21178041].
511 Lopez PP, Cohn SM. CT scanning in the management of acute appendicitis. Journal of the American College of Surgeons. Oct. 2010;211(4):567. author reply. [pmid: 20868979].
512 Loughborough W. Development of a plain radiograph requesting algorithm for patients presenting with acute abdominal pain. Quantitative imaging in medicine and surgery. Dec. 2012;2(4):239-44. [pmid: 23289083].
513 Love C, Tronco GG, Palestro CJ. Imaging of infection and inflammation with 99mTc-Fanolesomab. The quarterly journal of nuclear medicine and molecular imaging : official publication of the Italian Association of Nuclear Medicine (AIMN) [and] the International Association of Radiopharmacology (IAR), [and] Section of the So. Jun. 2006;50(2):113-20. [pmid: 16770301].
514 Lowe LH, Perez R Jr, Scheker LE, et al. Appendicitis and alternate diagnoses in children: findings on unenhanced limited helical CT. Pediatric radiology. Aug. 2001;31(8):569-77. [pmid: 11550769].
515 Lubarsky M, Kalb B, Sharma P, et al. MR imaging for acute nontraumatic abdominopelvic pain: rationale and practical considerations. Radiographics : a review publication of the Radiological Society of North America, Inc. Mar–Apr. 2013;33(2):313-37. [pmid: 23479698].
516 Lubat E, Balthazar EJ. The current role of computerized tomography in inflammatory disease of the bowel. The American journal of gastroenterology. Feb. 1988;83(2):107-13. [pmid: 3277394].
517 Lutwak N. CT scans in diagnosing diverticulitis in the emergency department: Is the radiation exposure warranted?. [pmid: 22228168].
518 Lyon C, Clark DC. Diagnosis of acute abdominal pain in older patients. American family physician. Nov. 1. 2006;74(9):1537-44. [pmid: 17111893].
519 Coppolino FF, Gatta G, Di Grezia G, Reginelli A, Iacobellis F, Vallone G, Giganti M, Genovese EA. Gastrointestinal perforation: Ultrasonographic diagnosis. [pmid: 23902744].
520 Maa J. Appendicitis: The great masquerader. [pmid: 23090201].
521 Macaluso CR, McNamara RM. Evaluation and management of acute abdominal pain in the emergency department. Int J Gen Med. 2012;5:789-97. [pmid: 23055768].
522 Macari M, Balthazar EJ. The acute right lower quadrant: CT evaluation. Radiologic clinics of North America. Nov. 2003;41(6):1117-36. [pmid: 14661661].
523 Macfarlane R, Pollard S. The use of laparoscopy in the management of right iliac fossa pain. Annals of the Royal College of Surgeons of England. Jan. 1987;69(1):40. [pmid: 2952044].
524 MacFayden BV Jr, Wolfe BM, McKernan JB. Laparoscopic management of the acute abdomen, appendix, and small and large bowel. The Surgical clinics of North America. Oct. 1992;72(5):1169-83. [pmid: 1388304].
525 Macias CG, Sahouria JJ. The appropriate use of CT: quality improvement and clinical decision-making in pediatric emergency medicine. Pediatric radiology. Sep. Suppl 2. 2011;41:498-504. [pmid: 21847729].
526 MacPherson N, Gani J. White cell count and appendicitis: the missing link. ANZ journal of surgery. Nov. 2003;73(11):963. [pmid: 14616580].
527 Madonna MB, Boswell WC, Arensman RM. Acute abdomen. Outcomes. Seminars in pediatric surgery. May. 1997;6(2):105-11. [pmid: 9159862].
528 Mahomed AA. Re: Should the macroscopically normal appendix be removed during laparoscopy for acute right iliac fossa pain when no other explanatory pathology is found?. Surgical laparoscopy, endoscopy & percutaneous techniques. Oct. 2009;19(5):395. discussion 6. [pmid: 19851268].
529 Makanjuola D, Al-Qasabi Q, Malabarey T. A comparative ultrasound and plain abdominal x-ray: Evaluation of non-classical clinical cases of appendicitis. Annals of Saudi medicine. Jan. 1993;13(1):41-6. [pmid: 17587990].
530 Makay B, Makay O, Unsal E. Can we use faecal calprotectin to distinguish abdominal pain of familial Mediterranean fever (FMF) from acute appendicitis?. Clinical rheumatology. Feb. 2009;28(2):239-40. [pmid: 19031094].
531 Malik Ali I, Tou Samson, Nelson Richard L. Early laparoscopy versus observation for patients with acute abdominal pain. Cochrane Database of Systematic Reviews [serial on the Internet]. 2009;(4). Available from: http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD008035/abstract. Last accessed.
532 Malone AJ, Shetty MR. Diagnosis of appendicitis. Lancet. Jun. 14. 1997;349(9067):1774. [pmid: 9193407].
533 Malone AJ. Unenhanced CT in the evaluation of the acute abdomen: the community hospital experience. Seminars in ultrasound, CT, and MR. Apr. 1999;20(2):68-76. [pmid: 10222515].
534 Manson WG, Reed MW, Phillips WS. Emergency laparoscopic surgery. The British journal of surgery. Sep. 1993;80(9):1212. [pmid: 8402134].
535 Marincek B. Nontraumatic abdominal emergencies: acute abdominal pain: diagnostic strategies. European radiology. Sep. 2002;12(9):2136-50. [pmid: 12195463].
536 Markar, Blackburn S, Cobb R, Karthikesalingam A, Evans J, Kinross J, Faiz O. Laparoscopic versus open appendectomy for complicated and uncomplicated appendicitis in children (Provisional abstract). [pmid: 22810297].
537 Masselli G, Brunelli R, Monti R, Guida M, Laghi F, Casciani E, Polettini E, Gualdi G. Utility of immature granulocyte percentage in pediatric appendicitis. [pmid: 24535757].
538 Matson DD, Tachdjian MO. INTRASPINAL TUMORS IN INFANTS AND CHILDREN; REVIEW OF 115 CASES. Postgraduate medicine. Sep. 1963;34:279-85. [pmid: 14045787].
539 Maturen KE, Wasnik AP, Kamaya A, et al. Ultrasound imaging of bowel pathology: technique and keys to diagnosis in the acute abdomen. AJR American journal of roentgenology. Dec. 2011;197(6):W1067-75. [pmid: 22109321].
540 Mavrogenis G, Delvaux M, Gay G, Doffoël M. An unusual cause of abdominal pain. Acta Gastroenterol Belg. Jun. 2013;76(2):261. [pmid: 23898569].
541 Maxfield CM, Bayindir P. Fat-containing lesions revealed by CT in children with right lower quadrant pain. Pediatric radiology. Apr. 2009;39(4):371-6. [pmid: 19142630].
542 Mayo SC, Pawlik TM. Propensity score methods: setting the score straight. Archives of surgery (Chicago, Ill : 1960). Jul. 2011;146(7):887-8. author reply 8–9. [pmid: 21768443].
543 Mazlam MZ, Hodgson HJ. Why measure C reactive protein?. Gut. Jan. 1994;35(1):5-7. [pmid: 8307448].
544 Mazzei MA, Guerrini S, Cioffi Squitieri N, Cagini L, Macarini L, Coppolino F, Giganti M, Volterrani L. The role of US examination in the management of acute abdomen. [pmid: 23902801].
545 Mc Anena OJ, Austin O, Hederman WP, et al. Laparoscopic versus open appendicectomy. Lancet. Sep. 14. 1991;338(8768):693. [pmid: 1679490].
546 McAnena OJ, Boyle TJ. Laparoscopic Appendicectomy. Seminars in laparoscopic surgery. Dec. 1995;2(4):252-61. [pmid: 10401092].
547 McAnena OJ, Willson PD. Laparoscopic appendicectomy: diagnosis and resection of acute and perforated appendices. Bailliere’s clinical gastroenterology. Dec. 1993;7(4):851-66. [pmid: 8118077].
548 McCartan D, Fleming FJ, Grace PA. Perforated appendicitis: does rural residency really explain the delay?. Ann Surg. Apr. 2014;259(4):e58. [pmid: 24608400].
549 McClure DN, Kiroff GK. Laparoscopic surgery in women with a clinical diagnosis of acute appendicitis. The Medical journal of Australia. May. 1. 1995;162(9):503-4. [pmid: 7746218].
550 McClure MJ, Khalili K, Sarrazin J, et al. Radiological features of epiploic appendagitis and segmental omental infarction. Clinical radiology. Oct. 2001;56(10):819-27. [pmid: 11895298].
551 McColl I. More precision in diagnosing appendicitis. The New England journal of medicine. Jan. 15. 1998;338(3):190-1. [pmid: 9428821].
552 McCollough M, Sharieff GQ. Abdominal pain in children. Pediatric clinics of North America. Feb. 2006;53(1):107-37. vi. [pmid: 16487787].
553 McGowan DR, Sims HM, Shaikh I, et al. The value of hyperbilirubinaemia in the diagnosis of acute appendicitis. Annals of the Royal College of Surgeons of England. Sep. 2011;93(6):498. [pmid: 21929944].
554 McIntire MS, Jahr HM. The leukocyte count: significance in children with abdominal pain. The Nebraska state medical journal. Jan. 1956;41(1):8-10. [pmid: 13279954].
555 McLoughlin RF, Mathieson JR. Imaging and intervention in abdominal emergencies. Bailliere’s clinical gastroenterology. Mar. 1995;9(1):1-19. [pmid: 7772809].
556 McLure H. Insights into development, innovation and interpretation of data. Trends in Anaesthesia and Critical Care. 2013;3(2):55. PMID:.
557 McSherry D. Avoiding premature closure in sequential diagnosis. Artificial intelligence in medicine. Jul. 1997;10(3):269-83. [pmid: 9232189].
558 Meakins JL. Appendectomy and appendicitis. Canadian journal of surgery Journal canadien de chirurgie. Apr. 1999;42(2):90. [pmid: 10223068].
559 Meer J, Beck S, Ali K. Symptom-based ultrasonography. Ultrasound Clinics. 2014;9(2):227-46. PMID:.
560 Meinke AK. Review article: appendicitis in groin hernias. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Oct. 2007;11(10):1368-72. [pmid: 17394046].
561 Mellado JM, Martín J, Solanas S, Yanguas N, Salceda J, Cozcolluela MR. Uncommon Causes of Acute Abdominal Pain: Multidetector Computed Tomography Pearls and Pitfalls for the Radiologist on Call. Curr Probl Diagn Radiol. Sep–Oct. 2012;41(5):179-88. [pmid: 22818838].
562 Memon S, Frye JN. Current application of diagnostic laparoscopy in suspected appendicitis and laparoscopic appendicectomy. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. Nov. 2010;12(11):1165. [pmid: 19906062].
563 Meradji M, Van Herreweghe W. The plain film of the acute abdomen in the neonate and infant. Journal belge de radiologie. 1980;63(1):33-42. [pmid: 7430058].
564 Merten DF. The acute abdomen in childhood. Current problems in diagnostic radiology. Nov–Dec. 1986;15(6):333-425. [pmid: 3829706].
565 Meshikhes AW. Management of appendiceal mass: controversial issues revisited. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Apr. 2008;12(4):767-75. [pmid: 17999120].
566 Meyers AB, Deshmukh T, Boyd KP. Comments and question regarding ‘Beyond acute appendicitis: imaging of additional pathologies of the pediatric appendix’. [pmid: 23703226].
567 Mindelzun RE, Jeffrey RB. The acute abdomen: current CT imaging techniques. Seminars in ultrasound, CT, and MR. Apr. 1999;20(2):63-7. [pmid: 10222514].
568 Mindelzun RE, Jeffrey RB. Unenhanced helical CT for evaluating acute abdominal pain: a little more cost, a lot more information. Radiology. Oct. 1997;205(1):43-5. [pmid: 9314959].
569 Moghadam-Kia S, Nawaz A, Newberg A, et al. Utility of 18F-FDG-PET/CT imaging in the diagnosis of appendicitis. Hellenic journal of nuclear medicine. Sep–Dec. 2009;12(3):281-2. [pmid: 19936346].
570 Mohamed F, Khoo KK. Acute appendicitis: leaving normal looking appendices. BMJ (Clinical research ed). Sep. 23. 2006;333(7569):652. [pmid: 16990329].
571 Moir CR. Abdominal pain in infants and children. Mayo Clinic proceedings. Oct. 1996;71(10):984-9. quiz 9. [pmid: 8820774].
572 Montgomery DF, Hormann MD. Acute abdominal pain: a challenge for the practitioner. Journal of pediatric health care : official publication of National Association of Pediatric Nurse Associates & Practitioners. May–Jun. 1998;12(3):157-9. [pmid: 9652286].
573 Moodley K, Wyatt, Jonathan. Highlights from the literature. Emergency medicine journal. 2012;29(8):690. Language: English. Entry Date: 20121012. Revision Date: 20130802. Publication Type: journal article. Journal Subset: Allied Health.
574 Moore L, Wilson SR. Ultrasonography in obstetric and gynecologic emergencies. Radiologic clinics of North America. Sep. 1994;32(5):1005-22. [pmid: 8084996].
575 Morgan Bates K, Bevan KE. Lower gastrointestinal emergencies and appendicitis. Surgery (United Kingdom). 2013;31(11):552-61. PMID:.
576 Hayakawa K, Tanikake M, Yoshida S, Urata Y, Inada Y, Narumi Y, Yamamoto E, Morimoto T. Radiological diagnosis of large-bowel obstruction: Nonneoplastic etiology. [pmid: 22744438].
577 Morin MJ. Diagnosing acute appendicitis in adults. AJR American journal of roentgenology. Dec. 2008;191(6):W315. author reply W6. [pmid: 19020223].
578 Morrison I. Interpreting a radiograph of the abdomen 2. Surgery. 2008;26(6):250-4.
579 Mosteller F. Dilemmas in the concept of unnecessary surgery. The Journal of surgical research. Sep. 1978;25(3):185-92. [pmid: 100658].
580 Moustafa MH, Kare J. Computed tomography of the appendix. The New England journal of medicine. Jun. 18. 1998;338(25):1847-8. [pmid: 9634363].
581 Moyes RB. Fluorescent staining of bacteria: viability and antibody labeling. Current protocols in microbiology. 2009. Nov. Appendix 3:Appendix 3K. [pmid: 19885938].
582 Mullins ME, Rhea JT, Novelline RA. Review of suspected acute appendicitis in adults and children using CT and colonic contrast material. Seminars in ultrasound, CT, and MR. Apr. 2003;24(2):107-13. [pmid: 12744504].
583 Murtagh J. Acute abdominal pain: a diagnostic approach. Australian family physician. Mar. 1994;23(3):358-61. 64. 74. [pmid: 8048870].
584 Muscari ME, Milks CJ. Assessing acute abdominal pain in adolescent females. Pediatric nursing. May–Jun. 1995;21(3):215-20. [pmid: 7792102].
585 Musielak M, Patel H, Fegelman E. Postcolonoscopy appendicitis: laparoscopy a viable option. The American surgeon. Nov. 2012;78(11):1300-3. [pmid: 23089454].
586 Musselman RC, Nunnelee JD, Ware DB. Appendicitis during pregnancy. Clinical excellence for nurse practitioners : the international journal of NPACE. Nov. 1998;2(6):338-42. [pmid: 12596836].
587 Mutter D, Marescaux J. Appendicitis/diverticulitis: minimally invasive surgery. Digestive diseases (Basel, Switzerland). 2013;31(1):76-82. [pmid: 23797127].
588 Nair U. Acute abdomen and abdominal pain in pregnancy. Current Obstetrics and Gynaecology. 2003;13(1):14-20. PMID:.
589 Naoum JJ. Do all patients with suspected appendicitis benefit from CT imaging in community-based emergency departments?. Southern medical journal. Dec. 2005;98(12):1157-8. [pmid: 16440910].
590 Navarro D, Weber PM. Inflammation imaging. Journal of nuclear medicine : official publication, Society of Nuclear Medicine. Oct. 1990;31(10):1746-7. [pmid: 2278572].
591 Navez B, Therasse A. Should every patient undergoing laparoscopy for clinical diagnosis of appendicitis have an appendicectomy?. Acta chirurgica Belgica. Feb. 2003;103(1):87-9. [pmid: 12658883].
592 Neblett WW 3rd, Pietsch JB, Holcomb GW Jr. Acute abdominal conditions in children and adolescents. The Surgical clinics of North America. Apr. 1988;68(2):415-30. [pmid: 3279555].
593 Neilan KH. Why won’t they help my patient?. Medical economics. Apr. 9. 2004;81(7):51-4. 7. 8. [pmid: 15124299].
594 Neugebauer E. Resolution of problem needed. American journal of surgery. Jun. 1999;177(6):525. [pmid: 10414707].
595 Neugebauer EA, Sauerland S. Guidelines for emergency laparoscopy. World journal of emergency surgery : WJES. 2006;1(1):31. [pmid: 17052332].
596 Neville AM, Paulson EK. MDCT of acute appendicitis: value of coronal reformations. Abdominal imaging. Jan–Feb. 2009;34(1):42-8. [pmid: 18493813].
597 Newman B. Ultrasound body applications in children. Pediatric radiology. Sep. Suppl 2. 2011;41:555-61. [pmid: 21847738].
598 Ninane G, Schmitz A. Letter: Specificity of N.B.T. test. Lancet. Jul. 20. 1974;2(7873):174. [pmid: 4135570].
599 Novak RW. The beleaguered band count. Clinics in laboratory medicine. Dec. 1993;13(4):895-903. [pmid: 8313688].
600 O’Brien P, Brown W. Assessing the acute abdomen in the bariatric patient: need for improvement. Obesity surgery. Oct. 2008;18(10):1215-6. [pmid: 18633682].
601 Observatory: New Studies. MLO: Medical Laboratory Observer. 2012;44(5):6. Language: English. Entry Date: 20120727. Revision Date: 20140704. Publication Type: journal article.
602 Obuchowski NA, Goske MJ, Applegate KE. Assessing physicians’ accuracy in diagnosing paediatric patients with acute abdominal pain: measuring accuracy for multiple diseases. Statistics in medicine. Nov. 15. 2001;20(21):3261-78. [pmid: 11746317].
603 Ochsner SF, Watson JD. Radiologic evaluation of early postoperative abdominal complaints. Southern medical journal. Nov. 1965;58(11):1439-46. [pmid: 5294404].
604 Oestreich A, Levine C, Gaylord G. Radiology pitfalls in the use of barium enema in pediatric appendicitis. European journal of radiology. Nov. 1981;1(4):322-5. [pmid: 7346279].
605 Old JL, Dusing RW, Yap W, et al. Imaging for suspected appendicitis. American family physician. Jan. 1. 2005;71(1):71-8. [pmid: 15663029].
606 O’Leary DP, Redmond HP, Andrews EJ. Low-dose abdominal CT for diagnosing appendicitis. The New England journal of medicine. Aug. 2. 2012;367(5):478. author reply -9. [pmid: 22853027].
607 Olive ST, Kiser WR. Diagnosis of appendicitis. The Journal of the American Board of Family Practice/American Board of Family Practice. Jul–Aug. 1996;9(4):306-7. [pmid: 8829085].
608 O’Malley ME, Wilson SR. Ultrasonography and computed tomography of appendicitis and diverticulitis. Seminars in roentgenology. Apr. 2001;36(2):138-47. [pmid: 11329656].
609 O’Malley ME, Wilson SR. US of gastrointestinal tract abnormalities with CT correlation. Radiographics : a review publication of the Radiological Society of North America, Inc. Jan–Feb. 2003;23(1):59-72. [pmid: 12533641].
610 Osborne SF. Medical diagnosis aboard submarines. Use of a computer-based Bayesian method of analysis in an abdominal pain diagnostic program. Journal of occupational medicine : official publication of the Industrial Medical Association. Feb. 1984;26(2):110-4. [pmid: 6368770].
611 Oyen WJ, Boerman OC, Corstens FH. Imaging acute appendicitis: an opportunity for nuclear medicine in the surgical emergency room. Journal of nuclear medicine : official publication, Society of Nuclear Medicine. Mar. 2000;41(3):456-8. [pmid: 10716318].
612 Panebianco NL, Jahnes K, Mills AM. Imaging and laboratory testing in acute abdominal pain. Emergency medicine clinics of North America. May. 2011;29(2):175-93. vii. [pmid: 21515175].
613 Panesar K. Antibiotic therapy for appendicitis in children. 2013:HS14-HS20.
614 Park NH, Oh HE, Park HJ, et al. Ultrasonography of normal and abnormal appendix in children. World journal of radiology. Apr. 28. 2011;3(4):85-91. [pmid: 21532869].
615 Park SH, Kim YH, Lee KH. The authors reply. New England Journal of Medicine. 2012;367(5):478-9. PMID:. [pmid: 22853027].
616 Parker L, Nazarian LN, Gingold EL, Palit CD, Hoey CL, Frangos AJ. Cost and radiation savings of partial substitution of ultrasound for CT in appendicitis evaluation: a national projection. [pmid: 24370137].
617 Parker SJ. Randomized clinical trial of early laparoscopy in the management of acute non-specific abdominal pain. The British journal of surgery. Apr. 2000;87(4):522-3. [pmid: 10809576].
618 Parker SJ. Would measurement of C-reactive protein reduce the rate of negative exploration for acute appendicitis?. Journal of the Royal College of Surgeons of Edinburgh. Jun. 2000;45(3):202. author reply 3. [pmid: 10881493].
619 Parks NA, Schroeppel TJ. Update on imaging for acute appendicitis. The Surgical clinics of North America. Feb. 2011;91(1):141-54. [pmid: 21184905].
620 Pasero C. Pain in the emergency department. The American journal of nursing. Jul. 2003;103(7):73-4. [pmid: 12865646].
621 Paterson HM, Qadan M, De Luca SM, et al. Authors’ reply: Changing trends in surgery for acute appendicitis (Br J Surg 2008; 95: 363–368). British Journal of Surgery. 2008;95(6):801.
622 Paterson-Brown S, Thompson JN. Non-specific abdominal pain: the resource implications. Annals of the Royal College of Surgeons of England. Sep. 1992;74(5):375. [pmid: 1416718].
623 Paterson-Brown S, Vipond MN. Modern aids to clinical decision-making in the acute abdomen. The British journal of surgery. Jan. 1990;77(1):13-8. [pmid: 2137357].
624 Paterson-Brown S. Emergency laparoscopic surgery. The British journal of surgery. Mar. 1993;80(3):279-83. [pmid: 8472132].
625 Paterson-Brown S. Strategies for reducing inappropriate laparotomy rate in the acute abdomen. BMJ (Clinical research ed). Nov. 2. 1991;303(6810):1115-8. [pmid: 1836146].
626 Paulman AA, Huebner DM, Forrest TS. Sonography in the diagnosis of acute appendicitis. American family physician. Aug. 1991;44(2):465-8. [pmid: 1858603].
627 Paulson EC. Value of the flat plate (x-ray) in diagnosis of acute abdominal conditions. Minnesota medicine. Sep. 1952;35(9):870-1. [pmid: 13002203].
628 Paulson EK, Coursey CA. CT protocols for acute appendicitis: time for change. AJR American journal of roentgenology. Nov. 2009;193(5):1268-71. [pmid: 19843740].
629 Paulson EK, Jaffe TA, Thomas J, et al. MDCT of patients with acute abdominal pain: a new perspective using coronal reformations from submillimeter isotropic voxels. AJR American journal of roentgenology. Oct. 2004;183(4):899-906. [pmid: 15385279].
630 Pavan MV, Mehta G, Thillainayagam AV. The clinical evaluation of abdominal pain in adults. Medicine. 2009;37(1):11-6. PMID:.
631 Payne SP, Gray DW. Role of sequential leucocyte counts and C-reactive protein measurements in acute appendicitis. The British journal of surgery. Mar. 1993;80(3):400. [pmid: 8472167].
632 Pearl RH, Irish MS, Caty MG, et al. The approach to common abdominal diagnoses in infants and children. Part II. Pediatric clinics of North America. Dec. 1998;45(6):1287-326. vii. [pmid: 9889755].
633 Pearson G, Eckford S, Cahill D. Should Gynaecologists perform female appendicetomy? PIDEENA - A study protocol. BJOG: An International Journal of Obstetrics and Gynaecology. 2012;119:130.
634 Pearson RH. Ultrasonography for diagnosing appendicitis. BMJ (Clinical research ed). Jul. 30. 1988;297(6644):309-10. [pmid: 3046706].
635 Pedrosa I, Zeikus EA, Levine D, et al. MR imaging of acute right lower quadrant pain in pregnant and nonpregnant patients. Radiographics : a review publication of the Radiological Society of North America, Inc. May–Jun. 2007;27(3):721-43. discussion 43–53. [pmid: 17495289].
636 Pelosi M, Pelosi M 3rd. Laparoscopic and open appendectomies. Surgical laparoscopy & endoscopy. Dec. 1995;5(6):492-3. [pmid: 8612001].
637 Pelosi MA, Pelosi MA 3rd. Laparoscopic appendectomy. Journal of laparoendoscopic surgery. Dec. 1995;5(6):419-21. [pmid: 8746997].
638 Pender N. CT Scans in the Diagnosis of Appendicitis. The virtual mentor : VM. 2006;8(3):154-6. [pmid: 23232347].
639 Pepper, Stanfill, Pearl. Diagnosis and management of pediatric appendicitis, intussusception, and meckel diverticulum. [pmid: 22595706].
640 Pereira JM, Sirlin CB, Pinto PS, et al. Disproportionate fat stranding: a helpful CT sign in patients with acute abdominal pain. Radiographics : a review publication of the Radiological Society of North America, Inc. May–Jun. 2004;24(3):703-15. [pmid: 15143223].
641 Perlmutter N. Pediatric gastrointestinal imaging. Current opinion in radiology. Dec. 1990;2(6):895-8. [pmid: 2282265].
642 Perry EP, Rhodes A. Which patients should undergo laparoscopy?. BMJ (Clinical research ed). Aug. 6. 1988;297(6645):423-4. [pmid: 2970275].
643 Peter DJ, Hedges JR, Radack KL. A scoring system for appendicitis and the likelihood ratio. Annals of emergency medicine. May. 1987;16(5):603-5. [pmid: 3565881].
644 Petroianu A. Diagnosis of acute appendicitis. International journal of surgery (London, England). 2012;10(3):115-9. [pmid: 22349155].
645 Petroianu A. Diagnosis of acute appendicitis. International Journal of Surgery. 2012;10(3):115-9. PMID:. [pmid: 22349155].
646 Petty W. The enemy is “us”!. The Pharos of Alpha Omega Alpha-Honor Medical Society Alpha Omega Alpha. Winter. 1995;58(1):40. [pmid: 7886142].
647 Pfadt E, Carlson DS. Acute appendicitis. Nursing. Dec. 2009;39(12):72. [pmid: 19934751].
648 Phillips SL, Burns GP. Acute abdominal disease in the aged. The Medical clinics of North America. Sep. 1988;72(5):1213-24. [pmid: 3045455].
649 Piccinni G1, Sciusco A, Gurrado A, Lissidini G, Testini M. Authors’ reply. J Minim Access Surg. Jan. 2013;9(1):46-7. [pmid: 23626424].
650 Pinto F, Pinto A, Russo A, Coppolino F, Bracale R, Fonio P, Macarini L, Giganti M. Accuracy of ultrasonography in the diagnosis of acute appendicitis in adult patients: review of the literature. Crit Ultrasound J. Jul. 15. Suppl 1. 2013;5:S2. [pmid: 23902717].
651 Pinto Leite N, Pereira JM, Cunha R, et al. CT evaluation of appendicitis and its complications: imaging techniques and key diagnostic findings. AJR American journal of roentgenology. Aug. 2005;185(2):406-17. [pmid: 16037513].
652 Pisarra VH. Recognizing the various presentations of appendicitis. The Nurse practitioner. Aug. 4. 9. 52. 1999;24(8):42-3. quiz 4–5. [pmid: 10479109].
653 Pisarra VH. Recognizing the various presentations of appendicitis. Dimensions of critical care nursing : DCCN. May–Jun. 2001;20(3):24-7. [pmid: 22076394].
654 Pitcher R, McKenzie C. Simultaneous ultrasound identification of acute appendicitis, septic thrombophlebitis of the portal vein and pyogenic liver abscess. South African medical journal. Suid-Afrikaanse tydskrif vir geneeskunde. Jun. 2003;93(6):426-8. [pmid: 12916378].
655 Pomp A. Laparoscopy and acute appendicitis. Canadian journal of surgery Journal canadien de chirurgie. Oct. 1999;42(5):326-7. [pmid: 10526511].
656 Poortman P, Hamming JF. Prospective trial of computed tomography and ultrasonography for diagnosing appendicitis in the atypical patient. American journal of surgery. Sep. 2001;182(3):305-6. [pmid: 11669077].
657 Poulin EC, Schlachta CM, Mamazza J. Early laparoscopy to help diagnose acute non-specific abdominal pain. Lancet. Mar. 11. 2000;355(9207):861-3. [pmid: 10752698].
658 Pregnant patient at risk for unnecessary appendectomy. Hospital case management : the monthly update on hospital-based care planning and critical paths. Mar. 2008;16(3):46-8. [pmid: 18383916].
659 Prosenz J, Hirtler L. Rovsing Sign Revisited-Effects of an Erroneous Translation on Medical Teaching and Research. [pmid: 24776856].
660 Prystowsky JB, Pugh CM, Nagle AP. Current problems in surgery. Appendicitis. Current problems in surgery. Oct. 2005;42(10):688-742. [pmid: 16198668].
661 Purkayastha S, Purkayastha S, Paraskevas P. Acute appendicitis: weighing up risks and benefits of investigations and treatments. BMJ (Clinical research ed). Sep. 23. 2006;333(7569):652-3. [pmid: 16990328].
662 Purysko AS, Remer EM, Filho HM, et al. Beyond appendicitis: common and uncommon gastrointestinal causes of right lower quadrant abdominal pain at multidetector CT. Radiographics : a review publication of the Radiological Society of North America, Inc. Jul–Aug. 2011;31(4):927-47. [pmid: 21768232].
663 Puylaert J. Acute appendicitis. Clinics in diagnostic ultrasound. 1994;29:75-91. [pmid: 7811526].
664 Puylaert JB, Rijke AM. An inflamed appendix at sonography when symptoms are improving: to operate or not to operate?. Radiology. Oct. 1997;205(1):41-2. [pmid: 9314958].
665 Puylaert JB, van der Zant FM, Rijke AM. Sonography and the acute abdomen: practical considerations. AJR American journal of roentgenology. Jan. 1997;168(1):179-86. [pmid: 8976943].
666 Puylaert JB, van der Zant FM. Mesenteric lymphadenitis or appendicitis?. AJR American journal of roentgenology. Aug. 1995;165(2):490. [pmid: 7618596].
667 Puylaert JB. Transvaginal sonography for diagnosis of appendicitis. AJR American journal of roentgenology. Sep. 1994;163(3):746. [pmid: 8079890].
668 Puylaert JB. Ultrasonography for diagnosing appendicitis. BMJ (Clinical research ed). Sep. 17. 1988;297(6650):740. [pmid: 3147754].
669 Puylaert JB. Ultrasonography of the acute abdomen: gastrointestinal conditions. Radiologic clinics of North America. Nov. 2003;41(6):1227-42. vii. [pmid: 14661668].
670 Puylaert JB. Ultrasonography of the acute abdomen: lost art or future stethoscope?. European radiology. Jun. 2003;13(6):1203-6. [pmid: 12846253].
671 Puylaert JB. US of appendicitis and diverticulitis. JBR-BTR : organe de la Societe royale belge de radiologie (SRBR) = orgaan van de Koninklijke Belgische Vereniging voor Radiologie (KBVR). 2012;95(6):392-3. PMID:.
672 Puylaert JB. US of appendicitis and diverticulitis. JBR-BTR : organe de la Societe royale belge de radiologie (SRBR) = orgaan van de Koninklijke Belgische Vereniging voor Radiologie (KBVR). 2012;95(6):392-3. PMID:.
673 Puylaert JB. US of the acute abdomen. JBR-BTR : organe de la Societe royale belge de radiologie (SRBR) = orgaan van de Koninklijke Belgische Vereniging voor Radiologie (KBVR). 2012;95(6):390. PMID:.
674 Puylaert JB. When in doubt, sound it out. Radiology. May. 1994;191(2):320-1. [pmid: 8153300].
675 Raffensperger JG. Angiographic diagnosis of acute appendicitis. The New England journal of medicine. Dec. 25. 1969;281(26):1490. [pmid: 5353322].
676 Ralls PW, Balfe DM, Bree RL, et al. Evaluation of acute right lower quadrant pain. American College of Radiology. ACR Appropriateness Criteria. Radiology. Jun. Suppl. 2000;215:159-66. [pmid: 11037421].
677 Raman SP, Fishman EK. Imaging: Multidetector CT in the diagnosis of suspected appendicitis. Nature reviews Gastroenterology & hepatology. Nov. 2011;8(11):607-9. [pmid: 21931366].
678 Ranji SR, Goldman LE, Simel DL, et al. Do opiates affect the clinical evaluation of patients with acute abdominal pain?. JAMA : the journal of the American Medical Association. Oct. 11. 2006;296(14):1764-74. [pmid: 17032990].
679 Rao PM, Mueller PR. Clinical and pathologic variants of appendiceal disease: CT features. AJR American journal of roentgenology. May. 1998;170(5):1335-40. [pmid: 9574612].
680 Rao PM, Rhea JT, Novelline RA. Helical CT of appendicitis and diverticulitis. Radiologic clinics of North America. Sep. 1999;37(5):895-910. [pmid: 10494277].
681 Rao PM. CT for suspected appendicitis. AJR American journal of roentgenology. May. 1999;172(5):1447-8. [pmid: 10227536].
682 Rao PM. CT of diverticulitis and alternative conditions. Seminars in ultrasound, CT, and MR. Apr. 1999;20(2):86-93. [pmid: 10222517].
683 Rao PM. Helical appendiceal CT. AJR American journal of roentgenology. Jan. 1999;172(1):243-4. [pmid: 9888779].
684 Rao PM. Nonenhanced CT for suspected appendicitis. Radiology. Sep. 2000;216(3):916. [pmid: 10966733].
685 Rao PM. Technical and interpretative pitfalls of appendiceal CT imaging. AJR American journal of roentgenology. Aug. 1998;171(2):419-25. [pmid: 9694467].
686 Raposo Rodriguez L, Anes Gonzalez G, Garcia Hernandez JB, et al. Usefulness of ultrasonography in children with right iliac fossa pain. Radiologia. Mar–Apr. 2012;54(2):137-48. [pmid: 22195569].
687 Rapp CL, Stavros AT, Meyers PR. Ultrasound of the normal appendix: the how and why. Journal of Diagnostic Medical Sonography. 1998;14(5):195. Language: English. Entry Date: 19990101. Revision Date: 20091218. Publication Type: journal article.
688 Rasmussen OO, Hoffmann J. Assessment of the reliability of the symptoms and signs of acute appendicitis. Journal of the Royal College of Surgeons of Edinburgh. Dec. 1991;36(6):372-7. [pmid: 1774704].
689 Ratliff CV, Summers S. Computerized nursing diagnosis: applications for the surgical patient. Journal of advanced medical-surgical nursing. Jun. 1989;1(3):63-72. [pmid: 2473165].
690 Raymond HW. Appendiceal imaging. Seminars in ultrasound, CT, and MR. Apr. 2003;24(2):63-4. [pmid: 12744496].
691 Razzak JA. Computed tomography and ultrasonography to detect appendicitis. Annals of internal medicine. May. 3. 2005;142(9):798. author reply 800. [pmid: 15867415].
692 Rectal examination in patients with abdominal pain. BMJ (Clinical research ed). Apr. 13. 1991;302(6781):908-9. [pmid: 2025738].
693 Reed MH. Imaging utilization commentary: a radiology perspective. Pediatric radiology. Nov. Suppl 4. 2008;38:S660-3. [pmid: 18810409].
694 Regent D, Tortuyaux JM, Bresler L, et al. Emergency computed tomography of the acute abdomen. Why? When and how to do it? Acta gastro-enterologica Belgica. Apr–Jun. 1996;59(2):137-9. [pmid: 8903059].
695 Reid SR, Losek JD. Imaging before appendectomy. Pediatrics. Dec. 2003;112(6 Pt 1):1461-2. author reply -2. [pmid: 14654636].
696 Renaud EJ. Reply. Journal of pediatric surgery. 2012;47(2):438. PMID:.
697 Rexroad JT. The CT arrowhead sign. Radiology. Apr. 2003;227(1):44-5. [pmid: 12668739].
698 Reynolds SL, Jaffe DM. Quick triage of children with abdominal pain. Emergency Medicine (00136654). 1990;22(14):39. Language: English. Entry Date: 19901101. Revision Date: 20091218. Publication Type: journal article.
699 Richardson E, Paulson CP, Hitchcock K, et al. Clinical inquiries. History, exam, and labs: is one enough to diagnose acute adult appendicitis? The Journal of family practice. Jun. 2007;56(6):474-6. [pmid: 17543259].
700 Richey RM. CT scans and appendicitis. Southern medical journal. Jun. 2006;99(6):632. [pmid: 16800425].
701 Rickes S, Ocran K, Lochs H, et al. Gastrointestinal: acute appendicitis. Journal of gastroenterology and hepatology. Oct. 2001;16(10):1165. [pmid: 11686845].
702 Rickham PP. POPR: the surgical view. Annales de radiologie. Mar–Apr. 1978;21(2–3):85-7. [pmid: 677753].
703 Riemann JF. Diagnostic laparoscopy. Endoscopy. Jan. 2003;35(1):43-7. [pmid: 12510225].
704 Ripolles T, Martinez-Perez MJ, Morote V, et al. Diseases that simulate acute appendicitis on ultrasound. The British journal of radiology. Jan. 1998;71(841):94-8. [pmid: 9534708].
705 Robertson DJ, Grimm IS. CT for appendicitis: no more surprises in the abdomen?. Gastroenterology. Dec. 1998;115(6):1596-8. [pmid: 9834294].
706 Roccarina, Garcovich M, Ainora ME, Caracciolo G, Ponziani F, Gasbarrini A, Zocco MA. Diagnosis of bowel diseases: The role of imaging and ultrasonography. [pmid: 23599640].
707 Rodgers PM, Verma R. Transabdominal ultrasound for bowel evaluation. Radiologic clinics of North America. Jan. 2013;51(1):133-48. [pmid: 23182513].
708 Rodgers PM, Verma, Ratan. Transabdominal ultrasound for bowel evaluation. Radiologic clinics of North America. 2013;51(1):133-48. Language: English. Entry Date: 20130222. Revision Date: 20130222. Publication Type: journal article. Journal Subset: Allied Health. [pmid: 23182513].
709 Roebuck DJ, Metreweli C. Radiation risk in CT for acute abdominal pain. Radiology. Oct. 1998;209(1):287-8. [pmid: 9769850].
710 Rogers LF. Alternative diagnoses: the story behind the helical CT story. AJR American journal of roentgenology. Dec. 1999;173(6):1437. [pmid: 10584777].
711 Rogers SO Jr. Equal access to health care does not eliminate disparities in the management of adults with appendicitis. The Journal of surgical research. Mar. 2012;173(1):49-50. [pmid: 21696774].
712 Rogers SO. Impact of race/ethnicity and insurance status on outcomes for appendicitis in children. The Journal of surgical research. Jun. 1. 2012;175(1):49-50. [pmid: 21920558].
713 Romero J, Sanabria A, Angarita M, et al. Cost-effectiveness of computed tomography and ultrasound in the diagnosis of appendicitis. Biomedica : revista del Instituto Nacional de Salud. Mar. 2008;28(1):139-47. [pmid: 18645669].
714 Roosinovich E, Reay-Jones N. Use of blood tests in the diagnosis of acute appendicitis. British journal of hospital medicine (London, England : 2005). Dec. 2012;73(12):C183-5. [pmid: 23519065].
715 Rosendahl K, Aukland SM, Fosse K. Imaging strategies in children with suspected appendicitis. European radiology. Mar. Suppl 4. 2004;14:L138-45. [pmid: 14752576].
716 Rosenquist CJ. The usefulness of diagnostic tests. AJR American journal of roentgenology. May. 1988;150(5):1189-90. [pmid: 3282408].
717 Rosin D. Value of laparoscopic appendectomy in the elderly. World journal of surgery. May. 2009;33(5):923-4. [pmid: 19280254].
718 Rosin RD. Editor’s perspectives - April 2014. [pmid: 24590223].
719 Ross A, LeLeiko NS. Acute abdominal pain. Pediatrics in Review. 2010;31(4):135-44. [pmid: 20360407].
720 Ross M, Thompson G. What happens to children with suspected appendicitis when the appendix cannot be visualized on ultrasound?. Canadian Journal of Emergency Medicine. 2013;15:S35.
721 Ross P. THE ACCURACY OF RADIOLOGICAL EXAMINATIONS: II. The Medical journal of Australia. Apr. 18. 1964;1:608-12. [pmid: 14142033].
722 Rothrock SG, Pagane J. Acute appendicitis in children: emergency department diagnosis and management. Annals of emergency medicine. Jul. 2000;36(1):39-51. [pmid: 10874234].
723 Rothschild JG. What alternatives has minimally invasive surgery provided the surgeon?. Archives of surgery (Chicago, Ill : 1960). Nov. 1998;133(11):1156-9. [pmid: 9820343].
724 Rowling SE, Jacobs JE, Birnbaum BA. Thin-section CT imaging of patients suspected of having appendicitis or diverticulitis. Academic radiology. Jan. 2000;7(1):48-60. [pmid: 10645459].
725 Rubin RH. In search of the hot appendix--a clinician’s view of inflammation imaging. Journal of nuclear medicine : official publication, Society of Nuclear Medicine. Mar. 1990;31(3):316-8. [pmid: 2308002].
726 Rucker CM, Menias CO, Bhalla S. Mimics of renal colic: alternative diagnoses at unenhanced helical CT. Radiographics : a review publication of the Radiological Society of North America, Inc. Oct. Suppl 1. 2004;24:S11-28. discussion S–33. [pmid: 15486235].
727 Rud B, Olafsson Lydur, Vejborg Thomas S, Wilhelmsen Michael, Reitsma Johannes B, Rappeport Eli D, Wille-Jørgensen Peer. Diagnostic accuracy of Computed Tomography for Appendicitis in Adults. Cochrane Database of Systematic Reviews [serial on the Internet]. 2012;(7). Available from: http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD009977/abstract. Last accessed.
728 Sachs CJ, Hsieh, Tiffany. Abdominal Pain: A Rational Approach, Part 2. Consultant (00107069). 2013;53(2):82-8. Language: English. Entry Date: 20130322. Revision Date: 20140613. Publication Type: journal article.
729 Sadiq A, Hershman M, Luke D, et al. Abdominal pain. BMJ (Clinical research ed). 2011;343:d4444. [pmid: 21917840].
730 Sadro CT, Dubinsky TJ. CT in pregnancy: Risks and benefits. Applied Radiology. 2013;42(10):6-16.
731 Saegesser F. The acute abdomen. Part I: Differential diagnosis. Clinics in gastroenterology. Jan. 1981;10(1):123-44. [pmid: 7249380].
732 Saha AK, Ibrahim M, Aldoori MI. Comment on: The role of the chest x-ray for the acute abdomen in the 21st century. Annals of the Royal College of Surgeons of England. May. 2011;93(4):333. [pmid: 21944814].
733 Saidi RF, Ghasemi M. Role of Alvarado score in diagnosis and treatment of suspected acute appendicitis. The American journal of emergency medicine. Mar. 2000;18(2):230-1. [pmid: 10750941].
734 Saito JM. Beyond appendicitis: evaluation and surgical treatment of pediatric acute abdominal pain. [pmid: 22450248].
735 Sallin K, Rothrock SG. Diagnosis of acute appendicitis: increasing accuracy, improving outcome, and decreasing liability. The Journal of the Florida Medical Association. 1997 Dec–1998 Jan. 84(9):543-8. [pmid: 9505474].
736 Sanabria A, Valdivieso E. Outcomes/cost effectiveness and clinical suspicion of appendicitis. Surgical infections. Summer. 2004;5(2):223-4. author reply 4–5. [pmid: 15353122].
737 Sanabria A. Improving diagnosis of acute appendicitis. Journal of the American College of Surgeons. Jun. 2009;208(6):1154. author reply -5. [pmid: 19476918].
738 Sanfilippo JS, Lobe TE. Laparoscopic surgery in girls and female adolescents. Seminars in pediatric surgery. Feb. 1998;7(1):62-72. [pmid: 9498269].
739 Sarr MG. CT scan in complicated appendicitis diagnosis: a very costly option. Digestive and liver disease : official journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. Mar. 2004;36(3):174. [pmid: 15046184].
740 Sauerland S, Neugebauer E. Laparoscopy for every acute appendicitis? The authors reply. Surgical endoscopy. Feb. 2007;21(2):342. [pmid: 17200907].
741 Sauerland S. Misdiagnosis of appendicitis. JAMA : the journal of the American Medical Association. Jan. 2. 2002;287(1):43-4. [pmid: 11754700].
742 Schatzki R, Gary JE, Schatzki S. Radiological diagnosis in acute abdominal disease of adults. The Surgical clinics of North America. Jun. 1966;46(3):513-26. [pmid: 5931804].
743 Schelleman A. Radiology quiz. Imaging appendicitis. Australian family physician. Dec. 2000;29(12):1186. 8. [pmid: 11140229].
744 Schimpl G. Appendicitis. Diagnosis and therapy 2. Padiatrische Praxis. 2012;78(2):241-7. PMID:.
745 Schizas AMP, Williams AB. Management of complex appendicitis. Surgery. 2010;28(11):544-8. PMID:.
746 Schmidt MH. Computed Tomography in Pregnant Patients. Journal of Medical Imaging and Radiation Sciences. 2009;40(3):100-4. PMID:.
747 Schneider TM, Moustafa MH, Newton E, Babb RR, Alvarado A, Hall FM, Wagner J. Does this patient have appendicitis? [1] (multiple letters). Journal of the American Medical Association. 1997;277(8):625-7. PMID:. [pmid: 9039869].
748 Schriger, Callaham, Barrett. Measuring and explaining computed tomography use in the United States and Canada: A consideration of health economics and use versus appropriateness, and interpreting potential conflict of interest: Answers to the November 2013 Journal Club Questions. [pmid: 24655448].
749 Schwartz DM. Imaging of suspected appendicitis: appropriateness of various imaging modalities. Pediatric annals. Jun. 2008;37(6):433-8. [pmid: 18616197].
750 Schwartz DT. The truth about the increase in computed tomography utilization. [pmid: 22525539].
751 Schwartz DT. Use of contrast with CT in patients suspected of having appendicitis: a contrasting opinion. Annals of emergency medicine. Oct. 2010;56(4):439-40. author reply 40–2. [pmid: 20868915].
752 Schwartz MZ, Bulas D. Acute abdomen. Laboratory evaluation and imaging. Seminars in pediatric surgery. May. 1997;6(2):65-73. [pmid: 9159856].
753 Schwartz SI. Tempering the technological diagnosis of appendicitis. The New England journal of medicine. Sep. 10. 1987;317(11):703-4. [pmid: 3306378].
754 Scott A, Mason S, Kinross J, Arunakirinathan M, Smith JJ. Evaluation of the appendicitis inflammatory response score in the management of acute appendicitis. Colorectal Disease. ((Scott A.; Mason S.; Kinross J.; Arunakirinathan M.; Smith J.J.) West Middlesex University Hospital, London, United Kingdom). 2013;15:60. PMID:.
755 See TC, Ng CS, Watson CJ, et al. Appendicitis: spectrum of appearances on helical CT. The British journal of radiology. Sep. 2002;75(897):775-81. [pmid: 12200249].
756 Selbst SM. Pediatric emergency medicine: legal briefs. Pediatr Emerg Care. Apr. 2014;30(4):279-82. [pmid: 24694887].
757 Senocak R, Mentes O. Diagnosing appendicitis at different time points in children with right lower quadrant pain: comparison between pediatric appendicitis score and the Alvarado score. World journal of surgery. Oct. 2012;36(10):2539. author reply 40. [pmid: 22543723].
758 Seow-Choen F. Randomized study of the value of laparoscopy before appendicectomy. The British journal of surgery. Jan. 1994;81(1):146. [pmid: 8313096].
759 Shademan A, Tappouni RF. Pitfalls in CT diagnosis of appendicitis: Pictorial essay. J Med Imaging Radiat Oncol. Jun. 2013;57(3):329-36. [pmid: 23721142].
760 Shaff MI, Tarr RW, Partain CL, et al. Computed tomography and magnetic resonance imaging of the acute abdomen. The Surgical clinics of North America. Apr. 1988;68(2):233-54. [pmid: 3279544].
761 Shaikh IA, McGowan DR, Sornum A, et al. Letter to the editor. Re: C-reactive protein is superior to bilirubin for anticipation of perforation in acute appendicitis. Scandinavian journal of gastroenterology. Jun. 2011;46(6):767. author reply -8. [pmid: 21405977].
762 Shaikh U. Re: a randomized, controlled trial of routine early abdominal computed tomography in patients presenting with non-specific acute abdominal pain. Clinical radiology. May. 2008;63(5):611. author reply. [pmid: 18374730].
763 Shalaby A, Ade-Ajayi N. Appendicitis and non-specific abdominal pain in children. Surgery (United Kingdom). 2013;31(12):608-13. PMID:.
764 Shao Jin O, Siobhan, Whitley, Hesham, Safar-Aly, Rudi, Borgstein. Imaging the patient with suspected appendicitis. British Journal of Hospital Medicine (17508460). 2012;73(12):C178-82. Language: English. Entry Date: 20130118. Revision Date: 20140620. Publication Type: journal article.
765 Shapiro MP, Gale ME, Gerzof SG. CT of appendicitis. Diagnosis and treatment. Radiologic clinics of North America. Jul. 1989;27(4):753-62. [pmid: 2657853].
766 Sharma M, Agrawal A. Pictorial essay: CT scan of appendicitis and its mimics causing right lower quadrant pain. Indian Journal of Radiology and Imaging. 2008;18(1):80-9. PMID:.
767 Sharp HT. The acute abdomen during pregnancy. Clinical obstetrics and gynecology. Jun. 2002;45(2):405-13. [pmid: 12048399].
768 Shaw RE. APPENDIX CALCULI AND ACUTE APPENDICITIS. The British journal of surgery. Jun. 1965;52:451-9. [pmid: 14296777].
769 Shelton T, McKinlay R, Schwartz RW. Acute appendicitis: current diagnosis and treatment. Current surgery. Sep–Oct. 2003;60(5):502-5. [pmid: 14972214].
770 Shepherd JA. Computer-aided diagnosis of acute abdominal pain. British medical journal. May. 6. 1972;2(5809):347-8. [pmid: 4553820].
771 Shiffman RN, Greenes RA. Use of augmented decision tables to convert probabilistic data into clinical algorithms for the diagnosis of appendicitis. Proceedings/the Annual Symposium on Computer Application [sic] in Medical Care Symposium on Computer Applications in Medical Care. 1991:686-90. [pmid: 1807691].
772 Shiga T, Wajima Z, Inoue T. Computed tomography and ultrasonography to detect appendicitis. Annals of internal medicine. May. 3. 2005;142(9):798-9. author reply 800. [pmid: 15867414].
773 Johari HG, Eskandari S. Stump appendicitis: a challenging clinical problem…. Pediatr Emerg Care. Jan. 2013;29(1):76-7. [pmid: 23283270].
774 Shorvon PJ. Imaging of appendicitis: a cautionary note. The British journal of radiology. Sep. 2002;75(897):717-20. [pmid: 12200238].
775 Showstack J. Predictive power of the MANTRELS score. Annals of emergency medicine. Sep. 1991;20(9):1048-9. [pmid: 1844349].
776 Shuman WP, Ralls PW, Balfe DM, et al. Imaging evaluation of patients with acute abdominal pain and fever. American College of Radiology. ACR Appropriateness Criteria. Radiology. Jun. Suppl. 2000;215:209-12. [pmid: 11037428].
777 Sibileau E, Boulay-Coletta I, Julles MC, et al. Appendicitis and diverticulitis of the colon: misleading forms. Diagnostic and interventional imaging. Jul–Aug. 2013;94(7–8):771-92. [pmid: 23759294].
778 Siegel MJ. Acute appendicitis in childhood: the role of US. Radiology. Nov. 1992;185(2):341-2. [pmid: 1410335].
779 Siewert B, Raptopoulos V. CT of the acute abdomen: findings and impact on diagnosis and treatment. AJR American journal of roentgenology. Dec. 1994;163(6):1317-24. [pmid: 7992721].
780 Simonovsky V. The specificity of appendiceal outer diameter at US. Radiology. Sep. 2001;220(3):828-30. [pmid: 11526290].
781 Simpson J, Scholefield JH. A normal appendix found during diagnostic laparoscopy should not be removed (Br J Surg 2001; 88: 251–4). The British journal of surgery. Oct. 2001;88(10):1417. [pmid: 11578303].
782 Simpson J, Scholefield JH. Acute appendicitis. Surgery. 2008;26(3):108-12. PMID:.
783 Simpson J, Speake W. Acute appendicitis. Clinical evidence. Jun. 2002;(7):386-91. [pmid: 12230663].
784 Simpson J, Speake W. Appendicitis. Clinical evidence. Dec. 2003;(10):491-8. [pmid: 15555104].
785 Simpson J, Speake W. Appendicitis. Clinical evidence. Jun. 2003;(9):470-7. [pmid: 15366153].
786 Simpson J, Speake W. Appendicitis. Clinical evidence. Jun. 2004;(11):544-51. [pmid: 15652021].
787 Simpson J, Speake W. Appendicitis. Clinical evidence. Dec. 2005;(14):529-35. [pmid: 16620418].
788 Sinclair JA, Marzalik P. Suspected appendicitis in the pregnant patient. Journal of obstetric, gynecologic, and neonatal nursing : JOGNN/NAACOG. Nov–Dec. 2009;38(6):723-9. [pmid: 19930288].
789 Singh A, Danrad R, Hahn PF, et al. MR imaging of the acute abdomen and pelvis: acute appendicitis and beyond. Radiographics : a review publication of the Radiological Society of North America, Inc. Sep–Oct. 2007;27(5):1419-31. [pmid: 17848700].
790 Singh AK, Gervais DA, Hahn PF, et al. Acute epiploic appendagitis and its mimics. Radiographics : a review publication of the Radiological Society of North America, Inc. Nov–Dec. 2005;25(6):1521-34. [pmid: 16284132].
791 Singh I, Collins RE. Right iliac fossa pain. British journal of hospital medicine (London, England : 2005). Nov. 2005;66(11):M76-8. [pmid: 16308955].
792 Singh S, Khardori NM. Intra-abdominal and pelvic emergencies. The Medical clinics of North America. Nov. 2012;96(6):1171-91. [pmid: 23102483].
793 Sinha S, Neen D. Re: Alvarado score: an admission criterion in patients with right iliac fossa pain. Surg Jr Coill Edinb Irel 1; 2003(1):39–41. The surgeon : journal of the Royal Colleges of Surgeons of Edinburgh and Ireland. Oct. 2003;1(5):308-9. author reply 9. [pmid: 15570788].
794 Sivit CJ, Applegate KE. Imaging of acute appendicitis in children. Seminars in ultrasound, CT, and MR. Apr. 2003;24(2):74-82. [pmid: 12744499].
795 Sivit CJ, Siegel MJ, Applegate KE, et al. When appendicitis is suspected in children. Radiographics : a review publication of the Radiological Society of North America, Inc. Jan–Feb. 2001;21(1):247-62. questionnaire 88–94. [pmid: 11158659].
796 Sivit CJ. Controversies in emergency radiology: acute appendicitis in children--the case for CT. Emergency radiology. Apr. 2004;10(5):238-40. [pmid: 15290467].
797 Sivit CJ. Diagnosis of acute appendicitis in children: spectrum of sonographic findings. AJR American journal of roentgenology. Jul. 1993;161(1):147-52. [pmid: 8517294].
798 Sivit CJ. Imaging children with acute right lower quadrant pain. Pediatric clinics of North America. Jun. 1997;44(3):575-89. [pmid: 9168869].
799 Sivit CJ. Imaging the child with right lower quadrant pain and suspected appendicitis: current concepts. Pediatric radiology. Jun. 2004;34(6):447-53. [pmid: 15105975].
800 Sivyer P. Pelvic ultrasound in women. World journal of surgery. Feb. 2000;24(2):188-97. [pmid: 10633146].
801 Skarstein A. The diagnosis of peritonitis. Scandinavian journal of gastroenterology Supplement. 1984;100:16-8. [pmid: 6237412].
802 Skipworth RJE, Fearon KCH. Acute abdomen: peritonitis. Surgery. 2008;26(3):98-101. PMID:.
803 Slim K, Chipponi J. Laparoscopy for every acute appendicitis?. Surgical endoscopy. Nov. 2006;20(11):1785-6. [pmid: 16960668].
804 Slim K. Observation for suspected appendicitis. Presse medicale (Paris, France : 1983). Mar. 2006;35(3 Pt 1):373-4. [pmid: 16550122].
805 Smith EI, Shopfner CE. The acute abdomen in the preschool child. Southern medical journal. Nov. 1966;59(11):1260-7. [pmid: 6005904].
806 Smith JK, Lobo DN. Investigation of the acute abdomen. Surgery (United Kingdom). 2012;30(6):296-305.
807 Smith JK, Lobo DN. Investigation of the acute abdomen. Surgery. 2008;26(3):91-7.
808 Smith JK, Lobo DN. Investigation of the acute abdomen. Surgery (United Kingdom). 2012;30(6):296-305.
809 Smith JT, Parchment-Smith C. The role of imaging in the management of adults with non-traumatic acute abdominal pain. Imaging. 2009;21(1):1-19. PMID:.
810 Sokolsky LP, Garmel GM. Image diagnosis: ultrasound in right lower quadrant pain. The Permanente journal. Fall. 2011;15(4):77-8. [pmid: 22319423].
811 Soter CS. The contribution of the radiologist to the diagnosis of acute appendicitis. Seminars in roentgenology. Oct. 1973;8(4):375-88. [pmid: 4751072].
812 Southgate, Vousden N, Karthikesalingam A, Markar SR, Black S, Zaidi A. Laparoscopic vs open appendectomy in older patients. [pmid: 22786544].
813 Spalluto LB, Woodfield CA, DeBenedectis CM, et al. MR imaging evaluation of abdominal pain during pregnancy: appendicitis and other nonobstetric causes. Radiographics : a review publication of the Radiological Society of North America, Inc. Mar–Apr. 2012;32(2):317-34. [pmid: 22411935].
814 Sporea I, Popescu A. Ultrasound examination of the normal gastrointestinal tract. Medical ultrasonography. Dec. 2010;12(4):349-52. [pmid: 21210023].
815 Stanbro WW. Radiologic procedures in the acute abdomen. Medical times. May. 1966;94(5):585-91. [pmid: 5932116].
816 Steinbrook RA, Brooks DC, Datta S. Laparoscopic surgery during pregnancy. American journal of surgery. Aug. 1997;174(2):222. [pmid: 9293850].
817 Stern RG. Medical radiation safety: Rational policy, irrational science. [pmid: 22657562].
818 Stoker J, van Randen A, Lameris W, et al. Imaging patients with acute abdominal pain. Radiology. Oct. 2009;253(1):31-46. [pmid: 19789254].
819 Stoker J. Magnetic resonance imaging and the acute abdomen. The British journal of surgery. Oct. 2008;95(10):1193-4. [pmid: 18763236].
820 Stone R. Primary care diagnosis of acute abdominal pain. The Nurse practitioner. Dec. 1996;21(12 Pt 1):19-20. 3. 30. 5. 9. quiz 40–1. [pmid: 9238349].
821 Strate T, Schneider CG, Bloechle C, et al. The introduction of appendiceal CT. Annals of surgery. Nov. 2000;232(5):721. [pmid: 11066147].
822 Strode JE. GRANULOMAS OF THE ILEOCECAL REGION: DIAGNOSIS AND TREATMENT. Diseases of the colon and rectum. Sep–Oct. 1964;7:410-3. [pmid: 14202631].
823 Strouse PJ. Imaging and the child with abdominal pain. Singapore medical journal. Jun. 2003;44(6):312-22. [pmid: 14560866].
824 Strouse PJ. Pediatric appendicitis: an argument for US. Radiology. Apr. 2010;255(1):8-13. [pmid: 20308438].
825 Sty JR, Wells RG. Tc-99m glucoheptonate imaging. Retroperitoneal abscess. Clinical nuclear medicine. Apr. 1990;15(4):270-1. [pmid: 2340664].
826 Sucher JF, MacFadyen BV Jr. Imaging modalities for acute abdominal pain. Seminars in laparoscopic surgery. Mar. 2002;9(1):3-9. [pmid: 11979405].
827 Summaries for patients. The role of multidetector computed tomography for diagnosing acute appendicitis. Annals of internal medicine. Jun. 21. 2011;154(12):I36. [pmid: 21690577].
828 Sung T, Callahan MJ, Taylor GA. Clinical and imaging mimickers of acute appendicitis in the pediatric population. AJR American journal of roentgenology. Jan. 2006;186(1):67-74. [pmid: 16357381].
829 Surpure JS. Pediatric emergencies. Indian journal of pediatrics. Nov–Dec. 1987;54(6):935-40. [pmid: 2894356].
830 Sutton GC. Computer-aided diagnosis: a review. The British journal of surgery. Jan. 1989;76(1):82-5. [pmid: 2645015].
831 Sutton GC. Computer-assisted diagnosis in acute abdominal pain. Lancet. Dec. 2. 1989;2(8675):1340-1. [pmid: 2574293].
832 Swarr D, Keren R. Comparison of alternative diagnostic approaches for managing appendicitis in children: the effect of disease prevalence and spectrum. Pediatrics. Aug. 2004;114(2):513-4. [pmid: 15286247].
833 Taddio, Rose, Lepore, Ventura. Dealing with abdominal pain in children affected by systemic lupus erythematosus. [pmid: 22340999].
834 Talwar S, Talwar R, Prasad P. Continuing diagnostic challenge of acute appendicitis: evaluation through modified alvarado score: comment. The Australian and New Zealand journal of surgery. Nov. 1999;69(11):821-2. [pmid: 10553974].
835 Tan EC, Severijnen RS, Rosman C, et al. Diagnosis and treatment of acute appendicitis in children: a survey among Dutch surgeons and comparison with evidence-based practice. World journal of surgery. Apr. 2006;30(4):512-8. discussion 9. [pmid: 16528461].
836 Taourel P, Pradel J, Fabre JM, et al. Role of CT in the acute nontraumatic abdomen. Seminars in ultrasound, CT, and MR. Apr. 1995;16(2):151-64. [pmid: 7794605].
837 Taylor GA. Abdominal ultrasound is specific but insufficiently sensitive in diagnosing appendicitis. [pmid: 24560323].
838 Taylor GA. Suspected appendicitis in children: in search of the single best diagnostic test. Radiology. May. 2004;231(2):293-5. [pmid: 15128978].
839 Taylor GA. Ultrasound scan for suspected appendicitis in children: risk of diagnostic inaccuracy increases with BMI at or above 85th percentile and clinical probability of appendicitis of 50% or lower. Evidence-based medicine. Jun. 2011;16(3):91-2. [pmid: 21377981].
840 Taylor JV. Leucocyte count and C-reactive protein in the diagnosis of acute appendicitis. The British journal of surgery. Sep. 1999;86(9):1223. [pmid: 10576899].
841 Tez M, Tez S, Gocmen E. Neurofuzzy is useful aid in diagnosing acute appendicitis. World journal of surgery. Sep. 2008;32(9):2126. [pmid: 18427889].
842 Tez M. What is the problem? Imaging or something else. The American journal of emergency medicine. Jan. 2013;31(1):259. [pmid: 23122422].
843 The incidence and value of rectal examination in children with suspected appendicitis. Annals of the Royal College of Surgeons of England. Nov. 1991;73(6):399-400. [pmid: 1759776].
844 Thomas EJ. Laparoscopic appendectomy. Canadian journal of surgery Journal canadien de chirurgie. Apr. 1996;39(2):168. [pmid: 8769931].
845 Thomson WH. Suspected acute appendicitis: trends in management over 30 years (Br J Surg 2001;88:1570–7). The British journal of surgery. May. 2002;89(5):624. [pmid: 12019500].
846 Thorpe SW. Basic anatomical concepts in the diagnosis of acute appendicitis. The Medical bulletin of the U S Army Far East. Dec. 1952;1(1):9-10. [pmid: 13012363].
847 Tobias M, Samuel E. Ultrasound and the Alvarado score. Journal of the Royal Society of Medicine. Sep. 1992;85(9):585-6. [pmid: 1433138].
848 Tonks T. Low dose CT for diagnosing appendicitis in young adults. BMJ: British Medical Journal (Overseas & Retired Doctors Edition). 2012;344(7855):12. Language: English. Entry Date: 20120921. Revision Date: 20130322. Publication Type: journal article. Journal Subset: Biomedical.
849 Torpy JM, Burke AE, Golub RM. Appendectomy. JAMA - Journal of the American Medical Association. 2011;306(21):2404. PMID:. [pmid: 22147387].
850 Torres US, de Oliveira EP, Schmitt VH, et al. Discordant computed tomography and histopathological findings in acute appendicitis: really a radiological “error?”. Clinical imaging. May–Jun. 2013;37(3):613-4. [pmid: 23102930].
851 Toshniwal, Soskin. Ultrasound-guided transversus abdominis plane block in obese patients. [pmid: 22529445].
852 Traughber P, Graham E. Absence of color Doppler signal in appendicitis. Radiology. Mar. 1994;190(3):906. [pmid: 8115655].
853 Truskett P. Acute appendicitis: is it time to reassess best management?. [pmid: 24099121].
854 Tschuor C, Raptis DA, Limani P, et al. The value of pancreatic stone protein in predicting acute appendicitis in patients presenting at the emergency department with abdominal pain. BMC gastroenterology. 2012;12:154. [pmid: 23098130].
855 Tuma J. CME Sonography No. 50/Solution: Acute abdominal pain. Praxis. 2013;102(4):243-5. PMID:. [pmid: 23399612].
856 Udgiri N, Curras E, Kella VK, et al. Appendicitis, is it an emergency?. The American surgeon. Jul. 2011;77(7):898-901. [pmid: 21944355].
857 Udwadia TE, Udwadia RT. Laparoscopic appendicectomy. The National medical journal of India. Nov–Dec. 1999;12(6):281-4. [pmid: 10732431].
858 Ultrasonography and appendicitis. The New England journal of medicine. Apr. 21. 1988;318(16):1064-5. [pmid: 3281013].
859 Uttley KF. The possible relationship between abdominal adenitis, appendicitis, tonsillitis and glandular fever. The New Zealand medical journal. Dec. 1949;48(268):540-55. 4 pl. [pmid: 15409923].
860 Vagholkar K. Laparoscopic cholecystectomy and appendicectomy in situ inversus totalis. [pmid: 22623831].
861 Vagholkar K. The “BASE FIRST” technique in laparoscopic appendectomy. Journal of minimal access surgery. Jan. 2013;9(1):45. [pmid: 23626423].
862 van Duren BH, Moghul M, Appleton SG, et al. The acute abdomen. BMJ (Clinical research ed). 2013;346:f2549. [pmid: 23616034].
863 Van Hoe L, Miserez M. Effectiveness of imaging studies in acute appendicitis: a simplified decision model. European journal of emergency medicine : official journal of the European Society for Emergency Medicine. Mar. 2000;7(1):25-30. [pmid: 10839375].
864 van Oudheusden, Aerts, de Hingh, Luyer. Challenges in diagnosing adhesive small bowel obstruction. [pmid: 24616565].
865 Van Ruyssevelt C, Pauls C. Sonography of appendicitis and acute diseases of the lower abdomen. Acta gastro-enterologica Belgica. Apr–Jun. 1996;59(2):152-3. [pmid: 8903064].
866 Vandermeer FQ, Wong-You-Cheong JJ. Imaging of acute pelvic pain. Clinical obstetrics and gynecology. Mar. 2009;52(1):2-20. [pmid: 19179858].
867 Vasavada P. Ultrasound evaluation of acute abdominal emergencies in infants and children. Radiologic clinics of North America. Mar. 2004;42(2):445-56. [pmid: 15136027].
868 Vasei M. 5-Hydroxyindoleacetic acid in appendicitis: the importance of test selection. The American journal of emergency medicine. Mar. 2012;30(3):504. [pmid: 22244225].
869 Velanovich V. Bayesian analysis in the diagnostic process. American journal of medical quality : the official journal of the American College of Medical Quality. Winter. 1994;9(4):158-61. [pmid: 7819823].
870 Velanovich V. Plain abdominal radiographs and acute abdominal pain. The British journal of surgery. Nov. 1988;75(11):1147. [pmid: 3208053].
871 Verde PE. Meta-analysis of diagnostic test data: a bivariate Bayesian modeling approach. Statistics in medicine. Dec. 30. 2010;29(30):3088-102. [pmid: 21170904].
872 Vernon S. Diagnosis in appendicitis: the two-thirds rule for atypical cases. The Journal of abdominal surgery. May. 1962;4:72. [pmid: 13925536].
873 Vettoretto N, Agresta F, Presenti L, et al. Evidence-based laparoscopic appendectomy practice requires national database studies. Surgical endoscopy. Jul. 2013;27(7):2652-3. [pmid: 23355173].
874 Veziant J, Slim K. Laparoscopic appendectomy. J Visc Surg. Jun. 2014;151(3):223-8. [pmid: 24768620].
875 Virmani V, Papadatos D, Fasih N, et al. Rule out appendicitis: “to be or not to be”. Canadian Association of Radiologists journal. Journal l’Association canadienne des radiologistes. Feb. 2012;63(1):47-60. [pmid: 20598500].
876 Vissers RJ, Lennarz WB. Pitfalls in appendicitis. Emergency medicine clinics of North America. Feb. 2010;28(1):103-18. viii. [pmid: 19945601].
877 Vogelaar FJ, Molenaar IQ, Adhin S, et al. Invagination of the appendix: diagnostic laparoscopy?. Digestive diseases and sciences. Feb. 2004;49(2):351-2. [pmid: 15104383].
878 Wagner LK, Huda W. When a pregnant woman with suspected appendicitis is referred for a CT scan, what should a radiologist do to minimize potential radiation risks?. Pediatric radiology. Jul. 2004;34(7):589-90. [pmid: 15164139].
879 Wagner OJ, Vorburger SA, Exadaktylos AK, et al. Digital rectal examination and its value for decision making. The American journal of emergency medicine. Feb. 2009;27(2):246. [pmid: 19371541].
880 Wallace GW, Davis MA, Semelka RC, et al. Imaging the pregnant patient with abdominal pain. Abdominal imaging. Oct. 2012;37(5):849-60. [pmid: 22160283].
881 Watkins, Lemonovich. Serum procalcitonin in the diagnosis and management of intra-abdominal infections. [pmid: 22339193].
882 Watters JM. The appendicitis inflammatory response score: a tool for the diagnosis of appendicitis that outperforms the Alvarado score. World journal of surgery. Aug. 2008;32(8):1850. [pmid: 18560932].
883 Weiss GN. Response to diagnosis of appendicitis. Southern medical journal. Jul. 2006;99(7):782. [pmid: 16866069].
884 Wells PN. Ultrasonography for diagnosing appendicitis. BMJ (Clinical research ed). Oct. 29. 1988;297(6656):1129. [pmid: 3143461].
885 Weyant MJ, Barie PS, Eachempati SR. Clinical role of noncontrast helical computed tomography in diagnosis of acute appendicitis. American journal of surgery. Jan. 2002;183(1):97-9. [pmid: 11869716].
886 Weyant MJ, Eachempati SR, Maluccio MA, et al. Is imaging necessary for the diagnosis of acute appendicitis?. Advances in surgery. 2003;37:327-45. [pmid: 12953640].
887 Whiteley MS. Randomized study of the value of laparoscopy before appendicectomy. The British journal of surgery. Nov. 1993;80(11):1490. [pmid: 8110257].
888 Whitford CM, Crade M. Transvaginal diagnosis of appendicitis. AJR American journal of roentgenology. Feb. 1994;162(2):469. [pmid: 8310957].
889 Whitley S, Sookur P, McLean A, et al. The appendix on CT. Clinical radiology. Feb. 2009;64(2):190-9. [pmid: 19103350].
890 Widlus DM. CT scan for suspected acute appendicitis. Journal of community hospital internal medicine perspectives. 2011;1(4). [pmid: 23882345].
891 Wijetunga R, Doust B, Bigg-Wither G. The CT diagnosis of acute appendicitis. Seminars in ultrasound, CT, and MR. Apr. 2003;24(2):101-6. [pmid: 12744503].
892 Wild Jonathan RL, Abdul Nicole, Ritchie Judith E, Rud Bo, Freels Sally, Nelson Richard L. Ultrasonography for diagnosis of acute appendicitis. Cochrane Database of Systematic Reviews [serial on the Internet]. 2013;(2). Available from: http://onlinelibrary.wiley.com/doi/10.1002/14651858.CD010402/abstract. Last accessed.
893 Wilkins FM. NEW PERSPECTIVES IN THE ROENTGEN DIAGNOSIS OF THE ACUTE ABDOMEN. The Journal of the American Osteopathic Association. Apr. 1965;64:795-811. [pmid: 14281338].
894 Wilkins T, Embry K, George R. Diagnosis and management of acute Diverticulitis. [pmid: 23668524].
895 Williams AF. Rovsing’s sign. Lancet. Dec. 22. 1956;271(6956):1282-3. [pmid: 13386234].
896 Williams JW, Levick RK. Ultrasonic diagnosis of appendicitis. British journal of hospital medicine. Oct. 1991;46(4):267-8. [pmid: 1954499].
897 Williams R, Mackway-Jones K. Towards evidence based emergency medicine:Best BETs from the Manchester Royal Infirmary. White cell count and diagnosing appendicitis in pregnancy. Journal of accident & emergency medicine. Sep. 2000;17(5):365. [pmid: 11005411].
898 Williams R, Mackway-Jones K. Towards evidence based emergency medicine: best BETs from the Manchester Royal Infirmary. White cell count and diagnosing appendicitis in adults. Emergency medicine journal : EMJ. Sep. 2002;19(5):429-30. [pmid: 12204994].
899 Williams R, Shaw J. Ultrasound scanning in the diagnosis of acute appendicitis in pregnancy. Emergency medicine journal : EMJ. May. 2007;24(5):359-60. [pmid: 17452707].
900 Wilson DH. The acute abdomen in the accident and emergency department. The Practitioner. Apr. 1979;222(1330):480-5. [pmid: 382172].
901 Wilson EB. Surgical evaluation of appendicitis in the new era of radiographic imaging. Seminars in ultrasound, CT, and MR. Apr. 2003;24(2):65-8. [pmid: 12744497].
902 Wilson JM. Principles of screening for disease. Proceedings of the Royal Society of Medicine. Dec. 1971;64(12):1255-6. [pmid: 5131278].
903 Windpessl M, Prischl FC. Surgical peritonitis in peritoneal dialysis patients: An absence of (radiological) evidence is not evidence of its absence. [pmid: 24633043].
904 Windrim CM, Czikk MJ. Appendicitis in pregnancy. Fetal and Maternal Medicine Review. 2012;23(3–4):276-95. PMID:.
905 Winter T. A plea for oral contrast administration in CT for emergency department patients. AJR American journal of roentgenology. Jul. 2010;195(1):W90. [pmid: 20566789].
906 Wiwanitkit V. Acute abdominal pain and dengue fever. [pmid: 24736128].
907 Wiwanitkit V. Diagnostic score for acute appendicitis: is it actually useful?. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Aug. 2011;396(6):867. author reply 9. [pmid: 20582433].
908 Woo EJ. Re: Racial disparities in outcomes after appendectomy for acute appendicitis. [pmid: 22658292].
909 Woodward A, Hemingway D, Greaney MG, et al. Which patients should undergo laparoscopy?. British medical journal (Clinical research ed). Jun. 18. 1988;296(6638):1740. [pmid: 2969761].
910 Woodward A. Randomized study of the value of laparoscopy before appendicectomy. The British journal of surgery. Jan. 1994;81(1):146. [pmid: 8313097].
911 Wray CJ, Kao LS, Millas SG, et al. Acute appendicitis: controversies in diagnosis and management. Current problems in surgery. Feb. 2013;50(2):54-86. [pmid: 23374326].
912 Wyatt SH, Fishman EK. The acute abdomen in individuals with AIDS. Radiologic clinics of North America. Sep. 1994;32(5):1023-43. [pmid: 8084997].
913 Wyer PC. Decision rule can help identify children at lower risk for appendicitis. The Journal of pediatrics. Jan. 2006;148(1):142-3. [pmid: 16440477].
914 Wysocki AP, Nankivell EC, McGowan B. Acute appendicitis in children: the goal posts have moved. [pmid: 23890309].
915 Yacoe ME, Jeffrey RB Jr. Sonography of appendicitis and diverticulitis. Radiologic clinics of North America. Sep. 1994;32(5):899-912. [pmid: 8085003].
916 Yadav D. Acute pancreatitis: Too many classifications-what is a clinician or researcher to do?. [pmid: 24090730].
917 Yagnik VD. Ingested foreign body lodged in the appendix. Journal of Indian Association of Pediatric Surgeons. Oct. 2011;16(4):174. [pmid: 22121325].
918 Yu J, Fulcher AS, Turner MA, et al. Helical CT evaluation of acute right lower quadrant pain: part I, common mimics of appendicitis. AJR American journal of roentgenology. Apr. 2005;184(4):1136-42. [pmid: 15788584].
919 Zagoria RJ. Retrospective view of “diagnosis of Acute Flank Pain: Value of Unenhanced Helical CT”. American Journal of Roentgenology. 2006;187(3):603-4. PMID:. [pmid: 16928918].
920 Zern JT. The appendix: little organ, big trouble. Delaware medical journal. Jun. 1995;67(6):326-34. [pmid: 7615131].
921 Ziegler MM. The diagnosis of appendicitis: an evolving paradigm. Pediatrics. Jan. 2004;113(1 Pt 1):130-2. [pmid: 14702461].
922 Zorman M, Eich HP, Stiglic B, et al. Does size really matter--using a decision tree approach for comparison of three different databases from the medical field of acute appendicitis. Journal of medical systems. Oct. 2002;26(5):465-77. [pmid: 12182210].

## B-13. Rejection Reason: No Reference Standard or Reference Standard Not Approved

1 Asch E, Shah S, Kang T, et al. Use of pelvic computed tomography and sonography in women of reproductive age in the emergency department. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Jul. 2013;32(7):1181-7. [pmid: 23804340].
2 Barksdale A, Gratton M, Hackman J, et al. Diagnosis and disposition are changed when board certified emergency physicians use CT for non-traumatic abdominal pain. Annals of emergency medicine. 2012;60(4):S61. PMID:.
3 Basak S, Nazarian LN, Wechsler RJ, et al. Is unenhanced CT sufficient for evaluation of acute abdominal pain?. Clinical imaging. Nov–Dec. 2002;26(6):405-7. [pmid: 12427436].
4 Bilku DK, Hall TC, Dennison AR, et al. Factors predicting significant pathology on ultrasonography in women presenting with non-specific lower abdominal pain. Annals of the Royal College of Surgeons of England. Apr. 2012;94(3):155-8. [pmid: 22507717].
5 Brodzisz A, Wieczorek P, Dybiec E, et al. High frequency ultrasound diagnostics of right lower quadrant abdominal pain in children. Annales Universitatis Mariae Curie-Sklodowska Sectio D: Medicina. 2003;58(1):437-43. [pmid: 15315029].
6 Caspi B, Zbar AP, Mavor E, et al. The contribution of transvaginal ultrasound in the diagnosis of acute appendicitis: an observational study. Ultrasound in obstetrics & gynecology : the official journal of the International Society of Ultrasound in Obstetrics and Gynecology. Mar. 2003;21(3):273-6. [pmid: 12666223].
7 Coyle JP, Brennan CR, Parfrey SF, et al. Is serum C-reactive protein a reliable predictor of abdomino-pelvic CT findings in the clinical setting of the non-traumatic acute abdomen?. Emergency radiology. Oct. 2012;19(5):455-62. [pmid: 22532154].
8 de Bakker JK, Dijksman LM, Donkervoort SC. Safety and outcome of general surgical open and laparoscopic procedures during pregnancy. Surgical endoscopy. May. 2011;25(5):1574-8. [pmid: 21052721].
9 El Kateb Y, Abou El Ghar M, Hussein MA, et al. The role of laparoscopy in evaluation of acute pelvic pain in young women. The Journal of the Egyptian Medical Association. 1978;61(9–10):593-6. [pmid: 162439].
10 Fonio P, Coppolino F, Russo A, D’Andrea A, Giannattasio A, Reginelli A, Grassi R, Genovese EA. Ultrasonography (US) in the assessment of pediatric non traumatic gastrointestinal emergencies. [pmid: 23902696].
11 Gafter-Gvili A, Paul M, Bernstine H, Vidal L, Ram R, Raanani P, Yeshurun M, Tadmor B, Leibovici L, Shpilberg O, Groshar D. The role of 18F-FDG PET/CT for the diagnosis of infections in patients with hematological malignancies and persistent febrile neutropenia. [pmid: 23849986].
12 Jang T, Chauhan V, Cundiff C, Kaji AH. Assessment of emergency physician-performed ultrasound in evaluating nonspecific abdominal pain. Am J Emerg Med. May. 2014;32(5):457-60. [pmid: 24529645].
13 Kozaci, Ay MO, Cetinkunar S, Soker G, Erkan BB, Celikdemir A, Acehan S, Gulen M, Satar S. The relationship between nonspecific inflammation markers and computerized tomography imaging in non-traumatic acute abdomen.
14 Lee SY, Coughlin B, Wolfe JM, et al. Prospective comparison of helical CT of the abdomen and pelvis without and with oral contrast in assessing acute abdominal pain in adult Emergency Department patients. Emergency radiology. May. 2006;12(4):150-7. [pmid: 16738930].
15 Magaam S. Acute appendicitis in patients with different ages at Hodeidah City, Yemen. World Journal of Medical Sciences. 2011;6(3):136-41. PMID:.
16 Moberg AC, Montgomery A. Appendicitis: laparoscopic versus conventional operation: a study and review of the literature. Surgical laparoscopy & endoscopy. Dec. 1997;7(6):459-63. [pmid: 9438626].
17 Raman S, Somasekar K, Winter RK, et al. Are we overusing ultrasound in non-traumatic acute abdominal pain?. Postgraduate medical journal. Mar. 2004;80(941):177-9. [pmid: 15016943].
18 Sooriakumaran P, Lovell D, Brown R. A comparison of clinical judgment vs the modified Alvarado score in acute appendicitis. International journal of surgery (London, England). 2005;3(1):49-52. [pmid: 17462258].
19 Swanick CW1, Gaca AM, Hollingsworth CL, Maxfield CM, Li X, Samei E, Paulson EK, McCarthy MB, Frush DP. Comparison of conventional and simulated reduced-tube current MDCT for evaluation of suspected appendicitis in the pediatric population. AJR Am J Roentgenol. Sep. 2013;201(3):651-8. [pmid: 23971460].
20 Thurston K, Magge S, Fuller R, et al. Focused versus screening CT scans for evaluation of nontraumatic abdominal pain in the emergency department. Open Access Emergency Medicine. 2010;2:25-7.

## B-14. Rejection Reason: Non-English

1 Acute abdomen. Revista de gastroenterologia de Mexico. Nov. Suppl 3. 2002;67:74-88. [pmid: 12696516].
2 Acute abdominal pain. A prospective multicentric study (author’s transl). La Nouvelle presse medicale. Dec. 19. 1981;10(46):3771-3. [pmid: 7033931].
3 Aid to diagnosis and decision making in an acute abdominal pain syndrome. Revue d’epidemiologie et de sante publique. 1984;32(1):40-4. [pmid: 6371950].
4 Appendectomy is often unnecessary 23755459
5 Appendicitis or appendectomy? A reply of pediatrician-surgeons of GRECPSE. Pediatrie. 1992;47(6):495-8. [pmid: 1331971].
6 Appendicitis. Recommendations and medical references. Agence Nationale pour le Developpement de l’Evaluation Medicale. Gastroenterologie clinique et biologique. 1997;21(1):50-70. [pmid: 9091391].
7 Discussion about therapeutic tactics in case of acute appendicitis 24816382
8 Does laparoscopic appendectomy still have value in acute appendicitis?. Langenbecks Archiv fur Chirurgie. 1992;377(5):317-21. [pmid: 1405959].
9 Intervention in acute abdomen or not? It must be rapidly assessed!. MMW Fortschritte der Medizin. Sep. 29. 2011;153(39):14-7. [pmid: 21991829].
10 Abdoulatif A, Bidamin N, Ahmed M, et al. Ultrasound and CT scan in retrocecal appendicitis. The Pan African medical journal. 2013;14:117. [pmid: 23717730].
11 Addis A. Opioids for acute abdominal pain. Ric Prat [serial on the Internet]. 1993;(52). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/010/CN-00510010/frame.html. Last accessed.
12 Addis A. Opioids for acute abdominal pain. OPPIACEI NEL DOLORE ADDOMINALE. Ric Prat [serial on the Internet]. 1993;(52). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/247/CN-00181247/frame.html. Last accessed.
13 Agadzhanian VV. ON THE ABDOMINAL SYNDROME OF PERIODIC DISEASE. Terapevticheskii arkhiv. Jun. 1963;35:73-9. [pmid: 14069317].
14 Agresta F, De Simone P, Michelet I, et al. The rationale of laparoscopic treatment in acute appendiceal disease. Chirurgia italiana. Mar–Apr. 2000;52(2):171-8. [pmid: 10832543].
15 Alamillo J, Caldera H, Angulo O, et al. Diagnostic problem. Boletin medico del Hospital Infantil de Mexico. Jun. 1. 1955;12(3):307-10. [pmid: 13260380].
16 Al-Gamrah A. Diagnostic and therapeutic management of acute abdomen in Hajah, Yemen. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jun. 2004;75(6):622-6. [pmid: 15007526].
17 Alimov ZZ. Diagnostic value of the zones of Zakharin-Head and Viliamovskii and of the viscero-vasomotor reflexes in acute appendicitis. Klinicheskaia meditsina. Sep. 1962;40:115-21. [pmid: 14012057].
18 Aliyev ES. The diagnosis and tactics of surgical management of acute appendicitis in pregnant women. Azerbaijan Medical Journal. 2012;(1):109-13. PMID:.
19 Allevi A, Cristina S, Rizzardi GP, et al. The influence of the clinical course and diagnosis on the length of surgical stays. Minerva chirurgica. Oct. 15. 1992;47(19):1549-56. [pmid: 1470410].
20 Alt-Epping S, Ostermann T, Schmidt J, et al. Diagnosis of appendicitis with particular consideration of the acupuncture point Lanwei--a prospective study. Forschende Komplementarmedizin und klassische Naturheilkunde. Research in complementary and natural classical medicine. Dec. 2002;9(6):338-45. [pmid: 12618551].
21 Alvarado-Aparicio A, Moreno-Portillo M, Pereira-Graterol F, et al. Laparoscopic appendectomy. Surgical technique description and literature review. Cirugia y cirujanos. Nov–Dec. 2003;71(6):442-8. [pmid: 14984668].
22 Alvarez Sanchez JA, Fernandez Lobato R, Marin Lucas J, et al. Diagnostic validity of signs and symptoms defining the diagnosis of acute appendicitis. Gastroenterologia y hepatologia. Jan. 1997;20(1):11-6. [pmid: 9072190].
23 Amadou A, Raissi C, N’Timon B, Marouane A, Matusila D, Bichri M. Ultrasound and computed tomography in retrocecal appendicitis. Feuillets de Radiologie. 2014. ((Amadou A., amadoulatif@yahoo.fr; Raissi C.; Matusila D.; Bichri M.) Service de radiologie, centre hospitalier de l’arrondissement de Montreuil dur Mer (CHAM), 140, route departementale, BP 08, 62180 Rang du Fliers, France). PMID:.
24 Amgwerd M, Rothlin M, Candinas D, et al. Ultrasound diagnosis of appendicitis by surgeons--a matter of experience? A prospective study. Langenbecks Archiv fur Chirurgie. 1994;379(6):335-40. [pmid: 7845158].
25 Anderegg A. Contribution of echography to the differential diagnosis of acute and subacute abdomen. Schweizerische Rundschau fur Medizin Praxis = Revue suisse de medecine Praxis. Nov. 27. 1984;73(48):1495-8. [pmid: 6393278].
26 Andersen E, Sondenaa K, Soreide JA, et al. Acute appendicitis. Preoperative observation time and diagnostic accuracy. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Feb. 20. 1992;112(5):630-4. [pmid: 1557729].
27 Andersson RE. Time to re-evaluate management of suspected appendicitis. Patients might be spared “unnecessary” surgery. Lakartidningen. Oct. 10. 2002;99(41):4034-8. [pmid: 12451939].
28 Andreichin MA, Gnatovich IG, Chemich ND, et al. Thermographic semeiotics of food poisoning and its differential diagnosis. Klinicheskaia meditsina. Apr. 1989;67(4):64-7. [pmid: 2755059].
29 Andren-Sandberg A, Martensson H, Siemert G. Leukocyte count in acute appendicitis - problems of interpreting laboratory data. Lakartidningen. May. 6. 1981;78(19):1959-61. [pmid: 7266149].
30 Andren-Sandberg A. Leukocyte count and CRP determination in acute appendicitis--does it affect the clinical findings?. Lakartidningen. Mar. 21. 2002;99(12):1375. [pmid: 11998174].
31 Andren-Sandberg A. Wrong about blood test in suspected appendicitis. Lakartidningen. Nov. 6. 2003;100(45):3699. [pmid: 14650046].
32 Angelescu N. The useless appendectomy. Chirurgia (Bucharest, Romania : 1990). May–Jun. 2001;96(3):265-8. [pmid: 12731177].
33 Anhoury P, Briancon S, Vidailhet M, et al. Prospective evaluation of admission for acute abdominal pain in children. Pediatrie. 1989;44(6):481-6. [pmid: 2798008].
34 Anokhin MI, Gorbachev OS. Skin electrothermia in the diagnosis of acute appendicitis. Khirurgiia. Jul. 1974;(7):74-6. [pmid: 4410889].
35 Antalik J, Dostalova E, Filakovsky J, et al. Ultrasonography in emergency abdominal surgery. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. May. 1989;68(5):351-9. [pmid: 2665134].
36 Aranda-Narvaez JM, Montiel-Casado MC, Gonzalez-Sanchez AJ, et al. Radiological support for diagnosis of acute appendicitis: use, effectiveness and clinical repercussions. Cirugia espanola. Nov. 2013;91(9):574-8. [pmid: 23827923].
37 Aranda-Narváez JM, Montiel-Casado MC, González-Sánchez AJ, Jiménez-Mazure C, Valle-Carbajo M, Sánchez-Pérez B, Santoyo-Santoyo J. Radiological support for diagnosis of acute appendicitis: Use, effectiveness and clinical repercussions. 2013. [pmid: 23827923].
38 Aranda-Narváez JM, Prieto-Puga Arjona T, García-Albiach B, Montiel-Casado MC, González-Sánchez AJ, Sánchez-Pérez B, Titos-García A, Santoyo-Santoyo J. Postappendectomy surgical site infection: Overall rate and type according to open/laparoscopic approach. [pmid: 23582194].
39 Arevin VI, Kat’ko VA, Svirskii AA. Laparoscopy in the diagnosis of abdominal diseases in children. Klinicheskaia khirurgiia. 1992;(6):47-8. [pmid: 1453630].
40 Arfa N, Gharbi L, Marsaoui L, et al. Value of admission for observation in the management of acute abdominal right iliac fossa pain. Prospective study of 205 cases. Presse medicale (Paris, France : 1983). Mar. 2006;35(3 Pt 1):393-8. [pmid: 16550128].
41 Argov S, Timna A, Barzilai A. Clinical versus histological diagnosis of acute appendicitis. Harefuah. Nov. 1. 1981;101(9):203-5. [pmid: 7347298].
42 Arnaud A, Sauvat F. Surgical abdominal pain in children. La Revue du praticien. May. 2011;61(5):626-9. [pmid: 21698888].
43 Atanov Iu P. Laparoscopy in the emergency surgery of abdominal organs. Vestnik khirurgii imeni I I Grekova. May. 1981;126(5):9-14. [pmid: 6455839].
44 Atila K, Ucar AD, Unek T, et al. Acute appendicitis in pregnancy. Ulusal travma dergisi. Turkish journal of trauma & emergency surgery : TJTES. Apr. 2002;8(2):98-101. [pmid: 12038031].
45 Austerhoff A, Hengels KJ, Fritsch WP, et al. Ultrasonic diagnosis in acute abdominal pain. Die Medizinische Welt. Dec. 15. 1978;29(50):1965-7. [pmid: 723595].
46 Azzola M, Croce E, Palazzini G. Laparoscopic appendectomy. Il Giornale di chirurgia. Apr. 1992;13(4):221-2. [pmid: 1386234].
47 Baccoli A, Manconi AR, Sau P, et al. Duplex US evaluation of mesenteric vessels in acute abdomen. Prospective study on 325 patients. Il Giornale di chirurgia. Oct. 2008;29(10):449-54. [pmid: 18947471].
48 Baeza Herrera C, Guido Ramires O, Gonzalez Galicia JA, et al. Appendicitis in children under 3. Revista de gastroenterologia de Mexico. Jul–Sep. 1994;59(3):213-7. [pmid: 7716361].
49 Bagdasar’ian SN, Klishevich IB, Troitskii GV. Change in the optical rotatory dispersion characteristics of serum albumin of patients with appendicitis and cholecystitis. Biulleten’ eksperimental’noi biologii i meditsiny. May. 1975;79(5):57-8. [pmid: 1227595].
50 Bagolan P. [Not Available]. Il Sangue. Jan–Feb. 1948;21(1):3-19. [pmid: 18912565].
51 Bairov GA, Gorelyi VV, Savvina AN, et al. Use of liquid crystals for diagnosis of inflammatory processes in children. Vestnik khirurgii imeni I I Grekova. Jan. 1973;110(1):121-3. [pmid: 4711026].
52 Bajka M. Gynecologic ultrasound in the acute abdomen--the predominant reasons. Praxis. Apr. 18. 2007;96(16):637-43. [pmid: 17474290].
53 Bakken IJ, Skjeldestad FE, Mjaland O, et al. Appendicitis and appendectomy in Norway 1990–2001. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Nov. 20. 2003;123(22):3185-8. [pmid: 14714004].
54 Balique JG. Acute appendicitis and its complications. Diagnosis, treatment. La Revue du praticien. Jan. 15. 2001;51(1):101-5. [pmid: 11234086].
55 Bandai Y, Itoh T, Takami M, et al. Ultrasonic diagnosis of gastrointestinal diseases. Rinsho hoshasen Clinical radiography. Oct. 1984;29(11):1255-64. [pmid: 6394833].
56 Bandtlow K, Bandhauer K. Radiologic diagnosis of the infantile acute abdomen from the urologist’s viewpoint. Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Suppl. 1972:34. [pmid: 4344572].
57 Baraev TM, Kachurin VS. Indications for laparoscopy in emergency abdominal surgery. Vestnik khirurgii imeni I I Grekova. Apr. 1986;136(4):126-30. [pmid: 2944273].
58 Baraev TM, Mishchenko NV. The diagnosis and treatment of acute nondestructive appendicitis. Klinicheskaia khirurgiia. 1994;(3):60-3. [pmid: 7637296].
59 Baraev TM. Acute nondestructive appendicitis: arguable questions in its diagnosis and treatment. Klinicheskaia khirurgiia. 1995;(2):34-6. [pmid: 9053189].
60 Baraev TM. Classification of diagnostic laparoscopies. Vestnik khirurgii imeni I I Grekova. Mar. 1991;146(3):42-3. [pmid: 1654638].
61 Baraev TM. Comments to dispute about catarrhal appendicitis. Khirurgiia. 2000;(4):19-21. [pmid: 10800305].
62 Baraev TM. Problem of acute appendicitis. Vestnik khirurgii imeni I I Grekova. 1999;158(4):35-8. [pmid: 10533220].
63 Barboni A, Golinelli G, Melli A. Laparoscopic examination in the diagnosis of certain diseases of the abdominal organs. L’ Arcispedale S Anna di Ferrara. 1967;20(4):549-88. [pmid: 6077028].
64 Barczynski M, Cichon S, Slowiaczek M, et al. Wrong diagnoses of acute appendicitis in women. Przeglad lekarski. 1995;52(12):575-7. [pmid: 8834653].
65 Baricza S, Vadnai M, Varga Z, et al. Possibilities for using emergency abdominal ultrasound study and its significance in acute diseases of the abdominal cavity. Zentralblatt fur Chirurgie. 1988;113(13):860-8. [pmid: 3051790].
66 Barrat C, Champault G, Catheline JM, et al. Does laparoscopy reduce the incidence of useless appendectomies?. Annales de chirurgie. 1998;52(10):965-9. [pmid: 9951095].
67 Barth X, Monneuse O. Appendicitis in the child and the adult. La Revue du praticien. Apr. 15. 2004;54(7):771-6. [pmid: 15253296].
68 Bashkov Iu A, Osintseva VS. Hemorrhagic fever as the cause of errors in diagnosis of acute diseases of the abdominal organs. Khirurgiia. Oct. 1979;(10):81-4. [pmid: 42826].
69 Bassols F, Prieto A. Radiology in the ileocecal region. Gaceta medica de Mexico. Jun. 1967;97(6):729-45. [pmid: 5611983].
70 Bast G. The daily blood picture. XII. Use of hemograms in the differential diagnosis of appendicitis and typhus abdominalis. Die Medizinische. May. 1957;17(20):755-6. [pmid: 13440442].
71 Batallan A, Benifla JL, Panel P, et al. Laparoscopic surgery during the second trimester of pregnancy: indications, technique, and fetal repercussions. Report of nine cases and review the literature. Annales de chirurgie. 1999;53(4):285-90. [pmid: 10327691].
72 Batvinkov NI, Garelik PV, Maslakova ND, et al. Diagnostic and therapeutic laparoscopy in surgical practice. Khirurgiia. Jul. 1990;(7):42-6. [pmid: 2146437].
73 Bauer BK, Rubenacker S. Laparoscopic appendectomy and conventional preparation technique. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Sep. 2001;72(9):1082-3. [pmid: 11594282].
74 Baumann S. Accuracy in the diagnosis of acute appendicitis in childhood. Bruns’ Beitrage fur klinische Chirurgie. 1971;219(2):146-9. [pmid: 5157735].
75 Beccaria A, Troncone S. Acute appendicitis due to a foreign body. Minerva gastroenterologica. Apr–Jun. 1965;11(2):90-2. [pmid: 5847520].
76 Becker H, Neufang T. Appendectomy 1997--open or closed?. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jan. 1997;68(1):17-29. [pmid: 9132344].
77 Bedoui R, Ali Ouaer M, Nouira R, et al. Acute left-sided appendicitis. La Tunisie medicale. Dec. 2009;87(12):873-4. [pmid: 20209857].
78 Belbusti F, Signoretti P, Stafoggia P, et al. Acute abdominal pain and appendicitis in childhood. Il Giornale di chirurgia. Jun–Jul. 1992;13(6–7):357-62. [pmid: 1389986].
79 Beliaeva OA, Rozinov VM, Ivanova MN, et al. Ultrasonic diagnosis of limited forms of appendicular peritonitis in children. Vestnik khirurgii imeni I I Grekova. Sep. 1986;137(9):103-6. [pmid: 3538620].
80 Bellanova G, Mastropasqua G, Iorio B, et al. Acute abdomen due to primary small bowel neoplasm. Diagnostic approach and therapeutic modalities. Chirurgia italiana. May–Jun. 2007;59(3):305-12. [pmid: 17663368].
81 Beltran MA, Villar MR, Cruces KS. Application of a diagnostic score for appendicitis by health-related non-physician professionals. Revista medica de Chile. Jan. 2006;134(1):39-47. [pmid: 16532160].
82 Beltrani B, Tacchino RM, Paci M, et al. Echography in general surgery. Potentialities of this new diagnostic technic in abdominal emergencies. Minerva chirurgica. Feb. 28. 1986;41(3–4):119-23. [pmid: 3515229].
83 Bengmark S, Jeppsson B. Ultrasound: a promising aid in the diagnosis of acute appendicitis. Lakartidningen. Sep. 14. 1988;85(37):2935. [pmid: 3054368].
84 Benhamou G. Useless appendectomy, its diagnostic difficulties. Annales de gastroenterologie et d’hepatologie. Nov. 1986;22(6):339-40. [pmid: 3813476].
85 Bentskivs’kyi BM, Zhegulovych VG, Kryzhanovs’kyi Ia I, et al. Differential approach to the diagnosis of acute appendicitis and acute gynecological pathology in pregnant women. Likars’ka sprava/Ministerstvo okhorony zdorov’ia Ukrainy. Jan–Mar. 2012;(1–2):107-12. [pmid: 23035609].
86 Berends FJ, Vermeulen MI, Leguit P. Perforation rate and diagnostic accuracy in acute appendicitis. Nederlands tijdschrift voor geneeskunde. Feb. 12. 1994;138(7):350-4. [pmid: 8121524].
87 Berezov Iu E, Sotnikov VN, Saakian NE, et al. Laparoscopy in the diagnosis and treatment of acute surgical diseases of the abdominal organs. Klinicheskaia khirurgiia. Sep. 1976;00(9):18-23. [pmid: 135857].
88 Berulava OI, Dzhalagoniia AA, Kozlov VA, et al. Changes in the peripheral blood picture in acute appendicitis in relation to accelerated development. Vestnik khirurgii imeni I I Grekova. Feb. 1981;126(2):35-7. [pmid: 7233715].
89 Besli GE, Bicer S, Kalaycik O, Keser N, Ozkanli S, Saf C, Erguven M, Vitrinel A. Diagnostic values of anamnesis and physical examination findings in acute abdominal pain and acute appendicitis in children. Nobel Medicus. 2013;9(2):86-90. PMID:.
90 Beyer D, Friedmann G, Krestin GP. Meaningful application of imaging technics in acute appendicitis. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Mar. 1984;140(3):269-75. [pmid: 6423480].
91 Beyer D, Rieker OR, Kaiser C, et al. Sonography in suspected appendicitis: a decisive factor in diagnosis and therapy? Results of a prospective study of 669 patients. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. May. 1990;152(5):510-5. [pmid: 2160681].
92 Beyer D, Schulte B, Kaiser C, et al. Sonography of acute appendicitis. A 5-year prospective study of 2074 patients. 2. Der Radiologe. Jul. 1993;33(7):399-406. [pmid: 8367603].
93 Beyer D, Schulte B, Kaiser C. Ultrasound diagnosis of the acute abdomen. Bildgebung. Imaging. Dec. 1993;60(4):241-7. [pmid: 8118194].
94 Beyer D. The task of the radiologist in the diagnosis and differential diagnosis of acute appendicitis. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Jan. 1992;156(1):1-2. [pmid: 1733466].
95 Beyrouti MI, Amar MB, Beyrouti R, et al. Complications of the meckel’s diverticulum, about 42 cases. Tunisie Medicale. 2009;87(4):253-6. PMID:. [pmid: 19835281].
96 Beyrouti MI, Ben Amar M, Beyrouti R, et al. Complications of Meckel’s diverticulum. Report of 42 cases. La Tunisie medicale. Apr. 2009;87(4):253-6. [pmid: 19835281].
97 Beyrouti MI, Gharbi A, Abid M, et al. Mucus secreting tumors of the appendix. Report of 22 cases. La Tunisie medicale. Dec. 2004;82(12):1101-6. [pmid: 15822512].
98 Bialas M, Taran K, Gryszkiewicz M, et al. Evaluation of neutrophil-lymphocyte ratio usefulness in the diagnosis of appendicitis. Wiadomosci lekarskie (Warsaw, Poland : 1960). 2006;59(9–10):601-6. [pmid: 17338113].
99 Bijnen AB, Boekhoudt FD, de Ruiter P. Is laparoscopy of value in acute appendicitis. Nederlands tijdschrift voor geneeskunde. Oct. 30. 1993;137(44):2271. author reply 2–3. [pmid: 8255324].
100 Bilich GL, Shedlovskaia MV, Maukh NM. C-reactive protein in several surgical diseases in children. Klinicheskaia khirurgiia. Nov. 1970;11:36-40. [pmid: 5533458].
101 Binkert CA, Benedetti R, Banyoczky G, et al. Sonographic identification of appendicolithiasis in the hepatorenal recess. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Jan. 1998;168(1):95-6. [pmid: 9501941].
102 Binnebosel M, Otto J, Stumpf M, et al. Acute appendicitis. Modern diagnostics--surgical ultrasound. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jul. 2009;80(7):579-87. [pmid: 19471900].
103 Birzle H, Berka W, Predic M, et al. Advances in the roentgenologic diagnosis of acute abdominal diseases. Deutsche medizinische Wochenschrift (1946). Dec. 17. 1965;90(51):2287-9. [pmid: 5322402].
104 Blank W, Braun B. Sonography in the diagnosis of appendicitis--a prospective study. Zeitschrift fur Gastroenterologie. Nov. 1988;26(11):708-14. [pmid: 3059705].
105 Blasinska MJ, Wilczynski J. Ceruloplasmin activity in various acute and chronic inflammatory conditions. Wiadomosci lekarskie (Warsaw, Poland : 1960). Jun. 1. 1980;33(11):871-6. [pmid: 7423990].
106 Blazquez Ruiz R, Lozano Parras MA, Poza Montoro A, et al. Self-limited abdominal pain: diagnostic imaging. Revista clinica espanola. Jan. 2005;205(1):33-4. [pmid: 15718017].
107 Bleck JS, Terkamp C, Manns M, et al. Ultrasound of acute abdomen. Der Internist. May. 2003;44(5):542-6. 8. 52. 54. 6. [pmid: 12966784].
108 Bloching H, Colakoglu Z, Reuss J, et al. Routine sonography in suspected appendicitis. A trial of 24-hour screening at a general hospital. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Jun. 1989;10(3):177-81. [pmid: 2672323].
109 Bobrzynski A, Budzynski A, Strzalka M. Laparoscopy in abdominal emergencies. Przeglad lekarski. 2002;59(10):873-6. [pmid: 12632933].
110 Bockemuhl J, Schmitt H, Bednarek I. Incidence of intestinal disease due to Yersinia enterocolitica (author’s transl). Zentralblatt fur Bakteriologie, Parasitenkunde, Infektionskrankheiten und Hygiene Erste Abteilung Originale Reihe A: Medizinische Mikrobiologie und Parasitologie. Nov. 1978;242(1):42-51. [pmid: 367003].
111 Boermeester MA, Stoker J. Accurate predictors for acute diverticulitis. Nederlands tijdschrift voor geneeskunde. 2011;155:A2848. [pmid: 21262029].
112 Bohner H, Yang Q, Franke K, et al. Avoiding abdominal roentgen images in acute abdominal pain--evaluation of a simple clinical decision support aid. Langenbecks Archiv fur Chirurgie Supplement Kongressband Deutsche Gesellschaft fur Chirurgie Kongress. 1998;115:982-4. [pmid: 9931766].
113 Bohner H, Yang Q, Franke K, et al. Significance of anamnesis and clinical findings for diagnosis of acute appendicitis. Acute Abdominal Pain Study Group. Zeitschrift fur Gastroenterologie. Oct. 1994;32(10):579-83. [pmid: 7716993].
114 Bombardieri T, Capocasale R, Cafiero C, et al. Diagnostic accuracy in 267 patients with suspected appendicitis: a retrospective study. Chirurgia italiana. Nov–Dec. 2004;56(6):805-10. [pmid: 15771034].
115 Bonzanigo C. Radiologic findings in abdominal pain in children (author’s transl). Monatsschrift Kinderheilkunde : Organ der Deutschen Gesellschaft fur Kinderheilkunde. Mar. 1979;127(3):125-34. [pmid: 423901].
116 Bonzanigo C. X-ray findings in children with abdominal pain (author’s transl). Monatsschrift Kinderheilkunde : Organ der Deutschen Gesellschaft fur Kinderheilkunde. Mar. 1982;130(3):143-4. [pmid: 7087972].
117 Boquien Y, Herbouiller M, Delumeau G, et al. VALUE OF PERITONEOSCOPY IN THE DIAGNOSIS OF ACUTE ABDOMINAL DISEASES. Presse medicale (Paris, France : 1983). Jun. 13. 1964;72:1701-6. [pmid: 14154046].
118 Borgnon J, Laffage PM, Sapin E. Acute appendicitis in children: is there an histo-clinical correlation?. Archives de pediatrie : organe officiel de la Societe francaise de pediatrie. Feb. 2005;12(2):234-8. [pmid: 15694557].
119 Borowik M, Nielubowicz J, Jakubowski W, et al. Evaluation of ultrasonic examination in the diagnosis of acute abdominal diseases. Polski przeglad radiologii/Polskie Lekarskie Towarzystwo Radiologiczne. Jan–Feb. 1988;52(1):23-8. [pmid: 3075025].
120 Borup K, Rasmussen KL, Knudsen TA. Complications in patients who underwent appendectomy for mistakenly diagnosed acute appendicitis. Ugeskrift for laeger. Apr. 20. 1992;154(17):1165-7. [pmid: 1604742].
121 Bostanov Kh A, Putiatin SV. Various clinical and hematological indicators in different forms of acute appendicitis. Klinicheskaia khirurgiia. Apr. 1985;(4):11-2. [pmid: 4010162].
122 Boudiaf M, Zidi SH, Soyer P, et al. Primary epiploic appendicitis: CT diagnosis for conservative treatment. Presse medicale (Paris, France : 1983). Feb. 12. 2000;29(5):231-6. [pmid: 10701398].
123 Bouillot JL, Aouad K, Alamowitch B, et al. Laparoscopic appendectomy in the adult. Chirurgie; memoires de l’Academie de chirurgie. Jun. 1998;123(3):263-9. discussion 9–70. [pmid: 9752517].
124 Bouillot JL, Ruiz A, Alamowitch B, et al. Suspected acute appendicitis. Role of enhanced helical computed tomography. Prospective study of 100 patients. Annales de chirurgie. Jun. 2001;126(5):427-33. [pmid: 11447793].
125 Boulmont M, Urbain P. Exploratory laparotomy under local anesthesia. Revue medicale de Bruxelles. Mar–Apr. 1995;16(2):69-70. [pmid: 7784739].
126 Bourrillon A. Acute abdominal pain in children. La Revue du praticien. Feb. 1. 1998;48(3):321-4. [pmid: 9781082].
127 Brandli H. Gray zones in colonoscopy. Schweizerische Rundschau fur Medizin Praxis = Revue suisse de medecine Praxis. Oct. 30. 1984;73(44):1327-31. [pmid: 6393276].
128 Braun B, Blank W. Ultrasonic diagnosis of acute appendicitis. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Jun. 1989;10(3):170-6. [pmid: 2672322].
129 Braun U, Stellamor K, Leitner H. Sonography in the diagnosis of acute abdomen. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Aug. 1984;5(4):160-3. [pmid: 6385242].
130 Breaud J, Montoro J, Lauron J, et al. Value of appendicitis scoring systems in children. Archives de pediatrie : organe officiel de la Societe francaise de pediatrie. Jun. 2008;15(5):553-5. [pmid: 18582670].
131 Breetholt A, Schelling J. Abdominal pain in a general practitioner’s practice. DoctorConsult - The Journal Wissen fur Klinik und Praxis. 2011;2(1):3-5. PMID:.
132 Breglia A, Prisco L. Behavior of leukocyte sedimentation rate in traumatic lesions and in acute surgical conditions. Rassegna internazionale di clinica e terapia. Jun. 15. 1967;47(11):609-23. [pmid: 5607585].
133 Brennhovd IO, Lied RO. Eosinopenia and acute appendicitis. Nordisk medicin. Jun. 10. 1954;51(24):811-3. [pmid: 13176747].
134 Bret P, Descos L, Amiel M. Radiology of the appendix. (Critical study of radiologic signs of appendicitis and its complications). Annales de radiologie. 1965;8(9):615-28. [pmid: 5850176].
135 Bretagnol F, Zappa M, Panis Y. Ultrasound and CT imaging in the diagnosis of acute appendicitis. Journal de chirurgie. Oct. 2009;146(Spec 1):8-11. [pmid: 19846096].
136 Brieler HS. Laparoscopic appendectomy. Krankenpflege Journal. Oct. 1992;30(10):478-82. [pmid: 1293357].
137 Brigand C, Steinmetz JP, Rohr S. The usefulness of scores in the diagnosis of appendicitis. Journal de chirurgie. Oct. 2009;146(Spec 1):2-7. [pmid: 19846100].
138 Brighenti GM. VELOCITY OF SEDIMENTATION OF LEUKOCYTES IN ACUTE ABDOMEN. Archivio di medicina interna. Sep–Dec. 1963;15:124-32. [pmid: 14158920].
139 Brinkmann WH. The significance of local leukocytosis for the diagnosis of appendicitis. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Aug. 1968;39(8):354-6. [pmid: 5679406].
140 Brontvein AT, Egorov VI, Vit’ko NK, et al. Radiodiagnosis of acute appendicitis. Khirurgiia. 2002;(12):13-6. [pmid: 12522920].
141 Brusori G, Motta R, Tonti R. Images of acute abdomen. Radiologic considerations. Minerva medica. Feb. 21. 1966;57(15):608-16. [pmid: 5929999].
142 Buchler MW, Wente MN. Acute appendicitis: current surgical value of diagnostics and therapy standards. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jul. 2009;80(7):577-8. [pmid: 19562238].
143 Budzynski A, Bobrzynski A, Rembiasz K, et al. Laparoscopic emergency surgery. Przeglad lekarski. Suppl 7. 2003;60:20-4. [pmid: 14679687].
144 Buianov VM, Perminova GI, Anakhasian VR, et al. Results of emergency laparoscopy in middle-aged and aged patients with acute diseases of the abdominal organs. Klinicheskaia khirurgiia. Apr. 1985;(4):48-51. [pmid: 3159931].
145 Buianov VM, Perminova GI, Sokolov AA, et al. Value of laparoscopy in the diagnosis and treatment of appendicular infiltrates. Sovetskaia meditsina. 1989;(4):98-100. [pmid: 2527413].
146 Buianov VM, Perminova GI. Laparoscopy in the diagnosis and treatment of acute diseases of the epiploic appendix. Khirurgiia. Jul. 1987;(7):102-5. [pmid: 2958653].
147 Bujnowska-Fedak MM, Krawiecka-Jaworska E. The role and usefulness of ultrasound in the diagnosis of abdominal pain in general practice. Family Medicine and Primary Care Review. 2009;11(1):21-5. PMID:.
148 Burcos T, Dimitriu C, Cristian D, et al. The place of laparoscopy in assessing and treating a pain syndrome of the right iliac fossa. Chirurgia (Bucharest, Romania : 1990). May–Jun. 1998;93(3):155-8. [pmid: 9755579].
149 Burlet G, Judlin P. Acute pelvic pain syndrome. Diagnostic and therapeutic approach in women. Revue francaise de gynecologie et d’obstetrique. Nov. 1994;89(11):537-42. [pmid: 7817082].
150 Burova RA, Tronin R, Nesterenko Iu A, et al. Laparoscopy in the differential diagnosis of acute abdomen. Khirurgiia. Mar. 1994;(3):16-20. [pmid: 8007605].
151 Butsenko VN, Popandopulo GD. Laparoscopic diagnosis in emergency surgery. Klinicheskaia khirurgiia. Apr. 1983;(4):64-5. [pmid: 6223174].
152 Fu JY, Chen C. Reason analysis of reoperation after failed laparoscopic surgery for acute abdomen. [pmid: 22736133].
153 Calvo Rigual F, Sendra Esteve S, Mialaret Lahiguera A, et al. The value of C-reactive protein in the diagnosis of acute appendicitis in children. Anales espanoles de pediatria. Apr. 1998;48(4):376-80. [pmid: 9629795].
154 Canarelli JP, Lenaerts C, Quintard JM, et al. Current aspects of the complications of acute appendicitis in children. Acta chirurgica Belgica. May–Jun. 1983;82(3):227-34. [pmid: 6880533].
155 Canavosso L, Carena P, Carbonell JM, et al. Right iliac fossa pain and Alvarado Score. Cirugia espanola. May. 2008;83(5):247-51. [pmid: 18448027].
156 Cardi F, Bucceri A, Petralia G, et al. Role of ultrasonography in abdominal surgical emergencies. Our experience. Annali italiani di chirurgia. Jan–Feb. 1996;67(1):61-4. [pmid: 8712619].
157 Cariati A, Brignole E, Tonelli E, et al. Laparoscopic or open appendectomy. Critical review of the literature and personal experience. Il Giornale di chirurgia. Oct. 2001;22(10):353-7. [pmid: 11816948].
158 Casciola L, Ceccarelli G, Bartoli A, et al. Laparoscopic approach versus laparotomy for suspected acute appendicitis. Il Giornale di chirurgia. Nov–Dec. 2002;23(11–12):440-4. [pmid: 12652921].
159 Cassina P, Rothlin M, Largiader F. Efficacy of basic surgical diagnosis in acute abdominal pain. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Mar. 1996;67(3):254-60. [pmid: 8681700].
160 Catalano O. Diagnostic value of computerized tomography in acute appendicitis in adults. La Radiologia medica. Jun. 1995;89(6):798-803. [pmid: 7644731].
161 Catani M, De Milito R, Chiaretti M, et al. Laparoscopy in emergency: treatment of choice in acute abdomen. Il Giornale di chirurgia. Oct. 2000;21(10):409-16. [pmid: 11126742].
162 Caterino S, Meli C, Capotondi C, et al. Role of ultrasonography in emergency surgery. Annali italiani di chirurgia. Jan–Feb. 1995;66(1):87-97. discussion -8. [pmid: 7668486].
163 Champault G, Rizk N, Lauroy J, et al. Right iliac fossa pain in women. Conventional diagnostic approach versus primary laparoscopy. A controlled study (65 cases). Annales de chirurgie. 1993;47(4):316-9. [pmid: 8352508].
164 Champault G, Rizk N, Ziol M, et al. Can we recognize the pathological character of the appendix during laparoscopy? Prospective study: 81 cases. Journal de chirurgie. Nov. 1996;133(7):320-3. [pmid: 9084733].
165 Chantada G. Radiation exposure from CT scans in childhood and subsequent risk of leukaemia and brain tumours: A retrospective cohort study. Archivos Argentinos de Pediatria. 2012;110(5):450-1.
166 Charrier T, Zinzindohoue F. Treatment of acute appendicitis: history and evolution of practices. La Revue du praticien. Apr. 2013;63(4):522-3. [pmid: 23682483].
167 Cherepanin AI, Nechaenko AM, Nechiporenko EI. Laparoscopic removal of intraabdominal foreign body. Khirurgiia. 2007;(12):47-8. [pmid: 18335596].
168 Chernetsov AA. Determining the capillary asymmetry index in the diagnosis of acute surgical diseases of the abdominal organs. Vestnik khirurgii imeni I I Grekova. Jan. 1989;142(1):127-9. [pmid: 2524922].
169 Chernomorskaia OD, Nikanorov AV, Bychkov Iu P. Prospects for ultrasound diagnosis of acute appendicitis and some of its complications. Eksperimental’naia i klinicheskaia gastroenterologiia. Experimental & clinical gastroenterology. 2003;(2):74-7. [pmid: 12875004].
170 Cheron G, Faesch S, Chalouhi C. Abdominal pain in children. Traps and diagnosis. Archives de pediatrie : organe officiel de la Societe francaise de pediatrie. Jun. 2006;13(6):814-6. [pmid: 16697589].
171 Cheskis AL. Rheumatic appendicitis in children. Sovetskaia meditsina. Dec. 1967;30(12):49-53. [pmid: 5606292].
172 Chetverikova VN, Polad’ko EP. Role of laparoscopy in the differential diagnosis of acute appendicitis and ovarian apoplexy. Klinicheskaia khirurgiia. Apr. 1982;(4):49-50. [pmid: 6212711].
173 Chipponi J, Pezet D. Complementary tests in acute appendicitis. La Revue du praticien. Mar. 15. 1992;42(6):689-92. [pmid: 1534630].
174 Chmielewski T, Wolter F. Value of ultrasound in diagnosis of appendicitis. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:38-40. [pmid: 9880869].
175 Chouchane A, Smaoui K, Beldi M, et al. Laparoscopic appendectomy. La Tunisie medicale. Mar. 1997;75(3):117-20. [pmid: 9506033].
176 Christoforov B. Acute appendicitis: can we reduce unnecessary surgery and imaging investigations?. Presse medicale (Paris, France : 1983). Mar. 2006;35(3 Pt 1):375-6. [pmid: 16550123].
177 Chumakov VI, Goncharov VG. Interspecies similarity of the trajectory of reactive leukocytosis. Biulleten’ eksperimental’noi biologii i meditsiny. Nov. 1987;104(11):620-2. [pmid: 3676505].
178 Cigliano B, Baltogiannis N, Sertimi A. Acute appendicitis. Medico e Bambino. 2003;22(2):99-102. PMID:.
179 Cinotti A, Duati M, Leprotti S, et al. Diagnostic impact of ultrasonography in abdominal diseases. La Radiologia medica. May. 1996;91(5):596-600. [pmid: 8693126].
180 Citterio O, Carioni N, Cabella R, et al. Use of ultrasonography in the diagnosis of acute appendicitis. La Radiologia medica. Nov. 1990;80(5):665-8. [pmid: 2267385].
181 Clavien PA, Junod P, Chapuis G. A prospective study of 776 cases of acute non-traumatic abdominal pain. Acute appendicitis and its diagnosis. Schweizerische medizinische Wochenschrift. Aug. 15. 1987;117(33):1205-12. [pmid: 3672066].
182 Clemente JL, Vicente F, de Oca J, et al. Evaluation in the diagnosis of acute appendicitis. Revista de medicina de la Universidad de Navarra. Mar. 1981;25(1):25-8. [pmid: 7336015].
183 Coburg AJ, Wolharn R, Reuter F, et al. Value of laparoscopy in suspected appendicitis. Langenbecks Archiv fur Chirurgie Supplement Kongressband Deutsche Gesellschaft fur Chirurgie Kongress. 1996;113:550-2. [pmid: 9101927].
184 Coche G, Vanthournout I, Moran V, et al. Tomographic study of the intra-abdominal digestive tract. Contributions of percutaneous echography and scanner in daily practice. Journal de radiologie. Sep. 1996;77(9):611-36. [pmid: 8944118].
185 Corsale I, Buccianelli E, Sorce S, et al. Appendicectomy: laparoscopic versus open treatment. A case survey. Minerva chirurgica. Feb. 2005;60(1):55-9. [pmid: 15902054].
186 Corvo M, Sartori A. The child with suspect acute appendicitis in emergency care. La Pediatria medica e chirurgica : Medical and surgical pediatrics. May–Aug. 2005;27(3–4):53-8. [pmid: 16910451].
187 Costa G, Tierno SM, Stella F, et al. Acute abdomen in renal transplant recipients. Epidemiology and treatment in not referral transplantation centers. Il Giornale di chirurgia. Nov–Dec. 2010;31(11–12):497-501. [pmid: 21232191].
188 Cougard P, Robert-Valla C, Coudert M, et al. Helical computed tomography in the diagnosis of acute appendicitis. Annales de chirurgie. Jan. 2002;127(1):73-4. [pmid: 11833313].
189 Covarelli P, Cristofani R, Bussotti C, et al. Acute abdomen: experience with 196 consecutive cases. Chirurgia italiana. May–Jun. 2007;59(3):291-7. [pmid: 17663366].
190 Cozza F. ON CHRONIC APPENDICITIS. VALUE OF PERITYPHLITIS IN THE INTRAOPERATIVE DIAGNOSIS OF CHRONIC APPENDICITIS “AB INITIO”. Annali di medicina navale. May–Jun. 1965;70:381-400. [pmid: 14345269].
191 Craus W, Di Giacomo A, Tommasino U, et al. Laparoscopic appendectomy and laparotomy appendectomy: comparison of methods. Chirurgia italiana. May–Jun. 2001;53(3):327-37. [pmid: 11452817].
192 Crismer R, Dreze C. Value of radiological signs in diagnosis of appendicular abscess. Acta gastro-enterologica Belgica. Mar. 1957;20(3):240-52. [pmid: 13424096].
193 Cristalli B, Nos C, Heid M, et al. Laparoscopy, appendicitis and pregnancy. Journal de gynecologie, obstetrique et biologie de la reproduction. 1992;21(4):449. [pmid: 1385602].
194 Crnogorac S, Lovrenski J. Validation of the Alvarado score in the diagnosis of acute appendicitis. Medicinski pregled. Nov–Dec. 2001;54(11–12):557-61. [pmid: 11921691].
195 Crombe A, Weber F, Gruner L, et al. Abdominopelvic ultrasonography in suspected acute appendicitis: prospective study in adults. Annales de chirurgie. Jan. 2000;125(1):57-61. [pmid: 10921186].
196 Crone-Munzebrock W, Steiner P. Sonography of the acute abdomen. Rontgenpraxis; Zeitschrift fur radiologische Technik. Jan. 1992;45(1):1-4. [pmid: 1539132].
197 Crone-Munzebrock W, Wegener C, Nicolas V, et al. The relevance of sonography in the diagnosis of acute abdomen in the intensive care unit. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Oct. 1990;153(4):379-84. [pmid: 2171081].
198 Cuenod CA, Wind P, Siauve N, et al. Emergency diagnosis of acute digestive tract abdominal pain in adults. Contribution of imaging. Gastroenterologie clinique et biologique. Nov. 1999;23(11):1170-86. [pmid: 10617824].
199 Cueto Garcia J, Ribe Bello J, Giorgiana LA, et al. Morbidity and mortality of appendicitis. Revista de gastroenterologia de Mexico. Sep–Dec. 1977;42(3):126-38. [pmid: 616979].
200 Cziupka K, Kunath H, Seidel U, Mirow L. Diverticulitis of the small intestine as a rare differential diagnosis in patients with upper abdominal pain. [pmid: 21544756].
201 D’Abbicco D, Amoruso M, Notarnicola A, et al. Acute appendicitis: is this common pathology still of interest?. Chirurgia italiana. Mar–Apr. 2007;59(2):155-70. [pmid: 17500172].
202 Dapra L, Olino P. The use of ultrasonics in the diagnosis of some abdominal diseases. Minerva medica. Jun. 21. 1952;43(50):1341-6. [pmid: 12992713].
203 Datuashvili DL, Megreladze Iu P, Gugava I. Value of radioisotope renography in the differential diagnosis of renal colic and acute abdomen. Urologiia i nefrologiia. May–Jun. 1972;37(3):58-60. [pmid: 5028926].
204 Daudet M, Deferenne P, Grobert JF. Acute appendicitis in the infant and very young child. Possibilities and value of an early diagnosis. Annales de chirurgie infantile. Sep. 1965;6(3):155-87. [pmid: 5850167].
205 Daudet M, Deffenne P, Grobert JF. ACUTE APPENDICITIS IN INFANTS AND VERY YOUNG CHILDREN. POSSIBILITIES AND VALUE OF AN EARLY DIAGNOSIS. Pediatrie. Mar. 1965;20:167-80. [pmid: 14347413].
206 Dauphin J. Appendix and foreign bodies. Journal de radiologie, d’electrologie & archives d’electricite medicale. 1951;32(1–2):95-6. [pmid: 14841708].
207 Davidovics S. Quality control--results of the first survey of pediatric surgery in Hungary. Orvosi hetilap. Aug. 31. 1997;138(35):2181-3. [pmid: 9324679].
208 de Brito P, Gomez MA, Besson M, et al. Frequency and epidemiology of primary epiploic appendagitis on CT in adults with abdominal pain. Journal de radiologie. Feb. 2008;89(2):235-43. [pmid: 18354354].
209 de Brito P, Gomez MA, Besson M, Scotto B, Huten N, Alison D. Frequency and epidemiology of primary epiploic appendagitis on CT in adults with abdominal pain. Journal de radiologie. 2008;89(2):235-43. PMID:. [pmid: 18354354].
210 de Carvalho BR, Diogo-Filho A, Fernandes C, et al. Leukocyte count, C reactive protein, alpha-1 acid glycoprotein and erythrocyte sedimentation rate in acute appendicitis. Arquivos de gastroenterologia. Jan–Mar. 2003;40(1):25-30. [pmid: 14534661].
211 De Mestier du Bourg P. Diagnosis of a pelvic mass. Journal de chirurgie. Oct. 1998;135(4):168. [pmid: 9827396].
212 De Miguel E, Somoza A. Laparoscopy in acute abdominal syndromes. Revista espanola de las enfermedades del aparato digestivo y de la nutricion. Aug–Sep. 1959;18:1073-5. [pmid: 13814926].
213 De Rosa G, Peppas C, D’Ambrosio R, et al. Acute appendicitis in pregnancy. Our experience. Minerva chirurgica. Nov. 1996;51(11):939-44. [pmid: 9072722].
214 De Vries J, De Kleine MJ. Ancillary diagnostic imaging is useful if there is atypical evidence of appendicitis. Nederlands tijdschrift voor geneeskunde. Jun. 30. 2007;151(26):1484-5. author reply 5. [pmid: 17633980].
215 Decker K. Indications and results of diagnostic laparoscopy in the assessment of lower abdominal pain. Geburtshilfe und Frauenheilkunde. Dec. 1988;48(12):884-6. [pmid: 2976698].
216 Degenhart C. Diagnostic value of multislice computed tomography for thoracic and abdominal emergencies. Notfall und Rettungsmedizin. 2010;13(6):451-7. PMID:.
217 del Arco Galan C, Parra Gordo ML, Garcia-Casasola Sanchez G. Imaging tests in acute abdominal pain. Revista clinica espanola. Nov. 2008;208(10):520-4. [pmid: 19100135].
218 del Rio Martin JV, Ashraf Memon M. The justification for laparoscopic appendectomy. Revista espanola de enfermedades digestivas : organo oficial de la Sociedad Espanola de Patologia Digestiva. Jun. 1999;91(6):447-55. [pmid: 10431093].
219 Demharter J. Ultrasound diagnosis of acute appendicitis--really an additional source of information?. Rontgenpraxis; Zeitschrift fur radiologische Technik. 1999;52(3–4):130-6. [pmid: 10522454].
220 Demircan A, Aygencel G, Karamercan M, et al. Ultrasonographic findings and evaluation of white blood cell counts in patients undergoing laparotomy with the diagnosis of acute appendicitis. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. May. 2010;16(3):248-52. [pmid: 20517752].
221 Denisov GF, Larichev OI, Malygin VP, et al. Diagnosis of acute surgical diseases of the abdominal organs using a shipboard computer during a cruise. Voenno-meditsinskii zhurnal. Jan. 1988;(1):58-9. [pmid: 3284192].
222 Derelle A, Tissier S, Granger P, Barbary C, Rousseau A, Laurent V, Tortuyaux J, Marchal F, Régent D. Diagnostic précoce de pseudomyxome péritonéal localisé à la zone de rupture d’une mucocèle appendiculaire : imagerie et aspects anatomopathologiques. [pmid: 24928799].
223 Dhiman N, Chi A, Pawlik TM, et al. Increased death and complications after appendectomy in patients with cerebral palsy: Are special needs patients at risk for disparities in outcomes?. Journal of Surgical Research. 2013;179(2). PMID:.
224 Diau GY, Chu CC, Wu MC, Hsu TM. No drain for perforated appendicitis in children: A single institute experience. Journal of Surgical Association Republic of China [serial on the Internet]. 1995;(3). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/294/CN-00392294/frame.html. Last accessed.
225 Diaz Moreno E, Garcia Gomez M, Castejon Casado J, et al. Analysis of the medical decision in abdominal pain suggestive of acute appendicitis. Cirugia pediatrica : organo oficial de la Sociedad Espanola de Cirugia Pediatrica. Jan. 2012;25(1):40-5. [pmid: 23113412].
226 Dietlein M, Sieske L, Otto R. Your ultrasound diagnosis? Chronic appendicitis. Praxis. Nov. 15. 2001;90(46):1997-9. [pmid: 11817243].
227 Dirks K. Acute appendicitis. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Oct. 2001;22(5):M83. [pmid: 11789473].
228 Doletskii S, Shchitinin VE, Dvorovenko EV. Characteristics of surgical tactics in children with acute appendicitis. Khirurgiia. Feb. 1990;(2):93-7. [pmid: 2335900].
229 Domergue J, Noel P, Fabre JM, et al. The role of celioscopy in the diagnosis of acute abdomen. Annales de chirurgie. 1992;46(4):287-9. [pmid: 1535186].
230 Domergue J. Contribution of celioscopy in abdominal emergencies. Soins Chirurgie (Paris, France : 1982). Aug–Sep. 1992;(138–139):11-3. [pmid: 1492167].
231 Dong P, Li J, Cui H, et al. Anatomical evaluation of multiple-detector spiral CT for medical attachment of the posterior renal fascia. Journal of Clinical Rehabilitative Tissue Engineering Research. 2009;13(4):793-6. PMID:.
232 Doringer E, Feurstein M. What does ultrasound study contribute in acute appendicitis (using dosed compression)?. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Aug. 1988;9(4):185-8. [pmid: 3051363].
233 Drapala B, Trognon B, Canarelli JP, et al. Neonatal appendicitis. Archives de pediatrie : organe officiel de la Societe francaise de pediatrie. Aug. 2000;7(8):896-7. [pmid: 10985195].
234 Dreuw B, Truong S, Riesener KP, et al. The value of sonography in the diagnosis of appendicitis. A prospective study of 100 patients. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Dec. 1990;61(12):880-6. [pmid: 2286106].
235 Drinkovic N. Age distribution and clinical characteristics in acute appendicitis. Vojnosanitetski pregled Military-medical and pharmaceutical review. Mar–Apr. 1991;48(2):115-9. [pmid: 1897169].
236 Dronov AF, Kotlobovskii VI, Dzhenalaev BK, et al. Initial experience with laparoscopic appendectomy in children. Khirurgiia. Apr. 1994;(4):20-4. [pmid: 8041065].
237 Dronov AF, Kuznetsova MN, Onika MD, et al. Laparoscopy in the diagnosis of inflammatory processes in the lesser pelvis of girls. Akusherstvo i ginekologiia. Mar. 1987;(3):26-8. [pmid: 2954479].
238 Dronov AF, Mainugin VV, Blinnikov OI. Achievements in the field of the objective diagnosis of acute appendicitis in children. Vestnik Akademii meditsinskikh nauk SSSR. 1984;(9):38-42. [pmid: 6238490].
239 Dronov AF, Poddubnyi IV, Smirnov AN, et al. Urgent laparoscopic surgeries in children of the first year of life. Khirurgiia. 2006;(2):18-22. [pmid: 16715979].
240 Dronov AF, Smirnov AN, Blinnikov OI. Hyperdiagnosis of acute appendicitis in children. Khirurgiia. Nov. 1989;(11):16-20. [pmid: 2533301].
241 Druart ML, Deschreyer M. Acute abdomen in octogenarians. Acta chirurgica Belgica. Mar–Apr. 1985;85(2):135-8. [pmid: 4013582].
242 Dubrov E, Chervonenkis AV. Ultrasonic diagnosis in acute surgical diseases of the organs of the abdominal cavity. Khirurgiia. Jan. 1984;(1):89-91. [pmid: 6700182].
243 Duhamel P, Chapuis F, Neidhardt JP, et al. Appendectomy: evaluation of medical record maintenance in a series of 200 cases. Annales de chirurgie. 1998;52(9):896-904. [pmid: 9882879].
244 Durand C, Piolat C, Nugues F, et al. Contribution of radiology to the diagnosis of appendicitis in children. Archives de pediatrie : organe officiel de la Societe francaise de pediatrie. Jun. 2008;15(5):556-8. [pmid: 18582671].
245 Dusek M, Skaba R, Heroldova D, et al. Uncommon clinical aspects of appendicitis. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Dec. 2002;81(12):631-4. [pmid: 12666478].
246 Dussaut J, Paoletti H, Colineau X, et al. What is it? Left-sided appendicitis. Journal de radiologie. Jan. 2000;81(1):59-61. [pmid: 10671727].
247 Dzhalagoniia AA, Achba ZI, Vakhrushev EN, et al. Intravenous administration of a hypertonic solution for the detection of “latent” leukocytosis in acute appendicitis. Vestnik khirurgii imeni I I Grekova. Nov. 1984;133(11):71-3. [pmid: 6523668].
248 Dzienis H, Rudy J, Miernik A. Value of white blood cell index determination in acute appendicitis. Wiadomosci lekarskie (Warsaw, Poland : 1960). Nov. 15. 1971;24(22):2091-3. [pmid: 5139141].
249 Eberle F. Functional colonic pain. An important clinical and sonographic differential diagnosis. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Jun. 1992;13(3):138-40. [pmid: 1502537].
250 Echeverria Alvarez E. Angiography in abdominal emergency. Cirugia y cirujanos. Sep–Dec. 1970;38(5):513-32. [pmid: 5315946].
251 Echeverry JA, Ceres L, Alonso I, et al. Acute appendicitis: echographic diagnosis and current therapy. Cirugia pediatrica : organo oficial de la Sociedad Espanola de Cirugia Pediatrica. Apr. 1988;1(2):91-4. [pmid: 3152891].
252 Eckel H. Sonography in emergency diagnosis of the abdomen (author’s transl). Rontgen-Blatter; Zeitschrift fur Rontgen-Technik und medizinisch-wissenschaftliche Photographie. May. 1980;33(5):244-8. [pmid: 7375770].
253 Efimenko NA, Chursin VV, Stepanov AA, et al. Medicinal and diagnostic laparoscopy in conditions of appendicitis. Voenno-meditsinskii zhurnal. Aug. 2007;328(8):19-24. 96. [pmid: 18154159].
254 Eichen R, Heuser H. Complications in laparoscopic appendectomy incorrect analysis, consequences. Minimal Invasive Chirurgie [serial on the Internet]. 1996. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/748/CN-00382748/frame.html. Last accessed.
255 Eichen R, Heuser H, Nitschke B. Laparoscopic or conventional appendectomy:a prospective study. Langenbecks Archiv fur Chirurgie [serial on the Internet]. 1994. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/998/CN-00335998/frame.html. Last accessed.
256 Eizaguirre Sexmilo I. Value of abdominal ultrasonography in the diagnosis of acute appendicitis. Anales de pediatria (Barcelona, Spain : 2003). Dec. 2003;59(6):603. [pmid: 14636530].
257 Elwertowski M, Graban W, Jakubowski W, et al. Ultrasonic diagnosis of suppurative lesions. Polski przeglad radiologii/Polskie Lekarskie Towarzystwo Radiologiczne. Mar–Apr. 1984;48(2):99-104. [pmid: 6395114].
258 Elwertowski M, Jakubowski W, Bazko E, et al. Ultrasonic diagnosis of suppurative conditions. Polski przeglad radiologii/Polskie Lekarskie Towarzystwo Radiologiczne. Jan–Feb. 1985;49(1):38-43. [pmid: 3903686].
259 Engebraten O. Diagnoses in medical and surgical patients. Experiences of a junior physician. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Apr. 20. 1994;114(10):1179-84. [pmid: 8209314].
260 Engelberg PE, D’Andretta Neto C, Pereira V, et al. Acute appendicitis: histopathologic picture, various aspects of its diagnosis and complications. AMB : revista da Associacao Medica Brasileira. Aug. 1980;26(8):279-84. [pmid: 6970950].
261 Erfani Fam T, Izadi SH, Niksirat A. Factors increasing the likelihood of positive pathology among one hundred appendectomy cases in Ayatollah Mousavi hospital of Zanjan. Journal of Zanjan University of Medical Sciences and Health Services. 2013;21(88). PMID:.
262 Eriksson S, Josephson T, Styrud J. A high degree of accuracy is possible in the diagnosis of appendicitis. Laboratory tests, ultrasonography and computerized tomography are of great value. Lakartidningen. Jun. 23. 1999;96(25):3058-61. [pmid: 10418251].
263 Ermolov AS, Bil’kovskii PI, Zharakhovich IA, et al. Emergency laparoscopy in abdominal surgery. Khirurgiia. Mar. 1986;(3):35-40. [pmid: 2939284].
264 Ermolov AS, Zharakhovich IA, Mosienko NI, et al. Laparoscopy in the diagnosis of acute appendicitis. Khirurgiia. Mar. 1987;(3):37-40. [pmid: 2953929].
265 Ermolov AS, Zharakhovich IA, Norman IM, et al. Emergency laparoscopy in the examination of middle-aged and elderly patients with acute surgical diseases of the abdominal cavity. Vestnik khirurgii imeni I I Grekova. Feb. 1988;140(2):124-8. [pmid: 2968709].
266 Eryilmaz R, Sahin M, Alimoglu O, et al. The value of C-reactive protein and leucocyte count in preventing negative appendectomies. Ulusal travma dergisi. Turkish journal of trauma & emergency surgery : TJTES. Jul. 2001;7(3):142-5. [pmid: 11705213].
267 Espinoza R, Balbontin P, Feuerhake S, et al. Acute abdomen in the elderly. Revista medica de Chile. Dec. 2004;132(12):1505-12. [pmid: 15743162].
268 Espinoza R, Ohmke J, Garcia-Huidobro I, et al. Negative appendectomy: experience at a university hospital. Revista medica de Chile. Jan. 1998;126(1):75-80. [pmid: 9629757].
269 Ethier S, Bier R, Laperriere J, et al. The value of echography in severe pain in the right hypochondrium. L’union medicale du Canada. Sep. 1979;108(9):1057-9. [pmid: 543043].
270 Everarts P, Clapuyt P, Claus D, et al. The role of ultrasonography in abdominal pain in children in the emergency room. Journal belge de radiologie. Oct. 1994;77(5):201-3. [pmid: 7961362].
271 Excoffier S, Poletti PA, Brandstatter H. Acute abdominal pain of the upper abdomen: which imaging to choose?. Rev Med Suisse. Sep. 25. 1712. 2013;9(399):1710-4. [pmid: 24163877].
272 Eypasch E, Menningen R, Paul A, et al. Value of laparoscopy in diagnosis and therapy of the acute abdomen. Zentralblatt fur Chirurgie. 1993;118(12):726-32. [pmid: 8147145].
273 Fabiani P, Bartels AM, Cursio R, et al. Laparoscopic treatment of appendiceal peritonitis in adults. Annales de chirurgie. 1996;50(10):892-5. [pmid: 9183874].
274 Fadeev OA, Klimanskii VA. Emergency laparoscopy in hematology practice. Gematologiia i transfuziologiia. May–Jun. 1995;40(3):23-6. [pmid: 7642077].
275 Faggi U, Giovane A. Diagnostic laparoscopy in non traumatic abdominal emergencies. Minerva chirurgica. Feb. 2003;58(1):9-16. [pmid: 12692492].
276 Fagniez PL, Koffi E, Panis Y. Appendicular peritonitis. La Revue du praticien. Mar. 15. 1992;42(6):706-10. [pmid: 1598523].
277 Fahrlander H. Emergency laparoscopy. Report on 248 examinations. Langenbecks Archiv fur Chirurgie. Dec. 29. 1972;331(4):315-20. [pmid: 4268123].
278 Fahrner R, Guller U. Abdominal pain without any identifiable cause: a guide for the general practitioner. Therapeutische Umschau Revue therapeutique. Aug. 2011;68(8):456-8. [pmid: 21796597].
279 Fanzago G. Anatomopathological study of allergic appendicitis, with special reference to local eosinophilia. Minerva ginecologica. Nov. 30. 1954;6(22):780-4. [pmid: 14355788].
280 Federici PV, Preziosi P, Karakaci F, et al. Echographic study in evaluating gastrointestinal pathology. Minerva medica. Dec. 15. 1986;77(47–48):2205-8. [pmid: 3543739].
281 Feneyrou B, Courty P, Prioton JB. Acute abdomen in familial Mediterranean fever. False or true surgical abdomen?. Presse medicale (Paris, France : 1983). Sep. 20. 1986;15(30):1422. [pmid: 2947064].
282 Fenyo G, de Dombal FT, Clamp SE, et al. Clinical and computer-assisted diagnosis of 233 patients with acute abdomen. Lakartidningen. Apr. 13. 1983;80(15):1607-12. [pmid: 6348448].
283 Fenyo G. Computers and point systems as diagnostic aids in acute abdomen. Lakartidningen. Feb. 15. 1989;86(7):546-8. [pmid: 2645489].
284 Feres O, Parra RS. Acute abdomen. Medicina. 2008;41(4):430-6. PMID:.
285 Ferlengez E, Ferlengez AG, Akbulut H, Kadioglu H. Evaluation of four different scoring systems in the management of acute appendicitis; a prospective clinical study. Haseki Tip Bulteni. 2013;51(1):15-7. PMID:.
286 Fernandez Lobato R. Imaging tests and acute appendicitis: the importance of quality health care. Revista de calidad asistencial : organo de la Sociedad Espanola de Calidad Asistencial. Jul–Aug. 2010;25(4):183-5. [pmid: 20435497].
287 Fernez F, Karaorman M, Richter A, Lorenz D, Trede M. Laparoscopic verses conventional appendectomy Results of a prospective study on 571 patients. Zentralblatt fur Chirurgie [serial on the Internet]. 1997. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/761/CN-00352761/frame.html. Last accessed.
288 Ferrari P. The leukocyte sedimentation rate in some inflammatory diseases of surgical interest. Rivista di patologia e clinica. Feb. 1963;18:55-64. [pmid: 13944851].
289 Ferrari Parabita G, Repossini L. Critical review on the significance of some “acute lesion” indices. Rivista di patologia e clinica. Dec. 1962;17:1189-99. [pmid: 13962944].
290 Ferret Maldonado O, Bueno Bruzon R, Arendt R. Diagnostic reliability of emergency laparoscopy (author’s transl). Deutsche Zeitschrift fur Verdauungs- und Stoffwechselkrankheiten. 1980;40(3–4):119-25. [pmid: 6450043].
291 Ferri E, Bonvicini U, Pisani M. Ultrasonography of normal vermiform appendix. Chirurgia italiana. Jan–Feb. 2001;53(2):231-8. [pmid: 11396073].
292 Ficek W. Value of a leukogram in acute appendicitis in children. Pediatria polska. Aug. 1958;33(8):943-8. [pmid: 13600890].
293 Fiedler H, Thiele G. The value of clinical and paraclinical parameters in the diagnosis of acute abdominal diseases as based on the patient material of a medical clinic. Zeitschrift fur die gesamte innere Medizin und ihre Grenzgebiete. Apr. 1. 1978;33(7):215-7. [pmid: 664804].
294 Filippkin MA, Shchitinin VE, Pykov MI, et al. Potentialities of echography in the diagnosis of uncomplicated acute appendicitis in children. Vestnik rentgenologii i radiologii. Sep–Oct. 1997;(5):25-9. [pmid: 9412045].
295 Findeisen B. Accuracy of appendicitis diagnosis in ambulatory care. Das Deutsche Gesundheitswesen. Apr. 27. 1972;27(17):791-4. [pmid: 5036939].
296 Fingerhut A, Yahchouchy-Chouillard E, Etienne JC, et al. Appendicitis or non-specific pain in the right iliac fossa?. La Revue du praticien. Oct. 1. 2001;51(15):1654-6. [pmid: 11759534].
297 Fingerhut A, Yahchouchy-Chouillard E, Etienne JC, Ghiles E. Appendicitis or right lower quadrant non-specific abdominal pain?. Revue du Praticien. 2001;51(15):1654-6. PMID:. [pmid: 11759534].
298 Flamant Y, Lacaine F, Hay JM, et al. Acute abdominal pain syndrome. The computer as an aid to diagnosis (author’s transl). La Nouvelle presse medicale. Dec. 19. 1981;10(46):3767-9. [pmid: 7033930].
299 Flamant Y, Zantain OL, Barge J. Questionable appendectomies. La Revue du praticien. Mar. 15. 1992;42(6):697-700. [pmid: 1598522].
300 Flamant Y. Appendicitis. Computer-assisted diagnosis. A clinical complementary test. La Revue du praticien. Mar. 15. 1992;42(6):694-6. [pmid: 1598521].
301 Foinant M, Lipiecka E, Buc E, et al. Impact of computed tomography on patient’s care in nontraumatic acute abdomen: 90 patients. Journal de radiologie. Apr. 2007;88(4):559-66. [pmid: 17464254].
302 Forsstrom JJ. The ROC curve in the measurement of the diagnostic value of tests. Duodecim; laaketieteellinen aikakauskirja. 1995;111(3):237-44. [pmid: 8654286].
303 Foulard M, Deconinck B, Grand M. Value of abdominal echotomography in children. Lille medical : journal de la Faculte de medecine et de pharmacie de l’Universite de Lille. Apr. 1976;21(4):302-7. [pmid: 950884].
304 Fournet C, Merzoug V, Adamsbaum C. Which imaging in front of abdominal pain in children?. La Revue du praticien. May. 2011;61(5):630-4. [pmid: 21698889].
305 Fournier AM, Guerin P. APPENDICULAR LITHIASIS. Journal de radiologie, d’electrologie, et de medecine nucleaire. Oct. 1963;44:670-2. [pmid: 14092874].
306 Fragoso-Maiz C, Ramos-Martinez E, Garcia-Martinez R, et al. Acute appendicitis. A clinicopathological analysis of 200 cases. Revista de gastroenterologia de Mexico. Oct–Dec. 1993;58(4):342-5. [pmid: 8159900].
307 Franco-Del Rio G, Gomez-Castro AG, Velasco-Ariza J, et al. Acute appendicitis in children. Experience at a general hospital. Boletin medico del Hospital Infantil de Mexico. Jan. 1989;46(1):35-40. [pmid: 2713047].
308 Francois Y, Bonvoisin S, Descos L, et al. Prospective study of a predictive scoring system for the diagnosis of appendicitis in patients with right lower quadrant pain. Long-term outcome. Gastroenterologie clinique et biologique. 1991;15(11):794-9. [pmid: 1769468].
309 Francois Y, Bonvoisin S, Descos L, Vignal J. Right lower quadrant pain: Prospective study of a clinical scoring system. Gastroenterologie clinique et biologique. 1991;15(11):794-9. PMID:. [pmid: 1769468].
310 Franke C, Ohmann C, Bohner H, et al. Is ultrasound examination in acute appendicitis dispensable? Acute Abdominal Pain Study Group. Langenbecks Archiv fur Chirurgie Supplement Kongressband Deutsche Gesellschaft fur Chirurgie Kongress. 1998;115:1114-6. [pmid: 9931808].
311 Franke C, Ohmann C, Yang Q. Clinical value of diagnostic score for appendicitis: results of a prospective intervention study. Langenbecks Archiv fur Chirurgie Supplement Kongressband Deutsche Gesellschaft fur Chirurgie Kongress. 1998;115(Suppl I):511-5. [pmid: 14518308].
312 Franke C, Verreet P, Ohmann C, et al. Clinical standardization in acute abdominal pain. Langenbecks Archiv fur Chirurgie. 1996;381(2):65-74. [pmid: 8649127].
313 Franke K. CT diagnosis of appendicitis - Neutral versus positive oral contrast agent. RoFo Fortschritte auf dem Gebiet der Rontgenstrahlen und der Bildgebenden Verfahren. 2011;183(8):690. PMID:.
314 Frassineti A, Momoli G, Aguzzoli RS. Diagnosis of acute abdominal conditions in gynecology, clinical, and radiologic picture. 3. Acute adnexitis connected with mechanical intestinal disorder. Ospedali d’Italia - chirurgia. Aug. 1967;17(2):167-79. [pmid: 5621255].
315 Frieling T. Acute abdomen - The medical point of view. Deutsche Medizinische Wochenschrift. 2009;134(6):246-50. PMID:. [pmid: 19180416].
316 Fuessl HS. Emergency checklist: acute cholecystitis. MMW Fortschritte der Medizin. Nov. 1. 2007;149(44):37. [pmid: 18080369].
317 Fujita W, Shigemoto H, Nishimoto T, et al. Acute appendicitis: a study on 118 patients. Nihon Geka Gakkai zasshi. Apr. 1985;86(4):464-9. [pmid: 4000102].
318 Gaidarski R, Georgiev T. The diagnostic significance of leukocytosis in the clinical picture of acute appendicitis. Khirurgiia. 1974;27(5):383-7. [pmid: 4466857].
319 Galindo Gallego M, Calleja Lopez S, Nieto MA, et al. The diagnostic value of echography in appendicitis in children. Anales espanoles de pediatria. Jan. 1998;48(1):28-32. [pmid: 9542224].
320 Gallico E, Markovits S. Clinico-radiologic observations on relations between gastroduodenal ulcer and appendicitis. Minerva medica. Jan. 17. 1966;57(5):120-31. [pmid: 5903549].
321 Gallinas-Victoriano F, Garde-Lecumberri C, Perez-Martinez A, et al. Ultrasonography for surgical pathology discrimination in acute abdominal pain. Prospective study. Cirugia pediatrica : organo oficial de la Sociedad Espanola de Cirugia Pediatrica. Jul. 2004;17(3):141-4. [pmid: 15503952].
322 Garcia JC. What is new in the diagnosis of appendicitis? Borborygmi in the cecal region. Journal de chirurgie. Nov. 1989;126(11):630-2. [pmid: 2584292].
323 Garcia JM. Value of Courvoisier’s law in the differential diagnosis of cholelithiasis; indications for the removal of the gallbladder and the appendix in related syndromes. Imprensa medica. May. 1951;27(449):63-6. [pmid: 14897389].
324 García Marín A, Mella Laborde M, Pérez Bru S, Nofuentes Riera C, Pérez López M, Compañ Rosique A, García García S. Appendiceal diverticulitis: comparative study of 7 cases versus 442 acute appendicitis. [pmid: 24847625].
325 Garcia-Baron A. The temperature in gastroduodenal ulcer perforations (and its comparison with that of appendicitis). Revista clinica espanola. Apr. 30. 1960;77:125-8. [pmid: 13826462].
326 Garlipp B, Arlt G. Laparoscopy for suspected appendicitis. Should an appendix that appears normal be removed?. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jul. 2009;80(7):615-21. [pmid: 19562237].
327 Gas’maev VK, Sheviakova TV. The differential diagnosis of acute appendicitis. Vestnik rentgenologii i radiologii. Mar–Apr. 1992;(2):54-6. [pmid: 1455673].
328 Gas’maev VK, Sheviakova TV. The ultrasonic diagnosis of acute appendicitis and its complications. Khirurgiia. Feb. 1992;(2):57-62. [pmid: 1388215].
329 Gassel HJ, Meyer D, Sailer M, et al. Nononcologic abdominal surgery in the elderly. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jan. 2005;76(1):35-42. [pmid: 15551006].
330 Gastinger I, Koch A, Lippert H, et al. Current status of treatment of appendicitis. Results of 2 prospective multicenter studies in East Germany. East German Working Group “Outcome Assessment and Quality Assurance in Surgery” of the CAQ of the German Society of Surgery. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:8-10. [pmid: 9880860].
331 Gegenava AP, Iakovlev A. Acute appendicitis manifesting itself by symptoms of infectious disease. Sovetskaia meditsina. Aug. 1976;(8):154-5. [pmid: 1006416].
332 Geitung JT. Use of computer tomography in acute abdomen. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Apr. 7. 2005;125(7):890. [pmid: 15835031].
333 Gerdes B, Tobollik S, Lausen M. Rectal endosonography for detection of free fluid in the abdomen. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Aug. 1994;65(8):709-13. [pmid: 7956537].
334 Gerharz CD, Gabbert HE. Pathomorphological aspects of acute appendicitis. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jan. 1997;68(1):6-11. [pmid: 9132350].
335 Ghelase F, Georgescu I, St Ghelase M, et al. Septic complications in acute appendicitis. Problems of diagnosis and treatment. Chirurgia (Bucharest, Romania : 1990). Jan–Feb. 2007;102(1):43-9. [pmid: 17410729].
336 Gianom D, Kostler T, Goti F, et al. Effect of new technologies on diagnosis and therapy of acute appendicitis. Praxis. Feb. 13. 2002;91(7):275-84. [pmid: 11883363].
337 Gibbaoui H, Arnalsteen L, Bougard V, et al. Intestinal obstruction by a hernia through the foramen of Winslow. Annales de chirurgie. Jun. 2001;126(5):493-4. [pmid: 11447808].
338 Gil VF, Peinado E, Obrador E, et al. Validity of clinical tests to confirm or to exclude the diagnosis of acute appendicitis. Medicina clinica. Suppl 2. 2000;114:48-51. [pmid: 10916806].
339 Gille-Johnson P. Gangrene formation leading to fatal hemolysis. Lakartidningen. Feb. 21. 1996;93(8):686-9. [pmid: 8642943].
340 Gimondo P, Mirk P. Ultrasonographic diagnosis of acute appendicitis: current indications and limitations of the method. La Radiologia medica. Jun. 1997;93(6):751-8. [pmid: 9411525].
341 Glisenti P, Allemann F, Kunz-Caflisch I. Acute abdominal pain. Praxis. Aug. 11. 2010;99(16):949-59. [pmid: 20700869].
342 Gokce AH, Aren A, Gokce FS, et al. Reliability of ultrasonography for diagnosing acute appendicitis. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Jan. 2011;17(1):19-22. [pmid: 21341129].
343 Goldburt NN. ANALYSIS AND COMPARISON OF HISTOLOGICAL, MACRO-MICROSCOPIC AND HISTOTOPOGRAPHIC INVESTIGATIONS OF THE VERMIFORM APPENDIX. Khirurgiia. Oct. 1963;39:106-11. [pmid: 14135642].
344 Goldstein M. Value of radiography without contrast preparation in the diagnosis of acute abdominal disorders. Acta chirurgica Belgica. Jan. 1959;58(1):23-56. [pmid: 13660680].
345 Gomez MA, Bretagnol F. Epiploic appendagitis: a radiologic diagnosis. Journal de chirurgie. Dec. 2002;139(6):328-31. [pmid: 12538952].
346 Gomez Moreno R, Jimenez Vaquero I, Monge Ropero N, et al. Importance of primary care in early diagnosis of acute appendicitis and its repercussion on the population of Segovia. Approach to this pathology. Atencion primaria/Sociedad Espanola de Medicina de Familia y Comunitaria. Nov. 30. 2001;28(9):620. [pmid: 11747777].
347 Goncalves JP, Cerqueira A, Martins S. The Alvarado score validation in diagnosing acute appendicitis in children at Braga Hospital. Acta medica portuguesa. Dec. Suppl 2. 2011;24:583-8. [pmid: 22849950].
348 Gordeeva IP, Ivanova MN, Tsvetkova EI, et al. Cytochemical indicators of phagocytes in children with destructive appendicitis. Khirurgiia. Dec. 1984;(12):41-5. [pmid: 6097741].
349 Goshkina AI, Kolesov EV. Studies on C-reactive proteins in acute surgical diseases of abdominal organs. Vestnik khirurgii imeni I I Grekova. Aug. 1961;87:24-6. [pmid: 13707353].
350 Goudet P, Michelin T, Bernard A, et al. Practical role of ultrasonography and clinical examination for the diagnosis of acute appendicitis. Prospective study. Gastroenterologie clinique et biologique. 1991;15(11):812-6. [pmid: 1769470].
351 Grandjean JP, Arefiev A. Laparoscopic appendectomy. Review based on an homogeneous series of 906 cases. Annales de chirurgie. 1999;53(4):280-4. [pmid: 10327690].
352 Grantcharov TP, Schulze S. Diagnostic laparoscopy under local anaesthesia. Ugeskrift for laeger. Nov. 14. 2005;167(46):4360-2. [pmid: 16287520].
353 Grebeldinger S. Ultrasonographic diagnosis of acute appendicitis. Medicinski pregled. 1996;49(11–12):487-91. [pmid: 9019634].
354 Gresz M. Appendicitis in Hungary through the eyes of a health insurance specialist. Orvosi hetilap. Nov. 13. 2011;152(46):1843-8. [pmid: 22030361].
355 Grigoliia NG, Gogotishvili GT, Giorgobiani GT. The presense of acute appendicitis in the sac of inguinal hernia: case study. Georgian medical news. May. 2008;(158):7-10. [pmid: 18560031].
356 Grigovich IN, Derbenets VV. Into the 21st century with the problem of acute simple appendicitis. Vestnik khirurgii imeni I I Grekova. 2000;159(3):97-9. [pmid: 10983356].
357 Grishchenko EE. Acute appendicitis in patients with diabetes mellitus. Khirurgiia. Jun. 1989;(6):36-8. [pmid: 2779120].
358 Gritzmann N, Hubner E. Sonography of acute appencitis and the main differential diagnoses. Praxis. Apr. 19. 2006;95(16):631-7. [pmid: 16681156].
359 Groebli Y, Deruaz C, Merlini M, et al. Outcome of nonspecific right iliac fossa pain syndromes. Annales de chirurgie. 1998;52(10):959-64. [pmid: 9951094].
360 Gronroos JM. Too many unnecessary appendectomies. Leukocyte count and CRP value for safer diagnosis. Lakartidningen. Feb. 28. 2002;99(9):891-3. [pmid: 11962009].
361 Grossmann E, Krogh J. Emergency ultrasonic examinations. Ugeskrift for laeger. Jun. 18. 1990;152(25):1828-31. [pmid: 2194335].
362 Grundmann RT, Petersen M, Lippert H, et al. The acute (surgical) abdomen - epidemiology, diagnosis and general principles of management. Zeitschrift fur Gastroenterologie. Jun. 2010;48(6):696-706. [pmid: 20517808].
363 Grussner R, Pistor G, Engelskirchen R, et al. Appendicitis in childhood. Monatsschrift Kinderheilkunde : Organ der Deutschen Gesellschaft fur Kinderheilkunde. Mar. 1985;133(3):158-66. [pmid: 4010671].
364 Gualdi GF, Volpe A, Polettini E, et al. Role of CT in the evaluation of patients with painful symptoms located in the lower right abdominal quadrant. La Clinica terapeutica. Aug–Sep. 1995;146(8–9):519-28. [pmid: 8536434].
365 Guillemin F, Cao MM, Girard F, et al. Cost of medical imaging practices in acute abdominal syndromes. Presse medicale (Paris, France : 1983). Apr. 22–29. 2000;29(15):829-34. [pmid: 10827785].
366 Guillon F, Baron MP, Fagot H. Painful acute abdominal syndromes. Diagnostic and therapeutic contribution of tomodensitometry. Soins Chirurgie (Paris, France : 1982). Aug–Sep. 1992;(138–139):8-10. [pmid: 1492182].
367 Gunvén P. More rectal palpation!. Lakartidningen. Feb. 19–25. 2014;111(8):347. [pmid: 24669458].
368 Guthy E. Clinical signs and diagnosis of acute appendicitis. Zentralblatt fur Chirurgie. 1999;124(6):554-5. discussion 5–6. [pmid: 10436515].
369 Guzman-Valdivia Gomez G. An useful classification for acute appendicitis. Revista de gastroenterologia de Mexico. Oct–Dec. 2003;68(4):261-5. [pmid: 15125327].
370 Habek D, Premuzic M, Cerkez Habek J. Syndrome of acute abdomen in gynaecology and obstetrics. Acta medica Croatica : casopis Hravatske akademije medicinskih znanosti. Jun. 2006;60(3):227-35. [pmid: 16933835].
371 Haddad-Zebouni S, Daher P, Ghoraib Z, et al. Role of ultrasonography in the diagnosis of acute appendicitis in children. Apropos of 35 cases. Le Journal medical libanais The Lebanese medical journal. Mar–Apr. 1998;46(2):79-83. [pmid: 10095832].
372 Hafid M, Erraji M, Kisra M, et al. Study of acute appendicitis in less than 5 years old children. Journal de Pediatrie et de Puericulture. 2009;22(1):14-8. PMID:.
373 Hahn H, Hopner F, von Kalle T, et al. Appendicitis in childhood. Der Radiologe. Jun. 1997;37(6):454-8. [pmid: 9340674].
374 Hahn H, Macdonald E, Steinborn M. Sonographic detection of normal appendix in children and adolescents. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Jun. 2008;29(3):281-5. [pmid: 18516771].
375 Hahn H, von Kalle T, Pfadler E, et al. Ultrasound appendix imaging in mucoviscidosis patients. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Feb. 1999;170(2):181-4. [pmid: 10101359].
376 Hahnloser P. Nonspecific abdominal pain and appendectomy: will interventional laparoscopy change the indication for surgery?. Revue medicale de la Suisse romande. Aug. 1993;113(8):589-93. [pmid: 8372299].
377 Hallfeldt K, Puhlmann M, Waldner H, et al. Diagnostic problems in acute appendicitis and indications for laparoscopic appendectomy. Langenbecks Archiv fur Chirurgie Supplement Kongressband Deutsche Gesellschaft fur Chirurgie Kongress. 1996;113:553-5. [pmid: 9101928].
378 Hamm M, Hackel T, Wawroschek F, et al. Unenhanced spiral computerized tomography in acute diagnosis of flank pain. Examination in contraindications for contrast medium administration. Der Urologe Ausg A. Sep. 2001;40(5):388-93. [pmid: 11594214].
379 Hamminga JT, Hofker HS, Haveman JW. Laparoscopic evaluation of the appendix. Nederlands tijdschrift voor geneeskunde. 2013;157(14):A5879. [pmid: 23548189].
380 Han SG, Sun HR, Bai RJ, Wang JP, Li YJ. Predictive value of MSCT for pathological type of acute appendicitis. Chinese Journal of Medical Imaging Technology. 2012;28(5):943-7. PMID:.
381 Haner C, Inderbitzi R, Kurath J, et al. Acute appendicitis: avoiding unnecessary laparotomy in young women. Helvetica chirurgica acta. Jun. 1990;57(1):33-5. [pmid: 2228682].
382 Hanggi S, Ruttimann S, Dubach UC. Diagnostic value of emergency ultrasonography of the abdomen. Schweizerische medizinische Wochenschrift. Mar. 14. 1992;122(11):382-4. [pmid: 1557617].
383 Hansson LE. Pain relief in acute abdominal pain. Randomized trials confirm that diagnostic accuracy is not affected by analgesics. Lakartidningen. Apr. 1. 2004;101(14):1254-5. [pmid: 15101211].
384 Haraldsson H, Rosmundsson T, Oskarsson K, et al. Appendicitis and appendectomy in children in Reykjavik Hospitals in 1996 and 2006. Laeknabladid. Sep. 2008;94(9):599-604. [pmid: 18784386].
385 Haram K, Kibsgaard L, Stordahl A. C-reactive protein (CRP) in clinical practice. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Dec. 10. 1980;100(34–36):2043-5. [pmid: 7456069].
386 Hasala P. Torsion of the omentum--an uncommon cause of acute abdomen. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Nov. 2010;89(11):670-1. [pmid: 21409799].
387 Havlik J, Tesar O, Niederle B, et al. Laparoscopy in acute abdominal conditions. Ceskoslovenska gastroenterologie a vyziva. Mar. 1971;25(2):64-5. [pmid: 5574753].
388 Hay JM, Flamant Y. Quantified symptomatology of acute appendicitis in adults. The signs and their value. La Revue du praticien. Mar. 15. 1992;42(6):678-87. [pmid: 1598520].
389 He L, Tao YT, Shen Y, et al. Clinical features and therapeutic strategies of acute appendicitis after radical gastrectomy for gastric carcinoma. Zhonghua yi xue za zhi. Dec. 25. 2012;92(48):3426-8. [pmid: 23327705].
390 He Y, Yuan AC. Misdiagnosis of appendicitis in children: analysis of 42 cases. Zhongguo dang dai er ke za zhi. Chinese journal of contemporary pediatrics. Jun. 2009;11(6):496-7. [pmid: 19558820].
391 Hebebrand D, Troidl H, Spangenberger W, et al. Laparoscopic or classical appendectomy? A prospective randomized study. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Feb. 1994;65(2):112-20. [pmid: 8162812].
392 Heinzelmann M, Schob O, Gianom D, et al. Role of laparoscopy in the management of acute appendicitis. Zentralblatt fur Chirurgie. 1999;124(12):1130-6. [pmid: 10670101].
393 Heistermann HP, Joosten U, Krawzak HW, et al. Effect of intestinal ultrasound on choice of surgical procedure in acute abdominal pain. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Dec. 1995;16(6):288-92. [pmid: 8584911].
394 Heloury Y, Leclair MD, Plattner V. The place of laparoscopy in pediatric surgery. Annales de chirurgie. 1998;52(10):1003-7. [pmid: 9951101].
395 Helzel MV, Lucas D. Digital CT scanogram versus conventional general image in the diagnosis of ileus--a prospective study. Rontgen-Blatter; Zeitschrift fur Rontgen-Technik und medizinisch-wissenschaftliche Photographie. Nov. 1987;40(11):355-9. [pmid: 3432970].
396 Henle KP, Beller S, Rechner J, et al. Laparoscopic versus conventional appendectomy: a prospective randomized study. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. May. 1996;67(5):526-30. discussion 2. [pmid: 8777883].
397 Hermel AA. Diagnostic value of nitroblue tetrazolium (NBT) reduction test in acute appendicitis. Polski przeglad chirurgiczny. Jul. 1977;49(7):679-82. [pmid: 896597].
398 Heron B, Alass F, Fayad F, et al. Acute appendicitis in newborn infants. Value of repeated clinical examinations and directed ultrasonography. Presse medicale (Paris, France : 1983). Apr. 15–22. 1995;24(15):736. [pmid: 7784410].
399 Herzberg W, Nolden K. Sonography in diagnosis of appendicitis. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Apr. 1987;58(4):286-8. [pmid: 3297542].
400 Hess J. Value of transparietal ultrasonography in gastrointestinal pathology. Revue medicale de la Suisse romande. May. 1998;118(5):477-81. [pmid: 9673495].
401 Hisa N. Non-traumatic abdominal disease: indication and limitation of ultrasound and computed tomography. Rinsho hoshasen Clinical radiography. Jun. 1984;29(6):711-6. [pmid: 6384585].
402 Hittinger M, Reiser MF, Zech CJ. Acute intestinal inflammation. Der Radiologe. Mar. 2010;50(3):237-45. [pmid: 20157691].
403 Hoffmann J, Rasmussen OO. Diagnostic aids in acute appendicitis. Ugeskrift for laeger. Aug. 7. 1989;151(32):2012-6. [pmid: 2672495].
404 Hofmann V. Sonography for detection of abdominal masses in children. Zentralblatt fur Chirurgie. 1980;105(19):1305-12. [pmid: 6259853].
405 Hollerweger A, Rettenbacher T, Macheiner P, et al. Spontaneous fatty tissue necrosis of the omentum majus and epiploic appendices: clinical, ultrasonic and CT findings. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Dec. 1996;165(6):529-34. [pmid: 9026094].
406 Homolka P, Leithner R, Billinger J, Gruber M. Results of the Austrian CT Dose Study 2010: Typical effective Doses of the most frequent CT examinations. [pmid: 24440650].
407 Hornoy B, Char G, Marotel M, et al. Appendicitis in the sub-hepatic site. Journal de radiologie. May. 1997;78(5):388-92. [pmid: 9239344].
408 Horvath E, Majlis S, Seguel S, et al. Primary epiploic appendicitis: clinical and radiological diagnosis. Revista medica de Chile. Jun. 2000;128(6):601-7. [pmid: 11016058].
409 Hovendal CP. Laparoscopy in acute abdomen. Ugeskrift for laeger. Apr. 22. 1996;158(17):2366. [pmid: 8685987].
410 Füessl HS. What to ask, how to manage?. [pmid: 23901563].
411 Huang D, Han M, Xie Y. Value of blood inflammatory markers in the diagnosis of acute appendicitis in children. Nan fang yi ke da xue xue bao. Journal of Southern Medical University. Aug. 2012;32(8):1154-6. [pmid: 22931611].
412 Hulskamp P. Pain on decompression; its diagnostic value in acute abdomen. Prensa medica argentina. Feb. 22. 1957;44(8):544-8. [pmid: 13453234].
413 Hulsse B, Rompel O, Bodenschatz K, et al. Diagnosis of appendicitis using harmonic ultrasound imaging. Zentralblatt fur Chirurgie. Apr. 2007;132(2):118-23. [pmid: 17516317].
414 Hurtado Andrade H, Barraza Bon C, Boom Anglada R, et al. Usefulness of a computer algorithm in the diagnosis of acute abdominal pain of the right lower quadrant. Revista de gastroenterologia de Mexico. Jan–Mar. 1988;53(1):15-21. [pmid: 3287573].
415 Huwart L, El Khoury M, Lesavre A, et al. Is appendicolith a reliable sign for acute appendicitis at MDCT?. Journal de radiologie. Apr. 2006;87(4 Pt 1):383-7. [pmid: 16691166].
416 Huwart L, El Khoury M, Lesavre A, et al. What is the thickness of the normal appendix on MDCT?. Journal de radiologie. Mar. 2007;88(3 Pt 1):385-9. [pmid: 17457270].
417 Iartsev PA, Ermolov AS, Pakhomova GV, et al. Laparoscopy for the diagnostic and treatment of the acute appendicitis. Khirurgiia. 2010;(4):21-5. [pmid: 20517233].
418 Ibelings MS, Bonjer HJ, Lucas IS, et al. Right-sided diverticulitis masquerading as acute appendicitis. Nederlands tijdschrift voor geneeskunde. Jun. 6. 1998;142(23):1350. [pmid: 9752050].
419 Ignatius J. “Tenderness in McBurney’s point” Charles McBurney 1845–1913. Duodecim; laaketieteellinen aikakauskirja. 1993;109(7):597-8. [pmid: 8062731].
420 Ikeda H1, Aoki M, Igarashi A, Hatanaka M, Suzuki M, Fujino J, Tahara K, Ishimaru Y, Arai T. Diagnosis and treatment of acute appendicitis in children. Masui. Sep. 2012;61(9):925-30. discussion 930–1. [pmid: 23012829].
421 Ilgar M, Elmali M, Nural MS. The role of abdominal computed tomography in determining perforation findings and site in patients with gastrointestinal tract perforation. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Jan. 2013;19(1):33-40. [pmid: 23588977].
422 Iljin W. Diagnosing appendicitis in cases of situs viscerum inversus totalis. Wiadomosci lekarskie (Warsaw, Poland : 1960). Mar. 15. 1972;25(6):539-42. [pmid: 5019801].
423 Imdahl A. Insidious and often fatal. Appendicitis with few symptoms in the elderly patient. MMW Fortschritte der Medizin. Jun. 20. 2002;144(25):42-4. [pmid: 12136673].
424 Isakov Iu F, Geras’kin VI, Milekhin AP, et al. Ultrasonic scanning of the abdominal organs and retroperitoneal space in children. Khirurgiia. Feb. 1983;(2):40-4. [pmid: 6843012].
425 Italiani E, Costa S, Falda G, et al. Emergency ultrasonography. La Radiologia medica. Nov. 1996;92(5):614-8. [pmid: 9036455].
426 Itzhak I. Role of ultrasound in the diagnosis of appendicitis. Harefuah. Apr. 15. 1990;118(8):497-8. [pmid: 2192961].
427 Iudin Ia B, Gabinskaia TA, Bukhtiiarov AP. Laparoscopy in the diagnosis of acute appendicitis in children. Khirurgiia. Aug. 1990;(8):28-31. [pmid: 2147968].
428 Izbicki JR, Wilker DK, Mandelkow HK, et al. Retro- and prospective studies on the value of clinical and laboratory chemical data in acute appendicitis. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Dec. 1990;61(12):887-93. discussion 93–4. [pmid: 2286107].
429 Jacobson G, Sandin T. Value of leukocyte count in the diagnosis of acute appendicitis. Lakartidningen. Oct. 22. 1975;72(43):4160-2. [pmid: 1177627].
430 Jang SO, Kim BS, Moon DJ. Application of alvarado score in patients with suspected appendicitis. The Korean journal of gastroenterology. Taehan Sohwagi Hakhoe chi. Jul. 2008;52(1):27-31. [pmid: 19077488].
431 Janic N, Golubovic Z, Jovanovic B. Laparoscopic operations in pediatric surgery. Srpski arhiv za celokupno lekarstvo. Oct. Suppl 1. 2004;132:14-6. [pmid: 15615458].
432 Jatzko G, Judmaier G, Laske G. Indications of laparoscopy in abdominal diseases (author’s transl). Wiener medizinische Wochenschrift (1946). 1980;130(24):790-2. [pmid: 6451986].
433 Javelle JM, Gueret A, Maupin JM, et al. THE RADIOLOGICAL SIGNS OF PSEUDOTUMORAL APPENDICITIS. BARIUM ENEMA. Archives des maladies de l’appareil digestif et des maladies de la nutrition. Oct. 1963;52:1007-16. [pmid: 14092400].
434 Jenny M. Acute appendicitis: can diagnosis and surgical indications be more precisely ascertained?. Schweizerische medizinische Wochenschrift. May. 30. 1981;111(22):816-8. [pmid: 7244604].
435 Ji J, Lu C, Yang H, Wang Z, Xiao Y, Hui J. Diagnostic value of multi-slice CT for adult non traumatic acute abdomen. Chinese Journal of Radiology (China). 2014;48(5):391-4. PMID:.
436 Jobst M. Diagnosis of appendicitis in early childhood. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:77-9. [pmid: 9880880].
437 Jobst M. The diagnosis of appendicitis in childhood. Padiatrie und Grenzgebiete. 1991;30(6):485-90. [pmid: 1758706].
438 Jocu I, Ilie E. Value of radiological examination in the diagnosis of chronic inflammatory diseases of the appendix. Medicina interna. Mar. 1973;25(3):339-49. [pmid: 4793934].
439 Johanet H, Marmuse JP, Benhamou G, et al. Appendicitis and acquired immunodeficiency syndrome. Apropos of 19 cases. Chirurgie; memoires de l’Academie de chirurgie. 1991;117(7):557-62. discussion 62–3. [pmid: 1842952].
440 John H, Neff U, Kelemen M. Diagnostic significance of clinical symptoms versus ultrasonography in appendicitis. A prospective study. Schweizerische Rundschau fur Medizin Praxis = Revue suisse de medecine Praxis. Oct. 22. 1991;80(43):1173-8. [pmid: 1947551].
441 John H, Neff U, Kelemen M. Does sonography help in the diagnosis of appendicitis?. Helvetica chirurgica acta. Feb. 1991;57(5):671-7. [pmid: 1864732].
442 Jonson G, Neovius G. Appendicitis and white blood cells from a different point of view. Lakartidningen. Jun. 7. 1989;86(23):2223-5. [pmid: 2747353].
443 Jung JY, Park YS, Baek DH, et al. The prevalence of Yersinia infection in adult patients with acute right lower quadrant pain. The Korean journal of gastroenterology. Taehan Sohwagi Hakhoe chi. Jan. 2011;57(1):14-8. [pmid: 21258196].
444 Jungling A, Holzgreve A, Kaiser R. Indications for appendectomy from the ultrasound-clinical viewpoint. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:32-7. [pmid: 9880868].
445 Kabanov AN, Dekker AF, Sitko LA, et al. Low frequency ultrasonics in the treatment of purulent wounds and cavities. Vestnik khirurgii imeni I I Grekova. Nov. 1982;129(11):26-9. [pmid: 7157590].
446 Kahrau S, Foitzik T, Klinnert J, et al. Acute appendicitis. Analysis of surgical indications. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:17-8. [pmid: 9880863].
447 Kaindl E, Umek W, Heinz-Peer G, et al. Diagnostic imaging in gynecological emergencies. Wiener medizinische Wochenschrift (1946). 2001;151(21–23):568-72. [pmid: 11762257].
448 Kalf-Kalif JJ. Haematological differentiation of different forms and phases of acute appendicitis; the use of the author’s leukocyte index in surgery. Khirurgiia. 1947;(7):40-3. [pmid: 18907457].
449 Kalina Z. Emergency ultrasonic diagnosis in acute abdomen. Polski tygodnik lekarski (Warsaw, Poland : 1960). Apr. 23. 1984;39(17):583-6. [pmid: 6384966].
450 Kallinowski F, Buhr H. The value of clinical, laboratory and sonographic findings in acute appendicitis--effect of surgical experience and bacteriologic diagnosis on the rate of wound healing disorders. Langenbecks Archiv fur Chirurgie. 1992;377(3):162-7. [pmid: 1619977].
451 Kallinowski F. Diagnostic score for acute abdominal pain. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Apr. 1995;66(4):460. [pmid: 7634968].
452 Kamenicek V, Masek M. Pelvic pain--appendiceal diseases and laparoscopic treatment. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Feb. 2002;81(2):83-7. [pmid: 11925648].
453 Kapischke M, Bley K, Tepel J, et al. Open versus laparoscopic operation for perforated appendicitis--a comparative study. Zentralblatt fur Chirurgie. Apr. 2005;130(2):137-41. [pmid: 15849658].
454 Kapshitar AV. Laparoscopy in the differential diagnosis of acute disorders of the mesenteric blood circulation and acute pancreatitis. Klinicheskaia khirurgiia. 1993;(5):17-9. [pmid: 7933853].
455 Kapshitar AV. The indications for performing diagnostic and therapeutic laparoscopy in emergency surgery on the abdominal organs. Klinicheskaia khirurgiia. 1998;(11):12-4. [pmid: 10077913].
456 Kapshitar AV. The use of laparoscopy in patients with a presumed diagnosis of acute appendicitis. Klinicheskaia khirurgiia. 1995;(2):19-20. [pmid: 9053180].
457 Karagiulian SR, Shutov SA, Grzhimolovskii AV, et al. Acute abdominal syndrome in blood system diseases. Terapevticheskii arkhiv. 2010;82(12):39-43. [pmid: 21516737].
458 Karahan OI, Kurt A, Baykara M, et al. Detectability of intraperitoneal free air by ultrasonography. Tanisal ve girisimsel radyoloji : Tibbi Goruntuleme ve Girisimsel Radyoloji Dernegi yayin organi. Mar. 2003;9(1):60-2. [pmid: 14661294].
459 Karimov Sh N, Zemskoi VS. Superfrequency thermoscopy in the diagnosis of acute pancreatitis. Khirurgiia. Jan. 1992;(1):67-71. [pmid: 1578847].
460 Karul M, Avanesov M, Yamamura J. Acute appendicitis: a clinical diagnosis?. Der Radiologe. Dec. 2012;52(12):1089-90. [pmid: 23114710].
461 Kasimov RR, Mukhin AS, Tutaev OI, et al. First experience of laparoscopic appendectomy in the 150-bed garrison hospital. Voenno-meditsinskii zhurnal. Jun. 2011;332(6):25-31. [pmid: 21899075].
462 Kasimov RR, Mukhin AA. Integral diagnosis of acute appendicitis. Sovremennye Tehnologii v Medicine. 2012;2012(4):112-4. PMID:.
463 Kazmagmbetov Zh K. Diagnostic puncture of the abdomen in acute appendicitis. Vestnik khirurgii imeni I I Grekova. Sep. 1975;114(9):39-41. [pmid: 1198800].
464 Keeman JN. New diagnostic imaging technology often offers no advantage in the differential diagnosis of acute abdomen. Nederlands tijdschrift voor geneeskunde. Nov. 6. 1999;143(45):2225-9. [pmid: 10578418].
465 Kekomaki M. Appendicitis or not?. Duodecim; laaketieteellinen aikakauskirja. 1992;108(18):1564-9. [pmid: 1366181].
466 Keller R, Kleemann M, Hildebrand P, et al. Diagnostic laparoscopy in acute abdomen. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Nov. 2006;77(11):981-5. [pmid: 17043803].
467 Khaavel AA, Birkenfeldt RR. Nature of the relation of acute appendicitis morbidity to meteorological and heliogeophysical factors. Vestnik khirurgii imeni I I Grekova. Apr. 1978;120(4):67-70. [pmid: 654016].
468 Khadzhivaev AM, Atadzhanov Sh K, Aripov UR, et al. The role of laparoscopy in diagnostics and treatment of acute surgical diseases and traumas of organs of the abdominal cavity. Vestnik khirurgii imeni I I Grekova. 2006;165(3):58-60. [pmid: 16881178].
469 Khekilaev UT. The diagnostic and prognostic importance of investigation of C-reactive protein in acute appendicitis. Khirurgiia. Mar. 1967;43(3):79-84. [pmid: 5616613].
470 Khemakhem R, Boukedi A, Rahay H, Nouira F, Ghorbel S, Louati H, Jlidi S, Bellagha I, Chaouachi B. Contribution of the abdominal ultrasound in therapeutic decision in case of right iliac fossa pains in children. about 266 cases. Journal de Pediatrie et de Puericulture. 2013;26(1):31-7. PMID:.
471 Khimich SD. Pulse-leukocytic-temperature index of intoxication. Klinicheskaia khirurgiia. 1992;(12):51-3. [pmid: 1298848].
472 Khokhlov NF, Balaba T, Merkur’eva RV, et al. Diagnostic value of the determination of sialic acids and hexosamines in the blood serum in acute appendicites. Khirurgiia. Sep. 1971;47(9):63-6. [pmid: 5150246].
473 Khosid IG. Informative value of various symptoms in the differential diagnosis between acute appendicitis and ovarian rupture. Vestnik khirurgii imeni I I Grekova. Nov. 1982;129(11):95-6. [pmid: 7157604].
474 Kilpatrick CC, Chohan L, Orejuela FJ. The use of MRI in acute abdomen in pregnancy. Salud(i)Ciencia. 2011;18(5):437-40. PMID:.
475 Kirkeby OJ, Birkeland S, Risoe C, et al. Computer-assisted diagnosis of acute abdominal pain. Experiences from a small county hospital. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Aug. 30. 1985;105(24):1596-7. [pmid: 3904074].
476 Kiselev Iu I, Markov IS. Acute appendicitis in patients with Yersinia infection. Khirurgiia. Oct. 1990;(10):122-7. [pmid: 2149395].
477 Kishida P, de Godoy AC, Goffi FS. Clinical, laboratory and anatomosurgical correlation in acute appendicitis. AMB : revista da Associacao Medica Brasileira. Nov. 1970;16(11):389-92. [pmid: 5313009].
478 Kisli E, Ozgoren E, Arslanturk H, et al. The role of peritoneal aspiration cytology diagnosis of acute appendicitis. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Apr. 2003;9(2):107-10. [pmid: 12836105].
479 Kitamura T. Abdominal ultrasonographic diagnosis. Nihon rinsho Japanese journal of clinical medicine. May. Suppl. 1978:2150-1. [pmid: 691671].
480 Kiyak G, Korukluoglu B, Ozgun Y, et al. Evaluation of Ohmann and Eskelinen scores, leukocyte count and ultrasonography findings for diagnosis of appendicitis. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Jan. 2009;15(1):77-81. [pmid: 19130343].
481 Klaiber C, Metzger A, Z’Graggen K, et al. From diagnostic laparoscopy to laparoscopic surgery. Helvetica chirurgica acta. Feb. 1991;57(5):693-7. [pmid: 1830873].
482 Klasen J, Antoch G, Blondin D. MR imaging of the abdomen in pregnancy. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Jun. 2011;183(6):514-22. [pmid: 21487979].
483 Klose KJ. Technique and value of unenhanced roentgen image in acute abdomen in the age of sectional imaging procedures (US, CT, MRI)?. Der Internist. Jun. 1993;34(6):574. [pmid: 8335448].
484 Klotter HJ, Zielke A, Nies C, et al. Sonography in acute abdominal emergency. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Aug. 1992;63(8):597-605. [pmid: 1395854].
485 Knaebel HP, Seiler CM, Weigand MA, et al. Current status of diagnostics and therapy of complicated intraabdominal infections. Zentralblatt fur Chirurgie. Oct. 2007;132(5):419-26. [pmid: 17907084].
486 Knapp W. Pseudotuberculosis in humans. Clinical aspects, diagnosis, therapy and epidemiology. Therapeutische Umschau Revue therapeutique. Apr. 1968;25(4):195-200. [pmid: 5727979].
487 Knudsen JH. Acute appendicitis and gastrointestinal tuberculosis with negative thoracic X-ray and positive sputum culture. Ugeskrift for laeger. Mar. 9. 1992;154(11):724-5. [pmid: 1546402].
488 Kobayashi A, Sawada S, Kobayashi S. Angiography in the diagnosis of acute abdominal disease (author’s transl). Rinsho hoshasen Clinical radiography. Aug. 1977;22(10):951-63. [pmid: 616462].
489 Koch A, Lippert H. Diagnostic laparoscopy within the scope of appendicitis treatment. East German Working Group “Outcome Assessment and Quality Assurance in Surgery” of the CAQ of the German Society of Surgery. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:43-5. [pmid: 9880871].
490 Koch A, Marusch F, Schmidt U, et al. Appendicitis in the last decade of the 20th century--Analysis of two prospective multicenter clinical observational studies. Zentralblatt fur Chirurgie. Apr. 2002;127(4):290-6. [pmid: 12085278].
491 Koch A, Schreiber LD, Mokros W, et al. Quality assurance in appendicitis--what has changed? Analysis of 2 prospective multicenter quality assurance studies. Zentralblatt fur Chirurgie. Suppl 2. 2000;125:185-91. [pmid: 11190643].
492 Kochnev OS, Fedotov SS. Liquid crystal thermography in the diagnosis of acute appendicitis, cholecystitis and pancreatitis. Vestnik khirurgii imeni I I Grekova. Feb. 1983;130(2):52-5. [pmid: 6845582].
493 Kogan I, Barzilai N, Hay E, et al. Ultrasound evaluation of acute abdominal pain in the emergency department. Harefuah. Apr. 16. 1995;128(8):484-7. 527. [pmid: 7750849].
494 Kogon AI, Ie S. APROPOS OF THE CLINIC-ROENTGENOLOGIC DIAGNOSIS OF DESTRUCTIVE APPENDICITIS. Vestnik rentgenologii i radiologii. Nov–Dec. 1964;39:55-7. [pmid: 14333475].
495 Kolmorgen K, Hausswald HR, Havemann O. Chronic lower abdominal complaints in the woman - a postlaparoscopic analysis. Zentralblatt fur Gynakologie. 1976;98(23):1434-40. [pmid: 138321].
496 Kolmorgen K, Havemann O, Hausswald HR. Acute and chronic appendicitis; gynaecologic laparoscopy (author’s transl). Zentralblatt fur Chirurgie. 1977;102(9):531-9. [pmid: 142404].
497 Kolmorgen K, Seidenschnur G. How can the frequency of perforative appendicitis be decreased?. Zeitschrift fur arztliche Fortbildung. Nov. 1. 1978;72(21):1051-2. [pmid: 154214].
498 Kolmorgen K. Laparoscopic diagnosis and therapy of appendicitis from the gynecologic viewpoint. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:53-4. [pmid: 9880874].
499 Kolovrat M, Lovric Z, Busic Z, et al. Laparoscopic versus open appendectomy: our experience and literature review. Acta medica Croatica : casopis Hravatske akademije medicinskih znanosti. Dec. 2012;66(5):383-5. [pmid: 23814967].
500 Kondo N, Kitagawa Y, Satake T, Mayumi T, Kohno H. Selection of nonessential intravenous contrast enhanced-computed tomography for diagnosing acute appendicitis. Japanese Journal of Gastroenterological Surgery. 2007;40(1):8-14. PMID:.
501 Konecna L, Heczko P, Vetr M. Association of appendicitis with extra-uterine pregnancy. Ceskoslovenska gynekologie. Jun. 1993;58(3):122-3. [pmid: 8348635].
502 Kononov AG, Makarov VI, Sotnichenko BA. Effectiveness of laparoscopy in the diagnosis of diseases simulating “acute abdomen”. Vestnik khirurgii imeni I I Grekova. Jul. 1989;143(7):37-9. [pmid: 2531952].
503 Kopylkov AI. Differential diagnosis of acute appendicitis and certain acute infectious diseases. Sovetskaia meditsina. Mar. 1975;(3):65-9. [pmid: 807976].
504 Korfel Z, Lukaszewicz M, Panek M, et al. Determination of white blood cell count in acute appendicitis: an evaluation. Polski przeglad chirurgiczny. Apr. 1973;45(4):461-6. [pmid: 4699772].
505 Korkan IP. Laparoscopy in the diagnosis of acute appendicitis in pregnant women. Khirurgiia. Feb. 1992;(2):63-6. [pmid: 1388216].
506 Korkan IP. The value of ultrasonic diagnosis of acute appendicitis in pregnant women. Vestnik khirurgii imeni I I Grekova. Feb. 1990;144(2):123-4. [pmid: 2165658].
507 Koslowski L, Schmolke M. Proceedings: Do the history and clinical findings allow any conclusion on the stage of appendicitis? (author’s transl). Langenbecks Archiv fur Chirurgie. 1973;334:851-8. [pmid: 4776171].
508 Koslowski L, Schmolke M. Significance of leukocyte count and temperature determination in the diagnosis of appendicitis? Observations on 9561 patients. Deutsche medizinische Wochenschrift (1946). Apr. 25. 1969;94(17):892-8. [pmid: 5778744].
509 Kostic A, Slavkovic A, Marjanovic Z, et al. Evaluation of using Alvarado score and C-reactive protein in diagnosing acute appendicitis in children. Vojnosanitetski pregled Military-medical and pharmaceutical review. Aug. 2010;67(8):644-8. [pmid: 20845667].
510 Kostin AE. Value of the leukocyte index of intoxication in the prognosis and diagnosis of suppurative complications after intra-abdominal interventions. Vestnik khirurgii imeni I I Grekova. Feb. 1988;140(2):100-1. [pmid: 3388690].
511 Kotlobovskii VI, Dronov AF, Poddubnyi IV, et al. Comparative study of surgical and endosurgical treatment of generalized appendicular peritonitis in children. Khirurgiia. 2003;(7):32-7. [pmid: 12926337].
512 Kouame DB, Garrigue MA, Lardy H, et al. Is procalcitonin able to help in pediatric appendicitis diagnosis?. Annales de chirurgie. Mar. 2005;130(3):169-74. [pmid: 15784220].
513 Koudelka J, Preis J, Kralova M. Diagnostic value of the rectal examination and the difference in axillo-rectal temperatures in acute appendicitis in childhood. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Feb. 1991;70(1–2):36-41. [pmid: 1925781].
514 Kovaleva EV. THE ABDOMINAL SYNDROME AND RHEUMATIC PERITONITIS IN CHILDREN. Pediatriia. May. 1964;43:55-60. [pmid: 14228999].
515 Krahenbuhl L, Buchler M. Problems with studies of open versus laparoscopic appendectomy (comment). Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen [serial on the Internet]. 1997;(1). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/781/CN-00208781/frame.html. Last accessed.
516 Kreitner KF, Mildenberger P, Maurer M, et al. The value of imaging techniques in the diagnosis of non-specific abdominal pain in young patients. Aktuelle Radiologie. Jul. 1992;2(4):234-8. [pmid: 1504123].
517 Kremer K, Kraemer M, Fuchs KH, et al. The diagnostic value of rectal examination of patients with acute appendicitis. Langenbecks Archiv fur Chirurgie Supplement Kongressband Deutsche Gesellschaft fur Chirurgie Kongress. 1998;115:1120-2. [pmid: 9931810].
518 Kriger AG, Shurkalin BK, Shogenov AA, et al. Laparoscopy in the diagnosis of acute appendicitis. Khirurgiia. 2000;(8):14-9. [pmid: 10996998].
519 Krikava K, Rod Z, Houstek S. Appendicitis and ultrasound diagnosis in children. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Jun. 1999;78(6):266-9. [pmid: 10596555].
520 Krikava K. Changes in the phagocytosis index of blood elements in inflammation of the appendix. Ceskoslovenska epidemiologie, mikrobiologie, imunologie. Sep. 1988;37(5):282-5. [pmid: 3197126].
521 Krohn K, Heinrich M, Teusch V, et al. Acute abdominal pain in children. MMW Fortschritte der Medizin. Mar. 8. 2012;154(4):47-50. 2. [pmid: 22619838].
522 Krome S. Appendix - CT: Special image processing makes reliable display possible. Zeitschrift fur Gastroenterologie. 2010;48(1):14-5. PMID:.
523 Krome S. CT diagnosis in appendicitis -What role does the contrast agent application play?. RoFo Fortschritte auf dem Gebiet der Rontgenstrahlen und der Bildgebenden Verfahren. 2010;182(3):218-9. PMID:.
524 Krska Z, Svab J. Chronic appendicitis--vanishing or current diagnosis?. Casopis lekaru ceskych. 2007;146(2):144-7. [pmid: 17373110].
525 Kucherenko AE, Kucherenko EM. Surgical interventions on organs in the abdominal cavity in patients with rheumatism. Sovetskaia meditsina. Sep. 1962;26:30-5. [pmid: 13927280].
526 Kudriavtsev BP, Saks LA, Vedula VN. Laparoscopy in the emergency diagnosis of surgical pathology. Voenno-meditsinskii zhurnal. Sep. 2000;321(9):20-3. [pmid: 11077526].
527 Kuleshov EV, Deikalo IN, Salaida NA, et al. Errors in the diagnosis of acute appendicitis in gynecologic diseases. Klinicheskaia meditsina. Oct. 1986;64(10):104-7. [pmid: 2949107].
528 Kulik Ia P, Pokoliukhin SN. High time to make choice: preventive or curative appendectomy?. Khirurgiia. 1999;(7):23-6. [pmid: 10459181].
529 Kulik Ia P, Sedov VM, Strizheletskii VV, et al. Laparoscopic appendectomy in acute appendicitis. Vestnik khirurgii imeni I I Grekova. 1995;154(2):34-6. [pmid: 8540183].
530 Kulik Ia P, Sedov VM, Strizheletskii VV, et al. Laparoscopy in the differential diagnosis and treatment of acute appendicitis and acute gynecological diseases. Vestnik khirurgii imeni I I Grekova. 1996;155(3):31-3. [pmid: 8966934].
531 Kulik Ia P, Strizheletskii VV, Rutenburg GM, et al. Laparoscopy in acute appendicitis. Vestnik khirurgii imeni I I Grekova. Mar–Apr. 1994;152(3–4):101-2. [pmid: 7709510].
532 Kummerle F. Acute appendicitis and ultrasonic diagnosis. Deutsche medizinische Wochenschrift (1946). Mar. 31. 1988;113(13):491-2. [pmid: 3280293].
533 Kunze W, Groger HU. Experience with peri-operative antibiotic prophylaxis in children with appendicitis. Padiatrische Praxis. 2014;82(2):231-9. PMID:.
534 Kupchik BM, Molokanov NF, Kaplan SM. Diagnostic value of roentgenologic examination in chronic appendicitis. Klinicheskaia meditsina. 1957;35(11):106-11. [pmid: 13503145].
535 Kupesic S, Aksamija A, Vucic N, et al. Ultrasonography in acute pelvic pain. Acta medica Croatica : casopis Hravatske akademije medicinskih znanosti. 2002;56(4–5):171-80. [pmid: 12768897].
536 Kushch NL, Timchenko AD. Laparoscopy in children. Vestnik khirurgii imeni I I Grekova. May. 1969;102(5):92-4. [pmid: 5408353].
537 Kuster GG, Gilroy SB, Torres N. Laparoscopy in acute appendicitis. Revista espanola de enfermedades digestivas : organo oficial de la Sociedad Espanola de Patologia Digestiva. Jul. 1992;82(1):29-31. [pmid: 1387795].
538 Kutasy B, Mohay G, Pinter A. Indication for and execution of rectal examination in children with suspected appendicitis. Magyar sebeszet. Feb. 2011;64(1):3-5. [pmid: 21330256].
539 Kuzel D, Bak V, Benda P, et al. Laparoscopically-directed appendectomy. Ceskoslovenska gynekologie. Aug. 1990;55(7):503-8. [pmid: 2146035].
540 Kuznetsov VI, Popov GK, Svezhintsev AP, et al. Characteristics of the blood leukocyte migration capacity in acute appendicitis. Klinicheskaia khirurgiia. 1987;(4):60. [pmid: 3599699].
541 Kuznetsov VI, Svezhintsev AP. Diagnostic value of the blood leukocyte picture in acute appendicitis. Khirurgiia. Sep. 1980;(9):74-7. [pmid: 7420916].
542 Lachman E, Schienfeld A, Boldes R, et al. Operative laparoscopy in pregnancy. Harefuah. Mar. 1. 1999;136(5):343-6. 420. [pmid: 10914233].
543 Lakyova L, Belak J, Kudlac M, et al. Appendicitis in pregnancy. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Oct. 2008;87(10):536-41. [pmid: 19110948].
544 Lambot K, Lougue-Sorgho L, Gorincour G, et al. Non-traumatic abdominal emergencies in paediatric practice. Journal de radiologie. Feb. 2005;86(2 Pt 2):223-33. [pmid: 15798635].
545 Lambot K, Lougue-Sorgho LC, Gorincour G, et al. Non-traumatic abdominal emergencies in paediatric practice. Journal de radiologie. Feb. 2005;86(2 Pt 2):234-6. [pmid: 15798636].
546 Langberg A, Montoya JC, Cevallos M. LAPAROSCOPIC APPENDECTOMY: EXPERIENCE IN THIRTY CASES. Revista de gastroenterologia del Peru : organo oficial de la Sociedad de Gastroenterologia del Peru. Sep–Dec. 1997;17(3):242-8. [pmid: 12177719].
547 Lange JF, van der Donckt H, van Spengler J. Echography in appendicitis. Nederlands tijdschrift voor geneeskunde. Apr. 7. 1990;134(14):725. [pmid: 2183072].
548 Langlois P. Not Available. Comptes rendus de la Societe francaise de gynecologie. Jan. 1959;29(1):54-63. [pmid: 13663516].
549 Lapa IV, Dzhuravets RI. Cytoluminescent examination of peripheral blood leukocytes in early diagnosis of acute appendicitis in children. Klinicheskaia khirurgiia. Jun. 1973;6:78-9. [pmid: 4770975].
550 Larsen TS, Trap R. Training in basic laparoscopic technique and implementation of diagnostic laparoscopy. Ugeskrift for laeger. Mar. 6. 2006;168(10):1007-10. [pmid: 16522290].
551 Larssen T, Evensen A, Samseth J, et al. Computed tomography in acute abdomen. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Nov. 10. 1979;99(31):1599-602. [pmid: 531835].
552 Laurent V, Regent D. Questions about appendiceal CT. Journal de radiologie. Dec. 1999;80(12):1681-9. [pmid: 10642666].
553 Le Hors-Albouze H. Conducting complementary exams in the diagnosis of acute appendicitis in children. Archives de pediatrie : organe officiel de la Societe francaise de pediatrie. May. Suppl 2. 2002;9:223s-5s. [pmid: 12108274].
554 Leardi S, Delmonaco S, Ventura T, et al. Recurrent abdominal pain and “chronic appendicitis”. Minerva chirurgica. Jan–Feb. 2000;55(1–2):39-44. [pmid: 10832282].
555 Lebeau R, Diane B, Koffi E, et al. Appendicitis and pregnancy: 21 cases. Journal de gynecologie, obstetrique et biologie de la reproduction. Oct. 2005;34(6):600-5. [pmid: 16208203].
556 Lebedev AI. Cellular immunity in peritonitis caused by appendicitis and peptic ulcer perforation. Klinicheskaia khirurgiia. 1990;(4):17-8. [pmid: 2391823].
557 Lecuru F, Taurelle R, Lafay-Pillet MC. Is appendectomy by laparoscopy a dangerous technique?. Journal de gynecologie, obstetrique et biologie de la reproduction. 1992;21(2):259. [pmid: 1533865].
558 Ledermann HP, Heinz W, Stuckmann G, et al. Transabdominal sonography of the gastrointestinal tract: what is the clinical value?. Praxis. Aug. 18. 2004;93(34):1351-4. [pmid: 15468692].
559 Ledezma Martinez G, Garassini Serra MA. Ultrasonography in acute appendicitis. Gen. Jan–Mar. 1989;43(1):72-6. [pmid: 2518024].
560 Leeuwenburgh MM, Bakker OJ, Gorzeman MP, et al. Fewer unnecessary appendectomies following ultrasonography and CT. Nederlands tijdschrift voor geneeskunde. 2010;154:A869. [pmid: 20456809].
561 Leeuwenburgh MMN, Bakker OJ, Gorzeman MP, et al. Less inappropriate appendectomy by echography and CT. Nederlands tijdschrift voor geneeskunde. 2010;154(17):795-800. PMID:.
562 Lehmann D, Uebel P, Weiss H, et al. Sonographic representation of the normal and acute inflamed appendix--in patients wi right-sided abdominal pain. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Jun. 2000;21(3):101-6. [pmid: 10929595].
563 Lehmann K, Attinger B, Villiger P, et al. Fewer negative appendectomies thanks to improved clinical diagnosis. Schweizerische medizinische Wochenschrift. Mar. 7. 1992;122(10):334-8. [pmid: 1532100].
564 Lehmann K, Jenny M. Clinical examination remains the most important part of the diagnosis in suspected appendicitis. Schweizerische Rundschau fur Medizin Praxis = Revue suisse de medecine Praxis. May. 28. 1991;80(22):610-2. [pmid: 1828904].
565 Lehmann K, Villiger P, Jenny M. Negative appendectomies can be decreased by improved clinical assessment alone. Helvetica chirurgica acta. May. 1992;58(6):837-40. [pmid: 1386595].
566 Leichner-Weil S. THE VALUE OF ROUTINE ROENTGEN EXAMINATIONS OF THE ILEOCECAL REGION AND THE APPENDIX IN UNDETERMINED ABDOMINAL PAINS. Zeitschrift fur arztliche Fortbildung. Feb. 15. 1964;58:217-22. [pmid: 14151732].
567 Lemine M, Collet M, Brettes JP. Abdominal emergencies and pregnancy. Revue francaise de gynecologie et d’obstetrique. Nov. 1994;89(11):553-9. [pmid: 7817085].
568 Leonidas JC, Harris DJ, Amoury RA. How accurate is the roentgen diagnosis of acute appendicitis in children. Annales de radiologie. May–Jun. 1975;18(4):479-87. [pmid: 1225163].
569 Levin LA, Peshekhonov SI. Videolaparoscopy for suspected acute appendicitis. Vestnik khirurgii imeni I I Grekova. 2005;164(5):84-7. [pmid: 16768348].
570 Levin MD, Khomich VM, Nalibotskii BV. The possibility of x-ray diagnosis of acute appendicitis in children. Klinicheskaia khirurgiia. 1989;(6):38-40. [pmid: 2770143].
571 Li D, Liu JH, Kang CB, Chen XF, Li XB, Lin DP, Li XW, Ye B, Zhang P, Liu QL. Re-evaluation of Alvarado score in diagnosis of acute appendicitis using transumbilical single-port laparoscopic exploration. World Chinese Journal of Digestology. 2013;21(28):3024-9.
572 Li SK, Wang HK, Li YB, et al. Diagnostic value of combined modified Alvarado scores and computed tomography imaging in the pathological types of acute appendicitis in adults. Zhonghua wei chang wai ke za zhi. Chinese journal of gastrointestinal surgery. Dec. 2012;15(12):1227-31. [pmid: 23268265].
573 Li Voti G, Pepe E, Acierno C, et al. Acute appendicitis in childhood. Evaluation of a computerized diagnostic model. Minerva pediatrica. Jun. 30. 1986;38(11–12):447-50. [pmid: 3526108].
574 Limousin IT, Azcarate JM, Cendon RG, et al. Fast track antibiotic protocol in acute appendicitis. Cirugia pediatrica : organo oficial de la Sociedad Espanola de Cirugia Pediatrica. Jul. 2009;22(3):142-4. [pmid: 19957862].
575 Lindner H, Kirchhof M. Explorative laparoscopy or laparotomy? (author’s transl). MMW, Munchener medizinische Wochenschrift. Feb. 4. 1977;119(5):143-6. [pmid: 138793].
576 Lipensky S, Toldy M, Lanyi E, et al. Concerning the use of laparoscopy in differential diagnosis of adnexitis (author’s transl). Bratislavske lekarske listy. Sep. 1979;72(3):382-5. [pmid: 159748].
577 Lippert V, Zaage J, Pilz F. Diagnostic laparoscopy and laparoscopic appendectomy in the diagnosis and therapy concept of abdominal pain of unknown origin. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:46-9. [pmid: 9880872].
578 Liu W, Qiang JW, Jing L, Liao ZH. Multi-slice CT diagnosis of early acute appendicitis. Chinese Journal of Radiology (China). 2012;46(9):807-11. PMID:.
579 Llanio R, Ferret O, Sotto A, et al. Diagnosis of acute abdomen by means of laparoscopy (experience in 6,400 cases). Gen. Oct–Dec. 1977;32(2):179-84. [pmid: 149693].
580 Llanio R, Sotto A, Jimenez G, et al. Emergency laparoscopy (study of 1265 cases). La semaine des hopitaux : organe fonde par l’Association d’enseignement medical des hopitaux de Paris. Mar. 8. 1973;49(12):873-7. [pmid: 4352983].
581 Llanio R. Emergency laparoscopy in the diagnosis of acute abdomen. Acta gastroenterologica Latinoamericana. 1986;16(3):177-85. [pmid: 2958985].
582 Lobenko AA, Chuzhina ES, Asmolov AK, et al. Liquid crystalline thermography in the diagnosis of acute appendicitis. Vestnik khirurgii imeni I I Grekova. Oct. 1983;131(10):66. [pmid: 6229087].
583 Lobenko AA, Gozhenko AI, Mishchenko VV. Dynamic radiation telethermometry in the diagnosis of acute appendicitis. Likars’ka sprava/Ministerstvo okhorony zdorov’ia Ukrainy. Apr–May. 1999;(3):103-6. [pmid: 10474950].
584 Lorcher U, Peters J. Appendicitis in the computed tomographic image. Digitale Bilddiagnostik. Jun. 1989;9(2):76-82. [pmid: 2752676].
585 Lorenz EP, Ehren G, Schmidt M, et al. Laparoscopic appendectomy as standard procedure. Technique and outcome in 409 patients. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:97-100. [pmid: 9880886].
586 Lorenz W, Koller M, Ehret C, et al. Diagnosis and clinical decision making: a conceptional framework for predictive pathology. Verhandlungen der Deutschen Gesellschaft fur Pathologie. 2006;90:25-30. [pmid: 17867576].
587 Lorenz W. Surgical decision process. Langenbecks Archiv fur Chirurgie. 1984;364:403-5. [pmid: 6503550].
588 Loyarte HF, Fares Taie F. Diagnosis of acute abdominal processes by means of Sgambati test. (Preliminary note). El Dia medico. May. 30. 1963;35:697-8. [pmid: 13931316].
589 Ludvigsen TC, Swensen T. Ultrasonography in acute appendicitis. A prospective study of 129 patients with clinically suspected acute appendicitis. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Oct. 20. 1988;108(29):2479-81. [pmid: 3061061].
590 Lutfi A, Weinke R, Eherer A, Fuchsjäger M. Acute abdomen. There is nothing that does not exist!. [pmid: 23760621].
591 Luthi F, Dusmet M, Merlini M. Pain syndrome in the right iliac fossa and laparoscopy: routine appendectomy or not?. Helvetica chirurgica acta. Sep. 1993;60(1–2):39-42. [pmid: 8226080].
592 Lutsenko SM, Shapoval SD, Andreeva GI. Features of changes in leukocyte and serum enzyme activity in acute appendicitis. Khirurgiia. Aug. 1984;(8):41-3. [pmid: 6482253].
593 Lutsenko SM. CLINICAL FEATURES OF PERITONITIS IN AGED AND SENILE PATIENTS. Khirurgiia. Sep. 1963;39:66-72. [pmid: 14094371].
594 Lych SA. Symptoms of acute appendicitis in retrocecal location of the vermiform process. Klinicheskaia khirurgiia. May. 1970;5:53-5. [pmid: 5448968].
595 Lysenko AI, Strashok IF. C-reactive protein in acute appendicitis in children. Klinicheskaia khirurgiia. Aug. 1965;8:29-31. [pmid: 5871400].
596 Lytkin MI, Korovkin BV, Vagner VK, et al. Changes in leukocyte lysosomal acid and alkaline phosphatase activity in acute surgical diseases of the abdominal cavity organs. Vestnik khirurgii imeni I I Grekova. Oct. 1977;119(10):54-9. [pmid: 929879].
597 Ma YL. B-mode ultrasonography in the diagnosis of appendicitis. Zhonghua wai ke za zhi. Chinese journal of surgery. Sep. 1993;31(9):539-41. [pmid: 8033717].
598 Maalej A, Akid F, Haddar S, et al. Ischemic diseases of the omentum: Importance of imaging. Annales Francaises de Medecine d’Urgence. 2013;3(4):212-6. PMID:.
599 Mahler CW, Boermeester MA, Stoker J, et al. Diagnostic modalities in diagnosis of adult patients with acute abdominal pain. Nederlands tijdschrift voor geneeskunde. Dec. 11. 2004;148(50):2474-80. [pmid: 15638193].
600 Maillard JN. Abdominal emergencies: contribution of the computer. La Nouvelle presse medicale. Dec. 19. 1981;10(46):3765-6. [pmid: 7033929].
601 Majewski W, Kaminski M, Sulikowski T, et al. Diagnostic and therapeutic value of laparoscopy in acute abdomen. Wiadomosci lekarskie (Warsaw, Poland : 1960). Suppl 1 Pt 1. 1997;50:204-7. [pmid: 9446353].
602 Makar DA, Kopystianskii IN. Use of combined laparoscopy in the differential diagnosis of acute appendicitis in young women. Klinicheskaia khirurgiia. 1986;(4):14-6. [pmid: 2940408].
603 Malinowski ML, Pisarek-Miedziniska D. Non-obstetric surgery during pregnancy. Ginekologia polska. Jul. 2009;80(7):523-7. [pmid: 19697817].
604 Mallah MQ, Shaikh U, Sikander e A, et al. Outcome of early appendicectomy in appendicular mass versus conservative approach. Medical Forum Monthly. 2011;22(10):20-3.
605 Malnati R, Capasso G, Stagni S, et al. Current diagnostic-therapeutic trends in treatment of pediatric appendicitis. Minerva pediatrica. Mar. 1994;46(3):117-21. [pmid: 8035758].
606 Manner M, Stickel W. Diagnosis in suspected appendicitis. Can ultrasonography rule out acute appendicitis?. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Sep. 2001;72(9):1036-42. [pmid: 11594273].
607 Manzotti LN, Bolino MC, Cerisoli C, Caro LE. Infrequent etiology of a common symptom. [pmid: 23940906].
608 Marincas M, Cirimbei C, Daha C, et al. The role of laparoscopy in the management of the right iliac fossa syndrome. Chirurgia (Bucharest, Romania : 1990). Jul–Aug. 2005;100(4):339-44. [pmid: 16238196].
609 Marjanovic Z, Spasic Z, Zivanovic D, et al. Acute appendicitis in the first three years of life. Srpski arhiv za celokupno lekarstvo. May–Jun. 2006;134(5–6):203-7. [pmid: 16972406].
610 Marque B, Montaigut JY, Wafflart E, et al. What diagnosis? Appendicular abscess. Journal de radiologie. Jan. 1998;79(1):65-7. [pmid: 9757225].
611 Martel JM. The physician, his approach and decisions: 3. The decision tree. L’union medicale du Canada. Sep. 1979;108(9):1003-8. [pmid: 543037].
612 Marusch F, Allecke K, Gastinger I. Value of ultrasound in diagnosis of appendicitis. Results of the East German Multicenter Study. East German Working Group “Outcome Assessment and Quality Assurance in Surgery” of the CAQ of the German Society of Surgery. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:29-31. [pmid: 9880867].
613 Masek T, Poulova M, Schwarz J, et al. Ultrasonography as an auxiliary method in diagnosis of acute appendicitis. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Jun. 2003;82(6):320-3. [pmid: 12898783].
614 Mazza E, Acquafresca M, Giannardi G. Acute abdomen following dislocation of transhepatic-duodenal biliary drainage. Resolution by use of percutaneous perihepatic drainage. La Radiologia medica. May. 1992;83(5):650-2. [pmid: 1631345].
615 Medvedev AM. Acute appendicitis in Zivert-Kartagener syndrome. Khirurgiia. 2001;(8):69. [pmid: 11552537].
616 Mehl HJ, Mothes W. Diagnosis of appendicitis in children. Zeitschrift fur arztliche Fortbildung. Nov. 15. 1972;66(22):1138-42. [pmid: 4656137].
617 Mehring CE, Munster. Unusual findings in the white blood picture of the population in recent times. Die Medizinische Welt. Oct. 24. 1970;43:1855-7. [pmid: 5475556].
618 Meiser G, Heinerman M, Boeckl O. Ultrasonic diagnosis in appendiceal perforation. Schweizerische Rundschau fur Medizin Praxis = Revue suisse de medecine Praxis. Feb. 6. 1990;79(6):135-9. [pmid: 2406843].
619 Meiser G, Meissner K, Sattlegger P. Experimental ultrasound analysis of the appendix. Contribution to improving the diagnosis of acute inflammation in routine clinical practice. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Mar. 1989;60(3):172-7. [pmid: 2656123].
620 Meiser G, Meissner K, Sattlegger P. Right-sided acute abdomen--ultrasonic diagnosis of a normal appendix. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Feb. 1988;59(2):108-10. [pmid: 3282827].
621 Meiser G, Waclawiczek HW, Heinerman M, et al. Intermittent incomplete ileus of the small intestine. Sonographic diagnosis and trends. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Sep. 1990;61(9):651-5. discussion 6. [pmid: 2176961].
622 Menendez P, Villarejo P, Padilla D, et al. Serum microRNA-21 usefulness in inflammatory pathology of the colon. Revista de gastroenterologia de Mexico. Apr–Jun. 2013;78(2):70-4. [pmid: 23680051].
623 Menendez-Arzac R, Cardenas-Lailson E, Sanjuan-Martinez CA, et al. Acute intestinal ischemia serum markers for the diagnosis of acute appendicitis. Cirugia y cirujanos. Nov–Dec. 2005;73(6):449-52. [pmid: 16454957].
624 Mentula P. Diagnosis and treatment of appendicitis. Duodecim. 2014;130(4):333-8. [pmid: 24673004].
625 Merkle P. Strategy in acute abdomen. Langenbecks Archiv fur Chirurgie Supplement Kongressband Deutsche Gesellschaft fur Chirurgie Kongress. 1991:96-8. [pmid: 1838949].
626 Messina G. Role of abdominal echography in internal medicine. Recenti progressi in medicina. Jun. 1998;89(6):308-10. [pmid: 9658901].
627 Meucci D, Messina M, Garzi A, et al. Acute-phase proteins in appendicitis in childhood: new findings. La Pediatria medica e chirurgica : Medical and surgical pediatrics. Nov–Dec. 1996;18(6):601-6. [pmid: 9173409].
628 Meyer C, Rohr S, Thiry CL, et al. 10 years of laparoscopic surgery: reflections on 5000 cases. Chirurgia (Bucharest, Romania : 1990). Nov–Dec. 2000;95(6):487-92. [pmid: 14870526].
629 Meyer P. Computers as an aid in diagnosis. Acute abdominal pains. Revue medicale de la Suisse romande. Oct. 1990;110(10):829-31. [pmid: 2244088].
630 Meyer-Marcotty W, Plarre I. Chronic appendicitis. Langenbecks Archiv fur Chirurgie. 1986;369:187-90. [pmid: 3807516].
631 Michon J, Seneque J. Value of urography in diagnosis of acute abdominal syndromes. Journal de chirurgie. Aug–Sep. 1956;72(8–9):612-22. [pmid: 13367124].
632 Miederer SE, Lindstaedt H, Koischwitz D, et al. The acute abdomen from an internistic viewpoint. Die Medizinische Welt. Jan. 18. 1980;31(3):96-9. [pmid: 7366387].
633 Migliaro M1, Rada V. Appendagitis (epiploic appendicitis). [pmid: 23570763].
634 Milart P, Paszkowski T, Wozniakowska E, et al. Non-obstetrical causes of “acute abdomen” during pregnancy - Review of recent cases. Ginekologia i Poloznictwo. 2013;28(2):44-9.
635 Milart P, Paszkowski T, Wozniakowska E, et al. Non-obstetrical causes of “acute abdomen” during pregnancy - Review of recent cases. Ginekologia i Poloznictwo. 2013;28(2):44-9.
636 Mil’kov BO, Kokshchuk GI, Kulachek FG, et al. Dynamics of the lysosomal-cation test in patients with appendicitis before and after surgery. Klinicheskaia khirurgiia. 1991;(1):25-7. [pmid: 2067223].
637 Minushkin ON, Sokolov LK, Savrasov VM, et al. The value of ultrasonic and x-ray endoscopic methods in the diagnosis of acute surgical diseases of the abdominal organs. Khirurgiia. Feb. 1989;(2):28-32. [pmid: 2523498].
638 Miranda L, Capasso P, Settembre A, et al. Video-assisted appendectomy. Minerva chirurgica. Oct. 2001;56(5):539-42. [pmid: 11568732].
639 Mishchenko NV, Bezkorovainyi VI. The differential diagnostic laparoscopy of acute appendicitis and acute diseases of the internal genitalia in women. Likars’ka sprava/Ministerstvo okhorony zdorov’ia Ukrainy. Oct–Dec. 1999;(7–8):93-5. [pmid: 10672702].
640 Miyanaga T, Negishi H, Kimura N. Relationship between pathological and clinical findings in chronic appendicitis. Shujutsu Operation. Apr. 1969;23(4):476-83. [pmid: 5802772].
641 Moenne K, Fernandez M, Palma R, et al. Utility of high-resonance ultrasonography in the diagnosis of acute appendicitis. Revista medica de Chile. Dec. 1992;120(12):1383-7. [pmid: 1343378].
642 Moll van Charante E, de Jongh TO. Physical examination of patients with acute abdominal pain. Nederlands tijdschrift voor geneeskunde. 2011;155:A2658. [pmid: 21418700].
643 Montgomery A, Moberg AC. Laparoscopy in acute abdomen as diagnostic and surgical aid. Lakartidningen. Feb. 10. 1999;96(6):593-6. [pmid: 10087799].
644 Motta-Ramírez GA, Ruiz-Castro E, Torres-Hernández V, Herrera-Avilés RA, Rodríguez-Treviño C. The role of the computed tomography in the identification of the syndrome of pelvic congestion. [pmid: 23971386].
645 Moya A, Planells MV, Galeano J, Pous S, García P, García R, Iserte J, Pacheco F, Rodero D. Laparoscopic appendectomy versus standard appendectomy: a prospective study. Cirugia espanola [serial on the Internet]. 1993. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/023/CN-00402023/frame.html. Last accessed.
646 Msika S. How can we limit the number of unnecessary appendectomies?. Journal de chirurgie. Dec. 1999;136(6):299-300. [pmid: 10675818].
647 Msika S. In clinical practice. Revue du Praticien. 2001;51(15):1682-5. PMID:.
648 Muller AM, Kaucevic M, Coerdt W, et al. Appendicitis in childhood: correlation of clinical data with histopathological findings. Klinische Padiatrie. Dec. 2010;222(7):449-54. [pmid: 20830659].
649 Muller M, Terzic A, Rodehorst A, et al. Laparoscopic appendectomy as training procedure for all stages of appendicitis. Zentralblatt fur Chirurgie. Feb. 2007;132(1):10-5. discussion 5. [pmid: 17304429].
650 Muller RC, Kurmanavicius J. Abdominal pain in pregnancy--ultrasound as the diagnostic tool of choice for rapid decision making. Praxis. Jul. 18. 2007;96(29–30):1131-5. [pmid: 17691448].
651 Munteanu R, Copaescu C, Litescu M, et al. Laparoscopic appendectomy--considerations in about 1000 cases. Chirurgia (Bucharest, Romania : 1990). Nov–Dec. 2005;100(6):541-9. [pmid: 16553194].
652 Mussack T, Schmidbauer S, Nerlich A, et al. Chronic appendicitis as an independent clinical entity. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jul. 2002;73(7):710-5. [pmid: 12242981].
653 Naess F. Laparoscopy and suspected acute appendicitis. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Jun. 30. 2005;125(13):1820-1. [pmid: 16012550].
654 Naf R, Bischofberger U, Buchmann P. Advantages of laparoscopic appendectomy. Revue medicale de la Suisse romande. Jul. 1996;116(7):537-40. [pmid: 8765567].
655 Nageli J, Zund M, Lange J. Laparoscopic diagnosis in suspected acute appendicitis. Helvetica chirurgica acta. Jul. 1994;60(5):787-91. [pmid: 7960909].
656 Nasiri S, Mohebbi F, Sodagari N, Hedayat A. Diagnostic values of ultrasound and the Modified Alvarado Scoring System in acute appendicitis. International Journal of Emergency Medicine. 2012;5(1). PMID:.
657 Nasr A, Avni EF, Houben JJ, et al. Complicated appendicitis in children: contribution of echography to diagnosis and treatment. Journal belge de radiologie. 1987;70(2):115-9. [pmid: 3298203].
658 Natroshvili AG, Shulutko AM, Nasirov FN, et al. The use of modified diagnostic scale in patients with acute appendicitis. Khirurgiia. 2010;(8):24-7. [pmid: 20823816].
659 Navarra G, Ascanelli S, Turini A, et al. Laparoscopic appendectomy versus open appendectomy in suspected acute appendicitis in female patients. Annali italiani di chirurgia. Jan–Feb. 2002;73(1):59-63. [pmid: 12148423].
660 Navarro Cantarero E, Carro Alonso B, Castillo Lario C, et al. Diagnosis of Anisakis infestation: experience in our environment. Allergologia et immunopathologia. Jan–Feb. 2005;33(1):27-30. [pmid: 15777520].
661 Navarro I, Poletti PA, Bréchet BA. What imaging to choose for low abdominal pain?. [pmid: 24163878].
662 Navarro I, Poletti PA, Brechet Bachmann AC. What radiological imaging for a low abdominal pain?. Revue medicale suisse. 2013;9(399):1715-9. PMID:. [pmid: 24163878].
663 Navez B, d’Udekem Y, Cambier E, et al. Value of celioscopy in non-traumatic acute abdomen. Annales de chirurgie. 1994;48(7):625-31. [pmid: 7864539].
664 Neikov GN, Kaparulina LT. Comparative assessment of C-reactive protein and sialic acids in the diagnosis of acute appendicitis. Vestnik khirurgii imeni I I Grekova. Oct. 1969;103(10):67-70. [pmid: 5366653].
665 Nekrasov A. Application of videolaparoscopy methods in the diagnostics and treatment of acute appendicitis. Eksperimental’naia i klinicheskaia gastroenterologiia. Experimental & clinical gastroenterology. 2005;(4):49-52. 112. 3. [pmid: 16255538].
666 Nemsadze G, Urushadze OP, Tokhadze LT, et al. The role and place of helical ct for preporative diagnosis of acute appendicitis. Georgian medical news. Sep. 2009;(174):10-3. [pmid: 19801721].
667 Nerdrum HJ. Laboratory tests and nuclear medical examinations in acute abdomen. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Nov. 10. 1979;99(31):1585-8. [pmid: 531832].
668 Nesterenko Iu A, Grinberg AA, Shapovaliants SG, et al. Ultrasound diagnosis of acute appendicitis. Khirurgiia. Jul. 1994;(7):26-9. [pmid: 7967390].
669 Ngowe Ngowe M, Bissou Mahop J, Atangana R, et al. Current clinical features of acute appendicitis in adult in Yaounde, Cameroon. Bulletin de la Societe de pathologie exotique (1990). Dec. 2008;101(5):398-9. [pmid: 19192608].
670 Nguyen QK, Nguyen VD, Nguyen VT, et al. Ultrasonographic diagnosis of appendicitis. Value and limitations. Journal de radiologie. Oct. 1994;75(10):537-9. [pmid: 7799276].
671 Nichitailo ME, Skums VV, Diachenko AN, et al. Simultaneous operations during laparoscopic cholecystectomy. Klinicheskaia khirurgiia. Feb. 2004;(2):5-7. [pmid: 15124463].
672 Nicolau AE. Laparoscopic appendectomy. Chirurgia (Bucharest, Romania : 1990). Jul–Aug. 2011;106(4):495-503. [pmid: 21991876].
673 Niebuhr H, Nahrstedt U, Born O. Routine ultrasound in diagnosis of acute appendicitis. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:26-8. [pmid: 9880866].
674 Niedworok J, Grigoriew A, Tchorzewski H. Study of leukocyte ahderence in the course of various surgical diseases. Polski tygodnik lekarski (Warsaw, Poland : 1960). Jul. 16. 1979;34(29):1145-7. [pmid: 493167].
675 Niemann U, Imdahl A, Richter M. Acute abdomen: diagnostic approach. [pmid: 24761491].
676 Niemann U, Tabatabai K, Jordan U, et al. Differential diagnosis of right abdominal pain. MMW Fortschritte der Medizin. Mar. 5. 2009;151(10):38-41. quiz 2. [pmid: 19472667].
677 Nishida A, Ohtani H. Acute phase protein, especially with reference to the rapid quantitation of CRP. Rinsho byori The Japanese journal of clinical pathology. Nov. 1986;34(11):1322-34. [pmid: 3820696].
678 Nisolle JF, Bodart E, de Caniere L, et al. Acute left-side appendicitis: diagnostic contribution of tomodensitometry. Archives de pediatrie : organe officiel de la Societe francaise de pediatrie. Jan. 1996;3(1):47-50. [pmid: 8745827].
679 Nko’o Amvene S, Shasha W, Koki Ndombo P, et al. Transvaginal ultrasonography in the diagnosis of abnormal uterine bleeding in women of reproductive age. Comparison with transvesical ultrasonography. Revue francaise de gynecologie et d’obstetrique. Apr. 1993;88(4):219-22. [pmid: 8502892].
680 Nordshus T. Ultrasonic diagnosis in acute abdomen. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Nov. 10. 1979;99(31):1595-9. [pmid: 531834].
681 Nosaka S, Hayakawa M, Miyazaki O, et al. Ultrasonography of pediatric right lower abdominal pain: correlation with clinical and pathological results. Nihon Igaku Hoshasen Gakkai zasshi Nippon acta radiologica. Oct. 1995;55(12):855-60. [pmid: 8539103].
682 Nosaka S. Diagnostic radiology in acute pediatric abdomen. Nihon Igaku Hoshasen Gakkai zasshi Nippon acta radiologica. Jan. 2000;60(1):5-13. [pmid: 10689883].
683 Novitskii VV, Riazantseva NV, Chasovskikh N, et al. The role of p53 and NF-kappaB transcription factors in redox-dependent dysregulation of mononuclear leukocyte apoptosis. Vestnik Rossiiskoi akademii meditsinskikh nauk/Rossiiskaia akademiia meditsinskikh nauk. 2009;(4):3-7. [pmid: 19517606].
684 Nowak W, Werner G, Dorn HU. Appendicitis in the aged. Zentralblatt fur Chirurgie. 1986;111(13):794-800. [pmid: 3765927].
685 Odegaard S. Rapid ultrasonic diagnosis in acute abdominal diseases. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Nov. 20. 1981;101(32):1831-4. [pmid: 7342368].
686 Ohmann C, Franke C, Yang Q, et al. Diagnostic score for acute appendicitis. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Feb. 1995;66(2):135-41. [pmid: 7712857].
687 Ohmann C, Kraemer M, Jager S, et al. Acute abdominal pain--standardized findings as diagnostic support. Results of a prospective multicenter intervention study and testing of a computer-assisted diagnosis system. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Feb. 1992;63(2):113-22. discussion 22–3. [pmid: 1541219].
688 Olsen JB, Myren CJ, Haahr PE. Randomized trial on the value of diagnostic laparoscopy before appendectomy. Ugeskrift for laeger. Jan. 30. 1995;157(5):584-5. [pmid: 7638913].
689 Onder A, Kapan M, Gul M, et al. Gynecological pathologies in negative acute appendicitis. Duzce Medical Journal. 2012;14(3):1-4. PMID:.
690 Onder A, Kapan M, Gul M, et al. Gynecological pathologies in negative acute appendicitis. Duzce Medical Journal. 2012;14(3):1-4. PMID:.
691 Orlov NS, Cherniaev Iu S. Thermography in acute appendicitis. Klinicheskaia khirurgiia. Aug. 1974;0(8):5-11. [pmid: 4277955].
692 Orozco-Sanchez J, Sanchez-Hernandez J, Samano-Martinez A. Acute appendicitis in the first 3 years of life: presentation of 72 cases and review of the literature. Boletin medico del Hospital Infantil de Mexico. Apr. 1993;50(4):258-64. [pmid: 8471172].
693 Osingol’ts SL, Zil’berman DB. The diagnostic value of transaminase in acute pancreatitis and several other surgical diseases. Klinicheskaia khirurgiia. Aug. 1968;8:14-8. [pmid: 4879585].
694 Ostrovskii AD, Magomedov AD. Natural resistance of the body in appendicular peritonitis in children. Vestnik khirurgii imeni I I Grekova. Mar. 1977;118(3):105-7. [pmid: 878173].
695 Ostrovskii VK, Alimov RR, Mashchenko AV, et al. Normal parameters of leukocyte index of intoxication. Klinicheskaia laboratornaia diagnostika. Jan. 2003;(1):45-6. [pmid: 12619511].
696 Otte WD, Schneiders K. Value of laparoscopy in acute abdomen. Zentralblatt fur Chirurgie. 2000;125(1):74-6. [pmid: 10703172].
697 Ovaska J, Molander P. Laparoscopy: a handy method in many problematic acute abdomen cases. Duodecim; laaketieteellinen aikakauskirja. 2000;116(20):2201-7. [pmid: 12017625].
698 Ovchinnikov VA, Marchenko VI, Kolobova OI, et al. Laparoscopy in the diagnosis and treatment of acute diseases of the abdominal organs. Vestnik khirurgii imeni I I Grekova. Oct. 1985;135(10):21-5. [pmid: 2935989].
699 Overbeck B, Briele B, Hotze A, et al. 99mTc-anti-granulocyte antibodies (BW 250/183) in the detection of appendicitis. Nuklearmedizin Nuclear medicine. Feb. 1992;31(1):24-8. [pmid: 1561117].
700 Ovrebo KK, Eckerbom RM, Haram S, et al. Acute abdomen among children and adolescents. A retrospective study of 470 children and adolescents with acute abdominal pain. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Oct. 30. 1993;113(26):3244-7. [pmid: 8236218].
701 Ozerov VF, Levkovskii SN. Differential diagnosis of acute appendicitis and appendicular colic. Vestnik khirurgii imeni I I Grekova. Mar. 1989;142(3):83-6. [pmid: 2750015].
702 Ozguc H, Cakin N, Duman U. Diagnostic accuracy of symptoms, signs and one-year prognosis of patients with acute non-specific abdominal pain: prospective survey. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Apr. 2008;14(2):118-24. [pmid: 18523902].
703 Ozkan F, Inci MF, Okumus M, Yuksel M, Pircanoglu EM, Bozkurt S, Menzilcioglu MS. Computed tomography findings in patients admitted to the emergency service with acute abdominal pain. Duzce Medical Journal. 2013;15(2):19-22. PMID:.
704 Pacheco RC, de Nishioka SA, de Oliveira LC. Validity of serum amylase and lipase in the differential diagnosis between acute/acutized chronic pancreatitis and other causes of acute abdominal pain. Arquivos de gastroenterologia. Oct–Dec. 2003;40(4):233-8. [pmid: 15264045].
705 Pannen F, Frangenheim H. “Surgical” laparoscopy indications and value. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Sep. 1975;46(9):405-10. [pmid: 130232].
706 Paolaggi JA. Emergency laparoscopy in abdominal pathology. La Nouvelle presse medicale. Feb. 17. 1973;2(7):411-3. [pmid: 4265854].
707 Paolaggi JA. Emergency laparoscopy. Archives francaises des maladies de l’appareil digestif. Apr–May. 1972;61(4):433-8. [pmid: 4263031].
708 Paredes Esteban RM, Salas Molina J, Ocana Losa JM, et al. Indication of appendectomy in the recurrent abdominal pain. Cirugia pediatrica : organo oficial de la Sociedad Espanola de Cirugia Pediatrica. Apr. 2004;17(2):65-9. [pmid: 15285587].
709 Parkhomenko Iu G, Ali-Riza AE, Lozovskaia LS, et al. The immunomorphological characteristics of the appendix in a viral-bacterial lesion in children with appendicitis. Arkhiv patologii. 1991;53(5):33-8. [pmid: 1883273].
710 Parsa H, Javadi A, Harami M. Evaluation of the role of hyperbilirubinemia in the diagnosis of complicated appendicitis. Scientific Journal of Kurdistan University of Medical Sciences. 2012;17(3):35-42. PMID:.
711 Parsa H, Javadi A, Harami M. Evaluation of the role of hyperbilirubinemia in the diagnosis of complicated appendicitis. Scientific Journal of Kurdistan University of Medical Sciences. 2012;17(3):35-42. PMID:.
712 Paschetta V. Value of indirect radiologic signs in chronic appendicitis. Journal de radiologie, d’electrologie & archives d’electricite medicale. 1950;31(7–8):509-11. [pmid: 14804535].
713 Pasquini G, Rubino F, Bruni V, et al. Laparoscopic appendectomy: retrospective studies of 172 consecutive procedures. Chirurgia italiana. Mar–Apr. 2004;56(2):257-60. [pmid: 15152519].
714 Patraschkov T. Appendicovesical fistula. Zeitschrift fur Urologie und Nephrologie. Jan. 1983;76(1):39-42. [pmid: 6845896].
715 Pauls S, Bahr MJ, Eisold S. Pitfall: contrast appendix after previous oral contrast medium administration - erroneous interpretation as postoperative foreign body. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Nov. 2012;184(11):1055-6. [pmid: 22851301].
716 Pautrat K, Soyer P, Pocard M. Why should an abdominal CT scan be performed for suspected appendicitis in the adult patient? Lessons from ten clinical cases. Journal de chirurgie. Oct. 2009;146(Spec 1):12-6. [pmid: 19850295].
717 Pavlovskii MP, Orel GL, Omodzhokun O. Laparoscopy in emergency surgery on “acute abdomens”. Klinicheskaia khirurgiia. Jan. 1983;(1):31-3. [pmid: 6220174].
718 Pedersen AG, Petersen OB, Wara P, et al. Laparoscopy in suspected acute appendicitis. Experiences with the first 233 laparoscopies at a university hospital department. Ugeskrift for laeger. Apr. 22. 1996;158(17):2377-80. [pmid: 8685990].
719 Peiper HJ, Schmid A, Steffens H, et al. Ultrasound diagnosis in acute abdomen and blunt abdominal trauma. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Apr. 1987;58(4):189-98. [pmid: 3297536].
720 Perale R, Talenti E, Toffolutti T, et al. Diagnostic role of echography in acute appendicitis in children. La Radiologia medica. Jun. 1991;81(6):849-56. [pmid: 1857794].
721 Perez EM, Fernandez-Castroagudin J, Munoz JED. Diagnostic protocol of patient with fever and pain in upper right quadrant of abdomen. Medicine. 2012;11(8):510-3. PMID:.
722 Perez-Martinez A, Conde-Cortes J, Martinez-Bermejo MA, et al. Programmed surgery for acute appendicitis. Cirugia pediatrica : organo oficial de la Sociedad Espanola de Cirugia Pediatrica. Jul. 2005;18(3):109-12. [pmid: 16209370].
723 Perminova GI, Sirotinskii VV, Sokolov AA. Laparoscopic diagnosis of acute mesenteric lymphadenitis. Klinicheskaia khirurgiia. 1989;(4):38-9. [pmid: 2526896].
724 Peskova M, Krsnakova M, Linhart O. Problems of nonspecific mesenteric lymphadenitis. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Feb. 1974;53(2):135-40. [pmid: 4847395].
725 Petit P, Pracros J. Role of ultrasound in children with emergency gastrointestinal diseases. Journal de radiologie. Jun. 2001;82(6 Pt 2):764-78. discussion 79–80. [pmid: 11443295].
726 Petroianu A, Alberti LR, Zac RI. Importance of the radiographic sign of fecal loading in the cecum for the differential diagnosis of acute appendicitis. Acta medica portuguesa. Mar–Apr. 2007;20(2):151-6. [pmid: 17868521].
727 Petrov A. More complete and more accurate diagnosis in acute appendicitis. Khirurgiia. 1977;30(2):170-2. [pmid: 916571].
728 Petrushenko VV, Verba AV, Humeniuk KV, et al. Observation of a foreign body in the appendix. Klinicheskaia khirurgiia. Oct. 2011;(10):69. [pmid: 22295559].
729 Pfeifer G. Leukocyte count in appendicitis. Medizinische Klinik. Dec. 15. 1961;56:2120-1. [pmid: 14486120].
730 Philippe P, Desjardins M. Differential diagnosis of appendicitis and nonspecific mesenteric lymphadenitis in children: contribution of discriminant analysis. L’union medicale du Canada. Jun. 1978;107(6):592-9. [pmid: 664102].
731 Pichler W, Meiser G. Ultrasonic diagnosis in acute right hypogastrium. Attempt at the evaluation of effectiveness. Wiener medizinische Wochenschrift (1946). Mar. 15. 1985;135(5):115-8. [pmid: 3887770].
732 Pignatelli V, Ruiu U, Savino A, et al. The echographic diagnosis of acute appendicitis and its complications. La Radiologia medica. Mar. 1990;79(3):215-9. [pmid: 2186443].
733 Pinedo-Onofre JA, Guevara-Torres L. Omental torsion. An acute abdomen etiology. Gaceta medica de Mexico. Jan–Feb. 2007;143(1):17-20. [pmid: 17388092].
734 Pirro N, Berdah SV. Appendicitis: yes or no to laparoscopic approach?. Journal de chirurgie. May–Jun. 2006;143(3):155-9. [pmid: 16888600].
735 Pirtkien R. Difficulties and diagnostic errors in abdominal diseases. Zeitschrift fur Allgemeinmedizin. May. 31. 1970;46(15):779-83. [pmid: 4942597].
736 Planells MV, García R, Moya A, Rodero D. Laparoscopic appendectomy versus traditional appendectomy A prospective study of 93 consecutive cases. Cirugía Española [serial on the Internet]. 1994. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/437/CN-00308437/frame.html. Last accessed.
737 Planka L, Tuma J, Rak V, et al. Results of the elective laparoscopic appendectomy in unexplained pains in the right hypogastrium. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Jul. 2006;85(7):343-6. [pmid: 17044278].
738 Pocard M. Computer tomography scanning for acute appendicitis in adults: latest fad or real progress?. Annales de chirurgie. May. 2000;125(4):313-4. [pmid: 10900730].
739 Podil’chak MD, Makar DA, Ohonovs’kyi VK. The prognostic significance of natural killers and dehydrogenases of the peripheral blood lymphocytes in patients with a suppurative inflammation. Klinicheskaia khirurgiia. 1994;(5):55-6. [pmid: 7807906].
740 Podilchak MD, Ohonovskyi VK. Clinical value of lymphocyte adhesion inhibition test. Klinicheskaia khirurgiia. 1993;(6):7-9. [pmid: 8271726].
741 Poeze M, Greve JW, Ramsay G. No additional benefit derived from determination of serum lactase levels for the evaluation of a patient with an acute abdomen. Nederlands tijdschrift voor geneeskunde. Jun. 6. 1998;142(23):1346-7. [pmid: 9752044].
742 Poletti PA, Andereggen E, Rutschmann O, et al. Indications for low-dose CT in the emergency setting. Revue medicale suisse. Aug. 19. 2009;5(213):1590-4. [pmid: 19754008].
743 Poletti PA, Andereggen E, Rutschmann O, et al. Indications to low-dose CT in emergency setting. Revue medicale suisse. 2009;5(213):1590-4. PMID:. [pmid: 19754008].
744 Polous Iu M, Gerasimets Iu M, Bulat LP. Heat flow in the differential diagnosis of acute appendicitis and right-sided renal colic. Vestnik khirurgii imeni I I Grekova. Jul–Aug. 1991;147(7–8):53-4. [pmid: 1668937].
745 Polous Iu M, Gerasimets Iu M, Bulat LP. Use of thermography in the diagnosis of acute appendicitis. Klinicheskaia khirurgiia. 1991;(2):3-4. [pmid: 1829124].
746 Porcel A, Arrive L, Mehdi M, et al. Abdominal emergencies of infectious origin. Annales de radiologie. 1996;39(1):15-36. [pmid: 8794574].
747 Porfilio Gularte G, Parquet R, Nakamura J, et al. Ischemic acute abdomen. Acta gastroenterologica Latinoamericana. 2005;35(4):206. 52. [pmid: 16496849].
748 Pouliquen X. Laparoscopic appendectomy. Journal de chirurgie. Jan–Feb. 2005;142(1):35-9. [pmid: 15883506].
749 Prado E, Garcia-Alcala H, Dominguez-Cocco A, et al. Comparative study of laparoscopic appendectomy vs open appendectomy. Revista de gastroenterologia de Mexico. Oct–Dec. 1997;62(4):254-9. [pmid: 9528295].
750 Protsenko AV, Starosek VN. State of the system of proteolytic enzyme inhibitors in inflammatory destructive processes in the abdominal cavity. Khirurgiia. Apr. 1984;(4):49-52. [pmid: 6610795].
751 Pruvost I, Aubry E, Martinot A. Diagnosis of acute abdominal pain in infants. La Revue du praticien. May. 2011;61(5):621-5. [pmid: 21698887].
752 Putzki H, Reichert B. Does measuring axillo-rectal temperature difference help in the diagnosis of acute appendicitis?. Langenbecks Archiv fur Chirurgie. 1988;373(5):310-2. [pmid: 3268712].
753 Puylaert JB, Coerkamp EG, de Vries BC. New diagnostic technology often offers no advantage in the differential diagnosis of acute abdomen. Nederlands tijdschrift voor geneeskunde. Jan. 1. 2000;144(1):52-3. [pmid: 10665303].
754 Puylaert JB, Koumans RK. Echography in appendicitis. Nederlands tijdschrift voor geneeskunde. Feb. 10. 1990;134(6):280-2. [pmid: 2406626].
755 Quarti-Trevano GM, Pagani M, Poma S, et al. False acute abdomen. Minerva chirurgica. Oct. 15. 1978;33(19):1325-38. [pmid: 692915].
756 Raakow R, Keck H, Neuhaus P. Results of laparoscopic appendectomy in camparison to conventional surgical technique. Langenbecks Archiv fur Chirurgie [serial on the Internet]. 1993. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/962/CN-00338962/frame.html. Last accessed.
757 Raakow R, Keck H, Steinmuller T, Bechstein WO, Neuhaus P. Laparoscopic appendectomy in comparison to conventional operative techniques. Minimal Invasive Chirurgie [serial on the Internet]. 1993. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/023/CN-00384023/frame.html. Last accessed.
758 Rachail M, Corallo J, Maurel G. Emergency laparoscopy. Archives francaises des maladies de l’appareil digestif. Mar. 1974;63(2):103-8. [pmid: 4280285].
759 Racloz Y, Rohner A. Laparoscopy in acute abdomen. Schweizerische Rundschau fur Medizin Praxis = Revue suisse de medecine Praxis. Jun. 4. 1985;74(23):622-4. [pmid: 2931792].
760 Rakotomavo FA, Riel AM, Rakotoarison RCN, et al. Acute peritonitis: Epidemiological, clinical and etiological aspects in a malagasy surgical emergency unit. About 60 cases. Journal Africain d’Hepato-Gastroenterologie. 2012;6(1):33-7. PMID:.
761 Ramos-Alvarez M, Bessudo L, Porras G, et al. Appendicitis in private pediatric practice. Boletin medico del Hospital Infantil de Mexico. May–Jun. 1974;31(3):487-503. [pmid: 4433405].
762 Raschka S, Raschka C. On the relationship between body dimensions and appendix length. Anthropologischer Anzeiger; Bericht uber die biologisch-anthropologische Literatur. Mar. 2008;66(1):67-72. [pmid: 18435206].
763 Ratner GL, Demidov GI, Basovich SN. Use of the specialized Diama electronic computer in the diagnosis of acute diseases of the abdominal cavity organs. Vestnik khirurgii imeni I I Grekova. Mar. 1980;124(3):132-6. [pmid: 6445620].
764 Ravari H, Ghaemi M, Vojdani A, Khashayar P. Does analgesia affect the diagnostic process in acute abdomen? A randomized clinical trial. Tehran University Medical Journal [serial on the Internet]. 2008;(10). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/365/CN-00707365/frame.html. Last accessed.
765 Reck T, Rupprecht H, Klein P, et al. Appendicitis in early childhood. Fortschritte der Medizin. Dec. 20. 1991;109(36):733-6. [pmid: 1778532].
766 Regimbeau JM, Couchard AC, Panis Y. Value of imaging in acute appendicitis diagnosis in the adult: the surgeon’s point of view. Journal de radiologie. Feb. 2001;82(2):107. [pmid: 11428204].
767 Regoly-Merei J, Ihasz M, Zaborszky A, et al. The role of real-time sonography in the differential diagnosis of acute appendicitis and in the detection of post-appendectomy complications. Orvosi hetilap. Apr. 16. 1989;130(16):827-31. [pmid: 2657560].
768 Reguera Garcia A, Leon Martinez MD, Aguayo Jimenez C, et al. Fever and recurrent abdominal pain. Gastroenterologia y hepatologia. Oct. 2010;33(8):615. [pmid: 20435385].
769 Reinbold WD, Seemann WR. Acute abdomen. Der Radiologe. Jun. 1984;24(6):299-300. [pmid: 6473764].
770 Reisener KP, Tittel A, Truong SN, et al. Value of sonography in routine diagnosis of acute appendicitis. A retrospective analysis. Leber, Magen, Darm. Feb. 9. 1994;24(1):16-22. [pmid: 8145622].
771 Repossini L, Ferrari-Parabita G. The behavior of the leukocyte sedimentation rate in acute abdominal diseases. Rivista di patologia e clinica. Nov. 1962;17:917-22. [pmid: 13981712].
772 Rettenbacher T, Hollerweger A, Macheiner P, et al. Ultrasonography of the normal vermiform appendix. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Jun. 1997;18(3):139-42. [pmid: 9340741].
773 Retzke U, Graf H, Schmidt M. Appendicitis in pregnancy. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:61-5. [pmid: 9880877].
774 Reymond MA, Merlini M, Tschantz P, et al. How to reduce the number of negative appendectomies? A prospective two-center study of 120 patients. Helvetica chirurgica acta. Apr. 1994;60(4):647-51. [pmid: 8034548].
775 Riabkov MG, Izmailov SG, Lukoianychev EE, et al. Intraabdominal hypertension in patients with acute conditions of abdominal cavity. Khirurgiia. 2013;(3):48-54. [pmid: 23612338].
776 Ribero F, Comotti F, Scaglia M, et al. Diagnostic-operative laparoscopy. Our experience. Minerva chirurgica. Jun. 1994;49(6):533-7. [pmid: 7970057].
777 Richter M, Laffer U, Ayer G, et al. Is appendectomy really performed too frequently? Results of the prospective multicenter study of the Swiss Society of General Surgery. Swiss surgery. Schweizer Chirurgie = Chirurgie suisse = Chirurgia svizzera. 2000;6(3):101-7. [pmid: 10894009].
778 Riesener KP, Klever P, Truong SN, et al. Role of sonography as primary diagnostic method in acute abdomen--a prospective study. Langenbecks Archiv fur Chirurgie Supplement Kongressband Deutsche Gesellschaft fur Chirurgie Kongress. 1997;114:1196-8. [pmid: 9574376].
779 Rilinger N, Pascu M, Haberle HJ, et al. Sonographic aspects of clinically suspected acute appendicitis. Aktuelle Radiologie. Jul. 1994;4(4):180-3. [pmid: 7918706].
780 Ring-Mrozik E, Naegele S, Soder J, et al. The value of C-reative protein analysis for the differential diagnosis of non-acute appendicitis. Klinische Padiatrie. Sep–Oct. 1991;203(5):377-80. [pmid: 1942946].
781 Risi D, Alessi G, Meli C, et al. Ultrasonography in abdominal emergencies. La Radiologia medica. May. 1989;77(5):485-7. [pmid: 2664917].
782 Rivera Diaz EM. Comparative evaluation of the surgical treatment of acute appendicitis: open appendicetomy versus laparoscopic appendicectomy in the national hospital hospital Carlos a. Seguin e. Essalud. Revista de gastroenterologia del Peru : organo oficial de la Sociedad de Gastroenterologia del Peru. Oct–Dec. 2002;22(4):287-96. [pmid: 12525844].
783 Robbers J, Mohr VD. External comparative quality assurance in appendectomy. Results of 2001 federal evaluation, 1. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Feb. 2003;74(2):M34-9. [pmid: 12691057].
784 Roche J, Vancina S, Tohoubi W, et al. Ultrasonographic findings in peridiverticulitis of the appendix. Gastroenterologie clinique et biologique. 1992;16(1):97-8. [pmid: 1537490].
785 Rodeck B. Acute abdominal pain in childhood. MMW Fortschritte der Medizin. Apr. 29. 2004;146(18):36-9. [pmid: 15366466].
786 Rodriguez Cuellar E, Gutierrez Andreu M, Gomez Rodriguez P, et al. Impact of imaging tests on the negative appendectomy rate. Revista de calidad asistencial : organo de la Sociedad Espanola de Calidad Asistencial. Jul–Aug. 2010;25(4):188-92. [pmid: 20227901].
787 Rogister G. Mesocolon cysts. Acta chirurgica Belgica. Dec. 1967;66(9):843-70. [pmid: 5601327].
788 Romano N, Prosperi V, Gabellieri C, et al. Laparoscopic approach in acute appendicitis: experience with 501 consecutive cases. Chirurgia italiana. May–Jun. 2009;61(3):327-35. [pmid: 19694235].
789 Rondbjerg J, Christensen M, Reimer E. C-reactive protein in acute appendicitis. A prospective blind study. Ugeskrift for laeger. Jun. 17. 1985;147(25):1989-90. [pmid: 4024350].
790 Rozsos I. Common abdominal emergency cases a the end of the 20th century. Orvosi hetilap. Jun. 21. 1998;139(25):1515-20. [pmid: 9676112].
791 Ruchalla E. Appendicitis--additional ultrasound diagnosis of suspected inflammation. [pmid: 24511607].
792 Rückbeil O, Fritze-Büttner F, Gellert K. Rare differential diagnosis for acute appendicitis. [pmid: 23238852].
793 Runarsdottir VA, Gudbjartsson T, Magnusson J. Is there a connection between skin temperature and appendicitis? A prospective study on the predictive value of traditional tests and skin temperature for acute appendicitis. Laeknabladid. Jun. 1996;82(6):465-70. [pmid: 20065438].
794 Rusakov VI, Chernov VN, Voloshchenko OI, et al. Diagnostic value of the analysis of immune complexes in acute appendicitis. Klinicheskaia khirurgiia. Apr. 1985;(4):12-4. [pmid: 3159930].
795 Rusakov VI, Voloshchenko OI, Pereskokov SV. Comparative informative value of the leukogram and the level of circulating immune complexes in patients with acute appendicitis. Vestnik khirurgii imeni I I Grekova. May. 1985;134(5):56-8. [pmid: 2930932].
796 Ruzek V, Vanecek T. Emergency states in internal medicine--diagnostic contribution of emergency abdominal ultrasonography. Vnitrni lekarstvi. Aug. 1992;38(8):745-50. [pmid: 1455755].
797 Rybakov AI, Dovzhikova VI. Changes in the phagocytic activity of leukocytes in patients with acute appendicitis. Vestnik khirurgii imeni I I Grekova. Feb. 1975;114(2):42-4. [pmid: 1189213].
798 Rychkovskii GF. The value of rectal and rectovaginal examination in the diagnosis of acute appendicitis in women. Khirurgiia. Oct. 1972;48(10):59-63. [pmid: 4658067].
799 Rzepecki A. Correlation between white blood count and leukocyte pattern in peripheral blood and the bacterial flora of appendix cultured under aerobic conditions in cases of acute appendicitis. Polski przeglad chirurgiczny. Oct. 1975;47(10):1201-8. [pmid: 1187464].
800 Saccia A. Laparoscopic surgery in abdominal emergencies. Minerva chirurgica. Oct. 1995;50(10):859-61. [pmid: 8684632].
801 Saccomani GE, Ingravalieri V, Rovida S, et al. Use of the discriminatory analysis in the diagnosis of acute appendicitis. Minerva chirurgica. Oct. 31. 1985;40(20):1391-4. [pmid: 4080212].
802 Salahova SS, Bayramov NY. Comparative valuation of the results of open and laparoscopic surgery for complicated forms of acute appendicitis. Azerbaijan Medical Journal. 2008;(3):126-8. PMID:.
803 Salem A, Fourati H, Mnif N. Image in clinical practice. La Tunisie medicale. Oct. 2007;85(10):880-4. [pmid: 18236813].
804 Salimov Sh T, Abdurakhmanov AA, Choriev MP, et al. Laparoscopy in diagnosis and treatment of acute abdominal diseases in children. Khirurgiia. 2000;(12):27-9. [pmid: 11195672].
805 Samofalov AA. Use of electrolaboratory tests in the diagnosis of acute appendicitis. Vestnik khirurgii imeni I I Grekova. Oct. 1967;99(10):50-4. [pmid: 5603749].
806 Sanabria A, Dominguez LC, Bermudez C, et al. Evaluation of diagnostic scales for appendicitis in patients with lower abdominal pain. Biomedica : revista del Instituto Nacional de Salud. Sep. 2007;27(3):419-28. [pmid: 18320107].
807 Sanchez Echaniz J, Luis Garcia M, Vazquez Ronco MA, et al. Diagnostic value of reactive C protein in suspected acute appendicitis in children. Anales espanoles de pediatria. May. 1998;48(5):470-4. [pmid: 9656532].
808 Sanchez Echaniz J, Luis Garcia M, Vazquez Ronco MA, Mintegui Raso S, Benito Fernandez J, Lopez Alvarez-Buhilla P. Diagnostic value of C-reactive protein in suspected acute appendicitis during childhood. Anales espanoles de pediatria. 1998;48(5):470-4. PMID:. [pmid: 9656532].
809 Sanchezmedal L. ACUTE APPENDICITIS. HEMATOLOGICAL ASPECTS. Cirugia y cirujanos. Jan–Feb. 1964;32:24-6. [pmid: 14188507].
810 Sandholzer H. Diagnostic work-up of abdominal pain by the family doctor: an avertable potentially threatening situation must be excluded. MMW Fortschritte der Medizin. Mar. 30. 2. 2006;148(13):30-4. 6. 7. [pmid: 16642703].
811 Sanogo ZZ, Koita AK, Diakite S, et al. Laparoscopic appendicectomy in Bamako. Journal Africain d’Hepato-Gastroenterologie. 2012;6(4):298-302. PMID:.
812 Sanogo ZZ, Koita AK, Diakite S, et al. Laparoscopic appendicectomy in Bamako. Journal Africain d’Hepato-Gastroenterologie. 2012;6(4):298-302. PMID:.
813 Sanou A, Zongo N, Ouedraogo T, et al. A retrospective study of 21 cases of intussusception in adults undergoing surgery in emergency visceral Centre Hospitalier Universitaire Yalgado Ouedraogo (CHUYO). Journal Africain d’Hepato-Gastroenterologie. 2012;6(1):28-32. PMID:.
814 Santamaria JI, Vega JM, Valverde JM, et al. Study of intestinal motility in the child with acute appendicitis using phonoenterography. Cirugia pediatrica : organo oficial de la Sociedad Espanola de Cirugia Pediatrica. Jul. 1993;6(3):117-9. [pmid: 8217506].
815 Sapisochin E. Acute abdomen. El Dia medico. Jun. 13. 1963;35:793-802. [pmid: 13991433].
816 Sauberli H, Laube W. Is technical progress in the diagnosis of acute abdomen in daily practice fiction or reality? Analysis of 660 cases. Schweizerische medizinische Wochenschrift. Apr. 16. 1983;113(15):559-61. [pmid: 6857213].
817 Savey L, Colau JC. Acute pelvic pain in women. La Revue du praticien. Oct. 1. 2001;51(15):1657-60. [pmid: 11759535].
818 Sazhin AV, Mosin SV, Kodzhoglian AA, et al. Epidemiological aspects of chronic appendicitis. Khirurgiia. 2011;(4):4-8. [pmid: 21512453].
819 Sazhin AV, Mosin SV, Kodzhoglian AA, et al. Principles of diagnostics and treatment of chronic appendicitis. Khirurgiia. 2011;(5):32-8. [pmid: 21606919].
820 Sazhin VP, Avdovenko AL, Klimov DE, et al. Possibilities in diagnostic laparoscopy of acute appendicitis. Khirurgiia. 2002;(8):24-7. [pmid: 12389496].
821 Sazhin VP, Klimov DE, Sazhin IV, et al. Laparoscopic appendectomy during pregnancy. Khirurgiia. 2009;(2):12-5. [pmid: 19365328].
822 Scheye T, Vanneuville G. Trial of a diagnostic score in painful abdominal syndromes suggestive of appendicitis in children over 3. Journal de chirurgie. Mar. 1988;125(3):166-9. [pmid: 3372603].
823 Schiedeck T. A difficult case and how do you clarify it. Appendicitis in spite of appendectomy scar. MMW Fortschritte der Medizin. Aug. 4. 2005;147(31–32):15. [pmid: 16128190].
824 Schietroma M, Cappelli S, Carlei F, et al. Acute abdomen: emergency laparoscopy or observation?. Chirurgia italiana. May–Jun. 2005;57(3):309-16. [pmid: 16231818].
825 Schildberg CW, Skibbe J, Croner R, et al. Rational diagnostics of acute abdomen. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Nov. 2010;81(11):1013-9. [pmid: 20464353].
826 Schima W. Diagnostic imaging of the acute abdomen. Wiener medizinische Wochenschrift (1946). 2001;151(21–23):532-5. [pmid: 11762248].
827 Schimpl G. Appendicitis. Monatsschrift fur Kinderheilkunde. 2010;158(5):493-501. PMID:.
828 Schindler G. Value of computerized tomography in the radiological diagnosis of acute abdomen. Rontgenpraxis; Zeitschrift fur radiologische Technik. Feb. 1984;37(2):48-57. [pmid: 6369564].
829 Schippers E. Appendicectomy laparoscopic vs open. Langenbecks Archiv fur Chirurgie [serial on the Internet]. 1993. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/412/CN-00339412/frame.html. Last accessed.
830 Schlosser HW. Appendicitis. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Apr. 1991;62(4):357. [pmid: 1860364].
831 Schmandra TC, Hanisch E. Routine computerized tomography in suspected acute appendicitis?. Zeitschrift fur Gastroenterologie. Jul. 1998;36(7):609-11. [pmid: 9738310].
832 Schmidt K, Samsula M, Raffaj J, et al. The contribution of laparoscopy in the differential diagnosis of adnexitis and appendicitis and in the conditions post-appendectomy (author’s transl). Ceskoslovenska gynekologie. Nov. 1974;39(9):664-5. [pmid: 4281362].
833 Schmidt SA, Juchems MS, Kramer K. A rare differential diagnosis of acute abdomen. [pmid: 23564197].
834 Schmidt SC, Henrich W, Schmidt M, et al. Laparoscopic appendectomy in pregnancy. Zentralblatt fur Chirurgie. Apr. 2007;132(2):112-7. [pmid: 17516316].
835 Schmolke M, Kern E. Clinical findings in appendicitis. Bruns’ Beitrage fur klinische Chirurgie. May. 1969;217(3):200-12. [pmid: 5370496].
836 Schmutz GR. Imaging of acute abdomen. Contribution of new radiological methods and practices. L’union medicale du Canada. Nov–Dec. 1992;121(6):358-65. [pmid: 1481295].
837 Schneider HJ. Value of urinary sediment in the differential diagnosis of acute appendicitis. Der Landarzt. Nov. 20. 1965;41(32):1392-4. [pmid: 5885975].
838 Scholmerich J, Volk BA, Jelitto HU, et al. Significance of sonography in internal acute diagnosis. Die Medizinische Welt. Jan. 13. 1984;35(1–2):67-71. [pmid: 6700413].
839 Scholz A. Complicated appendicitis intra partum. Zentralblatt fur Gynakologie. Jul. 31. 1971;93(31):1054-5. [pmid: 5114865].
840 Scholz M, David S, Stover B, et al. Value of ultrasound in diagnosis of appendicitis in childhood. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:41-2. [pmid: 9880870].
841 Schramm H, Arnold F, Melchert T. Changes in indications in laparoscopic appendectomy?. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:19-23. [pmid: 9880864].
842 Schramm R, Lang RD, Unger S, Thiele H. Laparoscopic appendectomy in acute appendicitis. Langenbecks Archiv fur Chirurgie [serial on the Internet]. 1994;(Suppl Kongressbericht). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/507/CN-00339507/frame.html. Last accessed.
843 Schratter M, Hermann M, Knittel M, et al. Complicated appendicitis in a caudal cecum--ectopically displaced normal roentgen markers. Rontgenpraxis; Zeitschrift fur radiologische Technik. Jun. 1995;48(6):187-9. [pmid: 7638674].
844 Schreiber HW, Koch W, Bartsch WM. Acute appendicitis and granulocytosis. Zentralblatt fur Chirurgie. Dec. 23. 1967;92(51):3027-30. [pmid: 5589429].
845 Schreiber LD, Zimmermann H, Pickart L. Endoscopic surgical technique in appendectomy. Experiences and results of 950 laparoscopic appendectomies. Zentralblatt fur Chirurgie. Suppl 4. 1998;123:85-9. [pmid: 9880883].
846 Schreiner M, Spazier M, Wayand W. Diagnosis of acute appendicitis over two decades - effects of increasing number of imaging procedures on costs, preoperative reliability and patient outcome. Zentralblatt fur Chirurgie. Aug. 2010;135(4):336-9. [pmid: 20806136].
847 Schroder H. Acute abdomen--emergency radiography in the aged. ZfA Zeitschrift fur Alternsforschung. 1981;36(4):289-91. [pmid: 6982568].
848 Schumpelick V, Schippers E, Tittel A, et al. Ambulatory surgery in abdominal surgery. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Aug. 1991;62(8):582-6. [pmid: 1834441].
849 Schutte HE. Appendix and radiologist. Nederlands tijdschrift voor geneeskunde. Jun. 7. 1975;119(23):905-11. [pmid: 1143574].
850 Schutz W. Acute abdomen. Deutsches medizinisches Journal. Jun. 5. 1970;21(11):808-13. [pmid: 5512350].
851 Schwarzenbach HR, Jenzer S. Diagnosis and anagement of suspected nephrolithiasis in a primary care setting. Praxis. 2012;101(18):1187-92. PMID:. [pmid: 22945820].
852 Schwerk WB, Braun B. Sonographic differential diagnosis in acute abdomen. Medizinische Klinik. Feb. 2. 1979;74(5):161-5. [pmid: 763209].
853 Schwerk WB, Wichtrup B, Maroske D, et al. Ultrasonics in acute appendicitis. A prospective study. Deutsche medizinische Wochenschrift (1946). Mar. 31. 1988;113(13):493-9. [pmid: 3280294].
854 Schwerk WB. Ultrasonic diagnosis in gastroenterology. Indications and results. Der Internist. Jan. 1982;23(1):36-46. [pmid: 7040282].
855 Schwerk WB. Ultrasound first in acute appendix? Unnecessary laparotomies can often be avoided. MMW Fortschritte der Medizin. Jul. 6. 2000;142(26–27):29-32. [pmid: 10929479].
856 Seelen JL, Puylaert JB. Bacterial ileocecitis: a “new” disease. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Dec. 1991;12(6):269-71. [pmid: 1796286].
857 Seguel Ramirez F, de Mingo Misena L, Rollan Villamarin V. Nine years of experience with laparoscopic appendectomy in children. Cirugia pediatrica : organo oficial de la Sociedad Espanola de Cirugia Pediatrica. Jul. 2002;15(3):94-6. [pmid: 12601980].
858 Seitz K, Vasilakis D, Ziegler M. Efficiency of a portable B-scan ultrasound device in comparison to a high-end machine in abdominal ultrasound. Results of a pilot study. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Apr. 2003;24(2):96-100. [pmid: 12698374].
859 Sejor E, Gugenheim J. Diagnosing acute appendicitis. La Revue du praticien. Sep. 2011;61(7):981-2. [pmid: 22039744].
860 Selz F, Maggi S, Heisler K, et al. Observations on the advent of abdominal surgery via laparoscopy. Revue medicale de la Suisse romande. Feb. 1994;114(2):103-9. [pmid: 8140361].
861 Semeniuk Iu S, Panasiuk MH, Ievkevych SA, et al. Ultrasound diagnosis of acute appendicitis. Klinicheskaia khirurgiia. Feb. 2013;(2):75-6. [pmid: 23705490].
862 Semm K. Pelviscopic appendectomy. Deutsche medizinische Wochenschrift (1946). Jan. 8. 1988;113(1):3-5. [pmid: 2961552].
863 Serengbe BG, Gaudeuille A, Soumouk A, et al. Acute abdominal pain in children at the Pediatric Hospital in Bangui (Central African Republic). Epidemiological, clinical, paraclinical, therapeutic and evolutive aspects. Archives de pediatrie : organe officiel de la Societe francaise de pediatrie. Feb. 2002;9(2):136-41. [pmid: 11915494].
864 Serste JP, Theunis A. Use of laparoscopy in abdominal emergencies, traumatic or not (author’s transl). Acta chirurgica Belgica. Sep. 1973;72(5):387-92. [pmid: 4272708].
865 Sezeur A, Bure Rossier AM, Rio D, Savigny B, Tricot C, Martel P, Baubion O. Does laparoscopy increase the bacterial risk of appendectomy? Results of a prospective randomized study. Annales de chirurgie [serial on the Internet]. 1997. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/732/CN-00548732/frame.html. Last accessed.
866 Sezeur A, Bure-Rossier AM, Rio D, et al. Does laparoscopy increase the bacteriological risk of appendectomy? Results of a randomized prospective study. Annales de chirurgie. 1997;51(3):243-7. [pmid: 9297886].
867 Sfairi A, Farah A, Patel JC. Acute appendicitis in patients over 70 years of age. Presse medicale (Paris, France : 1983). Apr. 27. 1996;25(15):707-10. [pmid: 8685135].
868 Sfairi A, Patel JC. Laparoscopy for appendicular syndromes in young women. Results of a prospective study. Journal de chirurgie. Aug–Sep. 1995;132(8–9):333-5. [pmid: 8550714].
869 Timofeev ME, Fedorov ED, Krechetova AP, Shapoval’iants SG. Video-laparoscopic interventions in diagnostics and treatment of torsion and necrosis of appendices epiploica. [pmid: 24738200].
870 Shabanov Iu A. An improved method of laparoscopic diagnosis. Vestnik khirurgii imeni I I Grekova. Jun. 1983;130(6):126-7. [pmid: 6225236].
871 Shalygin VA, Eroshenko LB, Solnyshko AL, et al. Diagnostic and prognostic significance of study of acute phase proteins in children with appendicular peritonitis. Klinicheskaia laboratornaia diagnostika. Jul. 2002;(7):7-9. [pmid: 12187593].
872 Shaposhnikov AV, Goncharenko AV. Leukocytic index of intoxication in acute surgical diseases of the abdominal organs. Klinicheskaia khirurgiia. May. 1985;(5):66. [pmid: 4021353].
873 Shcherbatenko MK, Beresneva EA, Evdokimov VN, et al. Scanning x-ray study in acute surgical diseases of the abdominal cavity organs. Vestnik rentgenologii i radiologii. Sep–Oct. 1980;(5):28-36. [pmid: 7423836].
874 Shebuev MG. The leukocyte index in the dynamics of acute appendicitis. Khirurgiia. Nov. 1965;41(11):20-3. [pmid: 4862222].
875 Shen H, Yuan J, Hong F, Xie X, Lu XM. Diagnostic value of CT versus BUS in detection of acute appendicitis. World Chinese Journal of Digestology. 2013;21(18):1776-9.
876 Shestobuz SV, Bodnar BM, Brozhyk VL, et al. Differences in differential diagnosis between acute mesenterial lymphadenitis and appendicitis in children. Klinicheskaia khirurgiia. Jul. 2000;(7):39-40. [pmid: 11033955].
877 Shi H, Wu BY, Liu WH, et al. The value of serum intestinal fatty acid binding protein measurement in discriminating intestinal ischemia in patients with acute abdomen. Zhonghua nei ke za zhi. Sep. 2012;51(9):690-3. [pmid: 23158918].
878 Shikata J, Okinaga K, Ukishima H. Significance of simple abdominal radiography in acute appendicitis. Rinsho hoshasen Clinical radiography. Dec. 1969;14(12):969-78. [pmid: 5199423].
879 Shikata J, Tanaka K. Study of discrimination in computer-assisted diagnosis, the weighted likelihood method in conjuction with an orthogonal table. Iyo denshi to seitai kogaku Japanese journal of medical electronics and biological engineering. Apr. 1977;15(2):81-6. [pmid: 328963].
880 Shmauss AK, Pavlik RD. A comment on the work of A.A. Samofalov. “The importance of the phenomena of local temperature and local leukocytosis in the diagnosis of acute appendicitis”. Klinicheskaia khirurgiia. Sep. 1968;9:84-5. [pmid: 5739268].
881 Shraiber MI, Braines SN, Brailovskii BL, et al. Diagnosis of chronic appendicitis by means of computer algorhythm recognition. Eksperimental’naia khirurgiia i anesteziologiia. Sep–Oct. 1967;12(5):26-8. [pmid: 4903613].
882 Shturich PI, Novikov DK, Adamenko GP. Study of bacterial allergy in acute appendicitis by the method of leukocyte migration inhibition in vitro. Vestnik khirurgii imeni I I Grekova. Apr. 1976;116(4):51-5. [pmid: 785785].
883 Sidler S, Heim D, Negri M, et al. The value of ultrasound diagnosis in “acute appendicitis” patient admission. Swiss surgery. Schweizer Chirurgie = Chirurgie suisse = Chirurgia svizzera. 2003;9(6):297-306. [pmid: 14725099].
884 Siewert JR, Holscher AH, Ultsch B. Ultrasound in surgery. Langenbecks Archiv fur Chirurgie. 1984;363(2):75-8. [pmid: 6394930].
885 Simmen HP, Decurtins M, Brutsch HP, et al. Emergency hospitalization for acute, non-accidental abdominal pain. Prospective data of a surgical university clinic. Helvetica chirurgica acta. May. 1991;57(6):957-60. [pmid: 1890000].
886 Simon R. Pseudo-appendicular acute abdomen and Bouillaud’s disease. Memoires Academie de chirurgie (France). Oct. 11–18. 1950;76(26–27):774-6. [pmid: 14806060].
887 Simonovsky V. Detection of acute appendicitis using ultrasonography. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. May. 2000;79(5):215-20. [pmid: 10916441].
888 Simonovsky V. Detection of diseases mimicking acute appendicitis using ultrasonography. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Sep. 2001;80(9):480-6. [pmid: 11715814].
889 Simonovsky V. The ultrasonic picture of acute appendicitis. Ceskoslovenska radiologie. Mar. 1990;44(2):85-98. [pmid: 2189580].
890 Siragusa G, Gelarda E, Epifanio E, et al. Video laparoscopy in abdominal emergencies. Minerva chirurgica. Apr. 1999;54(4):199-204. [pmid: 10380516].
891 Siragusa G, Geraci G, Albanese L, et al. Video laparoscopic appendectomy. Our experience. Minerva chirurgica. Jan–Feb. 1999;54(1–2):1-5. [pmid: 10230221].
892 Sitter H, Zielke A, Ohmann C. Making a decision in acute abdominal pain. Problem areas in particular patient groups and in routine quality assurance. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Apr. 1994;65(4):270-7. [pmid: 8020347].
893 Skaane P, Amland PF, Solheim K. Diagnostic imaging of acute appendicitis. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Feb. 10. 1988;108(4):313-4. 21. [pmid: 3281321].
894 Slim K. Diagnosis of appendiceal syndromes: for a rational management. Journal de chirurgie. Aug. 2001;138(4):253-4. [pmid: 11683141].
895 Smid D, Skalicky T, Treska V. Contribution of abdominal sonography in acute appendicitis diagnostics--our experience. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Aug. 2009;88(8):466-8. [pmid: 20055304].
896 Sobolev VE, Dudanov IP, Alontseva NN, et al. The role of laparoscopy in the diagnosis and treatment of early postoperative complications. Vestnik khirurgii imeni I I Grekova. 2005;164(1):95-9. [pmid: 15957821].
897 Solheim K. “Unnecessary laparotomy”. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Oct. 30. 1994;114(26):3048-9. [pmid: 7974420].
898 Solheim K. Acute laparoscopic surgery. Tidsskrift for den Norske laegeforening : tidsskrift for praktisk medicin, ny raekke. Oct. 20. 1993;113(25):3123-4. [pmid: 8273030].
899 Sommella L, Cirone MJ, Battaglia M, et al. Significance of ultrasonography in the diagnosis of appendicitis. Minerva chirurgica. Mar. 2000;55(3):129-32. [pmid: 10832296].
900 Sotje G, Schmidt S, Bertermann H. Acute abdomen caused by cystic epigastric tumor. Der Radiologe. Jan. 1995;35(1):73-4. [pmid: 7892443].
901 Soto-Lopez A, Aguila-Melero O, Reyes-Corcho A, et al. Diagnostic efficiency in acute appendicitis. Cirugia y cirujanos. May–Jun. 2003;71(3):204-9. [pmid: 14617408].
902 Souei-Mhiri M, Tlili-Graies K, Ben Cherifa L, et al. Mucocele of the appendix. Retrospective study of 10 cases. Journal de radiologie. Apr. 2001;82(4):463-8. [pmid: 11353901].
903 Sovtsov SA. The acute appendicitis: what has changed since the beginning of the new century?. Khirurgiia. 2013;(7):37-42. [pmid: 23887322].
904 Spehl-Robberecht M, Toppet-Hoegars-Muller V. Contribution of digestive system ultrasonography in the assessment of abdominal pain in children. Revue medicale de Bruxelles. Nov–Dec. 1994;15(6):376-81. [pmid: 7824831].
905 Stacher R, Portugaller H, Preidler KW, et al. Acute appendicitis in non-contrast spiral CT: a diagnostic luxury or benefit?. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Jul. 1999;171(1):26-31. [pmid: 10464501].
906 Stagnitti F, Salvi PF, Schillaci F, et al. Acute appendicitis or diverticulitis of the right colon? Diagnostic dilemma in emergency surgery. Il Giornale di chirurgia. Mar. 2005;26(3):89-93. [pmid: 15934628].
907 Staib I, Kann W. What value does laboratory diagnosis have in acute abdomen?. Fortschritte der Medizin. Nov. 5. 1981;99(41):1677-80. [pmid: 7319437].
908 Stamm D. Acute abdominal pain in children. Diagnostic orientation. La Revue du praticien. Nov. 1. 2000;50(17):1923-30. [pmid: 11151335].
909 Stanescu D, Sternberg D, Chirila R, et al. Virological research on appendicitis. Virologie. Jan–Mar. 1988;39(1):41-6. [pmid: 3287759].
910 Stapel A, Grotz M, Kirchner R. Acute appendicitis mimicking cholecystitis. Case reports and review with focus on medicolegal aspects. [pmid: 24114418].
911 Stefanutti G, Sabatti M, Gobbi D, et al. Values of white blood cell count in the diagnosis of acute appendicitis. La Pediatria medica e chirurgica : Medical and surgical pediatrics. Sep–Oct. 2002;24(5):368-73. [pmid: 12494538].
912 Steiner H, Thurner J, Zimmermann G. The problem of appendicitis. Wiener medizinische Wochenschrift (1946). Apr. 10. 1971;121(15):320-3. [pmid: 5555162].
913 Stenzel I, Klumair J, Fochem K. Sonography and computer tomography of an epiploic appendix. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. Jul. 1981;135(1):105. [pmid: 6214466].
914 Stepanov EA, Dronov AF, Smirnov AN, et al. Laparoscopy in the diagnosis of acute appendicitis in children. Pediatriia. 1988;(6):69-72. [pmid: 2972991].
915 Stepanov EA, Geras’kin VI, Dronov AF, et al. Clinical significance of nondestructive forms of appendicitis in children. Vestnik khirurgii imeni I I Grekova. Jun. 1983;130(6):85-9. [pmid: 6225237].
916 Steurer J. Pre-test and post-test probabilities. Who cares?. Therapeutische Umschau Revue therapeutique. Jan. 2009;66(1):5-7. [pmid: 19105149].
917 Stiefelhagen P. Difficult differential diagnosis. Appendicitis or right quadrant diverticulitis?. MMW Fortschritte der Medizin. Nov. 12. 2009;151(46):18. [pmid: 20043386].
918 Stiefelhagen P. Difficult differential diagnosis: Appendicitis or right-sided diverticulitis?. MMW-Fortschritte der Medizin. 2009;151(46):18. PMID:.
919 Storby G. Thoracic radiography is indicated in the examination of acute abdomen! The cause of abdominal symptoms may be found in the thorax. Lakartidningen. Sep. 6. 1995;92(36):3214-6. [pmid: 7674713].
920 Strittmatter F, Gratzke C, Graser A, et al. Imaging for diagnostics of urolithiasis including dual-energy CT. Der Urologe Ausg A. Apr. 2013;52(4):541-5. [pmid: 23483271].
921 Stroh C, Rauch J, Schramm H. Is there a chronic appendicitis in childhood? Analysis of pediatric surgical patients from 1993–1997. Zentralblatt fur Chirurgie. 1999;124(12):1098-102. [pmid: 10670095].
922 Strzalka M, Bobrzynski A, Budzynski A, et al. Acute appendicitis--open or laparoscopic surgery?. Przeglad lekarski. Suppl 7. 2003;60:70-4. [pmid: 14679698].
923 Subotic AM, Sijacki AD, Dugalic VD, et al. Evaluation of the Alvarado score in the diagnosis of acute appendicitis. Acta chirurgica Iugoslavica. 2008;55(1):55-61. [pmid: 18510062].
924 Sukhanova GA, Shalbueva NI, Shalygin VA. The activity of trypsin and proteolytic inhibitors in complicated forms of appendicitis in children. Klinicheskaia laboratornaia diagnostika. Nov–Dec. 1996;(6):31-3. [pmid: 9044727].
925 Sulberg D, Chromik AM, Kersting S, et al. Appendicitis in the elderly. CRP value as decision support for diagnostic laparoscopy. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jul. 2009;80(7):608-14. [pmid: 19562239].
926 Sun XL, Xu HB. Comparative study among open laparoscopic and video assisted appendectomies. World Chinese Journal of Digestion [serial on the Internet]. 1998. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/898/CN-00284898/frame.html. Last accessed.
927 Svitich Iu M, Veber VR, Faerman Ia I. Cutaneous thermometry of the anterior abdominal wall in emergency surgery. Klinicheskaia khirurgiia. Apr. 1984;(4):55. [pmid: 6233452].
928 Switalski W, Podwinski A. Value of peritoneal tapping in the diagnosis of acute abdominal diseases. Polski przeglad chirurgiczny. Apr. 1975;47(4):487-92. [pmid: 1135115].
929 Szavay P. Appendicitis: New and trusted methods in diagnosis, treatment, and surgery. Monatsschrift fur Kinderheilkunde. 2013;161(2):116-21. PMID:.
930 Szavay P. Appendicitis: New and trusted methods in diagnosis, treatment, and surgery. Monatsschrift fur Kinderheilkunde. 2013;161(2):116-21. PMID:.
931 Tada S. Non-traumatic abdominal disease: significance of plain abdomen film. Rinsho hoshasen Clinical radiography. Jun. 1984;29(6):705-10. [pmid: 6482054].
932 Takada T, Yasuda H, Uchiyama K, et al. Use of ultrasonography in the evaluation of acute appendicitis. Nihon Igaku Hoshasen Gakkai zasshi Nippon acta radiologica. Feb. 25. 1985;45(2):343-7. [pmid: 3892476].
933 Tanaka J. How to apply X-ray CT reasonably: obligation of the radiologists. Nihon Hoshasen Gijutsu Gakkai zasshi. Oct. 20. 2005;61(10):1374-5. [pmid: 16270014].
934 Taourel P, Kessler N, Blayac P, et al. Acute appendicitis: to image or not to image?. Journal de radiologie. Dec. 2002;83(12 Pt 2):1952-60. [pmid: 12592155].
935 Taourel P. Impact of CT on negative appendectomy and appendiceal perforation rates. Journal de radiologie. Mar. 2008;89(3 Pt 1):289-90. [pmid: 18408626].
936 Taourel P. Work-up of appendicitis with imaging: the end of certainty. Journal de radiologie. Apr. 2001;82(4):443-4. [pmid: 11353898].
937 Tarjan Z, Mako E, Winternitz T, et al. The value of ultrasonic diagnosis in acute appendicitis. Orvosi hetilap. Apr. 2. 1995;136(14):713-7. [pmid: 7731671].
938 Tas EE, Keskin HL, Nemutlu SA, Cali U, Sivaslioglu AA, Avsar AF. Five years analysis of the ectopic pregnancies: A single centre experience. Medical Journal of Bakirkoy. 2013;9(3):105-10. PMID:.
939 Tavolaro S, Cuenod CA. Acute appendicitis diagnosis in adults. La Revue du praticien. Apr. 2013;63(4):529-34. [pmid: 23682485].
940 Tebala GD, Innocenti P, De Chiara F, et al. Emergency laparoscopic surgery. Chirurgia italiana. Mar–Apr. 2008;60(2):199-212. [pmid: 18689167].
941 Ternovoi KS, Rozenfel’d LG, Chernushenko MF. Electroroentgenography in orthopedics and traumatology and in the diagnosis of various emergency conditions. Klinicheskaia khirurgiia. 1985;(12):34-6. [pmid: 3912592].
942 Testas P. Acute appendicitis and appendiceal peritonitis treated by celioscopy in adults. Results of a survey with 4,214 cases: synthesis and conclusions. Chirurgie; memoires de l’Academie de chirurgie. 1993;119(8):444-5. [pmid: 7805512].
943 Thomsen C. “How to reduce inappropriate appendectomies?”. Journal de chirurgie. Jun. 2000;137(3):193. [pmid: 11001661].
944 Thurnheer U. Comments from the viewpoint of a primary care physician. Praxis. Apr. 14. 2010;99(8):462. [pmid: 20391348].
945 Tikinskii OL. Errors in the diagnosis of surgical diseases of the organs of the abdominal cavity. Vestnik khirurgii imeni I I Grekova. Jun. 1974;112(6):105-8. [pmid: 4454154].
946 Till, Weiss, Kellnar, Bohm, Joppich. Laparoscopic appendectomy reduces post operative inflammation and shortens convalescence in children. Monatsschrift fur Kinderheilkunde [serial on the Internet]. 1995. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/087/CN-00340087/frame.html.
947 Tiu CM, Pan HB, Chou YH, et al. Computed tomography of appendical abscess. Taiwan yi xue hui za zhi Journal of the Formosan Medical Association. Jan. 1986;85(1):54-9. [pmid: 3458872].
948 Tolkachev ML. Appendicitis in typhoid fever. Klinicheskaia meditsina. Mar. 1950;3:60-2. [pmid: 15415989].
949 Tollner U, Pohlandt F. Ascites puncture for the differential diagnosis in acute abdomen in the newborn infant. Klinische Padiatrie. Sep–Oct. 1984;196(5):319-20. [pmid: 6492689].
950 Topal D, Metzger U. Comment on rule of thumb 3 in PRAXIS no. 7. “The patient who can climb on the cot with ease does not have appendicitis”. Praxis. Jun. 24. 2009;98(13):693-4. [pmid: 19551653].
951 Torgunakov AP. Correlation between changes in blood 17-hydroxycorticosteroid level, leukocyte count and the Kal’f-Kalif index in acute appendicitis. Laboratornoe delo. 1971;2:82-4. [pmid: 4104392].
952 Torgunakov AP. Interpretation of the Kal’f-Kalif index. Khirurgiia. 2008;(2):73-4. [pmid: 18589918].
953 Torgunakov AP. What shall we do in simple (catarrhal) appendicitis?. Khirurgiia. 2005;(7):60-2. [pmid: 16196161].
954 Toriello J. SIMPLE RADIOLOGIC STUDIES. STUDY OF THE ABDOMEN (EMPTY PLATE). Revista del Colegio Medico de Guatemala. Dec. 1963;14:152-3. [pmid: 14125655].
955 Trammer A, Hecker WC. Appendicitis in enteritis. Monatsschrift Kinderheilkunde : Organ der Deutschen Gesellschaft fur Kinderheilkunde. Jul. 1989;137(7):422-4. [pmid: 2677686].
956 Trentzsch H, Werner J, Jauch KW. Acute abdominal pain in the emergency department - a clinical algorithm for adult patients. Zentralblatt fur Chirurgie. Apr. 2011;136(2):118-28. [pmid: 21424993].
957 Treutner KH, Schumpelick V. Epidemiology of appendicitis. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jan. 1997;68(1):1-5. [pmid: 9132342].
958 Trimbos JB, Trimbos-Kemper GC. Young women with symptoms of acute abdomen; diagnosis through a keyhole. Nederlands tijdschrift voor geneeskunde. Jan. 29. 1983;127(5):185-7. [pmid: 6219295].
959 Tuchmann A, Sommer O, Zeidler G. Diagnosis and results of treatment in appendicitis. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. May. 1981;52(5):338-43. [pmid: 7238178].
960 Tundidor Bermudez AM, Amado Dieguez JA, Montes de Oca Mastrapa JL. Urological manifestations of acute appendicitis. Archivos espanoles de urologia. Apr. 2005;58(3):207-12. [pmid: 15906614].
961 Twena M, Avinoah E, Shaked G, et al. Experience with laparoscopic appendectomy. Harefuah. Jun. 1. 1993;124(11):676-8. 740. [pmid: 8344623].
962 Tzivian A, Sherman I, Yacobi Y, et al. First experiences in non-enhanced spiral computed tomography for diagnosis of acute flank pain. Harefuah. Jul. 2000;139(1–2):22-4. 79. [pmid: 10979447].
963 Khoshnood A, Ekelund U. Routine rectal palpation in acute abdomen has no proven value. A review of the literature. [pmid: 24552011].
964 Uchikov A, Uchikova E, Markova D, et al. Acute appendicitis and pregnancy. Khirurgiia. 2005;(4–5):12-5. [pmid: 18693510].
965 Udod VM, Andrun PK. Biochemical tests in the diagnosis of acute appendicitis. Khirurgiia. May. 1969;45(5):66-70. [pmid: 5347812].
966 Uebel P, Weiss H, Trimborn CP, et al. Ultrasound diagnosis of acute appendicitis--possibilities and limits of the method--results of prospective and retrospective clinical studies. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Jun. 1996;17(3):100-5. [pmid: 8767646].
967 Ulrich S, Furrer J, Boehm T, et al. Acute epigastric pain. Praxis. May. 14. 2003;92(20):959-64. [pmid: 12793122].
968 Ures J, Stacchini A, Prates JC, et al. Anatomoradiological patterns of vermiform appendix’s arterial supply (author’s transl). Arquivos de gastroenterologia. Oct–Dec. 1978;15(4):175-9. [pmid: 749855].
969 Vahl AC, Out NJ, Kapteijn BA, et al. Nothing gained from the determinations of plasma lactate levels in the evaluation of a patient with acute abdomen. Nederlands tijdschrift voor geneeskunde. Apr. 18. 1998;142(16):901-4. [pmid: 9623186].
970 Valladares Mendias JC, Alaminos Mingorance M, Castejon Casado J, et al. The usefulness of ultrasonography in the diagnosis of acute appendicitis in children. Cirugia pediatrica : organo oficial de la Sociedad Espanola de Cirugia Pediatrica. Apr. 1998;11(2):67-70. [pmid: 9608144].
971 Valladares Mendias JC, Rabaza Espigares MJ, Martinez Meca S, et al. Efficiency of ultrasonography in the diagnosis of acute appendicitis. Cirugia pediatrica : organo oficial de la Sociedad Espanola de Cirugia Pediatrica. Jul. 2000;13(3):121-3. [pmid: 12601942].
972 van den Ende ED, Boellaard WP, Allema JH, et al. Diagnostic surplus value of echography in children with acute abdominal pain. Nederlands tijdschrift voor geneeskunde. Jun. 14. 2003;147(24):1174-7. [pmid: 12845838].
973 van der Ham AC, van Gelder T, Yo TI. Surgical treatment of acute appendicitis in elderly patients. Nederlands tijdschrift voor geneeskunde. Aug. 1. 1987;131(31):1346-50. [pmid: 3658002].
974 van Erp WF. Laparoscopy useful in the diagnosis and surgery of acute appendicitis. Nederlands tijdschrift voor geneeskunde. Jul. 24. 1993;137(30):1500-4. [pmid: 8366937].
975 Van Galen JT. Rectal examination in chronic appendical disease. Nederlands tijdschrift voor geneeskunde. Jul. 5. 1952;96(27):1651-3. [pmid: 12993234].
976 van Gorp MJ, Rutgers DR, van Leeuwen MS, et al. Ancillary diagnostic imaging is useful if there is atypical evidence of appendicitis. Nederlands tijdschrift voor geneeskunde. Mar. 17. 2007;151(11):642. [pmid: 17441568].
977 van Herwaarden-Lindeboom MY, Rinkes IH, Gooszen HG. Ancillary diagnostic imaging is undesirable if there is evidence of appendicitis. Nederlands tijdschrift voor geneeskunde. Mar. 17. 2007;151(11):643. [pmid: 17441569].
978 van Laarhoven S, Schattenkerk ME. New guideline on acute appendicitis: routine preoperative imaging is too simple. Nederlands tijdschrift voor geneeskunde. 2010;154:A1571. [pmid: 20456805].
979 van Meeteren J, Bruyninckx CM. Acute appendicitis; a retrospective analysis. Nederlands tijdschrift voor geneeskunde. Mar. 30. 1985;129(13):586-9. [pmid: 3990847].
980 van Randen A, Laméris W, Luitse JSK, et al. The role of plain radiographs in patients with acute abdominal pain at the ED. American Journal of Emergency Medicine. 2011;29(6):582-9.e2. Language: English. Entry Date: 20110805. Revision Date: 20120817. Publication Type: journal article. [pmid: 20825832].
981 van Rijn RR, Robben SG. Ancillary diagnostic imaging is useful if there is atypical evidence of appendicitis. Nederlands tijdschrift voor geneeskunde. Oct. 20. 2007;151(42):2352-3. [pmid: 18064942].
982 van Weel C. An analysis of cases of missed acute appendicitis: for the time being there is no basis for a better policy. Nederlands tijdschrift voor geneeskunde. Aug. 10. 2002;146(32):1477-9. [pmid: 12198824].
983 Vasconi V, Merlo G. Practical value of a little-known reaction in differential diagnosis of acute abdomen. Minerva medica. Jul. 21. 1957;48(57–58):2447-9. [pmid: 13464646].
984 Vasen W. The difficult diagnosis of the surgical acute abdomen. Acta gastroenterologica Latinoamericana. 2004;34(1):4. 54. [pmid: 15328661].
985 Vasilenko IS, Egorov SN. On some objective data in the diagnosis of acute appendicitis in children. Vestnik khirurgii imeni I I Grekova. Feb. 1967;98(2):96-8. [pmid: 5610981].
986 Vasilev I, Milev M. APPENDICITIS IN THE AGED. Khirurgiia. 1964;17:224-6. [pmid: 14149080].
987 Vasil’ev VS, Komar VI, Sheiko MI, et al. Diagnosis of surgical diseases in an infectious disease hospital. Klinicheskaia meditsina. Sep. 1985;63(9):115-7. [pmid: 4068615].
988 Vas’kov VM, Piastolov A. Clinical characteristics of acute appendicitis in the middle-aged and elderly. Vestnik khirurgii imeni I I Grekova. Oct. 1981;127(10):54-8. [pmid: 7332659].
989 Vasyliuk SM, Lab’iak IR. Characteristic of hepatorenal perfusion in patients with acute appendicitis. Klin Khir. May. 2013;(5):32-4. [pmid: 23888806].
990 Vazquez Ronco MA, Morteruel Arizkuren E, Garcia Ojeda E, et al. Diagnostic yield of abdominal ultrasonography in acute appendicitis. Anales de pediatria (Barcelona, Spain : 2003). Jun. 2003;58(6):556-61. [pmid: 12781111].
991 Vegar-Zubovic S, Lincender L, Dizdarevic S, et al. Ultrasound in the diagnosis and differential diagnosis of acute appendicitis in childhood. Medicinski arhiv. 2003;57(4):233-6. [pmid: 14528718].
992 Velasquez Hawkins C, Aguirre Machado W, Valdivia Bejar C, et al. The value of ultrasound in the diagnosis and management of acute appendicitis. Revista de gastroenterologia del Peru : organo oficial de la Sociedad de Gastroenterologia del Peru. Jul–Sep. 2007;27(3):259-63. [pmid: 17934540].
993 Verner T, Vrany M. Laparoscopic appendectomy at the Department of Surgery in Jablonec nad Nisou. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. May. 1994;73(4):171-2. [pmid: 8052918].
994 Vilallonga-Puy R, Lopez-Cano M, Armengol-Carrasco M. Appendicectomy in pregnant women. Cirugia espanola. Apr. 2006;79(4):261. [pmid: 16753113].
995 Vilianskii MP, Nikitin VM, Chumakov AA, et al. Methods in remote diagnosis made by Regional Consultative Center in acute diseases of abdominal organs. Sovetskaia meditsina. Sep. 1978;(9):115-20. [pmid: 360430].
996 Vincent E. Intravenous urography in diagnosis of acute abdominal syndromes. Journal d’urologie medicale et chirurgicale. 1954;60(3–4):178-91. [pmid: 13192888].
997 Vinz H, Neu J. Malpractice claims relating to the diagnosis and treatment of acute appendicitis--decisions of the Norddeutsche Schlichtungsstelle (Expert Panel for Extrajudicial Claims Resolution of the Medical Associations in Northern Germany). Zeitschrift fur arztliche Fortbildung und Qualitatssicherung. 2007;101(8):553-63. [pmid: 18225407].
998 Vishnevskii AA, Braines SN, Brailovskii VL. Tabular method of differential diagnosis of chronic appendicitis. Eksperimental’naia khirurgiia i anesteziologiia. Jul–Aug. 1970;15(4):3-7. [pmid: 4931669].
999 Vishnevskii AA, Bykhovskii ML, Vilianskii MP, et al. Distance diagnosis of acute diseases of the abdominal organs with the aid of electronic computer. Eksperimental’naia khirurgiia i anesteziologiia. Jul–Aug. 1975;(4):3-6. [pmid: 765106].
1000 Vogel P, Jauch KW. Acute abdomen (1). Zentralblatt fur Chirurgie. Sep. 2001;126(9):W67-75. [pmid: 11699295].
1001 Voko Z. Basic rules for decision making at the bedside. Model for diagnostic reasoning based on Bayesian theory. Lege artis medicinae : uj magyar orvosi hirmondo. Mar. 2011;21(3):220-5. [pmid: 21650016].
1002 von Suchodoletz H, Volzer H. Distinctive features of appendicitis in childhood. Zentralblatt fur Chirurgie. Dec. 2008;133(6):554-8. [pmid: 19090432].
1003 Vons C. Diagnosis of appendicitis syndromes: what has changed. La Revue du praticien. Feb. 15. 2001;51(3):237-8. [pmid: 11265417].
1004 Vons C. Diagnosis of appendicular syndromes: for a rational approach. Journal de chirurgie. Jun. 2001;138(3):143-5. [pmid: 11471002].
1005 Vons C. Laparoscopy with a diagnostic aim in abdominal emergencies. Chirurgie; memoires de l’Academie de chirurgie. Apr. 1999;124(2):182-6. [pmid: 10349757].
1006 Vorypin DM, Eletskii IV, Denisov A, et al. Assessment of the value of certain clinical and laboratory indices in improvement of the diagnosis of acute appendicitis in children. Vestnik khirurgii imeni I I Grekova. 2000;159(4):43-5. [pmid: 11011402].
1007 Vuilleumier H, Cuttat JF, Wassmer FA. The role of emergency laparoscopy in abdominal pain syndrome and in the assessment of abdominal trauma. Schweizerische medizinische Wochenschrift. Jun. 4. 1994;124(22):970-3. [pmid: 8029678].
1008 Vykouril L, Zborilova I, Bedrna J. Ultrasonography in the diagnosis of acute appendicitis. Rozhledy v chirurgii : mesicnik Ceskoslovenske chirurgicke spolecnosti. Nov. 1997;76(11):571-3. [pmid: 9478116].
1009 Waclawiczek HW, Schneeberger V, Bekk A, et al. Value of diagnostic laparoscopy and minimal invasive procedures in acute abdomen. Zentralblatt fur Chirurgie. 1997;122(12):1108-12. [pmid: 9499536].
1010 Waldschmidt J, Biewald W, Tzannetakis P. Acute abdomen in immunoreaction mediated diseases. Langenbecks Archiv fur Chirurgie. 1987;372:725-9. [pmid: 2963182].
1011 Wang B, Chen MH, Li JG. Real-time ultrasonography in the diagnosis of acute abdomen. Zhonghua wai ke za zhi. Chinese journal of surgery. Mar. 1987;25(3):146-8. 89. [pmid: 3304875].
1012 Waninger J. Acute abdomen from the surgical perspective. MMW Fortschritte der Medizin. Oct. 4. 2007;149(40):31-4. [pmid: 18018506].
1013 Wara P. Laparoscopy in acute abdomen. Ugeskrift for laeger. Feb. 23. 2004;166(9):783-5. [pmid: 15042949].
1014 Waris E, Gronroos J, Paajanen H. Diagnostic accuracy of acute appendicitis. Duodecim; laaketieteellinen aikakauskirja. 2004;120(1):23-30. [pmid: 14976805].
1015 Wawrzynek Z. Ultrasonography and computer tomography in the diagnosis of certain abdominal diseases (author’s transl). Polski przeglad radiologii i medycyny nuklearnej. Sep–Oct. 1981;45(5):311-3. [pmid: 7342063].
1016 Weber B, Becker K, Strohmeyer G. Gastroenterology - accusations and errors in treatment: evaluation of the completed expertise process in internal medicine of the expert committee of North Rhineland for the years 2001 to 2005. Zeitschrift fur Gastroenterologie. Aug. 2008;46(8):766-70. [pmid: 18759199].
1017 Weber-Donat G, Pons-Ukkola E, Potet J, et al. Which imaging in acute abdominal pain management?. La Revue du praticien. Feb. 20. 2010;60(2):225-37. [pmid: 20225564].
1018 Weiler S, Rohmer P, Coche G, et al. Ultrasonics in abdominal emergencies. Results of a series of 179 cases. Journal de radiologie. Nov. 1986;67(11):765-8. [pmid: 3543323].
1019 Weill F, Bihr E, Zeltner F, et al. Contribution of ultrasonography to diagnosis in acute abdomen, particularly in the postoperative phase (author’s transl). Annales de radiologie. Dec. 1978;21(8):585-90. [pmid: 749637].
1020 Weill F, Bihr E, Zeltner F, et al. Ultrasonography and the acute abdomen (author’s transl). Chirurgie; memoires de l’Academie de chirurgie. 1981;107(3):254-5. [pmid: 7285695].
1021 Weill F, Le Mouel A, Bihr E, et al. Ultrasonic diagnosis of intraperitoneal fluid in Morrison’s pouch (and in the splenoperitoneal recess): the moon crescent sign (author’s transl). Journal de radiologie. Apr. 1980;61(4):251-6. [pmid: 7392002].
1022 Weiner RA, Blanco ER, Weiner S. Acute appendicitis--laparoscopic appendectomy--indications and outcomes. Kongressband/Deutsche Gesellschaft fur Chirurgie Deutsche Gesellschaft fur Chirurgie Kongress. 2002;119:204-9. [pmid: 12704883].
1023 Weitzel D. Pediatric sonography. Ultraschall in der Medizin (Stuttgart, Germany : 1980). Sep. 1983;4(3):124-8. [pmid: 6648489].
1024 Weitzel D. Significance of ultrasonic-incision technics for the abdominal diagnosis in children. Monatsschrift Kinderheilkunde : Organ der Deutschen Gesellschaft fur Kinderheilkunde. May. 1975;123(5):487-8. [pmid: 1219477].
1025 Welcker ER. Perforated appendicitis 1962. Zeitschrift fur arztliche Fortbildung. Feb. 1. 1965;59(3):113-22. [pmid: 5885794].
1026 Welter HF, Wendland S. Laparoscopic appendectomy--a lot of effort for a minor operation?. MMW Fortschritte der Medizin. Mar. 30. 2006;148(13):46-7. [pmid: 16642706].
1027 Wen F, Sun W, Liang HY, et al. CT diagnosis of high-position acute appendicitis. Chinese Journal of Medical Imaging Technology. 2011;27(4):760-3. PMID:.
1028 Wente MN, Waleczek H. Strategy for avoidance of negative appendectomies. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jul. 2009;80(7):588-93. [pmid: 19543860].
1029 Wetter D, Otto R. Pain in the right epigastrium. Praxis. Aug. 24. 2000;89(34):1339-40. [pmid: 11021188].
1030 Wiesner W. CT - diagnosis and differential diagnosis of inflammatory acute intestinal conditions. Praxis. Aug. 24. 2011;100(17):1033-9. [pmid: 21863573].
1031 Wilhelm KH. Perforative appendicitis among the clinical cases of the Chirurgische Universitatsklinik Rostock (1961–1964). Zentralblatt fur Chirurgie. Aug. 20. 1966;91(34):1240-51. [pmid: 5995389].
1032 Windeler J, Richter K. Ultrasonography in acute appendicitis. Deutsche medizinische Wochenschrift (1946). Jul. 15. 1988;113(28–29):1170. [pmid: 3292194].
1033 Wittig F, Waldner H. Diagnosis of acute appendicitis. Is physical examination enough to reach a surgical decision?. MMW Fortschritte der Medizin. Jul. 6. 2000;142(26–27):26-9. [pmid: 10929478].
1034 Wustner M, Horst F, Neufang T, et al. Effect of ultrasonic diagnosis and incidence of appendectomy and laparoscopy. Langenbecks Archiv fur Chirurgie Supplement Kongressband Deutsche Gesellschaft fur Chirurgie Kongress. 1998;115:1117-9. [pmid: 9931809].
1035 Wysocki A, Bolt L, Pozniczek M. Changing views in the 20-th century regarding acute appendicitis. Archiwum historii i filozofii medycyny/Polskii Towarzystwo Historii Medycyny i Farmacji. 2000;63(3–4):258-64. [pmid: 11770495].
1036 Xu H, Zhao J. Diagnosis of ileocecal diverticulitis with ultrasonography. Chinese Journal of Gastroenterology. 2013;18(1):37-9. PMID:.
1037 Yamamoto H. CT examination of emergency medical care. Nihon Hoshasen Gijutsu Gakkai zasshi. Oct. 20. 2006;62(10):1411-21. [pmid: 17094203].
1038 Yang JJ, Qin HL. Values of histidine decarboxylase, intestinal fatty acid binding protein, and diamine oxidase for diagnosing intestinal mucosal injury in patients with intestinal obstruction. Chinese Journal of Clinical Nutrition. 2011;19(2):67-73. PMID:.
1039 Yardeni D, Kawar B, Pressman A, et al. Open versus laparoscopic appendectomy in children in a regional hospital in Israel. Harefuah. Mar. 2007;146(3):173-5. 248. [pmid: 17460919].
1040 Yaşar M, Kayıkçı Ali, Taşkın Ali Kemal, Aydın Metin. Amyand Hernisi - Olgu Sunumu. [Turkish]. Konuralp Medical Journal/Konuralp Tip Dergisi. 2013;5(1):50-2. Language: Turkish. Entry Date: 20130322. Publication Type: journal article.
1041 Yetisir F, Salman AE, Osmanoglu G, Ciftci B, Kilic M. The comparison of the outcomes of early and late postoperative complications of open appendectomy and laparoscopic appendectomy. Chirurgia (Turin). 2013;26(1):1-4. PMID:.
1042 Yıldız T, Bozdağ Z, Erkorkmaz U, Emre A, Turgut T, Ilçe Z. Analysis of risk factors for the development of pediatric appendicitis. [pmid: 24347216].
1043 Yu AJ, Zhao LW, Zhang XJ, et al. Establishment and application of a scoring system for predicting the difficulty level of laparoscopic appendectomy. World Chinese Journal of Digestology. 2010;18(25):2719-23. PMID:.
1044 Yuan SW, Li H, Chen DY, Qiu Q, Lian F, Zhan ZP, Liang LQ, Xu HS, Yang XY. Associated factors for the occurrence of lupus enteritis. [pmid: 23902888].
1045 Yuksekkaya R, Akgul E, Inal M, et al. Unenhanced spiral CT in the diagnosis of acute appendicitis. Tanisal ve girisimsel radyoloji : Tibbi Goruntuleme ve Girisimsel Radyoloji Dernegi yayin organi. Jun. 2004;10(2):131-9. [pmid: 15236128].
1046 Zabarskii LT, Livshits Iu G. Laparoscopy in acute surgical pathology of the abdominal cavity organs. Klinicheskaia khirurgiia. Jul. 1977;(7):55-7. [pmid: 142859].
1047 Zachert HR, Meyer HJ. Acute appendicitis in advanced age. Fortschritte der Medizin. Mar. 30. 1998;116(9):36-9. [pmid: 9577072].
1048 Zakharash MP, Zaviernyi LH, Stel’makh AI, et al. Ultrasonic diagnosis of an acute appendicitis and its complications. Klinicheskaia khirurgiia. Jul. 2004;(7):13-7. [pmid: 15495606].
1049 Zakharov SN, Svitich Iu M, Baskakov VA. Electrothermometry in the diagnosis of destructive forms of acute appendicitis and acute cholecystitis. Khirurgiia. Oct. 1981;(10):37-9. [pmid: 6458732].
1050 Zakharova GN, Fursaev VA, Tarasov VN, et al. Laparoscopy in the diagnosis of acute appendicitis in children. Vestnik khirurgii imeni I I Grekova. Dec. 1988;141(12):45-8. [pmid: 2977864].
1051 Zantut LF, Rodriguez AJ Junior, Birolini D. Diagnostic laparoscopy in nontraumatic acute abdomen. AMB : revista da Associacao Medica Brasileira. Jul–Dec. 1990;36(3–4):120-3. [pmid: 1965920].
1052 Zantut LF, Zantut PE, Rodrigues AJ Junior, et al. Comparative analysis of the diagnostic value of ultrasonography and laparoscopy in acute abdomen. AMB : revista da Associacao Medica Brasileira. Jul–Sep. 1991;37(3):143-9. [pmid: 1668542].
1053 Zavgorodnii LG, Barilo VS. Diagnostic possibilities of laparoscopy in emergency surgery. Klinicheskaia khirurgiia. Sep. 1973;9:68-70. [pmid: 4272547].
1054 Zav’ialova NI, Driazhenkov IG, Baranov GA, et al. Diagnostic and therapeutic potentials of emergency laparoscopy. Klinicheskaia meditsina. 1995;73(2):61. [pmid: 7609427].
1055 Zeeuw GR, Kazemier G, Hop WCJ, Lange JF, Bonjer HJ. Laparoscopische behandeling van appendicitis acuta: minder pijn en wondinfecties, maar langere operatietijd; een gerandomiseerd onderzoek. Nederlands Tijdschrift voor de Geneeskunde [serial on the Internet]. 1998. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/523/CN-00415523/frame.html. Last accessed.
1056 Zerkalov VN, Dmitriev GI, Zharkin AA, et al. Information value of various methods of diagnosing acute intestinal obstruction. Voenno-meditsinskii zhurnal. Nov. 1983;(11):28-30. [pmid: 6659402].
1057 Zhai RL, Long YP, Wang GB. Clinical value of CT in early diagnosis and treatment of acute abdomen. World Chinese Journal of Digestology. 2013;21(32):3520-5. PMID:.
1058 Zhang SL, Chen HL, Yin S. Peripheral blood monocyte activation in acute abdominal diseases with sepsis and its treatment with fufang qingxia decoction. Journal of Dalian Medical University [serial on the Internet]. 2010;(3). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/059/CN-00804059/frame.html. Last accessed.
1059 Zhao Y, Yin J. Clinical and pathological characteristics in acute complicated appendicitis. [pmid: 25034739].
1060 Zhloba AF. The role of instrumental study methods in the diagnosis of “acute abdomen”. Vestnik khirurgii imeni I I Grekova. Mar–Apr. 1993;150(3–4):103-6. [pmid: 8379048].
1061 Zielke A, Malewski U, Lindlar R, et al. Ultrasonic diagnosis in suspected acute appendicitis: probable or certain indications for surgery?. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Oct. 1991;62(10):743-9. [pmid: 1760954].
1062 Zielke A, Sitter H, Rampp T, et al. Can diagnostic scoring systems help decision making in primary care of patients with suspected acute appendicitis?. Deutsche medizinische Wochenschrift (1946). May. 7. 1999;124(18):545-50. [pmid: 10356580].
1063 Zielke A, Sitter H, Rampp TA, et al. Validation of a diagnostic scoring system (Ohmann score) in acute appendicitis. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Jul. 1999;70(7):777-83. discussion 84. [pmid: 10448585].
1064 Zielke A. Appendicitis. Present-day diagnosis. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. Aug. 2002;73(8):782-90. [pmid: 12425154].
1065 Zoguereh DD, Lemaitre X, Ikoli JF, et al. Acute appendicitis at the National University Hospital in Bangui, Central African Republic: epidemiologic, clinical, paraclinical and therapeutic aspects. Sante (Montrouge, France). Apr–Jun. 2001;11(2):117-25. [pmid: 11440889].
1066 Zoller WG, Kellner H, Schwerk WB. Value of ultrasound in diagnosis of acute appendicitis. Bildgebung. Imaging. Jun. 1996;63(2):78-82. [pmid: 8756148].
1067 Zoller WG. Emergency ultrasound diagnosis. Bildgebung. Imaging. Suppl 2. 1987;56:67-72. [pmid: 3078265].

## B-15. Rejection Reason: Not Outcome of Interest

1 Assarsson J, Körner U, Lundholm K. Evaluation of Procalcitonin as a Marker To Predict Antibiotic Response in Adult Patients with Acute Appendicitis: A Prospective Observational Study. [pmid: 24865123].
2 Bailey B, Bergeron S, Gravel J, et al. Comparison of four pain scales in children with acute abdominal pain in a pediatric emergency department... 2007 Society for Academic Emergency Medicine Annual Meeting. Academic Emergency Medicine. 2007;14(5):S90-S. Language: English. Entry Date: 20091211. Revision Date: 20091218. Publication Type: journal article.
3 Bulian DR, Knuth J, Sauerwald A, Strohlein MA, Lefering R, Ansorg J, Heiss MM. Appendectomy in Germany - An analysis of a nationwide survey 2011/2012. International journal of colorectal disease. 2013;28(1):127-38. PMID:. [pmid: 22932909].
4 Burke KA, Patel A, Jayaratnam A, Thiruppathy K, Snooks SJ. Diagnosing abdominal tuberculosis in the acute abdomen. [pmid: 24560849].
5 Caperell K, Pitetti R, Cross KP. Race and Acute Abdominal Pain in a Pediatric Emergency Department. [pmid: 23690514].
6 Chang YJ, Hsia SH, Chao HC. Emergency medicine physicians performed ultrasound for pediatric intussusceptions. [pmid: 23989312].
7 Chap AD, Collins JN, Britt LD. Is surgery always necessary in patients with abdominal pain and computed tomography-suggested intussusception?. [pmid: 24666875].
8 Drake FT, Alfonso R, Bhargava P, Cuevas C, Dighe MK, Florence MG, Johnson MG, Jurkovich GJ, Steele SR, Symons RG, Thirlby RC, Flum DR. Writing Group for SCOAP-CERTAIN. Enteral Contrast in the Computed Tomography Diagnosis of Appendicitis: Comparative Effectiveness in a Prospective Surgical Cohort. [pmid: 24598250].
9 El Maati AAA, Ibrahim EAG, Mokhtar FZ. A two-stage imaging protocol for evaluating women presenting with acute pelvic pain. Egyptian Journal of Radiology and Nuclear Medicine. 2013. PMID:.
10 Enjoji M, Enomoto N, Kikuchi A, et al. Influence of CT-measured appendiceal diameter on operation time of laparoscopic appendectomy. Surgical laparoscopy, endoscopy & percutaneous techniques. Feb. 2011;21(1):20-3. [pmid: 21304383].
11 Fradin K, Racine AD, Belamarich PF. Obesity and symptomatic cholelithiasis in childhood: epidemiologic and case-control evidence for a strong relation. [pmid: 23969538].
12 Gonzalez MC, Rodriguez JCB, Moore EH, Atanay DA. Predictors of recurrent appendicitis after non-operative management of children with perforated appendicitis presenting with an appendicular inflammatory mass. Archives of disease in childhood. 2014;99(2):154-7. [pmid: 24214939].
13 Kameda T, Kawai F, Taniguchi N, Omoto K, Kobori Y, Arakawa K. Evaluation of whether the ultrasonographic onion skin sign is specific for the diagnosis of an appendiceal mucocele. Journal of Medical Ultrasonics. ((Kameda T., kamekame@pb3.so-net.ne.jp; Kawai F.) Department of Ultrasound Medicine, Saiseikai Utsunomiya Hospital, Utsunomiya, 321-0974, Japan). 2014:1-5.
14 Khan SA, Khokhar HA, Nasr AR, et al. Incidence of right-sided colonic tumors (non-appendiceal) in patient’s >/=40 years of age presenting with features of acute appendicitis. International journal of surgery (London, England). 2013;11(4):301-4. [pmid: 23416535].
15 Kharbanda AB, Stevenson MD, Macias CG, et al. Interrater reliability of clinical findings in children with possible appendicitis. Pediatrics. Apr. 2012;129(4):695-700. [pmid: 22392173].
16 Kim DH, Kang SH, Jeong WS, Moon HS, Lee ES, Kim SH, Sung JK, Lee BS, Jeong HY. Serum C-reactive protein (CRP) levels in young adults can be used to discriminate between inflammatory and non-inflammatory diarrhea. [pmid: 22926497].
17 Kurtz RJ, Heimann TM. Comparison of open and laparoscopic treatment of acute appendicitis (Structured abstract). American journal of surgery [serial on the Internet]. 2001;(3). Available from: http://onlinelibrary.wiley.com/o/cochrane/cleed/articles/NHSEED-22001001946/frame.html. Last accessed.
18 Leeuwenburgh MM, Wiarda BM, Bipat S, et al. Acute appendicitis on abdominal MR images: training readers to improve diagnostic accuracy. Radiology. Aug. 2012;264(2):455-63. [pmid: 22700556].
19 Lou Z, Yu ED, Zhang W, Meng RG, Hao LQ, Fu CG. Appropriate treatment of acute sigmoid volvulus in the emergency setting. [pmid: 23946604].
20 Mashiach R, Bar-On S, Boyko V, et al. Sudden/nocturnal onset of acute abdominal pain, lasting less than a day and accompanied by vomiting: A tell-tale sign of ovarian torsion. Gynecological Surgery. 2010;7(3):297-301. PMID:.
21 Mayumi T, Inui K, Maetani I, Yokoe M, Sakamoto T, Yoshida M, Ko S, Hirata K, Takada T. Urinary Trypsinogen-2 Dipstick for Acute Pancreatitis Study Group of Japanese Society of Abdominal Emergency Medicine (UtrAP Study Group). Validity of the urinary trypsinogen-2 test in the diagnosis of acute pancreatitis. [pmid: 22481290].
22 Newman K, Ponsky T, Kittle K, et al. Appendicitis 2000: variability in practice, outcomes, and resource utilization at thirty pediatric hospitals. Journal of pediatric surgery. Mar. 2003;38(3):372-9. discussion -9. [pmid: 12632352].
23 Okur MH, Karaçay S, Uygun I, Topçu K, Öztürk H. Amyand’s hernias in childhood (a report on 21 patients): a single-centre experience. [pmid: 23417545].
24 Rodriguez R, da Silva AC, Müller CA, Alves SL, Graeff-Teixeira C, Fornari F. PCR for the diagnosis of abdominal angiostrongyliasis in formalin-fixed paraffin-embedded human tissue. [pmid: 24705328].
25 Rousset P, Peyron N, Charlot M, Chateau F, Golfier F, Raudrant D, Cotte E, Isaac S, Réty F, Valette PJ. Bowel Endometriosis: Preoperative Diagnostic Accuracy of 3.0-T MR Enterography-Initial Results. [pmid: 24828001].
26 Ruchman RB, Jaeger J, Wiggins EF 3rd, et al. Preliminary radiology resident interpretations versus final attending radiologist interpretations and the impact on patient care in a community hospital. AJR American journal of roentgenology. Sep. 2007;189(3):523-6. [pmid: 17715095].
27 Sala E, Watson CJ, Beadsmoore C, et al. A randomized, controlled trial of routine early abdominal computed tomography in patients presenting with non-specific acute abdominal pain. Clinical radiology. Oct. 2007;62(10):961-9. [pmid: 17765461].
28 Shelton JA, Brown JJ, Young JA. Preoperative C-reactive protein predicts the severity and likelihood of complications following appendicectomy. [pmid: 24992421].
29 Singh JP, Mariadason JG. Role of the faecolith in modern-day appendicitis. Annals of the Royal College of Surgeons of England. Jan. 2013;95(1):48-51. [pmid: 23317728].
30 Socea B, Carâp A, Rac-Albu M, Constantin V. The value of serum bilirubin level and of white blood cell count as severity markers for acute appendicitis. [pmid: 24331322].
31 Sreeharsha H, Sp R, Sreekar H, Reddy R. Efficacy of possum score in predicting the outcome in patients undergoing emergency laparotomy. [pmid: 24988229].
32 Stare R, Kocman I, Cevra ZP, Zgrebec Z, Kovacic D. Results of a prospective randomised study of laparoscopic appendectomy in community hospital. 6th World Congress of Endoscopic Surgery. June 3–6, 1998. Rome, Italy. [serial on the Internet]. 1998. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/112/CN-00776112/frame.html. Last accessed.
33 Stevens T. Role of Endoscopic Ultrasonography in the Diagnosis of Acute and Chronic Pancreatitis. [pmid: 24079787].
34 Van Gompel JJ, Stoddard E, Chen H. Incidental carcinoid tumors of the appendix: do they affect presentation or prognosis?. International surgery. Nov–Dec. 2007;92(6):331-4. [pmid: 18402126].
35 Wong YS, Tam YH, Pang KKY, et al. Oophorectomy in children. Who and why: 13-year experience in a single centre. Journal of Paediatrics and Child Health. 2012;48(7):600-3. [pmid: 22404641].
36 Zwintscher NP, Steele SR, Martin MJ, Newton CR. The effect of race on outcomes for appendicitis in children: a nationwide analysis. [pmid: 24791639].

## B-16. Rejection Reason: Not Population of Interest

1 Adhikari S, Morrison D, Lyon M, Zeger W, Krueger A. Utility of point-of-care biliary ultrasound in the evaluation of emergency patients with isolated acute non-traumatic epigastric pain. [pmid: 24442493].
2 Agarwal MD, Levenson RB, Siewert B, Camacho MA, Raptopoulos V. Limited added utility of performing follow-up contrast-enhanced CT in patients undergoing initial non-enhanced CT for evaluation of flank pain in the emergency department. [pmid: 25082439].
3 Akisik MF, Jennings SG, Aisen AM, Sherman S, Cote GA, Sandrasegaran K, Tirkes T. MRCP in patient care: a prospective survey of gastroenterologists. [pmid: 23971448].
4 Ather MH, Faizullah K, Achakzai I, et al. Alternate and incidental diagnoses on noncontrast-enhanced spiral computed tomography for acute flank pain. Urology journal. Winter. 2009;6(1):14-8. [pmid: 19241335].
5 Aveline C. Ultrasound-guided axillary perivascular approach: Efficacy and safety remain to Be proved. [pmid: 23263218].
6 Barber MD, McLaren J, Rainey JB. Recurrent appendicitis. The British journal of surgery. Jan. 1997;84(1):110-2. [pmid: 9043472].
7 Biltjes IG, D’Archambeau OC, De Schepper AM, et al. Unusual presentation of ovarian pathology on CT. Journal belge de radiologie. Feb. 1996;79(1):9-11. [pmid: 8647787].
8 Andeweg CS, Mulder IM, Felt-Bersma RJ, Verbon A, van der Wilt GJ, van Goor H, Lange JF, Stoker J, Boermeester MA, Bleichrodt RP. Netherlands Society of Surgery; Working group from Netherlands Societies of Internal Medicine, Gastroenterologists, Radiology, Health echnology Assessment and Dieticians. Guidelines of diagnostics and treatment of acute left-sided colonic diverticulitis. [pmid: 23969324].
9 Gijsbers CF, Benninga MA, Schweizer JJ, Kneepkens CM, Vergouwe Y, Büller HA. Validation of the Rome III criteria and alarm symptoms for recurrent abdominal pain in children. [pmid: 24866784].
10 Butler H, Bryan PJ, LiPuma JP, et al. Magnetic resonance imaging of the abnormal female pelvis. AJR American journal of roentgenology. Dec. 1984;143(6):1259-66. [pmid: 6388282].
11 Cankorkmaz L, Ozer H, Guney C, et al. Amyand’s hernia in the children: a single center experience. Surgery. Jan. 2010;147(1):140-3. [pmid: 19910011].
12 Catalano O, Nunziata A, Sandomenico F, et al. Acute flank pain: comparison of unenhanced helical CT and ultrasonography in detecting causes other than ureterolithiasis. Emergency radiology. Sep. 2002;9(3):146-54. [pmid: 15290574].
13 Ceribelli C, Adami EA, Mattia S, Benini B. Bedside diagnostic laparoscopy for critically ill patients: A retrospective study of 62 patients. [pmid: 22710654].
14 Chao K, Farrell S, Kerdemelidis P, et al. Diagnostic laparoscopy for chronic right iliac fossa pain: a pilot study. The Australian and New Zealand journal of surgery. Nov. 1997;67(11):789-91. [pmid: 9396996].
15 Charoensak A, Pongpornsup S, Suthikeeree W. Wall thickness and outer diameter of the normal appendix in adults using 64 slices multidetector CT. Journal of the Medical Association of Thailand. Chotmaihet thangphaet. Dec. 2010;93(12):1437-42. [pmid: 21344807].
16 Chen MY, Zagoria RJ, Saunders HS, et al. Trends in the use of unenhanced helical CT for acute urinary colic. AJR American journal of roentgenology. Dec. 1999;173(6):1447-50. [pmid: 10584780].
17 Chichom Mefire A, Tchounzou R, Kuwong PM, et al. Clinical, ultrasonographic, and pathologic characteristics of patients with chronic right-lower-quadrant abdominal pain that may benefit from appendectomy. World journal of surgery. Apr. 2011;35(4):723-30. [pmid: 21301834].
18 Díaz R, Soundar E, Hartman SK, Dreyer Z, Teruya J, Hui SK. Granulocyte transfusions for children with infection and neutropenia or granulocyte dysfunction. [pmid: 24383443].
19 Eze KC, Salami TA, Kpolugbo JU. Acute abdominal pain in patients with lassa fever: Radiological assessment and diagnostic challenges. [pmid: 25013248].
20 Fayez JA, Toy NJ, Flanagan TM. The appendix as the cause of chronic lower abdominal pain. American journal of obstetrics and gynecology. Jan. 1995;172(1 Pt 1):122-3. [pmid: 7847518].
21 Ferguson IL. Laparoscopy for the diagnosis of nonspecific lower abdominal pain. The British journal of clinical practice. May. 1974;28(5):163-5. [pmid: 4277548].
22 Firetto MC, Lemos AA, Marini A, Avesani EC, Biondetti PR. Acute bowel ischemia: analysis of diagnostic error by overlooked findings at MDCT angiography. [pmid: 23053162].
23 Ianiro G, Delogu R, Bonomo P, Fiore L, Ruggeri FM. RotaNet-Italy Study Group. Molecular analysis of group A rotaviruses detected in adults and adolescents with severe acute gastroenteritis in Italy in 2012. [pmid: 24415411].
24 Fogli L, Brulatti M, Boschi S, et al. Laparoscopic appendectomy for acute and recurrent appendicitis: retrospective analysis of a single-group 5-year experience. Journal of laparoendoscopic & advanced surgical techniques Part A. Apr. 2002;12(2):107-10. [pmid: 12019568].
25 Fowler JC, Cutress ML, Abubacker Z, et al. Clinical evaluation of ultra-low dose contrast-enhanced CT in patients presenting with acute ureteric colic. British Journal of Medical and Surgical Urology. 2011;4(2):56-63. PMID:.
26 Fraser JD, Aguayo P, Leys CM, et al. A complete course of intravenous antibiotics vs a combination of intravenous and oral antibiotics for perforated appendicitis in children: a prospective, randomized trial. Journal of pediatric surgery. 2010;45(6):1198-202. PMID:. [pmid: 20620320].
27 García de Casasola Sánchez G, Torres Macho J, Casas Rojo JM, Cubo Romano P, Antón Santos JM, Villena Garrido V, Diez Lobato R. Working Group SEMI Clinical. Abdominal ultrasound and medical education. [pmid: 24168817].
28 Giuliano V, Giuliano C, Pinto F, et al. Chronic appendicitis “syndrome” manifested by an appendicolith and thickened appendix presenting as chronic right lower abdominal pain in adults. Emergency radiology. Mar. 2006;12(3):96-8. [pmid: 16404625].
29 Goldberg-Stein S, Liu B, Hahn PF, et al. Body CT during pregnancy: utilization trends, examination indications, and fetal radiation doses. AJR American journal of roentgenology. Jan. 2011;196(1):146-51. [pmid: 21178060].
30 Goldman M. The radiological investigations of recurrent appendicitis. Clinical radiology. Jul. 1966;17(3):289-94. [pmid: 5942777].
31 Gorenstin A, Serour F, Katz R, et al. Appendiceal colic in children: a true clinical entity?. Journal of the American College of Surgeons. Mar. 1996;182(3):246-50. [pmid: 8603245].
32 Gratz S, Schipper ML, Dorner J, et al. LeukoScan for imaging infection in different clinical settings: a retrospective evaluation and extended review of the literature. Clinical nuclear medicine. Apr. 2003;28(4):267-76. [pmid: 12642703].
33 Güzel M1, Sözüer EM, Salt Ö, İkizceli İ, Akdur O, Yazıcı C. The value of the serum I-FABP level for diagnosing acute mesenteric ischemia. [pmid: 24337529].
34 Harris RS, Foster WG, Surrey MW, et al. Appendiceal disease in women with endometriosis and right lower quadrant pain. The Journal of the American Association of Gynecologic Laparoscopists. Nov. 2001;8(4):536-41. [pmid: 11677333].
35 Homier V, Bellavance C, Xhignesse M. Prevalence of pneumonia in children under 12 years of age who undergo abdominal radiography in the emergency department. Cjem. Sep. 2007;9(5):347-51. [pmid: 17935650].
36 House JB, Bourne CL, Seymour HM, Brewer KL. Location of the appendix in the gravid patient. [pmid: 24484624].
37 Hozo I, Djulbegovic B. Calculating confidence intervals for threshold and post-test probabilities. MD computing : computers in medical practice. Mar–Apr. 1998;15(2):110-5. [pmid: 9540324].
38 Hurwitz LM, Yoshizumi T, Reiman RE, et al. Radiation dose to the fetus from body MDCT during early gestation. AJR American journal of roentgenology. Mar. 2006;186(3):871-6. [pmid: 16498123].
39 Husain M, Sachan PK, Khan S, Lama L, Khan RN. Role of diagnostic laparoscopy in chronic and recurrent abdominal pain. [pmid: 24851527].
40 Joshi AV, Sanghvi BV, Shah HS, et al. Laparoscopy in management of abdominal pain in children. Journal of laparoendoscopic & advanced surgical techniques Part A. Oct. 2008;18(5):763-5. [pmid: 18803522].
41 Junewick J, Dombrowski K, Woolpert L, Vandop S, Schreiner M, Sutton P, Horness C, Vandermeulen M. Rate of and factors affecting sonographic visualization of the appendix in asymptomatic children. [pmid: 23076804].
42 Kaoutzanis C, Davies E, Leichtle SW, Welch KB, Winter S, Lampman RM, Arneson W. Abdominal ultrasound versus hepato-imino diacetic acid scan in diagnosing acute cholecystitis--what is the real benefit?. [pmid: 24556232].
43 Kerrey BT, Rogers AJ, Lee LK, Adelgais K, Tunik M, Blumberg SM, Quayle KS, Sokolove PE, Wisner DH, Miskin ML, Kuppermann N, Holmes JF. Pediatric Emergency Care Applied Research Network. A multicenter study of the risk of intra-abdominal injury in children after normal abdominal computed tomography scan results in the emergency department. [pmid: 23622949].
44 Kundrotas LW, Clement DJ. Serum alanine aminotransferase (ALT) elevation in asymptomatic US Air Force basic trainee blood donors. Digestive diseases and sciences. Dec. 1993;38(12):2145-50. [pmid: 8261813].
45 Lacquaniti A, Chirico V, Mondello S, Buemi A, Lupica R, Fazio MR, Buemi M, Aloisi C. NGAL in peritoneal dialysis reflects the status of the peritoneum. [pmid: 23807648].
46 Lardenoye SW, Puylaert JB, Smit MJ, et al. Appendix in children with cystic fibrosis: US features. Radiology. Jul. 2004;232(1):187-9. [pmid: 15166328].
47 Lariño-Noia J, Lindkvist B, Iglesias-García J, Seijo-Ríos S, Iglesias-Canle J, Domínguez-Muñoz JE. Early and/or immediately full caloric diet versus standard refeeding in mild acute pancreatitis: a randomized open-label trial. [pmid: 24854611].
48 Liu H, Zhang G, Niu Y, Jiang N, Xiao W. Retroperitoneal fibrosis: a clinical and outcome analysis of 58 cases and review of literature. [pmid: 24756854].
49 Longstreth GF, Iyer RL, Chu LH, Chen W, Yen LS, Hodgkins P, Kawatkar AA. Acute diverticulitis: Demographic, clinical and laboratory features associated with computed tomography findings in 741 patients. [pmid: 22967027].
50 Mahmood I, Tawfek Z, Abdelrahman Y, Siddiuqqi T, Abdelrahman H, El-Menyar A, Al-Hassani A, Tuma M, Peralta R, Zarour A, Yakhlef S, Hamzawi H, Al-Thani H, Latifi R. Significance of computed tomography finding of intra-abdominal free fluid without solid organ injury after blunt abdominal trauma: time for laparotomy on demand. [pmid: 24368575].
51 Mhanna MJ, Iyer NP. Routine chest computed tomography scans in pediatric blunt thoracic injuries. [pmid: 23769632].
52 Moteki T, Ohya N, Horikoshi H. Evaluation of the maximum depth of intraluminal appendiceal fluid to diagnose appendicitis with a 64-detector row CT scanner. Journal of computer assisted tomography. Nov–Dec. 2011;35(6):703-10. [pmid: 22082540].
53 Murphy CG, Glickman JN, Tomczak K, et al. Acute appendicitis is characterized by a uniform and highly selective pattern of inflammatory gene expression. Mucosal immunology. Jul. 2008;1(4):297-308. [pmid: 19079191].
54 Oto A, Srinivasan PN, Ernst RD, et al. Revisiting MRI for appendix location during pregnancy. AJR American journal of roentgenology. Mar. 2006;186(3):883-7. [pmid: 16498125].
55 Ozturkmen Akay H, Akpinar E, Akgul Ozmen C, et al. Visualization of the normal appendix in children by non-contrast MDCT. Acta chirurgica Belgica. Sep–Oct. 2007;107(5):531-4. [pmid: 18074913].
56 Paajanen H, Julkunen K, Waris H. Laparoscopy in chronic abdominal pain: a prospective nonrandomized long-term follow-up study. Journal of clinical gastroenterology. Feb. 2005;39(2):110-4. [pmid: 15681904].
57 Panchalingam L, Driver C, Mahomed AA. Elective laparoscopic appendicectomy for chronic right iliac fossa pain in children. Journal of laparoendoscopic & advanced surgical techniques Part A. Apr. 2005;15(2):186-9. [pmid: 15898915].
58 Pates JA, Avendanio TC, Zaretsky MV, et al. The appendix in pregnancy: confirming historical observations with a contemporary modality. Obstetrics and gynecology. Oct. 2009;114(4):805-8. [pmid: 19888038].
59 Popovic D, Kovjanic J, Milostic D, et al. Long-term benefits of laparoscopic appendectomy for chronic abdominal pain in fertile women. Croatian medical journal. Apr. 2004;45(2):171-5. [pmid: 15103754].
60 Rajkumar, Bhalki, Hiremath, Sreekantha, Vinodchandran, Yogish. To study the efficacy of gastrografin in diagnosis of adhesive small bowel obstruction.
61 Ramakrishnaiah VP, Chandrakasan C, Dharanipragadha K, Sistla S, Krishnamachari S. Community acquired secondary bacterial peritonitis in a tertiary hospital of South India: an audit with special reference to peritoneal fluid culture. [pmid: 23923354].
62 Rao PM, Rhea JT, Novelline RA, et al. The computed tomography appearance of recurrent and chronic appendicitis. The American journal of emergency medicine. Jan. 1998;16(1):26-33. [pmid: 9451309].
63 Reavey HE, Alazraki AL, Simoneaux SF. Normal patterns of 18F-FDG appendiceal uptake in children. [pmid: 24287869].
64 Romosan G, Bjartling C, Skoog L, et al. Ultrasound for diagnosing acute salpingitis: a prospective observational diagnostic study. Human reproduction (Oxford, England). Jun. 2013;28(6):1569-79. [pmid: 23503942].
65 Saad J, Mustafa HA, Elsani AM, Alharbi F, Alghamdi S. Primary epiploic appendagitis: Reconciling CT and clinical challenges. [pmid: 24934824].
66 Schindlbeck C, Dziura D, Mylonas I. Diagnosis of pelvic inflammatory disease (PID): intra-operative findings and comparison of vaginal and intra-abdominal cultures. [pmid: 24474636].
67 Scott T, Swan H, Jurriaans E, et al. Sonographic detection of the normal appendix: does the combination of real-time spatial compounding and tissue harmonic imaging make a difference?. Journal of Diagnostic Medical Sonography. 2004;20(5):326-36. Language: English. Entry Date: 20050128. Revision Date: 20121228. Publication Type: journal article.
68 Sharp NE, Svetanoff WJ, Desai A, Alemayehu H, Raghavan MU, Sharp SW, Brown JC, Rivard DC, St Peter SD, Holcomb GW 3rd. Radiation exposure from head computed tomography scans in pediatric trauma. [pmid: 25082747].
69 Shetty MK, Jones MB, Athey PA. CT assessment of postpartum abdominal and pelvic complications. Journal of Women’s Imaging. 2002;4(3):108. Language: English. Entry Date: 20030627. Revision Date: 20091218. Publication Type: journal article.
70 Siriwardana RC, Renuka S, Kumarage S. Laparoscopy as a diagnostic and therapeutic option in evaluating chronic unexplained right iliac fossa pain. Surgical endoscopy. Nov. 2010;24(11):2793-5. [pmid: 20376495].
71 Solis CV, Chang Y, De Moya MA, Velmahos GC, Fagenholz PJ. Free air on plain film: Do we need a computed tomography too?. [pmid: 24550622].
72 Solomon M. Laparoscopic appendicectomy reduced chronic right lower-quadrant abdominal pain more than sham intervention: Commentary. Evidence-based medicine. 2008;13(5):144. [pmid: 18836112].
73 Steinbach C, Stockmann M, Jara M, Bednarsch J, Lock JF. Accidentally ingested toothpicks causing severe gastrointestinal injury: a practical guideline for diagnosis and therapy based on 136 case reports. [pmid: 24166027].
74 Stylianos S, Stein JE, Flanigan LM, et al. Laparoscopy for diagnosis and treatment of recurrent abdominal pain in children. Journal of pediatric surgery. Aug. 1996;31(8):1158-60. [pmid: 8863255].
75 Takahashi T, Herrera MF, Onuma L, et al. Diagnostic laparotomy in fever of unknown origin. Revista de investigacion clinica; organo del Hospital de Enfermedades de la Nutricion. Jan–Mar. 1991;43(1):25-30. [pmid: 1866493].
76 Tamburrini S, Brunetti A, Brown M, et al. CT appearance of the normal appendix in adults. European radiology. Oct. 2005;15(10):2096-103. [pmid: 15912331].
77 Teli B, Ravishankar N, Harish S, Vinayak CS. Role of elective laparoscopic appendicectomy for chronic right lower quadrant pain. [pmid: 24426475].
78 Thanapongsathron W, Kanjanabut B, Vaniyapong T, et al. Chronic right lower quadrant abdominal pain: laparoscopic approach. Journal of the Medical Association of Thailand. Chotmaihet thangphaet. Jun. Suppl 1. 2005;88:S42-7. [pmid: 16862668].
79 Timofeev J, Galgano MT, Stoler MH, et al. Appendiceal pathology at the time of oophorectomy for ovarian neoplasms. Obstetrics and gynecology. Dec. 2010;116(6):1348-53. [pmid: 21099601].
80 Turkoglu H, Onur MR, Poyraz AK, et al. Evaluation of normal appendix vermiformis in adults with multidetector computed tomography. Clinical imaging. Nov–Dec. 2012;36(6):758-62. [pmid: 23154006].
81 Uchino R, Sasahira N, Isayama H, Tsujino T, Hirano K, Yagioka H, Hamada T, Takahara N, Miyabayashi K, Mizuno S, Mohri D, Sasaki T, Kogure H, Yamamoto N, Nakai Y, Tada M, Koike K. Detection of painless pancreatitis by computed tomography in patients with post-endoscopic retrograde cholangiopancreatography hyperamylasemia. [pmid: 24555974].
82 Vayner N, Coret A, Polliack G, et al. Mesenteric lymphadenopathy in children examined by US for chronic and/or recurrent abdominal pain. Pediatric radiology. Dec. 2003;33(12):864-7. [pmid: 13679999].
83 Wang Y1, Zhang TP1, Xiao HL1, Qi HY1, Yin CH2. Formulation of an early warning infectivity score system for adult patients with acute bacterial diarrhea. [pmid: 24553378].
84 Webb EM, Wang ZJ, Coakley FV, et al. The equivocal appendix at CT: prevalence in a control population. Emergency radiology. Jan. 2010;17(1):57-61. [pmid: 19597855].
85 Wiersma F, Sramek A, Holscher HC. US features of the normal appendix and surrounding area in children. Radiology. Jun. 2005;235(3):1018-22. [pmid: 15914481].
86 Yabunaka K, Katsuda T, Sanada S, et al. Sonographic appearance of the normal appendix in adults. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Jan. 2007;26(1):37-43. quiz 5–6. [pmid: 17182707].
87 Zampieri N, Zamboni C, Corroppolo M, et al. Recurrent abdominal pain in young pre-menarchal female: clinical and surgical observations. Pediatric surgery international. Mar. 2008;24(3):277-81. [pmid: 18026737].
88 Zimmermann PG. Is it appendicitis?. The American journal of nursing. Sep. 2008;108(9):27-31. [pmid: 18756154].

## B-17. Rejection Reason: Not Retrieved

1 Abu-Qamar AA, Gazal AH. Randomized trial comparing laparoscopic versus open appendectomy. Journal of the Bahrain Medical Society [serial on the Internet]. 2001;(2). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/499/CN-00594499/frame.html. Last accessed.
2 Hocht B, Meyer T. Acute appendicitis in childhood. Indications and operative treatment. Padiatrische Praxis. 2010;75(1):113-25. PMID:.
3 Iqbal S, Memon AS, Shaikh U, et al. Frequency of normal appendicectomy in a tertiary care hospital. Medical Forum Monthly. 2011;22(12):30-3. PMID:.
4 Jalbani MA, Rind GH, Soomro AH. Comparison of Laparocopic Appendisectomy (LA) Versus Open Appendisectomy (OA) (a prospective randomizing audit of 1000 cases). Medical Forum Monthly. 2012;23(1):71-4. PMID:.
5 Jeong Kim W, Kang K, Kim K, Hwan Jo Y, Eui Rhee J, Hee Lee J, Kim YJ, Lee J, Kang SB, Kim DW, Lee KH, Hoon Kim Y, Mi Park H. Effect of pain control in suspected acute appendicitis on the diagnostic accuracy of surgical residents.
6 Khan AM, Dalwani AG, Memon M, et al. Appendecectomy during pregnancy. A comparison of laparoscopic with open appendicectomy in respect of safety and morbidity to mother and fetus. Medical Forum Monthly. 2012;23(7):51-5. PMID:.
7 Khan BAH, Ul Haq RN, Khan FB, et al. Role of diagnostic laparoscopy: A study of 58 patients. Medical Forum Monthly. 2010;21(12):3-5. PMID:.
8 Khatkov IY, Chudnih SM, Aliyev ES. Laparoscopy in diagnosis and treatment of acute appendicitis in pregnant women. Azerbaijan Medical Journal. 2011;(1):66-70. PMID:.
9 Laghari AA, Laghari QA, Qazi AR, et al. Role of investigations and Alvarado Score in acute appendicitis at Peoples Medical College Hospital Nawabshah. Medical Forum Monthly. 2011;22(2):7-9.
10 Masood R, Khan BA, Dur e S, et al. Urgent laparoscopic surgery for cholecystitis and appendicitis during pregnancy. Medical Forum Monthly. 2010;21(7):22-4.
11 Nunnelee JD, Musselman R, Spaner SD. Appendectomy in pregnancy and postpartum: analysis of data from a large private hospital. Clinical excellence for nurse practitioners : the international journal of NPACE. Sep. 1999;3(5):298-301. [pmid: 10763629].
12 Perveen S, Sarwar G, Saeed N, Channa GA. Laparoscopic versus open appendicectomy as an elective procedure. Med Channel [serial on the Internet]. 2007;(1). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/360/CN-00794360/frame.html.
13 Rodrigues SP, Van Hooff MHA, Van Aggelen GP, et al. Laparoscopic interventions during pregnancy. Nederlands tijdschrift voor geneeskunde. 2009;153(1–2):25-9. [pmid: 19198209].
14 Saeed A, Mehmood SQ, Awan AN. Acute abdomen, causes and outcome - Experience at DHQ Hospital Abbottabad. Medical Forum Monthly. 2013;24(1):38-40.
15 Saeed A, Mehmood SQ, Awan AN. Acute abdomen, causes and outcome - Experience at DHQ Hospital Abbottabad. Medical Forum Monthly. 2013;24(1):38-40.
16 Saeed T, Hasan A, Talmur M, et al. Acute abdomen cases presenting at Fauji foundation hospital, Rawalpindi. Medical Forum Monthly. 2011;22(6):56-8.
17 Siddiqui AH, Afzal S. Perforated appendicitis: accuracy of ct diagnosis and correlation of ct findings with the length of hospital stay. Journal of the College of Physicians and Surgeons--Pakistan : JCPSP. Dec. 2007;17(12):721-5. [pmid: 18182135].

## B-18. Rejection Reason: Not Test of Interest

1 Aarabi S, Sidhwa F, Riehle KJ, et al. Pediatric appendicitis in New England: epidemiology and outcomes. Journal of pediatric surgery. Jun. 2011;46(6):1106-14. [pmid: 21683207].
2 Abantanga FA, Nimako B, Amoah M. The range of abdominal surgical emergencies in children older than 1 year at the Komfo Anokye Teaching Hospital, Kumasi, Ghana. Annals of African medicine. Oct–Dec. 2009;8(4):236-42. [pmid: 20139546].
3 Abbas S, Ng A, Jones W. Examination under anesthesia prior laparoscopic appendicectomy: does it change the approach?. Surgical laparoscopy, endoscopy & percutaneous techniques. Feb. 2007;17(1):26-8. [pmid: 17318050].
4 Abou-Nukta F, Bakhos C, Arroyo K, et al. Effects of delaying appendectomy for acute appendicitis for 12 to 24 hours. Archives of surgery (Chicago, Ill : 1960). May. 2006;141(5):504-6. discussioin 6–7. [pmid: 16702523].
5 Adams-Ray J. The diagnostic value of Wernoe’s symptom in acute abdomen. Acta chirurgica Scandinavica. Oct. 29. 1953;106(2–3):224-37. [pmid: 13137833].
6 Adisa AO, Alatise OI, Arowolo OA, et al. Laparoscopic appendectomy in a Nigerian teaching hospital. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Oct–Dec. 2012;16(4):576-80. [pmid: 23484567].
7 Adisa AO, Arowolo OA, Salako AA, et al. Preliminary experience with laparoscopic surgery in Ile-Ife, Nigeria. African journal of medicine and medical sciences. Dec. 2009;38(4):351-6. [pmid: 20499629].
8 Adisa AO, Lawal OO, Arowolo OA, Alatise OI. Local adaptations aid establishment of laparoscopic surgery in a semiurban Nigerian hospital. [pmid: 22806524].
9 Affleck DG, Handrahan DL, Egger MJ, et al. The laparoscopic management of appendicitis and cholelithiasis during pregnancy. American journal of surgery. Dec. 1999;178(6):523-9. [pmid: 10670865].
10 Agafonoff S, Hawke I, Khadra M, et al. The influence of age and gender on normal appendicectomy rates. The Australian and New Zealand journal of surgery. Nov. 1987;57(11):843-6. [pmid: 3439927].
11 Aghamohammadi D, Gholipouri C, Hosseinzadeh H, et al. An evaluation of the effect of morphine on abdominal pain and peritonealirritation signs in patients with acute surgical abdomen. Journal of Cardiovascular and Thoracic Research. 2012;4(2):45-8. PMID:. [pmid: 24250982].
12 Agodirin O, Oguntola A, Adeoti M, Agbakwuru A, Oluwadiya K, Olofinbiyi B. Preoperative pain treatment in acute abdomen in Osogbo, Nigeria: A randomized double-blind placebo-controlled study. [pmid: 23343476].
13 Agrusa A, Romano G, Di Buono G, et al. Laparoscopic approach in abdominal emergencies: a 5-year experience at a single center. Il Giornale di chirurgia. Nov–Dec. 2012;33(11–12):400-3. [pmid: 23140925].
14 Agrusa A, Romano G, Di Buono G, Frazzetta G, Chianetta D, Sorce V, Billone V, Cucinella G, Gulotta G. Acute appendicitis and endometriosis: Retrospective analysis in emergency setting. Giornale Italiano di Ostetricia e Ginecologia. 2013;35(6):728-32. PMID:.
15 Ahmed I, Asgeirsson KS, Beckingham IJ, et al. The position of the vermiform appendix at laparoscopy. Surgical and radiologic anatomy : SRA. Mar. 2007;29(2):165-8. [pmid: 17318285].
16 Akhigbe T, Smith F, Adebowale A, et al. Open versus laparoscopic A ppendectomy in children: Comparison of outcomes in a regional hospital. Irish journal of medical science. 2011;180:S262.
17 Al Hadi HI, Maw A. The “double endoloop” technique--a simple alternative technique for laparoscopic appendectomy. Surgical laparoscopy, endoscopy & percutaneous techniques. Feb. 2008;18(1):67-9. [pmid: 18287987].
18 al-Ayoubi F1, Eriksson H, Myrelid P, Wallon C, Andersson P. Distribution of emergency operations and trauma in a Swedish hospital: need for reorganisation of acute surgical care?. [pmid: 22985447].
19 Al-Bassam AA. Laparoscopic appendectomy in children. Saudi medical journal. Apr. 2005;26(4):556-9. [pmid: 15900359].
20 Alder AC, Fomby TB, Woodward WA, et al. Association of viral infection and appendicitis. Archives of surgery (Chicago, Ill : 1960). Jan. 2010;145(1):63-71. [pmid: 20083756].
21 Alfraih Y, Postuma R, Keijzer R. How do you diagnose appendicitis? An international evaluation of methods. [pmid: 24211647].
22 Al-Ghnaniem R, Kocher HM, Patel AG. Prediction of inflammation of the appendix at open and laparoscopic appendicectomy: findings and consequences. The European journal of surgery. Acta chirurgica. 2002;168(1):4-7. [pmid: 12022370].
23 Alkhoury F, Malvezzi L, Knight CG, Diana J, Pasaron R, Mora J, Aserlind A, Stylianos S, Burnweit C. Routine same-day discharge after acute or interval appendectomy in children: A prospective study. [pmid: 22785642].
24 Alloo J, Gerstle T, Shilyansky J, et al. Appendicitis in children less than 3 years of age: a 28-year review. Pediatric surgery international. Jan. 2004;19(12):777-9. [pmid: 14730382].
25 Almond SL, Roberts M, Joesbury V, et al. It is not what you do, it is the way that you do it: impact of a care pathway for appendicitis. Journal of pediatric surgery. Feb. 2008;43(2):315-9. [pmid: 18280281].
26 Al-Mulhim AS, Al-Mulhim FM, Al-Suwaiygh AA, et al. Laparoscopic versus open appendectomy in females with a clinical diagnosis of appendicitis. Saudi medical journal. Nov. 2002;23(11):1339-42. [pmid: 12506292].
27 Al-Qudah MS, Amr M, Sroujieh A, et al. Appendectomy in pregnancy: the experience of a university hospital. Journal of obstetrics and gynaecology : the journal of the Institute of Obstetrics and Gynaecology. Jul. 1999;19(4):362-4. [pmid: 15512331].
28 Al-Saadi AS, Al-Wadan AH, Hamarnah SA, et al. Is abandoning routine peritoneal cultures during appendectomy justified?. Saudi medical journal. Dec. 2007;28(12):1827-9. [pmid: 18060210].
29 AlSalilli M, Vilos GA. Prospective evaluation of laparoscopic appendectomy in women with chronic right lower quadrant pain. The Journal of the American Association of Gynecologic Laparoscopists. Feb. 1995;2(2):139-42. [pmid: 9050547].
30 Ameh EA. Appendicitis versus genital disease in young women in tropical Africa. Tropical doctor. Apr. 2000;30(2):103-4. [pmid: 10842560].
31 Amoli HA, Golozar A, Keshavarzi S, et al. Morphine analgesia in patients with acute appendicitis: a randomised double-blind clinical trial. Emergency medicine journal : EMJ. Sep. 2008;25(9):586-9. [pmid: 18723709].
32 Anderson BO, Sun JH, Moore EE, et al. The development and evaluation of a clinical test of surgical resident proficiency. Surgery. Aug. 1989;106(2):347-52. discussion 52–3. [pmid: 2763033].
33 Anderson JL, Bridgewater FH. Laparoscopy in the diagnosis of acute lower abdominal pain. The Australian and New Zealand journal of surgery. Oct. 1981;51(5):462-4. [pmid: 6459079].
34 Andersson R, Hugander A, Thulin A, et al. Indications for operation in suspected appendicitis and incidence of perforation. BMJ (Clinical research ed). Jan. 8. 1994;308(6921):107-10. [pmid: 8298378].
35 Andersson RE, Hugander A, Ravn H, et al. Repeated clinical and laboratory examinations in patients with an equivocal diagnosis of appendicitis. World journal of surgery. Apr. 2000;24(4):479-85. discussion 85. [pmid: 10706923].
36 Andersson RE. Short and long-term mortality after appendectomy in Sweden 1987 to 2006. Influence of appendectomy diagnosis, sex, age, co-morbidity, surgical method, hospital volume, and time period. A national population-based cohort study. World journal of surgery. May. 2013;37(5):974-81. [pmid: 23192168].
37 Andreu-Ballester JC, Gonzalez-Sanchez A, Ballester F, et al. Epidemiology of appendectomy and appendicitis in the Valencian community (Spain), 1998–2007. Digestive surgery. 2009;26(5):406-12. [pmid: 19923829].
38 Antal A, Janaki H. New diagnostic adjunct in laparoscopic procedures. Intraoperative ultrasound. Acta chirurgica Hungarica. 1994;34(1–2):151-60. [pmid: 7604618].
39 Appendicitis and appendectomies among non-service member beneficiaries of the Military Health System, 2002–2011. Msmr. Dec. 2012;19(12):13-6. [pmid: 23311331].
40 Armstrong J, Merritt N, Jones S, Scott L, Bütter A. Non-operative management of early, acute appendicitis in children: is it safe and effective?. [pmid: 24851770].
41 Asarias JR, Schlussel AT, Cafasso DE, et al. Incidence of postoperative intraabdominal abscesses in open versus laparoscopic appendectomies. Surgical endoscopy. Aug. 2011;25(8):2678-83. [pmid: 21416175].
42 Attard AR, Corlett MJ, Kidner NJ, et al. Safety of early pain relief for acute abdominal pain. BMJ (Clinical research ed). Sep. 5. 1992;305(6853):554-6. [pmid: 1393034].
43 Austin O, Hederman WP, O’Connell PR, Gorey TF. Prospective evaluation of laparoscopic versus open appendicectomy abstract. Irish journal of medical science [serial on the Internet]. 1992. Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/657/CN-00548657/frame.html. Last accessed.
44 Axelrod DA, Sonnad SS, Hirschl RB. An economic evaluation of sonographic examination of children with suspected appendicitis. Journal of pediatric surgery. Aug. 2000;35(8):1236-41. [pmid: 10945702].
45 Aydelotte JD, Collen JF, Martin RR. Analgesic administration prior to surgical evaluation for acute appendicitis. Current surgery. Jul–Aug. 2004;61(4):373-5. [pmid: 15276343].
46 Aziz H, Kukar M, Zemon H. Laparoscopic endoscopic single-site surgery versus conventional laparoscopic surgery for acute appendicitis in an adult population. [pmid: 24401506].
47 Bachoo P, Mahomed AA, Ninan GK, et al. Acute appendicitis: the continuing role for active observation. Pediatric surgery international. Mar. 2001;17(2–3):125-8. [pmid: 11315270].
48 Bachur RG, Hennelly K, Callahan MJ, Monuteaux MC. Advanced radiologic imaging for pediatric appendicitis, 2005–2009: trends and outcomes. Journal of Pediatrics. 2012;160(6):1034-8. Language: English. Entry Date: 20120810. Revision Date: 20120810. Publication Type: journal article. [pmid: 22192815].
49 Baigrie RJ, Dehn TC, Fowler SM, et al. Analysis of 8651 appendicectomies in England and Wales during 1992. The British journal of surgery. Jul. 1995;82(7):933. [pmid: 7648113].
50 Baigrie RJ, Saidan Z, Scott-Coombes D, et al. Role of fine catheter peritoneal cytology and laparoscopy in the management of acute abdominal pain. The British journal of surgery. Feb. 1991;78(2):167-70. [pmid: 1826625].
51 Baigrie RJ, Scott-Coombes D, Saidan Z, et al. The selective use of fine catheter peritoneal cytology and laparoscopy reduces the unnecessary appendicectomy rate. The British journal of clinical practice. Autumn. 1992;46(3):173-6. [pmid: 1286016].
52 Baik SM, Hong KS, Kim YI. A comparison of transumbilical single-port laparoscopic appendectomy and conventional three-port laparoscopic appendectomy: from the diagnosis to the hospital cost. [pmid: 23908963].
53 Bailey B, Bergeron S, Gravel J, et al. Efficacy and impact of intravenous morphine before surgical consultation in children with right lower quadrant pain suggestive of appendicitis: a randomized controlled trial. Annals of emergency medicine. Oct. 2007;50(4):371-8. [pmid: 17597256].
54 Baker A. Laparoscopic appendicectomy--a trainee’s experience. The New Zealand medical journal. Jun. 11. 1999;112(1089):208-11. [pmid: 10414622].
55 Ball CG, Dixon E, MacLean AR, Kaplan GG, Nicholson L, Sutherland FR. The impact of an acute care surgery clinical care pathway for suspected appendicitis on the use of CT in the emergency department. [pmid: 24869612].
56 Balzarotti R, Smadja C, Saint Yves G, et al. Elective versus urgent laparoscopic appendectomy for complicated appendicitis. Minerva chirurgica. Feb. 2009;64(1):9-16. [pmid: 19202531].
57 Banani SA, Talei A. Can oral metronidazole substitute parenteral drug therapy in acute appendicitis? A new policy in the management of simple or complicated appendicitis with localized peritonitis: a randomized controlled clinical trial. The American surgeon. May. 1999;65(5):411-6. [pmid: 10231206].
58 Banez EI, Bacaling JH. An evaluation of the Technicon H-1 automated hematology analyzer in detecting peripheral blood changes in acute inflammation. Archives of pathology & laboratory medicine. Sep. 1988;112(9):885-8. [pmid: 3046558].
59 Barrett ML, Hines AL, Andrews RM. Trends in Rates of Perforated Appendix, 2001–2010. Statistical Brief #159. [pmid: 24199256].
60 Benini L, Bevilacqua D, Brocco G, et al. Lipase latex test for acute abdominal pain: comparison with serum lipase, trypsin, elastase and amylase. The Italian journal of gastroenterology. Feb. 1992;24(2):61-4. [pmid: 1374275].
61 Benkoe T, Baumann S, Angleitner P, et al. Immunphenotypical characterization of tissue and peripheral blood lymphocytes in appendicitis. European Surgery - Acta Chirurgica Austriaca. 2011;43:9. PMID:.
62 Berg ER, Mehta SD, Mitchell P, et al. Length of stay by route of contrast administration for diagnosis of appendicitis by computed-tomography scan. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Oct. 2006;13(10):1040-5. [pmid: 16973641].
63 Berne TV, Yellin AE, Appleman MD, et al. A clinical comparison of cefepime and metronidazole versus gentamicin and clindamycin in the antibiotic management of surgically treated advanced appendicitis. Surgery, gynecology & obstetrics. Suppl. 1993;177:18-22. discussion 35–40. [pmid: 8256187].
64 Bickel A, Gurevits M, Vamos R, et al. Perioperative hyperoxygenation and wound site infection following surgery for acute appendicitis: a randomized, prospective, controlled trial. Archives of surgery (Chicago, Ill : 1960). Apr. 2011;146(4):464-70. [pmid: 21502457].
65 Bilik R, Burnweit C, Shandling B. Is abdominal cavity culture of any value in appendicitis?. American journal of surgery. Apr. 1998;175(4):267-70. [pmid: 9568649].
66 Birch D. Discussion. American journal of surgery. 2012;203(5):612. PMID:.
67 Bjorsum-Meyer T, Schmidt TA. Consequences of peritonism in an emergency department setting. Open Access Emergency Medicine. ((Bjorsum-Meyer T., thmey10@sol.dk) Surgical Department, Holbaek Hospital, Smedelundsgade, Holbaek, Denmark). 2013;6:9-13.
68 Black NA, Moore L. Comparative audit between hospitals: the example of appendectomy. International journal of health care quality assurance. 1994;7(3):11-5. [pmid: 10136780].
69 Blakely ML, Lally KP. Using evidence-based medicine principles to improve quality of patient care in pediatric surgery. Seminars in pediatric surgery. Feb. 2002;11(1):42-5. [pmid: 11815941].
70 Blind PJ, Dahlgren ST. The continuing challenge of the negative appendix. Acta chirurgica Scandinavica. Oct. 1986;152:623-7. [pmid: 3811765].
71 Blomqvist P, Ljung H, Nyren O, et al. Appendectomy in Sweden 1989–1993 assessed by the Inpatient Registry. Journal of clinical epidemiology. Oct. 1998;51(10):859-65. [pmid: 9762879].
72 Boenigk H, Meyer F, Koch A, et al. Surgical determinants, perioperative course and outcome of a representative patient cohort with acute appendicitis undergoing appendectomy over 3 decades. Polski przeglad chirurgiczny. Oct. 2012;84(10):509-20. [pmid: 23324367].
73 Bouillot JL, Salah S, Fernandez F, et al. Laparoscopic procedure for suspected appendicitis. A prospective study in 283 consecutive patients. Surgical endoscopy. Sep. 1995;9(9):957-60. [pmid: 7482212].
74 Bratu I, Martens PJ, Leslie WD, et al. Pediatric appendicitis rupture rate: disparities despite universal health care. Journal of pediatric surgery. Nov. 2008;43(11):1964-9. [pmid: 18970925].
75 Brayton D. Acute perforated appendicitis in childhood; analysis of management, including the use of hypothermia. California medicine. Aug. 1956;85(2):89-92. [pmid: 13343013].
76 Brekke M, Eilertsen RK. Acute abdominal pain in general practice: Tentative diagnoses and handling. Scandinavian journal of primary health care. 2009;27(3):137-40. PMID:. [pmid: 19731181].
77 Brown J, Fleming R, Aristzabel J, et al. Does pelvic exam in the emergency department add useful information?. The western journal of emergency medicine. May. 2011;12(2):208-12. [pmid: 21691528].
78 Bryson K. Laparoscopic appendectomy. Journal of gynecologic surgery. Summer. 1991;7(2):93-5. [pmid: 10150024].
79 Buckley RC, Hall TJ, Muakkassa FF, et al. Laparoscopic appendectomy: is it worth it?. The American surgeon. Jan. 1994;60(1):30-4. [pmid: 8273971].
80 Busch M, Gutzwiller FS, Aellig S, et al. In-hospital delay increases the risk of perforation in adults with appendicitis. World journal of surgery. Jul. 2011;35(7):1626-33. [pmid: 21562871].
81 Buttrick SS, Choi JJ, Divino CM. Stump appendicitis after open and laparoscopic appendectomies. The American surgeon. Jan. 2012;78(1):143-4. [pmid: 22273334].
82 Byrne DS, Bell G, Morrice JJ, et al. Technique for laparoscopic appendicectomy. The British journal of surgery. Jun. 1992;79(6):574-5. [pmid: 1535262].
83 Caldwell MT, Watson RG. Peritoneal aspiration cytology as a diagnostic aid in acute appendicitis. The British journal of surgery. Feb. 1994;81(2):276-8. [pmid: 8156358].
84 Canty TG Sr, Collins D, Losasso B, et al. Laparoscopic appendectomy for simple and perforated appendicitis in children: the procedure of choice?. Journal of pediatric surgery. Nov. 2000;35(11):1582-5. [pmid: 11083428].
85 Caruso C, La Torre M, Benini B, et al. Is laparoscopy safe and effective in nontraumatic acute abdomen?. Journal of laparoendoscopic & advanced surgical techniques Part A. Sep. 2011;21(7):589-93. [pmid: 21774701].
86 Casarotto A, Zarantonello FR, Rebonato M. Appendectomy in Women. Is the Laparoscopic Approach Always Better Than the ‘Open’ Approach in Uncomplicated Appendicitis?. [pmid: 24910936].
87 Cawich SO, Mohanty SK, Simpson LK, Ramdass MJ, Naraynsingh V. Is laparoscopic appendectomy safe when performed in a low volume setting?. [pmid: 24711747].
88 Cecil RL, Bulkley K. ON THE LESIONS PRODUCED IN THE APPENDIX BY OXYURIS VERMICULARIS AND TRICHOCEPHALUS TRICHIURA. The Journal of experimental medicine. Mar. 1. 1912;15(3):225-45. [pmid: 19867519].
89 Champault A, Polliand C, Mendes da Costa P, et al. Laparoscopic appendectomies: retrospective study of 2074 cases. Surgical laparoscopy, endoscopy & percutaneous techniques. Apr. 2008;18(2):168-72. [pmid: 18427336].
90 Champault G, Taffinder N, Ziol M, et al. Recognition of a pathological appendix during laparoscopy: a prospective study of 81 cases. The British journal of surgery. May. 1997;84(5):671. [pmid: 9171760].
91 Chandler NM, Ghazarian SR, King TM, Danielson PD. Cosmetic outcomes following appendectomy in children: a comparison of surgical techniques. [pmid: 25062342].
92 Chang FC, Hogle HH, Welling DR. The fate of the negative appendix. American journal of surgery. Dec. 1973;126(6):752-4. [pmid: 4758793].
93 Charitou AN, New NE, Pettigrew GJ. Randomized study to examine the value of on-table inspection of the appendix mucosa. The British journal of surgery. Jun. 2001;88(6):837-8. [pmid: 11412254].
94 Chase CW, Barker DE, Russell WL, et al. Serum amylase and lipase in the evaluation of acute abdominal pain. The American surgeon. Dec. 1996;62(12):1028-33. [pmid: 8955242].
95 Chattopadhyay S, Rabhi F, Acharya UR, et al. An approach to model Right Iliac Fossa pain using pain-only-parameters for screening acute appendicitis. Journal of medical systems. Jun. 2012;36(3):1491-502. [pmid: 20949312].
96 Cheong LH, Emil S. Determinants of appendicitis outcomes in Canadian children. [pmid: 24851769].
97 Chianakwana GU, Ihegihu CC, Okafor PI, et al. Adult surgical emergencies in a developing country: the experience of Nnamdi Azikiwe University Teaching Hospital, Nnewi, Anambra State, Nigeria. World journal of surgery. Jun. 2005;29(6):804-7. discussion 8. [pmid: 15880283].
98 Chiarugi M, Buccianti P, Celona G, et al. Laparoscopic compared with open appendicectomy for acute appendicitis: a prospective study. The European journal of surgery. Acta chirurgica. May. 1996;162(5):385-90. [pmid: 8781920].
99 Chiou YY, Pitman MB, Hahn PF, et al. Rare benign and malignant appendiceal lesions: spectrum of computed tomography findings with pathologic correlation. Journal of computer assisted tomography. May–Jun. 2003;27(3):297-306. [pmid: 12794590].
100 Chong CF, Wang TL, Chen CC, et al. Preconsultation use of analgesics on adults presenting to the emergency department with acute appendicitis. Emergency medicine journal : EMJ. Jan. 2004;21(1):41-3. [pmid: 14734373].
101 Chou YH, Chiou HJ, Tiu CM, et al. Sonography of acute right side colonic diverticulitis. American journal of surgery. Feb. 2001;181(2):122-7. [pmid: 11425051].
102 Chua MW, Fazidah Y, Khalijah MY, et al. A review of acute appendicitis seen in the Taiping District Hospital from July to December, 1990. The Medical journal of Malaysia. Mar. 1993;48(1):28-32. [pmid: 8341169].
103 Chung KM, Lee SW, Chia NH, et al. Acute appendicitis---a recent audit of an old problem. Hong Kong medical journal/Hong Kong Academy of Medicine. Xianggang yi xue za zhi. Jun. 1997;3(2):149-52. [pmid: 11850564].
104 Ciardo LF, Agresta F, Bedin N. Day-case laparoscopic surgery for appendicitis and non-specific abdominal pain. Chirurgia italiana. May–Jun. 2007;59(3):299-304. [pmid: 17663367].
105 Clyde C, Bax T, Merg A, et al. Timing of intervention does not affect outcome in acute appendicitis in a large community practice. American journal of surgery. May. 2008;195(5):590-2. discussion 2–3. [pmid: 18367138].
106 Coelho JC, Fernandes FM, Cortiano LG, et al. Appendectomy. Comparative study between a public and a private hospital. Revista da Associacao Medica Brasileira (1992). Sep–Oct. 2010;56(5):522-7. [pmid: 21152822].
107 Cohen MM. Peritoneoscopy in general surgery. Canadian journal of surgery Journal canadien de chirurgie. Sep. 1981;24(5):490-3. [pmid: 6456802].
108 Colleran G, Heneghan H, Sweeney KJ, et al. A comparison of surgical impression, histological findings and microbiological results at open appendicectomy. Irish medical journal. Oct. 2007;100(9):593-6. [pmid: 18196884].
109 Cooke BK, Magas LT, Virgo KS, et al. Appendectomy for appendicitis in patients with schizophrenia. American journal of surgery. Jan. 2007;193(1):41-8. [pmid: 17188086].
110 Cooper JG, Hammond-Jones D, O’Neill E, et al. The Clinical Decision Unit has a role to play in the management of acute undifferentiated abdominal pain. European journal of emergency medicine : official journal of the European Society for Emergency Medicine. Oct. 2012;19(5):323-8. [pmid: 22082879].
111 Cortesi N, Zambarda E, Manenti A, et al. Laparoscopy in routine and emergency surgery: experience with 1,720 cases. American journal of surgery. May. 1979;137(5):647-9. [pmid: 156508].
112 Coughlin JP, Gauderer MW, Stern RC, et al. The spectrum of appendiceal disease in cystic fibrosis. Journal of pediatric surgery. Aug. 1990;25(8):835-9. [pmid: 2205712].
113 Covarelli P, Pimpinelli GA, Cirocchi R, et al. Acute appendicitis. How many uncorrect diagnosis? A clinical and histological evaluation of 124 cases treated with emergency procedure. Il Giornale di chirurgia. May. 1996;17(5):276-8. [pmid: 8755229].
114 Cox MR, McCall JL, Padbury RT, et al. Laparoscopic surgery in women with a clinical diagnosis of acute appendicitis. The Medical journal of Australia. Feb. 6. 1995;162(3):130-2. [pmid: 7854223].
115 Cross W, Chandru Kowdley G. Same-day surgery for laparoscopic appendectomy in appendicitis: is this safe?. [pmid: 24401507].
116 Crossley RB. Hospital admissions for abdominal pain in childhood. Journal of the Royal Society of Medicine. Oct. 1982;75(10):772-6. [pmid: 7131474].
117 Crum-Cianflone N, Weekes J, Bavaro M. Appendicitis in HIV-infected patients during the era of highly active antiretroviral therapy. HIV medicine. Jul. 2008;9(6):421-6. [pmid: 18705760].
118 Cuesta MA, Borgstein PJ, Meijer S. Laparoscopy in the diagnosis and treatment of acute abdominal conditions. Clinical review. The European journal of surgery. Acta chirurgica. Sep. 1993;159(9):455-6. [pmid: 8274551].
119 Cuesta MA, Eijsbouts QA, Gordijn RV, et al. Diagnostic laparoscopy in patients with an acute abdomen of uncertain etiology. Surgical endoscopy. Jul. 1998;12(7):915-7. [pmid: 9632859].
120 Das MK, Gautam D, Roy H, et al. Unnecessary appendicectomy in suspected cases of acute appendicitis. Journal of the Indian Medical Association. Jun. 6. 2009;107(6):354-7. [pmid: 19886373].
121 Davies MS, Cunningham S, Cooke DA, et al. Is the hot appendix really hot?. Postgraduate medical journal. Nov. 1993;69(817):862-4. [pmid: 8290431].
122 De Dombal FT, Gill PW, Leaper DJ, et al. Observer variation in clinical diagnosis: its magnitude and importance in patients with acute abdominal pain. The British journal of surgery. Apr. 1973;60(4):310. [pmid: 4573300].
123 de Dombal FT, Matharu SS, Staniland JR, et al. Presentation of cancer to hospital as ‘acute abdominal pain’. The British journal of surgery. Jun. 1980;67(6):413-6. [pmid: 6992915].
124 Delgado Cifuentes AF, Sotomayor RK. Comparison between open and laparoscopic appendectomy in non-complicated appendicitis. Boletin de la Asociacion Medica de Puerto Rico. Jan–Mar. 2008;100(1):20-5. [pmid: 18763393].
125 Di Lorenzo N, Manzelli A, Coscarella G, et al. Minilaparoscopic appendectomy for acute appendicitis. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Jan–Mar. 2006;10(1):52-5. [pmid: 16709358].
126 Dingemann J, Metzelder M, Kuebler JF, et al. Laparoscopy for suspected appendicitis in children: May a macroscopically normal appendix be left in situ?. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al]. Zeitschrift fur Kinderchirurgie. Jun. 2009;19(3):153-6. [pmid: 19347808].
127 do Amaral PC, de Filho EM, Galvao TD, et al. Factors leading to long-term hospitalization after laparoscopic appendectomy. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Jul–Sep. 2006;10(3):355-8. [pmid: 17212895].
128 Donnelly NJ, Semmens JB, Fletcher DR, et al. Appendicectomy in Western Australia: profile and trends, 1981–1997. The Medical journal of Australia. Jul. 2. 2001;175(1):15-8. [pmid: 11476196].
129 Doraiswamy NV. Progress of acute appendicitis: a study in children. The British journal of surgery. Dec. 1978;65(12):877-9. [pmid: 737426].
130 Drake FT, Mottey NE, Farrokhi ET, Florence MG, Johnson MG, Mock C, Steele SR, Thirlby RC, Flum DR. Time to Appendectomy and Risk of Perforation in Acute Appendicitis. [pmid: 24990687].
131 Driscoll PA, Vincent CA, Servant CJ, et al. Use of advisers in the diagnosis and management of abdominal pain in accident and emergency departments. The British journal of surgery. Dec. 1988;75(12):1173-5. [pmid: 3233466].
132 Duff SE, Dixon AR. Laparoscopic appendicectomy: safe and useful for training. Annals of the Royal College of Surgeons of England. Nov. 2000;82(6):388-91. [pmid: 11103154].
133 Dunn EL, Moore EE, Elerding SC, et al. The unnecessary laparotomy for appendicitis-can it be decreased?. The American surgeon. Jul. 1982;48(7):320-3. [pmid: 7091920].
134 Duqoum W. Appendicitis in pregnancy. Eastern Mediterranean health journal. La revue de sante de la Mediterranee orientale = al-Majallah al-sihhiyah li-sharq al-mutawassit. Jul–Sep. 2001;7(4–5):642-5. [pmid: 15332760].
135 Eakins C, Ellis WD, Pruthi S, et al. Second opinion interpretations by specialty radiologists at a pediatric hospital: rate of disagreement and clinical implications. AJR American journal of roentgenology. Oct. 2012;199(4):916-20. [pmid: 22997387].
136 Eisenberg RL, Heineken P, Hedgcock MW, et al. Evaluation of plain abdominal radiographs in the diagnosis of abdominal pain. Annals of surgery. Apr. 1983;197(4):464-9. [pmid: 6830353].
137 Ekeh AP, Monson B, Wozniak CJ, et al. Management of acute appendicitis by an acute care surgery service: is operative intervention timely?. Journal of the American College of Surgeons. Jul. 2008;207(1):43-8. [pmid: 18589360].
138 el Ghoneimi A, Valla JS, Limonne B, et al. Laparoscopic appendectomy in children: report of 1,379 cases. Journal of pediatric surgery. Jun. 1994;29(6):786-9. [pmid: 8078022].
139 El-Dhuwaib Y, Hamade AM, Issa ME, et al. An “all 5-mm ports” selective approach to laparoscopic cholecystectomy, appendectomy, and anti-reflux surgery. Surgical laparoscopy, endoscopy & percutaneous techniques. Jun. 2004;14(3):141-4. [pmid: 15471020].
140 Emil S, Laberge JM, Mikhail P, et al. Appendicitis in children: a ten-year update of therapeutic recommendations. Journal of pediatric surgery. Feb. 2003;38(2):236-42. [pmid: 12596112].
141 Eriksson S, Olander B, Pira U, et al. White blood cell count, leucocyte elastase activity, and serum concentrations of interleukin-6 and C-reactive protein after open appendicectomy. The European journal of surgery. Acta chirurgica. Feb. 1997;163(2):123-7. [pmid: 9076439].
142 Erkan T, Cam H, Ozkan HC, et al. Clinical spectrum of acute abdominal pain in Turkish pediatric patients: a prospective study. Pediatrics international : official journal of the Japan Pediatric Society. Jun. 2004;46(3):325-9. [pmid: 15151551].
143 Evans C, Rashid A, Rosenberg IL, et al. An appraisal of peritoneal lavage in the diagnosis of the acute abdomen. The British journal of surgery. Feb. 1975;62(2):119-20. [pmid: 1115873].
144 Fahim F, Shirjeel S. A comparison between presenatation time and delay in surgery in simple and advanced appendicitis. Journal of Ayub Medical College, Abbottabad : JAMC. Apr–Jun. 2005;17(2):37-9. [pmid: 16092648].
145 Faruquzzaman, Mazumder SK. Complicated appendectomy in children in relation to laparoscopic vs open procedures. Bratislavske lekarske listy. 2010;111(11):610-5. [pmid: 21384748].
146 Fataar S, Satyanath S. The radiographic evaluation of appendiceal calcification due to schistosomiasis. The American journal of tropical medicine and hygiene. Nov. 1986;35(6):1157-62. [pmid: 3098122].
147 Ferguson HJ, Hall NJ, Bhangu A. National Surgical Research Collaborative. A multicentre cohort study assessing day of week effect and outcome from emergency appendicectomy. [pmid: 24508682].
148 Ferraris VA. Exploratory laparotomy for potential abdominal sepsis in patients with multiple-organ failure. Archives of surgery (Chicago, Ill : 1960). Oct. 1983;118(10):1130-3. [pmid: 6615193].
149 Fleming JS. Laparoscopically directed appendicectomy. The Australian & New Zealand journal of obstetrics & gynaecology. Aug. 1985;25(3):238-40. [pmid: 2935138].
150 Flum DR, Koepsell TD. Evaluating diagnostic accuracy in appendicitis using administrative data. The Journal of surgical research. Feb. 2005;123(2):257-61. [pmid: 15680387].
151 Foulds KA, Beasley SW, Maoate K. Factors that influence length of stay after appendicectomy in children. The Australian and New Zealand journal of surgery. Jan. 2000;70(1):43-6. [pmid: 10696942].
152 Franke C, Gerharz CD, Bohner H, et al. Neurogenic appendicopathy in children. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al]. Zeitschrift fur Kinderchirurgie. Feb. 2002;12(1):28-31. [pmid: 11967756].
153 Franke C, Gerharz CD, Bohner H, et al. Neurogenic appendicopathy: a clinical disease entity?. International journal of colorectal disease. May. 2002;17(3):185-91. [pmid: 12049313].
154 Fraser JD, Aguayo P, Sharp SW, et al. Physiologic predictors of postoperative abscess in children with perforated appendicitis: subset analysis from a prospective randomized trial. Surgery. May. 2010;147(5):729-32. [pmid: 20004455].
155 Fraser SC, Smith K, Agarwal M, et al. Psychological screening for non-specific abdominal pain. The British journal of surgery. Dec. 1992;79(12):1369-71. [pmid: 1486444].
156 Frazee RC, Abernathy SW, Davis M, Hendricks JC, Isbell TV, Regner JL, Smith RW. Outpatient laparoscopic appendectomy should be the standard of care for uncomplicated appendicitis. [pmid: 24368360].
157 Frazee RC, Bohannon WT. Laparoscopic appendectomy for complicated appendicitis. Archives of surgery (Chicago, Ill : 1960). May. 1996;131(5):509-11. discussion 11–3. [pmid: 8624197].
158 Fredell CH. Was it hot? The accuracy of diagnosis of appendicitis in a small hospital. Arizona medicine. Jun. 1972;29(6):487-9. [pmid: 5035988].
159 Fried MW, Murthy UK, Hassig SR, et al. Creatine kinase isoenzymes in the diagnosis of intestinal infarction. Digestive diseases and sciences. Nov. 1991;36(11):1589-93. [pmid: 1935497].
160 Fukami Y, Hasegawa H, Sakamoto E, et al. Value of laparoscopic appendectomy in perforated appendicitis. World journal of surgery. Jan. 2007;31(1):93-7. [pmid: 17180555].
161 Gadomski A, Jenkins P. Ruptured appendicitis among children as an indicator of access to care. Health services research. Apr. 2001;36(1 Pt 1):129-42. [pmid: 11324740].
162 Garvey EM, Hebert JC, Osler T. Similar outcomes at a lower cost: an argument for open appendectomy in simple appendicitis. [pmid: 24480228].
163 Gatzen C, Paterson-Brown S, Touquet R, et al. Management of acute abdominal pain: decision making in the accident and emergency department. Journal of the Royal College of Surgeons of Edinburgh. Apr. 1991;36(2):121-3. [pmid: 2051408].
164 Gauderer MW, Crane MM, Green JA, et al. Acute appendicitis in children: the importance of family history. Journal of pediatric surgery. Aug. 2001;36(8):1214-7. [pmid: 11479859].
165 Gauderer MW. An individualized approach to appendectomy in children based on anatomico-laparoscopic findings. The American surgeon. Aug. 2007;73(8):814-7. [pmid: 17879692].
166 Ge B, Zhao H, Chen Q, Jin W, Liu L, Huang Q. A randomized comparison of gasless laparoscopic appendectomy and conventional laparoscopic appendectomy. [pmid: 24401566].
167 Gerst PH, Mukherjee A, Kumar A, et al. Acute appendicitis in minority communities: an epidemiologic study. Journal of the National Medical Association. Mar. 1997;89(3):168-72. [pmid: 9094841].
168 Ghazanfar A, Nasir SM, Choudary ZA, et al. Acute appendicitis complicating pregnancy; experience with the management of 50 patients. Journal of Ayub Medical College, Abbottabad : JAMC. Jul–Sep. 2002;14(3):19-21. [pmid: 12476858].
169 Ghonge NP, Setia V, Aggarwal B. “Surface map” of the appendix: a novel tool for the preoperative demonstration of appendicular location with reference to McBurneys point using a multidetector CT. Diagnostic and interventional radiology (Ankara, Turkey). Nov–Dec. 2012;18(6):582-6. [pmid: 22847172].
170 Gilchrist BF, Lobe TE, Schropp KP, et al. Is there a role for laparoscopic appendectomy in pediatric surgery?. Journal of pediatric surgery. Feb. 1992;27(2):209-12. discussion 12–4. [pmid: 1532981].
171 Gilliam AD, Anand R, Horgan LF, et al. Day case emergency laparoscopic appendectomy. Surgical endoscopy. Feb. 2008;22(2):483-6. [pmid: 17704876].
172 Giri SK, Shaikh FM, Sil D, et al. Our experience with selective laparoscopy through an open appendectomy incision in the management of suspected appendicitis. American journal of surgery. Aug. 2007;194(2):231-3. [pmid: 17618811].
173 Gladman MA, Knowles CH, Gladman LJ, et al. Intra-operative culture in appendicitis: traditional practice challenged. Annals of the Royal College of Surgeons of England. May. 2004;86(3):196-201. [pmid: 15140306].
174 Gleysteen JJ, Aldrete JS, Rutsky EA. Cholegraphy-induced acute renal failure: its relation to subsequent surgical therapy. Southern medical journal. Feb. 1976;69(2):173-6. [pmid: 1251238].
175 Golash V, Willson PD. Early laparoscopy as a routine procedure in the management of acute abdominal pain: a review of 1,320 patients. Surgical endoscopy. Jul. 2005;19(7):882-5. [pmid: 15920682].
176 Golash V. Laparoscopic assisted two port open appendicectomy. Oman medical journal. Jul. 2008;23(3):166-9. [pmid: 22359707].
177 Gomes CA, Junior CS, de Peixoto RO, Netto JM, Gomes CC, Gomes FC. Appendiceal stump closure by metal endoclip in the management of complicated acute appendicitis. [pmid: 24047531].
178 Goodson WH 3rd, Lopez-Sarmiento A, Jensen JA, et al. The influence of a brief preoperative illness on postoperative healing. Annals of surgery. Mar. 1987;205(3):250-5. [pmid: 3827360].
179 Graff L, Russell J, Seashore J, et al. False-negative and false-positive errors in abdominal pain evaluation: failure to diagnose acute appendicitis and unnecessary surgery. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Nov. 2000;7(11):1244-55. [pmid: 11073473].
180 Green RE. Acute appendicitis; a consideration of certain problems. Medical bulletin of the U S Army, Europe United States Army, Europe Medical Division. Sep. 1956;13(9):211-5. [pmid: 13358314].
181 Grimes C, Chin D, Bailey C, et al. Appendiceal faecaliths are associated with right iliac fossa pain. Annals of the Royal College of Surgeons of England. Jan. 2010;92(1):61-4. [pmid: 20056064].
182 Groves LB, Ladd MR, Gallaher JR, Swanson J, Becher RD, Pranikoff T, Neff LP. Comparing the cost and outcomes of laparoscopic versus open appendectomy for perforated appendicitis in children. [pmid: 24069976].
183 Guidry SP, Poole GV. The anatomy of appendicitis. The American surgeon. Jan. 1994;60(1):68-71. [pmid: 8273977].
184 Guller U, Rosella L, McCall J, et al. Negative appendicectomy and perforation rates in patients undergoing laparoscopic surgery for suspected appendicitis. The British journal of surgery. Apr. 2011;98(4):589-95. [pmid: 21259233].
185 Gungor F, Kartal M, Bektas F, et al. Randomized controlled trial of morphine in elderly patients with acute abdominal pain. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Sep. 2012;18(5):397-404. [pmid: 23188600].
186 Gupta R, Sample C, Bamehriz F, et al. Infectious complications following laparoscopic appendectomy. Canadian journal of surgery Journal canadien de chirurgie. Dec. 2006;49(6):397-400. [pmid: 17234067].
187 Gurbuz AT, Peetz ME. The acute abdomen in the pregnant patient. Is there a role for laparoscopy? Surgical endoscopy. Feb. 1997;11(2):98-102. [pmid: 9069135].
188 Gurleyik G, Gurleyik E, Unalmiser S. Abdominal surgical emergency in the elderly. The Turkish journal of gastroenterology : the official journal of Turkish Society of Gastroenterology. Mar. 2002;13(1):47-52. [pmid: 16378274].
189 Guss DA, Behling CA, Munassi D. Impact of abdominal helical computed tomography on the rate of negative appendicitis. The Journal of emergency medicine. Jan. 2008;34(1):7-11. [pmid: 18155380].
190 Hagendorf BA, Clarke JR, Burd RS. The optimal initial management of children with suspected appendicitis: a decision analysis. Journal of pediatric surgery. Jun. 2004;39(6):880-5. [pmid: 15185218].
191 Han TI. Improved sonographic visualization of the appendix with a saline enema in children with suspected appendicitis. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. May. 2002;21(5):511-6. [pmid: 12008813].
192 Harper AJ, Soules MR. Appendectomy as a consideration in operations for endometriosis. International journal of gynaecology and obstetrics: the official organ of the International Federation of Gynaecology and Obstetrics. Oct. 2002;79(1):53-4. [pmid: 12399097].
193 Hawkins JA, Mower WR, Nelson EW. Acute abdominal conditions in patients with leukemia. American journal of surgery. Dec. 1985;150(6):739-42. [pmid: 3878096].
194 Hay JM, Peyrard P, Lautard M, et al. Closed peritoneal lavage in the diagnosis of non traumatic acute abdomen. The Italian journal of surgical sciences/sponsored by Societa italiana di chirurgia. 1988;18(2):115-20. [pmid: 3066779].
195 Hemmila MR, Birkmeyer NJ, Arbabi S, et al. Introduction to propensity scores: A case study on the comparative effectiveness of laparoscopic vs open appendectomy. Archives of surgery (Chicago, Ill : 1960). Oct. 2010;145(10):939-45. [pmid: 20956761].
196 Hodjati H, Kazerooni T. Location of the appendix in the gravid patient: a re-evaluation of the established concept. International journal of gynaecology and obstetrics: the official organ of the International Federation of Gynaecology and Obstetrics. Jun. 2003;81(3):245-7. [pmid: 12767564].
197 Hoehne F, Ozaeta M, Sherman B, et al. Laparoscopic versus open appendectomy: is the postoperative infectious complication rate different?. The American surgeon. Oct. 2005;71(10):813-5. [pmid: 16468525].
198 Holdsworth PJ, Mayer AD, Wilson DH, et al. A simple screening test for acute pancreatitis. The British journal of surgery. Dec. 1984;71(12):958-9. [pmid: 6208966].
199 Horgan S, Meireles OR, Jacobsen GR, et al. Broad clinical utilization of NOTES: is it safe?. Surgical endoscopy. Jun. 2013;27(6):1872-80. [pmid: 23479251].
200 Horowitz JM, Nikolaidis P, Hammond NA, et al. Taking advantage of chemical shift imaging: using opposed-phase images to locate the normal appendix on MR. Clinical imaging. Nov–Dec. 2011;35(6):424-30. [pmid: 22040785].
201 Hussain A, Mahmood H, Singhal T, et al. What is positive appendicitis? A new answer to an old question. Clinical, macroscopical and microscopical findings in 200 consecutive appendectomies. Singapore medical journal. Dec. 2009;50(12):1145-9. [pmid: 20087549].
202 Hussain MI, Al-Akeely MH, Alam MK, et al. Management of appendiceal abscess. A 10-year experience in Central Saudi Arabia. Saudi medical journal. Jul. 2012;33(7):745-9. [pmid: 22821308].
203 Ibis C, Albayrak D, Hatipoglu AR, et al. The amount of comorbidities as a single parameter has no effect in predicting the outcome in appendicitis patients older than 60 years. Southern medical journal. Mar. 2010;103(3):202-6. [pmid: 20134382].
204 Iglesias S, Saunders LD, Tracy N, et al. Appendectomies in rural hospitals. Safe whether performed by specialist or GP surgeons. Canadian family physician Medecin de famille canadien. Mar. 2003;49:328-33. [pmid: 12675546].
205 Ilves I, Fagerström A, Herzig KH, Juvonen P, Miettinen P, Paajanen H. Seasonal variations of acute appendicitis and nonspecific abdominal pain in Finland. [pmid: 24833844].
206 Ilves I, Paajanen HE, Herzig KH, et al. Changing incidence of acute appendicitis and nonspecific abdominal pain between 1987 and 2007 in Finland. World journal of surgery. Apr. 2011;35(4):731-8. [pmid: 21327601].
207 Ingraham AM, Cohen ME, Bilimoria KY, et al. Effect of delay to operation on outcomes in adults with acute appendicitis. Archives of surgery (Chicago, Ill : 1960). Sep. 2010;145(9):886-92. [pmid: 20855760].
208 Isaksson K, Montgomery A, Moberg AC, Andersson R, Tingstedt B. Long-term follow-up for adhesive small bowel obstruction after open versus laparoscopic surgery for suspected appendicitis. [pmid: 24374517].
209 Issa N, Paran H, Yasin M, et al. Conservative treatment of right-sided colonic diverticulitis. European journal of gastroenterology & hepatology. Nov. 2012;24(11):1254-8. [pmid: 22872077].
210 Ito K, Ito H, Whang EE, et al. Appendectomy in pregnancy: evaluation of the risks of a negative appendectomy. American journal of surgery. Feb. 2012;203(2):145-50. [pmid: 21784406].
211 Jackson CR, Anderson B, Jaffray B. Childhood constipation is not associated with characteristic fingerprint patterns. Archives of disease in childhood. Dec. 2003;88(12):1076-7. [pmid: 14670772].
212 Jaffe TA, Miller CM, Merkle EM. Practice patterns in imaging of the pregnant patient with abdominal pain: a survey of academic centers. AJR American journal of roentgenology. Nov. 2007;189(5):1128-34. [pmid: 17954650].
213 Jamieson DH, Chait PG, Filler R. Interventional drainage of appendiceal abscesses in children. AJR American journal of roentgenology. Dec. 1997;169(6):1619-22. [pmid: 9393176].
214 Janzon L, Ryden CI, Zederfeldt B. Acute abdomen in the surgical emergency room. Who is taken care of when for what? Acta chirurgica Scandinavica. 1982;148(2):141-8. [pmid: 6983198].
215 Jedrzejewski G. Evaluation of mesenteric lymph nodes in children with abdominal pain. Polish Journal of Radiology. 2008;73(4):25-7. PMID:.
216 Jeffrey RB Jr, Tolentino CS, Federle MP, et al. Percutaneous drainage of periappendiceal abscesses: review of 20 patients. AJR American journal of roentgenology. Jul. 1987;149(1):59-62. [pmid: 3495993].
217 Jess P. Acute appendicitis: epidemiology, diagnostic accuracy, and complications. Scandinavian journal of gastroenterology. Mar. 1983;18(2):161-3. [pmid: 6369508].
218 Jess T, Jess P. Acute terminal ileitis, yersiniosis, and Crohn’s disease: a long-term follow-up study of the relationships. European journal of internal medicine. Apr. 2001;12(2):98-100. [pmid: 11297911].
219 Jiang X, Meng HB, Zhou DL, Ding WX, Lu LS. Comparison of clinical outcomes of open, laparoscopic and single port appendicectomies. [pmid: 24112490].
220 Jiborn H, Jonson G. Ornithine carbamoyl transferase activity in serum of patients with acute abdominal pains. Annals of clinical research. Oct. 1971;3(5):272-6. [pmid: 5156628].
221 Johnson AB, Peetz ME. Laparoscopic appendectomy is an acceptable alternative for the treatment of perforated appendicitis. Surgical endoscopy. Jul. 1998;12(7):940-3. [pmid: 9632866].
222 Johnson AM, Dahn CM, Cadiz LA. Deficiencies in physician knowledge of the risks of imaging in pregnancy.
223 Jones AE, Phillips AW, Jarvis JR, et al. The value of routine histopathological examination of appendicectomy specimens. BMC surgery. 2007;7:17. [pmid: 17692116].
224 Jones MW, Paterson AG. The correlation between gross appearance of the appendix at appendicectomy and histological examination. Annals of the Royal College of Surgeons of England. Mar. 1988;70(2):93-4. [pmid: 3408167].
225 Julkunen H, Vainio K. APPENDICITIS IN RHEUMATIC SUBJECTS. Annales medicinae internae Fenniae. 1963;52:249-53. [pmid: 14080538].
226 Kaplan M, Salman B, Yilmaz TU, et al. A quality of life comparison of laparoscopic and open approaches in acute appendicitis: a randomised prospective study. Acta chirurgica Belgica. May–Jun. 2009;109(3):356-63. [pmid: 19943593].
227 Karakus SC, Kilincaslan H, Koku N, Ertaskin I. Is single port incisionless-intracorporeal conventional equipment-endoscopic surgery feasible in patients with retrocecal acute appendicitis?. [pmid: 23908965].
228 Karim SS, O’Regan PJ. Laparoscopic appendectomy: a review of 95 consecutive suspected cases of appendicitis. Canadian journal of surgery Journal canadien de chirurgie. Oct. 1995;38(5):449-53. [pmid: 7553471].
229 Katkhouda N, Friedlander MH, Grant SW, et al. Intraabdominal abscess rate after laparoscopic appendectomy. American journal of surgery. Dec. 2000;180(6):456-9. discussion 60–1. [pmid: 11182397].
230 Kaya B, Sana B, Eris C, et al. Immediate appendectomy for appendiceal mass. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Jan. 2012;18(1):71-4. [pmid: 22290054].
231 Kazemier G, Zeeuw GR, Lange JF, Hop WC, Bonjer HJ. Laparoscopic vs open appendectomy. A randomized clinical trial. Surgical endoscopy [serial on the Internet]. 1997;(4). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/421/CN-00138421/frame.html. Last accessed.
232 Keckler SJ, Tsao K, Sharp SW, et al. Resource utilization and outcomes from percutaneous drainage and interval appendectomy for perforated appendicitis with abscess. Journal of pediatric surgery. Jun. 2008;43(6):977-80. [pmid: 18558168].
233 Kellnar S, Till H, Boehm R. Laparoscopy combined with conventional operative techniques. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al]. Zeitschrift fur Kinderchirurgie. Oct. 1999;9(5):294-6. [pmid: 10584186].
234 Kendrick DB, Sharp J. APPENDICITIS SURVEY IN USAREUR 1959–1961. Medical bulletin of the U S Army, Europe United States Army, Europe Medical Division. Oct. 1963;20:289-92. [pmid: 14069877].
235 Keyzer C, Pargov S, Tack D, et al. Normal appendix in adults: reproducibility of detection with unenhanced and contrast-enhanced MDCT. AJR American journal of roentgenology. Aug. 2008;191(2):507-14. [pmid: 18647924].
236 Khan AW, Sheikh SH, Rahman MA. Results of emergency appendectomy for appendicular mass. Mymensingh medical journal : MMJ. Jul. 2007;16(2):209-13. [pmid: 17703161].
237 Khan SA, Gafur MA, Islam A, et al. Correlation between clinical presentation, peroperative finding and histopathological report in acute appendicitis. Mymensingh medical journal : MMJ. Oct. 2011;20(4):570-7. [pmid: 22081172].
238 Kharbanda AB, Fishman SJ, Bachur RG. Comparison of pediatric emergency physicians’ and surgeons’ evaluation and diagnosis of appendicitis. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Feb. 2008;15(2):119-25. [pmid: 18275440].
239 Khiria LS, Ardhnari R, Mohan N, et al. Laparoscopic appendicectomy for complicated appendicitis: is it safe and justified?: A retrospective analysis. Surgical laparoscopy, endoscopy & percutaneous techniques. Jun. 2011;21(3):142-5. [pmid: 21654295].
240 Kieran JA, Curet MJ, Schermer CR. Institutional variations in the management of patients with acute appendicitis. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. May–Jun. 2003;7(4):523-8. [pmid: 12763410].
241 Kim JK, Ryoo S, Oh HK, et al. Management of appendicitis presenting with abscess or mass. Journal of the Korean Society of Coloproctology. Dec. 2010;26(6):413-9. [pmid: 21221242].
242 Kirshtein B, Roy-Shapira A, Lantsberg L, et al. Laparoscopic management of acute small bowel obstruction. Surgical endoscopy. Apr. 2005;19(4):464-7. [pmid: 15959710].
243 Knott EM, Thomas P, Sharp NE, Gasior AC, St Peter SD. Reduced use of computed tomography in patients treated with interval appendectomy after implementing a protocol from a prospective, randomized trial. [pmid: 23892423].
244 Kocataş A, Gönenç M, Bozkurt MA, Karabulut M, Gemici E, Alış H. Comparison of open and laparoscopic appendectomy in uncomplicated appendicitis: A prospective randomized clinical trial. [pmid: 23720105].
245 Kokoska ER, Bird TM, Robbins JM, et al. Racial disparities in the management of pediatric appenciditis. The Journal of surgical research. Jan. 2007;137(1):83-8. [pmid: 17109888].
246 Kong VY, Bulajic B, Allorto NL, et al. Acute appendicitis in a developing country. World journal of surgery. Sep. 2012;36(9):2068-73. [pmid: 22562453].
247 Kong VY, Van der Linde S, Aldous C, Handley JJ, Clarke DL. Quantifying the disparity in outcome between urban and rural patients with acute appendicitis in South Africa. [pmid: 24079626].
248 Kori T, Nemoto M, Maeda M, et al. Sonographic features of acute colonic diverticulitis: the “dome sign”. Journal of clinical ultrasound : JCU. Sep. 2000;28(7):340-6. [pmid: 10934333].
249 Korlacki W, Dzielicki J. Laparoscopic appendectomy for simple and complicated appendicitis in children--safe or risky procedure. Surgical laparoscopy, endoscopy & percutaneous techniques. Feb. 2008;18(1):29-32. [pmid: 18287979].
250 Korner H, Sondenaa K, Soreide JA, et al. Incidence of acute nonperforated and perforated appendicitis: age-specific and sex-specific analysis. World journal of surgery. Mar–Apr. 1997;21(3):313-7. [pmid: 9015177].
251 Kossi J, Luostarinen M. Initial experience of the feasibility of single-incision laparoscopic appendectomy in different clinical conditions. Diagnostic and therapeutic endoscopy. 2010;2010:240260. [pmid: 20396672].
252 Koumarelas K, Theodoropoulos GE, Spyropoulos BG, Bramis K, Manouras A, Zografos G. A prospective longitudinal evaluation and affecting factors of health related quality of life after appendectomy. [pmid: 25019228].
253 Kouwenhoven EA, Repelaer van Driel OJ, van Erp WF. Fear for the intraabdominal abscess after laparoscopic appendectomy: not realistic. Surgical endoscopy. Jul. 2005;19(7):923-6. [pmid: 15920693].
254 Kozomara D, Galic G, Brekalo Z, et al. Abdominal pain patient referrals to emergency surgical service: appropriateness of diagnosis and attitudes of general practitioners. Collegium antropologicum. Dec. 2009;33(4):1239-43. [pmid: 20102075].
255 Krajewski SA, Hameed SM, Smink DS, et al. Access to emergency operative care: a comparative study between the Canadian and American health care systems. Surgery. Aug. 2009;146(2):300-7. [pmid: 19628089].
256 Krasna IH. Abdominal pain and appendicitis: is there a difference in referrals between HMO pediatricians and private pediatricians?. Journal of pediatric surgery. Jul. 2000;35(7):1084-6. [pmid: 10917301].
257 Kumar B, Samad A, Khanzada TW, et al. Superiority of laparoscopic appendectomy over open appendectomy: The Hyderabad experience. Rawal Medical Journal. 2008;33(2):165-8. PMID:.
258 Kurtz RJ, Heimann TM. Comparison of open and laparoscopic treatment of acute appendicitis. American journal of surgery. Sep. 2001;182(3):211-4. [pmid: 11587679].
259 Kwon OK, Kim JO, Kee S, et al. Laparoscopic appendectomy as a treatment for perforated appendicitis. Surgical Endoscopy and Other Interventional Techniques. 2011;25:S97. PMID:.
260 Lal AK, Weaver AL, Hopkins MR, et al. Laparoscopic appendectomy in women without identifiable pathology undergoing laparoscopy for chronic pelvic pain. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Jan–Mar. 2013;17(1):82-7. [pmid: 23743376].
261 Lau DH, Yau KK, Chung CC, et al. Comparison of needlescopic appendectomy versus conventional laparoscopic appendectomy: a randomized controlled trial. Surgical laparoscopy, endoscopy & percutaneous techniques. Apr. 2005;15(2):75-9. [pmid: 15821618].
262 Lavonius MI, Liesjarvi S, Ovaska J, et al. Laparoscopic versus open appendectomy in children: a prospective randomised study. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al]. Zeitschrift fur Kinderchirurgie. Aug. 2001;11(4):235-8. [pmid: 11558012].
263 Law D, Law R, Eiseman B. The continuing challenge of acute and perforated appendicitis. American journal of surgery. May. 1976;131(5):533-5. [pmid: 1275138].
264 Leape LL, Ramenofsky ML. Laparoscopy in children. Pediatrics. Aug. 1980;66(2):215-20. [pmid: 6447270].
265 Lee CH, Lin YL. Laparoscopic appendectomy versus open appendectomy in children: another opinion. International surgery. Apr–Jun. 2003;88(2):92-4. [pmid: 12872902].
266 Lee CM, Teoh MK. Perforated appendicitis--the Malaysian experience. Journal of the Royal College of Surgeons of Edinburgh. Apr. 1990;35(2):83-7. [pmid: 2355382].
267 Lee HY, Jayalakshmi P, Noori SH. Acute appendicitis--the University Hospital experience. The Medical journal of Malaysia. Mar. 1993;48(1):17-27. [pmid: 8341168].
268 Lee JA, Sung KY, Lee JH, et al. Laparoscopic appendectomy with a single incision in a single institute. Journal of the Korean Society of Coloproctology. Aug. 2010;26(4):260-4. [pmid: 21152227].
269 Lee KR, Scully RE. Mucinous tumors of the ovary: a clinicopathologic study of 196 borderline tumors (of intestinal type) and carcinomas, including an evaluation of 11 cases with ‘pseudomyxoma peritonei’. The American journal of surgical pathology. Nov. 2000;24(11):1447-64. [pmid: 11075847].
270 Lee SL, Shekherdimian S, Chiu VY. Effect of race and socioeconomic status in the treatment of appendicitis in patients with equal health care access. Archives of surgery (Chicago, Ill : 1960). Feb. 2011;146(2):156-61. [pmid: 21339425].
271 Lejus C, Delile L, Plattner V, et al. Randomized, single-blinded trial of laparoscopic versus open appendectomy in children: effects on postoperative analgesia. Anesthesiology. Apr. 1996;84(4):801-6. [pmid: 8638833].
272 Lerch MM, Riehl J, Buechsel R, et al. Bedside ultrasound in decision making for emergency surgery: its role in medical intensive care patients. The American journal of emergency medicine. Jan. 1992;10(1):35-8. [pmid: 1736911].
273 Levas MN, Dayan PS, Mittal MK, Stevenson MD, Bachur RG, Dudley NC, Bajaj L, Macias CG, Bennett J, Dowd MD, Thomas AJ, Kharbanda AB. Pediatric Emergency Medicine Collaborative Research Committee of the American Academy of Pediatrics. Effect of Hispanic ethnicity and language barriers on appendiceal perforation rates and imaging in children. [pmid: 24565425].
274 Levine JM, Weiner M, Kelly KM. Routine use of PET scans after completion of therapy in pediatric Hodgkin disease results in a high false positive rate. Journal of pediatric hematology/oncology. Nov. 2006;28(11):711-4. [pmid: 17114956].
275 Lim GH, Shabbir A, So JB. Diagnostic laparoscopy in the evaluation of right lower abdominal pain: a one-year audit. Singapore medical journal. Jun. 2008;49(6):451-3. [pmid: 18581015].
276 Lindgren I, Aho AJ. Microangiographic investigations on acute appendicitis. Acta chirurgica Scandinavica. 1969;135(1):77-82. [pmid: 4896613].
277 Liu B, Feng J, Ma S, et al. Endoscopic retrograde appendicitis treatment (ERAT): A multicenter retrospective study in china. Gastrointestinal endoscopy. 2013;77(5):AB146. PMID:.
278 Liu SI, Siewert B, Raptopoulos V, et al. Factors associated with conversion to laparotomy in patients undergoing laparoscopic appendectomy. Journal of the American College of Surgeons. Mar. 2002;194(3):298-305. [pmid: 11893133].
279 Liu ZF, Yu JC, Hsieh HF, et al. Perforated appendicitis: urgency or interval surgery?. Zentralblatt fur Chirurgie. Dec. 2007;132(6):539-41. [pmid: 18098082].
280 Livingston EH, Fomby TB, Woodward WA, et al. Epidemiological similarities between appendicitis and diverticulitis suggesting a common underlying pathogenesis. Archives of surgery (Chicago, Ill : 1960). Mar. 2011;146(3):308-14. [pmid: 21422362].
281 Livingston EH, Woodward WA, Sarosi GA, et al. Disconnect between incidence of nonperforated and perforated appendicitis: implications for pathophysiology and management. Annals of surgery. Jun. 2007;245(6):886-92. [pmid: 17522514].
282 Livingstone AS, Sosa JL. Surgical laparoscopy: impact on the management of abdominal disorders. Digestive diseases (Basel, Switzerland). Jan–Feb. 1995;13(1):56-67. [pmid: 7606837].
283 Lloyd TD, Malin G, Pugsley H, et al. Women presenting with lower abdominal pain: a missed opportunity for chlamydia screening?. The surgeon : journal of the Royal Colleges of Surgeons of Edinburgh and Ireland. Feb. 2006;4(1):15-9. [pmid: 16459495].
284 Lo MC. Prevalence of Diagnosed Mental Disorders Among Florida Adult Appendectomy Patients: Implications for Medical Cost Offset with Mental Health Treatment. Internet Journal of Mental Health. 2012;8(1):1. Language: English. Entry Date: 20130816. Revision Date: 20130816. Publication Type: journal article.
285 Loening-Baucke V, Swidsinski A. Constipation as cause of acute abdominal pain in children. The Journal of pediatrics. Dec. 2007;151(6):666-9. [pmid: 18035149].
286 Lose G, Holm B, Bauer T, et al. The predictive value of the third day temperature in the decision whether to continue or terminate antibiotic treatment in perforated appendicitis. Annales chirurgiae et gynaecologiae. 1987;76(4):201-3. [pmid: 3434990].
287 Lu CL, Liu CC, Fuh JL, et al. Irritable bowel syndrome and negative appendectomy: a prospective multivariable investigation. Gut. May. 2007;56(5):655-60. [pmid: 17440183].
288 Ludvigsson JF, Askling J, Ekbom A, et al. Diagnosis underlying appendectomy and coeliac disease risk. Digestive and liver disease : official journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. Nov. 2006;38(11):823-8. [pmid: 16914396].
289 Mahanta H, Das MK, Choudhury SB. An experience with diagnostic paracentesis in 100 cases of acute abdomen. Journal of the Indian Medical Association. May. 1990;88(5):125-9. [pmid: 2280070].
290 Mahato IP, Karn NK, Lewis OD, et al. Effect of the Alvarado score on the diagnostic accuracy of right iliac fossa pain in an emergency. Tropical doctor. Jan. 2011;41(1):11-4. [pmid: 20880948].
291 Maitra AK, Briggs PJ, McGeehan D. Computer-unaided diagnosis of acute abdominal pain in an accident and emergency department. Archives of emergency medicine. Jun. 1988;5(2):74-8. [pmid: 3044379].
292 Malagon AM, Arteaga-Gonzalez I, Rodriguez-Ballester L. Outcomes after laparoscopic treatment of complicated versus uncomplicated acute appendicitis: a prospective, comparative trial. Journal of laparoendoscopic & advanced surgical techniques Part A. Dec. 2009;19(6):721-5. [pmid: 19895233].
293 Malatani TS, Latif AA, Al-Saigh A, et al. Surgical audit: A prospective study of the morbidity and mortality of acute appendicitis. Annals of Saudi medicine. Mar. 1991;11(2):209-12. [pmid: 17588084].
294 Malik AH, Wani RA, Saima BD, et al. Small lateral access--an alternative approach to appendicitis in paediatric patients: a randomised controlled trial. International journal of surgery (London, England). Aug. 2007;5(4):234-8. [pmid: 17660129].
295 Mallick R, Sun S, Schell SR. Predictors of efficacy and health resource utilization in treatment of complicated intra-abdominal infections: evidence for pooled clinical studies comparing tigecycline with imipenem-cilastatin. Surgical infections. Apr. 2007;8(2):159-72. [pmid: 17437361].
296 Mancini GJ, Mancini ML, Nelson HS Jr. Efficacy of laparoscopic appendectomy in appendicitis with peritonitis. The American surgeon. Jan. 2005;71(1):1-4. discussion -5. [pmid: 15757049].
297 Marco CA, Schoenfeld CN, Keyl PM, et al. Abdominal pain in geriatric emergency patients: variables associated with adverse outcomes. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Dec. 1998;5(12):1163-8. [pmid: 9864129].
298 Margenthaler JA, Longo WE, Virgo KS, et al. Risk factors for adverse outcomes after the surgical treatment of appendicitis in adults. Annals of surgery. Jul. 2003;238(1):59-66. [pmid: 12832966].
299 Martin LC, Puente I, Sosa JL, et al. Open versus laparoscopic appendectomy. A prospective randomized comparison. Annals of surgery. Sep. 1995;222(3):256-61. discussion 61–2. [pmid: 7677456].
300 Marudanayagam R, Williams GT, Rees BI. Review of the pathological results of 2660 appendicectomy specimens. Journal of gastroenterology. Aug. 2006;41(8):745-9. [pmid: 16988762].
301 Mason A, Or Z, Renaud T, Street A, Thuilliez J, Ward P. EuroDRG group. How well do diagnosis-related groups for appendectomy explain variations in resource use? An analysis of patient-level data from 10 European countries. [pmid: 22815110].
302 Mason LB, Deyden WE. Primary appendectomy. The American surgeon. Apr. 1976;42(4):239-43. [pmid: 1083704].
303 Masoomi H, Nguyen NT, Dolich MO, et al. Comparison of laparoscopic versus open appendectomy for acute nonperforated and perforated appendicitis in the obese population. American journal of surgery. Dec. 2011;202(6):733-8. discussion 8–9. [pmid: 21992808].
304 Maxwell JM, Ragland JJ. Appendicitis. Improvements in diagnosis and treatment. The American surgeon. May. 1991;57(5):282-5. [pmid: 2039123].
305 McAnena OJ, Austin O, O’Connell PR, et al. Laparoscopic versus open appendicectomy: a prospective evaluation. The British journal of surgery. Aug. 1992;79(8):818-20. [pmid: 1393483].
306 McCahill LE, Pellegrini CA, Wiggins T, et al. A clinical outcome and cost analysis of laparoscopic versus open appendectomy. American journal of surgery. May. 1996;171(5):533-7. [pmid: 8651403].
307 McConkey SJ. Case series of acute abdominal surgery in rural Sierra Leone. World journal of surgery. Apr. 2002;26(4):509-13. [pmid: 11910489].
308 McFee AS, Sutton PG, Ramos R. Diverticulitis of the right colon. Diseases of the colon and rectum. Apr. 1982;25(3):254-6. [pmid: 7067566].
309 McGory ML, Zingmond DS, Tillou A, et al. Negative appendectomy in pregnant women is associated with a substantial risk of fetal loss. Journal of the American College of Surgeons. Oct. 2007;205(4):534-40. [pmid: 17903726].
310 McGrath B, Buckius MT, Grim R, et al. Economics of appendicitis: cost trend analysis of laparoscopic versus open appendectomy from 1998 to 2008. The Journal of surgical research. Dec. 2011;171(2):e161-8. [pmid: 21962815].
311 McNeeley MF, Prabhu S, Vergnani J, et al. Percutaneous drainage of intraabdominal abscess in children with perforated appendicitis: Safety, efficacy, and prediction of outcome. Pediatric radiology. 2011;41:S362. PMID:.
312 Meguerditchian AN, Prasil P, Cloutier R, et al. Laparoscopic appendectomy in children: A favorable alternative in simple and complicated appendicitis. Journal of pediatric surgery. May. 2002;37(5):695-8. [pmid: 11987080].
313 Meier DE, Guzzetta PC, Barber RG, et al. Perforated appendicitis in children: is there a best treatment?. Journal of pediatric surgery. Oct. 2003;38(10):1520-4. [pmid: 14577079].
314 Memon MA, Fitztgibbons RJ Jr. The role of minimal access surgery in the acute abdomen. The Surgical clinics of North America. Dec. 1997;77(6):1333-53. [pmid: 9431343].
315 Millendez MB, Crane NJ, Elster EA, et al. Evaluation of intestinal viability using 3-charge coupled device image enhancement technology in a pediatric laparoscopic appendectomy model. Journal of pediatric surgery. Jan. 2012;47(1):142-7. [pmid: 22244407].
316 Miller JP. Laparoscopic appendectomy. Pediatric annals. Nov. 1993;22(11):663-7. [pmid: 8290322].
317 Miloudi N, Brahem M, Ben Abid S, et al. Acute appendicitis in pregnancy: specific features of diagnosis and treatment. Journal of visceral surgery. Aug. 2012;149(4):e275-9. [pmid: 22748895].
318 Mizrahi M, Mintz Y, Rivkind A, et al. A prospective study assessing the efficacy of abdominal computed tomography scan without bowel preparation in diagnosing intestinal wall and luminal lesions in patients presenting to the emergency room with abdominal complaints. World journal of gastroenterology : WJG. Apr. 7. 2005;11(13):1981-6. [pmid: 15800990].
319 Moore CB, Smith RS, Herbertson R, et al. Does use of intraoperative irrigation with open or laparoscopic appendectomy reduce post-operative intra-abdominal abscess?. The American surgeon. Jan. 2011;77(1):78-80. [pmid: 21396311].
320 Moore DE, Speroff T, Grogan E, Poulose B, Holzman MD. Cost perspectives of laparoscopic and open appendectomy (Structured abstract). Surgical endoscopy [serial on the Internet]. 2005;(3). Available from: http://onlinelibrary.wiley.com/o/cochrane/cleed/articles/NHSEED-22005001144/frame.html. Last accessed.
321 Moreira J, Bisoffi Z, Narvaez A, et al. Bayesian clinical reasoning: does intuitive estimation of likelihood ratios on an ordinal scale outperform estimation of sensitivities and specificities?. Journal of evaluation in clinical practice. Oct. 2008;14(5):934-40. [pmid: 19018928].
322 Morfesis FA, Ahmad F. Use of laparoscopy in the treatment of acute and chronic right lower quadrant pain. The Journal of the Kentucky Medical Association. Jan. 1996;94(1):16-21. [pmid: 8648269].
323 Muorah M, Hinds R, Verma A, et al. Liver abscesses in children: a single center experience in the developed world. Journal of pediatric gastroenterology and nutrition. Feb. 2006;42(2):201-6. [pmid: 16456416].
324 Mutter D, Vix M, Bui A, et al. Laparoscopy not recommended for routine appendectomy in men: results of a prospective randomized study. Surgery. Jul. 1996;120(1):71-4. [pmid: 8693426].
325 Naffis D. Laparoscopic appendectomy in children. Seminars in pediatric surgery. Aug. 1993;2(3):174-7. [pmid: 8062037].
326 Nagy AG, James D. Diagnostic laparoscopy. American journal of surgery. May. 1989;157(5):490-3. [pmid: 2523669].
327 Navez B, Delgadillo X, Cambier E, et al. Laparoscopic approach for acute appendicular peritonitis: efficacy and safety: a report of 96 consecutive cases. Surgical laparoscopy, endoscopy & percutaneous techniques. Oct. 2001;11(5):313-6. [pmid: 11668228].
328 Navez B, d’Udekem Y, Cambier E, et al. Laparoscopy for management of nontraumatic acute abdomen. World journal of surgery. May–Jun. 1995;19(3):382-6. discussion 7. [pmid: 7638993].
329 Neal GE, McClintic EC, Williams JS. Experience with laparoscopic and open appendectomies in a surgical residency program. Surgical laparoscopy & endoscopy. Aug. 1994;4(4):272-6. [pmid: 7952437].
330 Neighbor ML, Baird CH, Kohn MA. Changing opioid use for right lower quadrant abdominal pain in the emergency department. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Dec. 2005;12(12):1216-20. [pmid: 16293897].
331 Nemeth L, Rolle U, Reen DJ, et al. Nitrergic hyperinnervation in appendicitis and in appendices histologically classified as normal. Archives of pathology & laboratory medicine. May. 2003;127(5):573-8. [pmid: 12708900].
332 Neumayer L, Wako E, Fergestaad J, et al. Impact of journal articles and grand rounds on practice: CT scanning in appendicitis. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. May–Jun. 2002;6(3):338-41. [pmid: 12022984].
333 Ng CS, Palmer CR. Assessing diagnostic confidence: a comparative review of analytical methods. Academic radiology. May. 2008;15(5):584-92. [pmid: 18423315].
334 Nguyen DB, Silen W, Hodin RA. Appendectomy in the pre- and postlaparoscopic eras. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Jan–Feb. 1999;3(1):67-73. [pmid: 10457327].
335 Nguyen NT, Nguyen B, Shih A, Smith B, Hohmann S. Use of laparoscopy in general surgical operations at academic centers. [pmid: 22892343].
336 Nguyen NT, Zainabadi K, Mavandadi S, Paya M, Stevens CM, Root J, Wilson SE. Trends in utilization and outcomes of laparoscopic versus open appendectomy (Structured abstract). American journal of surgery [serial on the Internet]. 2004;(6). Available from: http://onlinelibrary.wiley.com/o/cochrane/cleed/articles/NHSEED-22005006084/frame.html. Last accessed.
337 Nomura O, Ishiguro A, Maekawa T, et al. Antibiotic administration can be an independent risk factor for therapeutic delay of pediatric acute appendicitis. Pediatric emergency care. Aug. 2012;28(8):792-5. [pmid: 22858754].
338 Nordentoft T, Bringstrup FA, Bremmelgaard A, et al. Effect of laparoscopy on bacteremia in acute appendicitis: a randomized controlled study. Surgical laparoscopy, endoscopy & percutaneous techniques. Oct. 2000;10(5):302-4. [pmid: 11083213].
339 Nosek AE, Hartin CW Jr, Bass KD, et al. Are facilities following best practices of pediatric abdominal CT scans?. The Journal of surgical research. May. 1. 2013;181(1):11-5. [pmid: 22682711].
340 Nowzaradan Y, Barnes JP Jr, Westmoreland J, et al. Laparoscopic appendectomy: treatment of choice for suspected appendicitis. Surgical laparoscopy & endoscopy. Oct. 1993;3(5):411-6. [pmid: 8261273].
341 Obinwa O, Motterlini N, Cassidy M, et al. Risk factors associated with advanced appendicitis and complications after childhood appendectomy. Irish journal of medical science. 2012;181:S43. PMID:.
342 Ogbonna BC, Obekpa PO, Momoh JT, et al. Laparoscopy in developing countries in the management of patients with an acute abdomen. The British journal of surgery. Sep. 1992;79(9):964-6. [pmid: 1422771].
343 Oguntola AS, Adeoti ML, Agodirin SO, Oremakinde AA, Ojemakinde KO. Further exploration during open appendicectomy; assessment of some common intraoperative findings. [pmid: 24772134].
344 Oguzturk H, Ozgur D, Turtay MG, et al. Tramadol or paracetamol do not effect the diagnostic accuracy of acute abdominal pain with significant pain relief - a prospective, randomized, placebo controlled double blind study. European review for medical and pharmacological sciences. Dec. 2012;16(14):1983-8. [pmid: 23242726].
345 Ohmann C, Eich HP, Sippel H. A data dictionary approach to multilingual documentation and decision support for the diagnosis of acute abdominal pain. (COPERNICUS 555, an European concerted action). Studies in health technology and informatics. 1998;52(Pt 1):462-6. [pmid: 10384499].
346 Oka T, Kurkchubasche AG, Bussey JG, et al. Open and laparoscopic appendectomy are equally safe and acceptable in children. Surgical endoscopy. Feb. 2004;18(2):242-5. [pmid: 14691709].
347 Okamoto T, Sano K, Ogasahara K. Receiver-operating characteristic analysis of leukocyte counts and serum C-reactive protein levels in children with advanced appendicitis. Surgery today. 2006;36(6):515-8. [pmid: 16715420].
348 Okur MH, Arslan MS, Arslan S, Aydogdu B, Türkçü G, Goya C, Uygun I, Cigdem MK. Önen A, Otcu S. Gastrointestinal tract duplications in children. [pmid: 24899610].
349 Oldham J. Preliminary investigations into surgeons diagnosing abdominal pain. Journal of the Royal College of Surgeons of Edinburgh. Mar. 1973;18(2):79-82. [pmid: 4571791].
350 Oldmeadow C, Mengersen K, Martin N, et al. Heritability and linkage analysis of appendicitis utilizing age at onset. Twin research and human genetics : the official journal of the International Society for Twin Studies. Apr. 2009;12(2):150-7. [pmid: 19335185].
351 Oliak D, Yamini D, Udani VM, et al. Can perforated appendicitis Be diagnosed preoperatively based on admission factors?. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. Sep–Oct. 2000;4(5):470-4. [pmid: 11077321].
352 Omundsen M, Dennett E. Delay to appendicectomy and associated morbidity: a retrospective review. ANZ journal of surgery. Mar. 2006;76(3):153-5. [pmid: 16626357].
353 Omundsen MS, Dennett E, Walker HC. Patient recall after diagnostic laparoscopy for abdominal pain. ANZ journal of surgery. Jan–Feb. 2008;78(1–2):49-51. [pmid: 18199205].
354 Onur OE, Guneysel O, Unluer EE, et al. Outpatient follow-up” or “Active clinical observation” in patients with nonspecific abdominal pain in the Emergency Department. A randomized clinical trial. Minerva chirurgica. Feb. 2008;63(1):9-15. [pmid: 18212722].
355 Oruc M, Muminagic S, Denjalic A, et al. Retrocaecal appendix position--findings during the clasic appendectomy. Medical archives (Sarajevo, Bosnia and Herzegovina). 2012;66(3):190-3. [pmid: 22822621].
356 Osborne AJ, Hawkins SC, Pournaras DJ, Chandratilake M, Welbourn R. An evaluation of operative self-assessment by UK postgraduate trainees. [pmid: 24152186].
357 Oto A, Ernst RD, Mileski WJ, et al. Localization of appendix with MDCT and influence of findings on choice of appendectomy incision. AJR American journal of roentgenology. Oct. 2006;187(4):987-90. [pmid: 16985147].
358 Owens BJ, Hamit HF. Appendicitis in the elderly. Annals of surgery. Apr. 1978;187(4):392-6. [pmid: 646478].
359 Oyetunji TA, Ong’uti SK, Bolorunduro OB, et al. Pediatric negative appendectomy rate: trend, predictors, and differentials. The Journal of surgical research. Mar. 2012;173(1):16-20. [pmid: 21696768].
360 Ozao-Choy J, Kim U, Vieux U, et al. Incidental findings on computed tomography scans for acute appendicitis: prevalence, costs, and outcome. The American surgeon. Nov. 2011;77(11):1502-9. [pmid: 22196665].
361 Ozmen MM, Zulfikaroglu B, Tanik A, et al. Laparoscopic versus open appendectomy: prospective randomized trial. Surgical laparoscopy, endoscopy & percutaneous techniques. Jun. 1999;9(3):187-9. [pmid: 10803997].
362 Pace S, Burke TF. Intravenous morphine for early pain relief in patients with acute abdominal pain. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Dec. 1996;3(12):1086-92. [pmid: 8959160].
363 Palanivelu C, Rangarajan M, John SJ, et al. Laparoscopic appendectomy for appendicitis in uncommon situations: the advantages of a tailored approach. Singapore medical journal. Aug. 2007;48(8):737-40. [pmid: 17657381].
364 Palesty JA, Wang XJ, Rutland RC, et al. Fifty-five consecutive laparoscopic appendectomy procedures without conversion. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Apr–Jun. 2004;8(2):141-5. [pmid: 15119658].
365 Papaziogas B, Tsiaousis P, Koutelidakis I, et al. Effect of time on risk of perforation in acute appendicitis. Acta chirurgica Belgica. Jan–Feb. 2009;109(1):75-80. [pmid: 19341201].
366 Pappalepore N, Tursini S, Marino N, et al. Transumbilical laparoscopic-assisted appendectomy (TULAA): a safe and useful alternative for uncomplicated appendicitis. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al]. Zeitschrift fur Kinderchirurgie. Dec. 2002;12(6):383-6. [pmid: 12548490].
367 Park HC, Kim BS, Lee BH. Laparoscopic treatment of presumed perforated appendicitis in consecutive patients. Surgical laparoscopy, endoscopy & percutaneous techniques. Aug. 2011;21(4):278-81. [pmid: 21857480].
368 Park HC, Yang DH, Lee BH. The laparoscopic approach for perforated appendicitis, including cases complicated by abscess formation. Journal of laparoendoscopic & advanced surgical techniques Part A. Dec. 2009;19(6):727-30. [pmid: 19792868].
369 Park J, Kwak H, Kim SG, et al. Single-port laparoscopic appendectomy: comparison with conventional laparoscopic appendectomy. Journal of laparoendoscopic & advanced surgical techniques Part A. Mar. 2012;22(2):142-5. [pmid: 22145571].
370 Partecke LI, Kessler W, von Bernstorff W, et al. Laparoscopic appendectomy using a single polymeric clip to close the appendicular stump. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Nov. 2010;395(8):1077-82. [pmid: 20577759].
371 Partecke LI, von Bernstorff W, Karrasch A, et al. Unexpected findings on laparoscopy for suspected acute appendicitis: a pro for laparoscopic appendectomy as the standard procedure for acute appendicitis. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. Nov. 2010;395(8):1069-76. [pmid: 19924435].
372 Patel SC, Jumba GF, Akmal S. Laparoscopic appendicectomy at the Aga Khan Hospital, Nairobi. East African medical journal. Sep. 2003;80(9):447-51. [pmid: 14640164].
373 Paterson-Brown S, Eckersley JR, Sim AJ, et al. Laparoscopy as an adjunct to decision making in the ‘acute abdomen’. The British journal of surgery. Dec. 1986;73(12):1022-4. [pmid: 2947659].
374 Paterson-Brown S, Olufunwa SA, Galazka N, et al. Visualisation of the normal appendix at laparoscopy. Journal of the Royal College of Surgeons of Edinburgh. Apr. 1986;31(2):106-7. [pmid: 2943893].
375 Patil VV, Delman BN, Wilck EJ, Simpson WL. Implementation and evaluation of a performance improvement intervention to address physician documentation deficiencies in abdominal ultrasound. [pmid: 24850025].
376 Peiser JG, Greenberg D. Laparoscopic versus open appendectomy: results of a retrospective comparison in an Israeli hospital. The Israel Medical Association journal : IMAJ. Feb. 2002;4(2):91-4. [pmid: 11875999].
377 Peled Y, Hiersch L, Khalpari O, Wiznitzer A, Yogev Y, Pardo J. Appendectomy during pregnancy-is pregnancy outcome depending by operation technique?. [pmid: 23795902].
378 Perry ZH, Netz U, Mizrahi S, et al. Laparoscopic appendectomy as an initial step in independent laparoscopic surgery by surgical residents. Journal of laparoendoscopic & advanced surgical techniques Part A. Jun. 2010;20(5):447-50. [pmid: 20518691].
379 Pesonen E, Eskelinen M, Juhola M. Treatment of missing data values in a neural network based decision support system for acute abdominal pain. Artificial intelligence in medicine. Jul. 1998;13(3):139-46. [pmid: 9698150].
380 Pesonen E, Ohmann C, Eskelinen M, et al. Diagnosis of acute appendicitis in two databases. Evaluation of different neighborhoods with an LVQ neural network. Methods of information in medicine. Jan. 1998;37(1):59-63. [pmid: 9550848].
381 Petrov MS, Gordetzov AS, Emelyanov NV. Usefulness of infrared spectroscopy in diagnosis of acute pancreatitis. ANZ journal of surgery. May. 2007;77(5):347-51. [pmid: 17497973].
382 Phillips AW, Jones AE, Sargen K. Should the macroscopically normal appendix be removed during laparoscopy for acute right iliac fossa pain when no other explanatory pathology is found?. Surgical laparoscopy, endoscopy & percutaneous techniques. Oct. 2009;19(5):392-4. [pmid: 19851267].
383 Pickhardt PJ, Levy AD, Rohrmann CA Jr, et al. Non-Hodgkin’s lymphoma of the appendix: clinical and CT findings with pathologic correlation. AJR American journal of roentgenology. May. 2002;178(5):1123-7. [pmid: 11959713].
384 Pieper R, Kager L, Lindberg AA, et al. Acute appendicitis and Bacteroides fragilis. Scandinavian journal of infectious diseases Supplementum. 1979;(19):92-7. [pmid: 379991].
385 Pines JM. Trends in the rates of radiography use and important diagnoses in emergency department patients with abdominal pain. Medical care. Jul. 2009;47(7):782-6. [pmid: 19536032].
386 Pittman-Waller VA, Myers JG, Stewart RM, et al. Appendicitis: why so complicated? Analysis of 5755 consecutive appendectomies. The American surgeon. Jun. 2000;66(6):548-54. [pmid: 10888130].
387 Planka L, Stary D, Tuma J, et al. Laparoscopic versus laparotomic appendectomy for generalised peritonitis in children. Scripta Medica Facultatis Medicae Universitatis Brunensis Masarykianae. 2009;82(2):83-9. PMID:.
388 Pledger HG, Buchan R. Deaths in children with acute appendicitis. British medical journal. Nov. 22. 1969;4(5681):466-70. [pmid: 5354836].
389 Podugu A, Lee PJ, Bhatt A, Holmes J, Lopez R, Stevens T. Positive predictive value of ICD-9 discharge diagnosis of acute pancreatitis. [pmid: 25010706].
390 Ponsky TA, Hafi M, Heiss K, et al. Interobserver variation in the assessment of appendiceal perforation. Journal of laparoendoscopic & advanced surgical techniques Part A. Apr. Suppl 1. 2009;19:S15-8. [pmid: 19371148].
391 Poortman P, Oostvogel HJM, De Lange-De Klerk ESM, et al. Imaging studies in suspected acute appendicitis: Views of surgeons in The Netherlands. Nederlands tijdschrift voor geneeskunde. 2009;153(28):1371-5. PMID:.
392 Pritchett CV, Levinsky NC, Ha YP, et al. Management of acute appendicitis: the impact of CT scanning on the bottom line. Journal of the American College of Surgeons. May. 2010;210(5):699-705. 7. [pmid: 20421033].
393 Puskar D, Bedalov G, Fridrih S, et al. Urinalysis, ultrasound analysis, and renal dynamic scintigraphy in acute appendicitis. Urology. Jan. 1995;45(1):108-12. [pmid: 7817461].
394 Puylaert JB, Van der Zant FM, Mutsaers JA. Infectious ileocecitis caused by Yersinia, Campylobacter, and Salmonella: clinical, radiological and US findings. European radiology. 1997;7(1):3-9. [pmid: 9000386].
395 Qasaimeh GR, Khader Y, Matalqah I, et al. Acute appendicitis in north of Jordan - A 10 year survey. Jordan Medical Journal. 2008;42(3):149-54. PMID:.
396 Qureshi A, Smith A, Wright F, et al. The impact of an acute care emergency surgical service on timely surgical decision-making and emergency department overcrowding. Journal of the American College of Surgeons. Aug. 2011;213(2):284-93. [pmid: 21601487].
397 Raahave D, Christensen E, Moeller H, et al. Origin of acute appendicitis: fecal retention in colonic reservoirs: a case control study. Surgical infections. Feb. 2007;8(1):55-62. [pmid: 17381397].
398 Rathaus V, Grunebaum M, Konen O, et al. Minimal pelvic fluid in asymptomatic children: the value of the sonographic finding. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. Jan. 2003;22(1):13-7. [pmid: 12523605].
399 Ravishankaran P, Shah AM, Bhat R. Correlation of interleukin-6, serum lactate, and C-reactive protein to inflammation, complication, and outcome during the surgical course of patients with acute abdomen. Journal of interferon & cytokine research : the official journal of the International Society for Interferon and Cytokine Research. Sep. 2011;31(9):685-90. [pmid: 21923250].
400 Reiertsen O, Larsen S, Trondsen E, et al. Randomized controlled trial with sequential design of laparoscopic versus conventional appendicectomy. The British journal of surgery. Jun. 1997;84(6):842-7. [pmid: 9189105].
401 Reiertsen O, Rosseland AR, Hoivik B, et al. Laparoscopy in patients admitted for acute abdominal pain. Acta chirurgica Scandinavica. 1985;151(6):521-4. [pmid: 2936052].
402 Reiss R, Deutsch AA, Eliashiv A. Decision-making process in abdominal surgery in the geriatric patient. World journal of surgery. Jul. 1983;7(4):522-6. [pmid: 6624127].
403 Remington-Hobbs J, Petts G, Harris T. Emergency department management of undifferentiated abdominal pain with hyoscine butylbromide and paracetamol: a randomised control trial. [pmid: 22307926].
404 Riber C, Tonnesen H, Aru A, et al. Observer variation in the assessment of the histopathologic diagnosis of acute appendicitis. Scandinavian journal of gastroenterology. Jan. 1999;34(1):46-9. [pmid: 10048732].
405 Ricci MA, Trevisani MF, Beck WC. Acute appendicitis. A 5-year review. The American surgeon. May. 1991;57(5):301-5. [pmid: 2039128].
406 Rice GE, Munro JM, Corless C, et al. Vascular and nonvascular expression of INCAM-110. A target for mononuclear leukocyte adhesion in normal and inflamed human tissues. The American journal of pathology. Feb. 1991;138(2):385-93. [pmid: 1704191].
407 Rice-Townsend S, Barnes JN, Hall M, Baxter JL, Rangel SJ. Variation in practice and resource utilization associated with the diagnosis and management of appendicitis at freestanding children’s hospitals: implications for value-based comparative analysis. [pmid: 24096770].
408 Rizzo AG. Laparoscopic surgery in pregnancy: long-term follow-up. Journal of laparoendoscopic & advanced surgical techniques Part A. Feb. 2003;13(1):11-5. [pmid: 12676015].
409 Roberts KE, Starker LF, Duffy AJ, et al. Stump appendicitis: a surgeon’s dilemma. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Jul–Sep. 2011;15(3):373-8. [pmid: 21985727].
410 Rollins MD, Chan KJ, Price RR. Laparoscopy for appendicitis and cholelithiasis during pregnancy: a new standard of care. Surgical endoscopy. Feb. 2004;18(2):237-41. [pmid: 14691706].
411 Saber AA, Elgamal MH, El-Ghazaly TH, et al. Simple technique for single incision transumbilical laparoscopic appendectomy. International journal of surgery (London, England). 2010;8(2):128-30. [pmid: 20005314].
412 Sabra J, Roh M, Paez X, et al. Use of sonography in diagnosing acute appendicitis: comparison of a teaching hospital and a community hospital. Academic radiology. May. 1996;3(5):438-41. [pmid: 8796698].
413 Sadot E, Telem DA, Arora M, et al. Laparoscopy: a safe approach to appendicitis during pregnancy. Surgical endoscopy. Feb. 2010;24(2):383-9. [pmid: 19551438].
414 Sadow KB, Atabaki SM, Johns CM, et al. Bilious emesis in the pediatric emergency department: etiology and outcome. Clinical pediatrics. Sep. 2002;41(7):475-9. [pmid: 12365309].
415 Salahuddin O, Malik MA, Sajid MA, et al. Acute appendicitis in the elderly; Pakistan Ordnance Factories Hospital, Wah Cantt. experience. JPMA The Journal of the Pakistan Medical Association. Sep. 2012;62(9):946-9. [pmid: 23139981].
416 Salky B. Diagnostic laparoscopy. Surgical laparoscopy & endoscopy. Apr. 1993;3(2):132-4. [pmid: 8269233].
417 Saravanan B, Muhammad R, Geach R, et al. Comparison of the history obtained by patient-completed questionnaires with doctors’ standard notes for patients with acute abdominal pain. Postgraduate medical journal. Dec. 2009;85(1010):634-6. [pmid: 20075399].
418 Saravanan K, Kumaran V, Rajamani G, et al. Minimally invasive pediatric surgery: Our experience. Journal of Indian Association of Pediatric Surgeons. Jul. 2008;13(3):101-3. [pmid: 20011483].
419 Savary D. Appendicitis in the pregnant woman: be less afraid for the pregnancy than for the consequences of inaction!. Journal of visceral surgery. Aug. 2012;149(4):e225-6. [pmid: 22771290].
420 Scammell S, Lansdale N, Sprigg A, et al. Ultrasonography aids decision-making in children with abdominal pain. Annals of the Royal College of Surgeons of England. Jul. 2011;93(5):405-9. [pmid: 21943467].
421 Scarborough JE, Bennett KM, Pappas TN. Racial disparities in outcomes after appendectomy for acute appendicitis. American journal of surgery. Jul. 2012;204(1):11-7. [pmid: 22154135].
422 Scarlett PY, Cooke WM, Clarke D, et al. Computer aided diagnosis of acute abdominal pain at Middlesbrough General Hospital. Annals of the Royal College of Surgeons of England. Jul. 1986;68(4):179-81. [pmid: 3538983].
423 Schafer M, Krahenbuhl L, Frei E, et al. Laparoscopic appendectomy in Switzerland: a prospective audit of 2, 179 cases. Digestive surgery. 2000;17(5):497-502. [pmid: 11124555].
424 Schier F, Waldschmidt J. Laparoscopy in children with ill-defined abdominal pain. Surgical endoscopy. Feb. 1994;8(2):97-9. [pmid: 8165492].
425 Schietroma M, Cappelli S, Carlei F, et al. “Acute abdomen”: early laparoscopy or active laparotomic-laparoscopic observation?. Hepato-gastroenterology. Jun. 2007;54(76):1137-41. [pmid: 17629056].
426 Schietroma M, Piccione F, Carlei F, Clementi M, Bianchi Z, de Vita F, Amicucci G. Peritonitis from perforated appendicitis: stress response after laparoscopic or open treatment. [pmid: 22546132].
427 Schofield PF, Hulton NR, Baildam AD. Is it acute cholecystitis?. Annals of the Royal College of Surgeons of England. Jan. 1986;68(1):14-6. [pmid: 3511830].
428 Schrenk P, Woisetschlager R, Wayand WU, et al. Diagnostic laparoscopy: a survey of 92 patients. American journal of surgery. Oct. 1994;168(4):348-51. [pmid: 7943593].
429 Schurman JV, Cushing CC, Garey CL, et al. Quality of life assessment between laparoscopic appendectomy at presentation and interval appendectomy for perforated appendicitis with abscess: analysis of a prospective randomized trial. Journal of pediatric surgery. Jun. 2011;46(6):1121-5. [pmid: 21683209].
430 Scott-Conner CE, Hall TJ, Anglin BL, et al. Laparoscopic appendectomy. Initial experience in a teaching program. Annals of surgery. Jun. 1992;215(6):660-7. discussion 7–8. [pmid: 1385942].
431 Senapathi PS, Bhattacharya D, Ammori BJ. Early laparoscopic appendectomy for appendicular mass. Surgical endoscopy. Dec. 2002;16(12):1783-5. [pmid: 12073001].
432 Senbanjo RO. Management of patients with equivocal signs of appendicitis. Journal of the Royal College of Surgeons of Edinburgh. Apr. 1997;42(2):85-8. [pmid: 9114675].
433 Serour F, Herman A, Witzling M, et al. Sonographic findings following appendectomy for uncomplicated appendicitis in children. Pediatric radiology. Sep. 2009;39(9):926-32. [pmid: 19455315].
434 Serralta A, Planells M, Bueno J, et al. A simple scoring system to reduce intraabdominal septic complications after laparoscopic appendectomy. Surgical endoscopy. Nov. 2000;14(11):1028-30. [pmid: 11116411].
435 Shah SA. Laparoscopic appendicectomy versus conventional open appendicectomy: A study at lahore general hospital. Esculapio J Services Inst Med Sci [serial on the Internet]. 2008;(4). Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/358/CN-00794358/frame.html. Last accessed.
436 Shalaby R, Arnos A, Desoky A, et al. Laparoscopic appendectomy in children: evaluation of different techniques. Surgical laparoscopy, endoscopy & percutaneous techniques. Feb. 2001;11(1):22-7. [pmid: 11269551].
437 Shamim M. Frequency, pattern and management of acute abdomen in dengue fever in Karachi, Pakistan. Asian journal of surgery/Asian Surgical Association. Jul. 2010;33(3):107-13. [pmid: 21163407].
438 Shapiro R, Eldar S, Sadot E, et al. The significance of occult carcinoids in the era of laparoscopic appendectomies. Surgical endoscopy. Sep. 2010;24(9):2197-9. [pmid: 20174936].
439 Shekherdimian S, DeUgarte D. Transumbilical laparoscopic-assisted appendectomy: An extracorporeal single-incision alternative to conventional laparoscopic techniques. American Surgeon. 2011;77(5):557-60. PMID:. [pmid: 21679587].
440 Shindholimath VV, Thinakaran K, Rao TN, et al. Laparoscopic management of appendicular mass. Journal of minimal access surgery. Apr. 2011;7(2):136-40. [pmid: 21523236].
441 Shum CF, Lim JF, Soo KC, et al. On-table diagnostic accuracy and the clinical significance of routine exploration in open appendectomies. Asian journal of surgery/Asian Surgical Association. Oct. 2005;28(4):257-61. [pmid: 16234075].
442 Siegal B, Hyman E, Lahat E, et al. Acute appendicitis in early childhood. Helvetica paediatrica acta. Jun. 1982;37(3):215-9. [pmid: 7118553].
443 Simonovsky V. Normal appendix: is there any significant difference in the maximal mural thickness at US between pediatric and adult populations?. Radiology. Aug. 2002;224(2):333-7. [pmid: 12147824].
444 Singh M, Kadian YS, Rattan KN, Jangra B. Complicated appendicitis: analysis of risk factors in children. [pmid: 24841008].
445 Singh MK, Kumar MK, Mohan L. Suprapubic approach for laparoscopic appendectomy. [pmid: 24082738].
446 Singhal V, Jadhav V. Acute appendicitis: are we over diagnosing it?. Annals of the Royal College of Surgeons of England. Nov. 2007;89(8):766-9. [pmid: 17999817].
447 Sivasankar E, Rajesh RS, Venkateshwaran SR. Appendicitis diagnosis system using fuzzy logic- And neural network-based classifier. International Journal of Medical Engineering and Informatics. 2011;3(4):337-50. PMID:.
448 Smink DS, Finkelstein JA, Kleinman K, et al. The effect of hospital volume of pediatric appendectomies on the misdiagnosis of appendicitis in children. Pediatrics. Jan. 2004;113(1 Pt 1):18-23. [pmid: 14702441].
449 Sodergren MH, Jethwa P, Wilkinson S, et al. Presenting features of Enterobius vermicularis in the vermiform appendix. Scandinavian journal of gastroenterology. 2009;44(4):457-61. [pmid: 19085426].
450 Sohn VY, Arthurs ZM, Martin MJ, et al. Incidental pathologic findings in open resectional gastric bypass specimens with routine cholecystectomy and appendectomy. Surgery for obesity and related diseases : official journal of the American Society for Bariatric Surgery. Sep–Oct. 2008;4(5):608-11. [pmid: 18586563].
451 Sorensen VJ, Bivins BA, Obeid FN, et al. Management of general surgical emergencies in pregnancy. The American surgeon. Apr. 1990;56(4):245-50. [pmid: 2194416].
452 Sosa JL, Sleeman D, McKenney MG, et al. A comparison of laparoscopic and traditional appendectomy. Journal of laparoendoscopic surgery. Apr. 1993;3(2):129-31. [pmid: 8518464].
453 Spear R, Kimmey MB, Wang KY, et al. Appendiceal US scans: histologic correlation. Radiology. Jun. 1992;183(3):831-4. [pmid: 1584942].
454 St Peter SD, Aguayo P, Fraser JD, et al. Initial laparoscopic appendectomy versus initial nonoperative management and interval appendectomy for perforated appendicitis with abscess: a prospective, randomized trial. Journal of pediatric surgery. Jan. 2010;45(1):236-40. [pmid: 20105610].
455 Stahlfeld K, Hower J, Homitsky S, et al. Is acute appendicitis a surgical emergency?. The American surgeon. Jun. 2007;73(6):626-9. discussion 9–30. [pmid: 17658102].
456 Stanfill AB, Matilsky DK, Kalvakuri K, et al. Transumbilical laparoscopically assisted appendectomy: an alternative minimally invasive technique in pediatric patients. Journal of laparoendoscopic & advanced surgical techniques Part A. Dec. 2010;20(10):873-6. [pmid: 20874231].
457 Stanley-Brown EG. ACUTE APPENDICITIS DURING FIRST FIVE YEARS OF LIFE. American journal of diseases of children (1960). Aug. 1964;108:134-8. [pmid: 14162888].
458 Steinman M, Rogeri PS, Lenci LL, Kirschner CC, Teixeira JC, Gonçalves PD, Akamine N, Possa S. Appendicitis: what does really make the difference between private and public hospitals?. [pmid: 23890214].
459 Stewart RJ, Holloway LJ, Isbister WH. Peritoneal neutrophilia: a potential indicator of the surgical acute abdomen. The Australian and New Zealand journal of surgery. Dec. 1984;54(6):565-8. [pmid: 6596077].
460 Stovroff MC, Totten M, Glick PL. PIC lines save money and hasten discharge in the care of children with ruptured appendicitis. Journal of pediatric surgery. Feb. 1994;29(2):245-7. [pmid: 8176600].
461 Strawbridge H, Kurland G, Watson R, et al. Radiation exposure from diagnostic imaging in the pediatric intensive care unit (PICU). American Journal of Respiratory and Critical Care Medicine. 2010;181(1). PMID:.
462 Stringel G, Zitsman JL, Shehadi I, et al. Laparoscopic appendectomy in children. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Jan–Mar. 1997;1(1):37-9. [pmid: 9876644].
463 Styrud J, Eriksson S, Nilsson I, et al. Appendectomy versus antibiotic treatment in acute appendicitis. a prospective multicenter randomized controlled trial. World journal of surgery. Jun. 2006;30(6):1033-7. [pmid: 16736333].
464 Sulu B, Gunerhan Y, Palanci Y, et al. Epidemiological and demographic features of appendicitis and influences of several environmental factors. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. Jan. 2010;16(1):38-42. [pmid: 20209394].
465 Surana R, Quinn F, Puri P. Is it necessary to perform appendicectomy in the middle of the night in children?. BMJ (Clinical research ed). May. 1. 1993;306(6886):1168. [pmid: 8369045].
466 Swedler DS, Nazir S, Larson SB, et al. Laparoscopic appendectomy for appendiceal abscess: Emergent versus interval appendectomy over a five-year period at an urban community hospital. Surgical Endoscopy and Other Interventional Techniques. 2013;27:S325. PMID:.
467 Taal BG, Smits M. Developments in diagnosis and treatment of metastatic midgut carcinoid tumors. A review. Minerva gastroenterologica e dietologica. Dec. 2005;51(4):335-44. [pmid: 16282961].
468 Tanaka S, Ishihara K, Uenishi T, Hashiba R, Kurashima Y, Ohno K, Tanaka S, Ohsawa M, Yamamoto T. Management of postoperative intraabdominal abscess in laparoscopic versus open appendectomy. [pmid: 23909076].
469 Tanaka S, Kubota D, Lee SH, et al. Effectiveness of laparoscopic approach for acute appendicitis. Osaka city medical journal. Jun. 2007;53(1):1-8. [pmid: 17867628].
470 Tanner AR, Dwarakanath AD, Tait NP. The potential impact of high-quality MRI of the biliary tree on ERCP workload. European journal of gastroenterology & hepatology. Jul. 2000;12(7):773-6. [pmid: 10929905].
471 Tate JJ, Dawson JW, Chung SC, et al. Laparoscopic versus open appendicectomy: prospective randomised trial. Lancet. Sep. 11. 1993;342(8872):633-7. [pmid: 8103144].
472 Taylor EW, Kennedy CA, Dunham RH, et al. Diagnostic laparoscopy in women with acute abdominal pain. Surgical laparoscopy & endoscopy. Apr. 1995;5(2):125-8. [pmid: 7773458].
473 Teixeira PG, Sivrikoz E, Inaba K, et al. Appendectomy timing: waiting until the next morning increases the risk of surgical site infections. Annals of surgery. Sep. 2012;256(3):538-43. [pmid: 22842128].
474 Telfer S, Fenyo G, Holt PR, et al. Acute abdominal pain in patients over 50 years of age. Scandinavian journal of gastroenterology Supplement. 1988;144:47-50. [pmid: 3165555].
475 Teoh AY, Chiu PW, Wong TC, et al. A case-controlled comparison of single-site access versus conventional three-port laparoscopic appendectomy. Surgical endoscopy. May. 2011;25(5):1415-9. [pmid: 20972583].
476 Teoh AY, Chiu PW, Wong TC, Poon MC, Wong SK, Leong HT, Lai PB, Ng EK. A double-blinded randomized controlled trial of laparoendoscopic single-site access versus conventional 3-port appendectomy. [pmid: 23154391].
477 Thambidorai CR, Aman Fuad Y. Laparoscopic appendicectomy for complicated appendicitis in children. Singapore medical journal. Dec. 2008;49(12):994-7. [pmid: 19122949].
478 Thomas JO. Acute appendicitis in Buraidah, Saudi Arabia. The Central African journal of medicine. Jul. 1998;44(7):176-8. [pmid: 10028192].
479 Thuluvath PJ, Connolly GM, Forbes A, et al. Abdominal pain in HIV infection. The Quarterly journal of medicine. Mar. 1991;78(287):275-85. [pmid: 1646462].
480 To T, Langer JC. Does access to care affect outcomes of appendicitis in children?--A population-based cohort study. BMC health services research. 2010;10:250. [pmid: 20735857].
481 Toorenvliet B, Vellekoop A, Bakker R, et al. Clinical differentiation between acute appendicitis and acute mesenteric lymphadenitis in children. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al]. Zeitschrift fur Kinderchirurgie. Mar. 2011;21(2):120-3. [pmid: 21157689].
482 Toumi Z, Kesterton A, Bhowmick A, et al. Nonagenarian surgical admissions for the acute abdomen: who benefits?. International journal of clinical practice. Oct. 2010;64(11):1570-2. [pmid: 20846205].
483 Towfigh S, Chen F, Katkhouda N, et al. Obesity should not influence the management of appendicitis. Surgical endoscopy. Dec. 2008;22(12):2601-5. [pmid: 18347857].
484 Tsai HL, Chen CY, Chen CW, et al. Computed Tomography-guided Percutaneous Drainage in the Management of Intraperitoneal Abscess. Fooyin Journal of Health Sciences. 2010;2(2):53-7.
485 Tsai HM, Shan YS, Lin PW, et al. Clinical analysis of the predictive factors for recurrent appendicitis after initial nonoperative treatment of perforated appendicitis. American journal of surgery. Sep. 2006;192(3):311-6. [pmid: 16920424].
486 Tsin DA. Pure Transvaginal Appendectomy Versus Traditional Laparoscopic Appendectomy for Acute Appendicitis. [pmid: 24374545].
487 Tucker O, Rashid Al-Faqih S, El-Amin O, et al. Laparoscopic appendicectomy: review of 331 cases over 7 years, in a Saudi Arabian hospital. Endoscopy. Aug. 2002;34(8):639-42. [pmid: 12173085].
488 Tugnoli G, Giorgini E, Biscardi A, et al. The NOTA study: non-operative treatment for acute appendicitis: prospective study on the efficacy and safety of antibiotic treatment (amoxicillin and clavulanic acid) in patients with right sided lower abdominal pain. BMJ open. Jan. 1. 2011;1(1):e000006. [pmid: 22021722].
489 Ure BM, Spangenberger W, Hebebrand D, et al. Laparoscopic surgery in children and adolescents with suspected appendicitis: results of medical technology assessment. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery [et al]. Zeitschrift fur Kinderchirurgie. Dec. 1992;2(6):336-40. [pmid: 1477059].
490 Ushenko YA. Concerted spatial-frequency and polarization-phase filtering of laser images of polycrystalline networks of blood plasma smears. Journal of biomedical optics. Nov. 2012;17(11):117005. [pmid: 23139045].
491 Valla JS, Limonne B, Valla V, et al. Laparoscopic appendectomy in children: report of 465 cases. Surgical laparoscopy & endoscopy. Sep. 1991;1(3):166-72. [pmid: 1669397].
492 Vallina VL, Velasco JM, McCulloch CS. Laparoscopic versus conventional appendectomy. Annals of surgery. Nov. 1993;218(5):685-92. [pmid: 8239785].
493 Van Hove C, Hardiman K, Diggs B, et al. Demographic and socioeconomic trends in the use of laparoscopic appendectomy from 1997 to 2003. American journal of surgery. May. 2008;195(5):580-3. discussion 3–4. [pmid: 18424278].
494 van Randen A, Lameris W, Nio CY, et al. Inter-observer agreement for abdominal CT in unselected patients with acute abdominal pain. European radiology. Jun. 2009;19(6):1394-407. [pmid: 19234705].
495 Vegunta RK, Ali A, Wallace LJ, et al. Laparoscopic appendectomy in children: technically feasible and safe in all stages of acute appendicitis. The American surgeon. Mar. 2004;70(3):198-201. discussion -2. [pmid: 15055841].
496 Velanovich V, Satava R. Balancing the normal appendectomy rate with the perforated appendicitis rate: implications for quality assurance. The American surgeon. Apr. 1992;58(4):264-9. [pmid: 1586087].
497 Ventham NT, Dungworth JC, Benzoni C. Transition Toward Laparoscopic Appendicectomy at an UK Center Over a 7-Year Period. [pmid: 24732741].
498 Verborg SA, Zejdl P, Williams IM. Laparoscopy as an adjuvant in appendectomy. Endoscopy. Jun. 1996;28(5):463. [pmid: 8858242].
499 Vettoretto N, Balestra L, Pettinato G, et al. Introduction of laparoscopic appendectomy: a retrospective comparison with the open technique. Chirurgia italiana. May–Jun. 2004;56(3):409-14. [pmid: 15287639].
500 Vipond MN, Paterson-Brown S, Tyrrell MR, et al. Evaluation of fine catheter aspiration cytology of the peritoneum as an adjunct to decision making in the acute abdomen. The British journal of surgery. Jan. 1990;77(1):86-7. [pmid: 2302522].
501 Wallander MA, Johansson S, Ruigomez A, et al. Unspecified abdominal pain in primary care: the role of gastrointestinal morbidity. International journal of clinical practice. Oct. 2007;61(10):1663-70. [pmid: 17681003].
502 Wan MJ, Krahn M, Ungar WJ, et al. Acute appendicitis in young children: cost-effectiveness of US versus CT in diagnosis--a Markov decision analytic model. Radiology. Feb. 2009;250(2):378-86. [pmid: 19098225].
503 Wang YC, Yang HR, Chung PK, et al. Laparoscopic appendectomy in the elderly. Surgical endoscopy. Jun. 2006;20(6):887-9. [pmid: 16738976].
504 Weakley SD Jr, Clegg CB. Diagnostic value of paracentesis in the acute surgical condition of the abdomen. American journal of surgery. May. 1957;93(5):802-6. [pmid: 13411380].
505 Wei PL, Huang MT, Chen TC, et al. Is mini-laparoscopic appendectomy feasible for children. Surgical laparoscopy, endoscopy & percutaneous techniques. Apr. 2004;14(2):61-5. [pmid: 15287602].
506 Willekens I, Peeters E, De Maeseneer M, de Mey J. The normal appendix on CT: does size matter?. [pmid: 24802879].
507 Willimann M, Thompson GC. Influence of triage time on patient care in children presenting with suspected appendicitis to Canadian pediatric emergency departments. Canadian Journal of Emergency Medicine. 2013;15:S16. PMID:.
508 Wittich AC, DeSantis RA, Lockrow EG. Appendectomy during pregnancy: a survey of two army medical activities. Military medicine. Oct. 1999;164(10):671-4. [pmid: 10544617].
509 Wong KK, Cheung TW, Tam PK. Diagnosing acute appendicitis: are we overusing radiologic investigations?. Journal of pediatric surgery. Dec. 2008;43(12):2239-41. [pmid: 19040943].
510 Wong SW, Haxhimolla H, Grieve DA, et al. Insurance and the risk of ruptured appendix in the adult. The Australian and New Zealand journal of surgery. Jan. 1999;69(1):31-3. [pmid: 9932917].
511 Wu JM, Chen KH, Lin HF, et al. Laparoscopic appendectomy in pregnancy. Journal of laparoendoscopic & advanced surgical techniques Part A. Oct. 2005;15(5):447-50. [pmid: 16185115].
512 Wu L, Zhang J, Guo Z, et al. Diagnosis and treatment of acute appendicitis after orthotopic liver transplant in adults. Experimental and clinical transplantation : official journal of the Middle East Society for Organ Transplantation. Apr. 2011;9(2):113-7. [pmid: 21453228].
513 Xiong J, Wang Y, Zhu Z, Liu J. Expression and significance of toll-like receptor 2,4 of peripheral blood mononuclear cells in acute abdomen patients associated with systemic inflammatory response syndrome. [pmid: 17219971].
514 Yao CC, Lin CS, Yang CC. Laparoscopic appendectomy for ruptured appendicitis. Surgical laparoscopy, endoscopy & percutaneous techniques. Aug. 1999;9(4):271-3. [pmid: 10871175].
515 Yardeni D, Hirschl RB, Drongowski RA, et al. Delayed versus immediate surgery in acute appendicitis: do we need to operate during the night?. Journal of pediatric surgery. Mar. 2004;39(3):464-9. discussion -9. [pmid: 15017571].
516 Yau KK, Siu WT, Tang CN, et al. Laparoscopic versus open appendectomy for complicated appendicitis. Journal of the American College of Surgeons. Jul. 2007;205(1):60-5. [pmid: 17617333].
517 Yeoh TM, Yusof M, Padmaan S. Laparoscopic surgery in the emergency setting - The HTAR experience. Medical Journal of Malaysia. 2010;65:62. PMID:.
518 Yong JL, Law WL, Lo CY, et al. A comparative study of routine laparoscopic versus open appendectomy. JSLS : Journal of the Society of Laparoendoscopic Surgeons/Society of Laparoendoscopic Surgeons. Apr–Jun. 2006;10(2):188-92. [pmid: 16882418].
519 Young DV. Results of urgent appendectomy for right lower quadrant tenderness. American journal of surgery. Apr. 1989;157(4):428-30. [pmid: 2929867].
520 Young VK, Caldwell MT, Watson RG. Correlation of peritoneal aspiration cytology with acute appendicitis. Irish journal of medical science. Aug. 1993;162(8):306-8. [pmid: 8244651].
521 Youssef NA, Gordon AJ, Moon TH, Patel BD, Shah SJ, Casey EM, McGowan AJ, Weiner SG. Emergency department patient knowledge, opinions, and risk tolerance regarding computed tomography scan radiation. [pmid: 24063878].
522 Zangos S, Steenburg SD, Phillips KD, et al. Acute abdomen: Added diagnostic value of coronal reformations with 64-slice multidetector row computed tomography. Academic radiology. Jan. 2007;14(1):19-27. [pmid: 17178362].
523 Zaninotto G, Rossi M, Anselmino M, et al. Laparoscopic versus conventional surgery for suspected appendicitis in women. Surgical endoscopy. Mar. 1995;9(3):337-40. [pmid: 7597610].
524 Zdichavsky M, Gogele H, Blank G, et al. Histological characterization of appendectomy specimens with intraoperative appearance of vascular injection. Surgical endoscopy. Mar. 2013;27(3):849-53. [pmid: 23052504].
525 Zganjer M, Roic G, Cizmic A, et al. Infectious ileocecitis--appendicitis mimicking syndrome. Bratislavske lekarske listy. 2005;106(6–7):201-2. [pmid: 16201735].
526 Zhang H, Wang K, Zhang D, et al. Computer aided tongue diagnosis system. Conference proceedings : Annual International Conference of the IEEE Engineering in Medicine and Biology Society IEEE Engineering in Medicine and Biology Society Conference. 2005;7:6754-7. [pmid: 17281824].
527 Zingone F, Sultan AA, Humes DJ, West J. Risk of Acute Appendicitis in and Around Pregnancy: A Population-Based Cohort Study From England. [pmid: 24950289].

## B-19. Rejection Reason: Selected on the Basis of Index Test Results

1 Adwan H, Weerasuriya CK, Endleman P, Barnes A, Stewart L, Justin T. Laparoscopic versus open appendicectomy in children: a UK District General Hospital experience. [pmid: 24528966].
2 Andre JB, Sebastian VA, Ruchman RM, et al. CT and appendicitis: evaluation of correlation between CT diagnosis and pathological diagnosis. Postgraduate medical journal. Jun. 2008;84(992):321-4. [pmid: 18644924].
3 Bagi P, Dueholm S. Nonoperative management of the ultrasonically evaluated appendiceal mass. Surgery. May. 1987;101(5):602-5. [pmid: 3554578].
4 Balthazar EJ, Megibow AJ, Gordon RB, et al. Computed tomography of the abnormal appendix. Journal of computer assisted tomography. Jul–Aug. 1988;12(4):595-601. [pmid: 3392258].
5 Checkoff JL, Wechsler RJ, Nazarian LN. Chronic inflammatory appendiceal conditions that mimic acute appendicitis on helical CT. AJR American journal of roentgenology. Sep. 2002;179(3):731-4. [pmid: 12185054].
6 Chen JJ, Changchien CS, Kuo CH. Causes of increasing width of right anterior extrarenal space seen in ultrasonographic examinations. Journal of clinical ultrasound : JCU. Jun. 1995;23(5):287-92. [pmid: 7642766].
7 Chiarugi M, Buccianti P, Decanini L, et al. “What you see is not what you get”. A plea to remove a ‘normal’ appendix during diagnostic laparoscopy. Acta chirurgica Belgica. Sep–Oct. 2001;101(5):243-5. [pmid: 11758109].
8 Christian F, Christian GP. A simple scoring system to reduce the negative appendicectomy rate. Annals of the Royal College of Surgeons of England. Jul. 1992;74(4):281-5. [pmid: 1416684].
9 Cobben LP, Groot I, Blickman JG, et al. Right colonic diverticulitis: MR appearance. Abdominal imaging. Nov–Dec. 2003;28(6):794-8. [pmid: 14753592].
10 Duda JB, Lynch ML, Bhatt S, et al. Computed tomography mimics of acute appendicitis: predictors of appendiceal disease confirmed at pathology. Journal of clinical imaging science. 2012;2:73. [pmid: 23350063].
11 Garcia K, Hernanz-Schulman M, Bennett DL, et al. Suspected appendicitis in children: diagnostic importance of normal abdominopelvic CT findings with nonvisualized appendix. Radiology. Feb. 2009;250(2):531-7. [pmid: 19188320].
12 Greason KL, Rappold JF, Liberman MA. Incidental laparoscopic appendectomy for acute right lower quadrant abdominal pain. Its time has come. Surgical endoscopy. Mar. 1998;12(3):223-5. [pmid: 9502700].
13 Gupta A, Regmi S, Hazra NK, et al. Clinically monitored delay-A valid option in cases with doubtful diagnosis of acute appendicitis. The Indian journal of surgery. Jun. 2010;72(3):215-9. [pmid: 23133250].
14 Jalil A, Shah SA, Saaiq M, et al. Alvarado scoring system in prediction of acute appendicitis. Journal of the College of Physicians and Surgeons--Pakistan : JCPSP. Dec. 2011;21(12):753-5. [pmid: 22166697].
15 Killen DA, Brooks DW Jr. GAS-FILLED APPENDIX: A ROENTGENOGRAPHIC SIGN OF ACUTE APPENDICITIS. Annals of surgery. Mar. 1965;161:474-8. [pmid: 14263974].
16 Kim HC, Yang DM, Kim SW, et al. Reassessment of CT images to improve diagnostic accuracy in patients with suspected acute appendicitis and an equivocal preoperative CT interpretation. European radiology. Jun. 2012;22(6):1178-85. [pmid: 22193372].
17 Kirshenbaum M, Mishra V, Kuo D, et al. Resolving appendicitis: role of CT. Abdominal imaging. Mar–Apr. 2003;28(2):276-9. [pmid: 12592478].
18 Kirshtein B, Perry ZH, Avinoach E, et al. Safety of laparoscopic appendectomy during pregnancy. World journal of surgery. Mar. 2009;33(3):475-80. [pmid: 19137365].
19 Kumar A, Muir MT, Cohn SM, et al. The etiology of pneumoperitoneum in the 21st century. The journal of trauma and acute care surgery. Sep. 2012;73(3):542-8. [pmid: 22929483].
20 Mazeh H, Epelboym I, Reinherz J, et al. Tip appendicitis: clinical implications and management. American journal of surgery. Feb. 2009;197(2):211-5. [pmid: 18789423].
21 Monneuse O, Abdalla S, Pilleul F, et al. Pain as the only consistent sign of acute appendicitis: lack of inflammatory signs does not exclude the diagnosis. World journal of surgery. Feb. 2010;34(2):210-5. [pmid: 20041246].
22 Moteki T, Horikoshi H. New CT criterion for acute appendicitis: maximum depth of intraluminal appendiceal fluid. AJR American journal of roentgenology. May. 2007;188(5):1313-9. [pmid: 17449776].
23 Nikolaidis P, Hwang CM, Miller FH, et al. The nonvisualized appendix: incidence of acute appendicitis when secondary inflammatory changes are absent. AJR American journal of roentgenology. Oct. 2004;183(4):889-92. [pmid: 15385277].
24 Park HC, Kim BS, Lee BH. Efficacy of short-term antibiotic therapy for consecutive patients with mild appendicitis. The American surgeon. Jun. 2011;77(6):752-5. [pmid: 21679646].
25 Piyarom P, Kaewlai R. False-negative appendicitis at ultrasound: nature and association. Ultrasound Med Biol. Jul. 2014;40(7):1483-9. [pmid: 24768483].
26 Puylaert JB, Vermeijden RJ, van der Werf SD, et al. Incidence and sonographic diagnosis of bacterial ileocaecitis masquerading as appendicitis. Lancet. Jul. 8. 1989;2(8654):84-6. [pmid: 2567879].
27 Rabinowitz CB, Egglin TK, Beland MD, et al. Outcomes in 74 patients with an appendicolith who did not undergo surgery: is follow-up imaging necessary?. Emergency radiology. Jul. 2007;14(3):161-5. [pmid: 17457624].
28 Raval B, Allan N, St Ville E. Use of computed tomography in appendicitis: technique, findings, and pitfalls. The Journal of computed tomography. Jan. 1987;11(1):17-25. [pmid: 3802875].
29 Scatarige JC, Yousem DM, Fishman EK, et al. CT abnormalities in right lower quadrant inflammatory disease: review of findings in 26 adults. Gastrointestinal radiology. 1987;12(2):156-62. [pmid: 3556977].
30 Seong NJ, Kim B, Lee S, Park HS, Kim HJ, Woo H, Kang HS, Lee KH. Off-site smartphone reading of CT images for patients with inconclusive diagnoses of appendicitis from on-call radiologists. [pmid: 24951190].
31 Shuaib W, Johnson JO, Salastekar N, Maddu KK, Khosa F. Incidental findings detected on abdomino-pelvic multidetector computed tomography performed in the acute setting. [pmid: 24475484].
32 Silverman PM, Kelvin FM, Baker ME, et al. Computed tomography of the ileocecal region. Computerized medical imaging and graphics : the official journal of the Computerized Medical Imaging Society. Sep–Oct. 1988;12(5):293-303. [pmid: 3179984].
33 Stengel JW, Webb EM, Poder L, et al. Acute appendicitis: clinical outcome in patients with an initial false-positive CT diagnosis. Radiology. Jul. 2010;256(1):119-26. [pmid: 20505066].
34 Teh SH, O’Ceallaigh S, McKeon JG, et al. Should an appendix that looks ‘normal’ be removed at diagnostic laparoscopy for acute right iliac fossa pain?. The European journal of surgery. Acta chirurgica. May. 2000;166(5):388-9. [pmid: 10881950].
35 Yasui H. Rovsing’s sign. British medical journal. May. 17. 1958;1(5080):1163. [pmid: 13536450].

## B-20. Rejection Reason: Selected on the Basis of Outcomes

1 Heindel W, Datene S, Lauterbach K, Gandjour A. Prospective observation of abdominal ultrasound in radiological emergency services: approaches to cost saving. RoFo : Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. 2003;175:1207-13. [pmid: 12964075].
2 Kaya M, Boleken ME, Kanmaz T, Erel O, Yucesan S. Total antioxidant capacity in children with acute appendicitis. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery et al. Zeitschrift fur Kinderchirurgie. 2006;16:34-8. [pmid: 16544224].
3 Bass JA, Goldman J, Jackson MA, Gasior AC, Sharp SW, Drews AA, et al. Pediatric Crohn disease presenting as appendicitis: differentiating features from typical appendicitis. European journal of pediatric surgery : official journal of Austrian Association of Pediatric Surgery et al. Zeitschrift fur Kinderchirurgie. 2012;22:274-8. [pmid: 22648194].
4 Citone G, Perri S, Pugno V, Lotti R, Amendolara M, Gola P, et al. Laparoscopic appendicectomy: an 8-year clinical experience. Minerva chirurgica. 2001;56:13-21. [pmid: 11283477].
5 Abadir JS, Cohen AJ, Wilson SE. Accurate diagnosis of infarction of omentum and appendices epiploicae by computed tomography. The American surgeon. 2004;70:854-7. [pmid: 15529836].
6 Abougabal AM, Afifi AH, Kasem MI. Role of multidetector computed tomography (MDCT) in diagnosis of subhepatic appendicitis. Egyptian Journal of Radiology and Nuclear Medicine. 2012;43:347-52.
7 Abu-Eshy SA, Malik GM, Khan AR, Khan GM, Al-Shehri MY. Schistosomal appendicitis. Annals of Saudi medicine. 1995;15:347-9. [pmid: 17590604].
8 Acosta S, Nilsson TK, Bjorck M. D-dimer testing in patients with suspected acute thromboembolic occlusion of the superior mesenteric artery. The British journal of surgery. 2004;91:991-4. [pmid: 15286959].
9 Adamyan LV. Surgical technologies decreasing of maternal and perinatal mortality. Journal of Perinatal Medicine. 2013;41.
10 Adibe OO, Barnaby K, Dobies J, Comerford M, Drill A, Walker N, Mattei P. Postoperative antibiotic therapy for children with perforated appendicitis: long course of intravenous antibiotics versus early conversion to an oral regimen (Provisional abstract). American journal of surgery. 2008:141-3. [pmid: 18070723].
11 Ahmed SA, Mohammed U, Sanda RB, Makama J, Shehu MS, Ameh EA, Mayun AA. Schistosomiasis of the appendix in a tertiary hospital in northern Nigeria: a 22-year review. J Lab Physicians. Jan. 2014;6(1):18-21. [pmid: 24696555].
12 Aisenberg GM, Grimes RM. Computed tomography in patients with abdominal pain and diarrhoea: Does the benefit outweigh the drawbacks?. Intern Med J. Oct. 2013;43(10):1141-4. [pmid: 24134171].
13 Akhator A. Appendicitis in the elderly-experience from Nigeria. Biosciences Biotechnology Research Asia. 2012;9:717-9.
14 Akyildiz HY, Sozuer E, Akcan A, Kucuk C, Artis T, Biri I, et al. The value of D-dimer test in the diagnosis of patients with nontraumatic acute abdomen. Ulusal travma ve acil cerrahi dergisi. Turkish journal of trauma & emergency surgery : TJTES. 2010;16:22-6. [pmid: 20209391].
15 Alanen A. Diagnostic aspiration of abdominal fluid in patients with acute abdomen. European journal of radiology. 1990;11:171-4. [pmid: 2265622].
16 Alhan E, Usta A, Çekiç A, Saglam K, Türkyılmaz S, Cinel A. A study on 107 patients with acute mesenteric ischemia over 30 years. Int J Surg. 2012;10(9):510-3. [pmid: 22885139].
17 Allen WE Jr, Payne VC, Jackson RC. Scout film of the abdomen in appendicitis. Journal of the National Medical Association. 1949;41:119-21. [pmid: 18127792].
18 Almagor M, Mintz A, Sibirsky O, Durst A. Preoperative and postoperative levels of interleukin-6 in patients with acute appendicitis: comparison between open and laparoscopic appendectomy. Surgical endoscopy. 2005;19:331-3. [pmid: 15645323].
19 Al-Shukri M, Mathew M, Al-Ghafri W, Al-Kalbani M, Al-Kharusi L, Gowri V. A clinicopathological study of women with adnexal masses presenting with acute symptoms.
20 Anandan S, Marino RV. Use of computed tomography in diagnosing appendicitis: redundant, expensive, toxic, and potentially unnecessary. The Journal of the American Osteopathic Association. 2012;112:121-5. [pmid: 22411966].
21 Andreescu N, Badulescu A, Gavrila S, Siderof AC. Study of the leptospirotic etiology in the digestive pathology, particularly in acute abdomen. Roumanian archives of microbiology and immunology. 1998;57:11-21. [pmid: 9745331].
22 Angel CA, Rao BN, Wrenn E Jr, Lobe TE, Kumar AP. Acute appendicitis in children with leukemia and other malignancies: still a diagnostic dilemma. Journal of pediatric surgery. 1992;27:476-9. [pmid: 1522462].
23 Anwar K, Desai M, Al-Bloushi N, Alam F, Cyprian FS. Prevalence and clinicopathological characteristics of appendiceal carcinoids in Sharjah (United Arab Emirates). World J Gastrointest Oncol. Jul. 15. 2014;6(7):253-6. [pmid: 25024816].
24 Appendicitis and appendectomies, active and reserve components, U.S. Armed Forces, 2002–2011. Msmr. 2012;19:7-12.
25 Aram FO. Preoperative use of analgesia in appendicitis. Saudi medical journal. 2008;29:859-62. [pmid: 18521465].
26 Archibong EA, Eskandar M, Sobande AA, Ajao OG. Right lower quadrant pain in females. Is it appendicitis or gynecological? Saudi medical journal. 2002;23:30-3. [pmid: 11938360].
27 Arif U, Ijaz M, Shah ZA, Khan MA, Khan MAR. Diagnostic accuracy of non-contrast-enhanced helical CT scan in comparison with ultrasonography in patients with acute flank pain. Pakistan Journal of Medical and Health Sciences. 2013;7.
28 Ariyarathenam AV, Nachimuthu S, Tang TY, Courtney ED, Harris SA, Harris AM. Enterobius vermicularis infestation of the appendix and management at the time of laparoscopic appendectomy: case series and literature review. International journal of surgery (London, England). 2010;8:466-9.
29 Armstrong GE. Clinical Remarks ON PELVIC APPENDICITIS AND THE IMPORTANCE OF RECTAL EXAMINATION. British medical journal. 1906;1:70-1. [pmid: 20762476].
30 Asrani A. Sonographic diagnosis of pneumoperitoneum using the ‘enhancement of the peritoneal stripe sign.’ A prospective study. Emergency radiology. 2007;14:29-39. [pmid: 17347768].
31 Atahan K, Ureyen O, Aslan E, Deniz M, Cokmez A, Gur S, et al. Preoperative diagnostic role of hyperbilirubinaemia as a marker of appendix perforation. The Journal of international medical research. 2011;39:609-18. [pmid: 21672366].
32 Aubertin JM, Prat F, Fritsch J, Choury A, Etienne JP. Diagnostic ERCP in the era of laparoscopic surgery. Hepato-gastroenterology. 1995;42:607-11. [pmid: 8751222].
33 Augustin T, Cagir B, Vandermeer TJ. Characteristics of perforated appendicitis: effect of delay is confounded by age and gender. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. 2011;15:1223-31. [pmid: 21557019].
34 Aydin O. Incidental parasitic infestations in surgically removed appendices: a retrospective analysis. Diagnostic pathology. 2007;2:16. [pmid: 17524150].
35 Azok JT, Kim DH, Munoz Del Rio A, Sonavane SK, Bhalla S, Anaya-Baez V, et al. Intraluminal air within an obstructed appendix: a CT sign of perforated or necrotic appendicitis. Academic radiology. 2012;19:1175-80. [pmid: 22818790].
36 Babaknia A, Parsa H, Woodruff JD. Appendicitis during pregnancy. Obstetrics and gynecology. 1977;50:40-4. [pmid: 876520].
37 Bader-Meunier B, Armengaud JB, Haddad E, Salomon R, Deschenes G, Kone-Paut I, et al. Initial presentation of childhood-onset systemic lupus erythematosus: a French multicenter study. The Journal of pediatrics. 2005;146:648-53. [pmid: 15870669].
38 Baker JL, Gull S, Jesudason EC, Abernethy LJ, Losty PD. Appendicitis masquerading as malignancy. Archives of disease in childhood. 2004;89:481-2. [pmid: 15102647].
39 Baldisserotto M, Valduga SG, da Cunha CF. MR imaging evaluation of the normal appendix in children and adolescents. Radiology. 2008;249:278-84. [pmid: 18710962].
40 Balthazar EJ, Megibow AJ, Hulnick D, Gordon RB, Naidich DP, Beranbaum ER. CT of appendicitis. AJR American journal of roentgenology. 1986;147:705-10. [pmid: 3489369].
41 Band RA, Gaieski DF, Mills AM, Sease KL, Shofer FS, Robey JL, et al. Discordance between serum creatinine and creatinine clearance for identification of ED patients with abdominal pain at risk for contrast-induced nephropathy. The American journal of emergency medicine. 2007;25:268-72. [pmid: 17349899].
42 Bansal J, Jenaw RK, Rao J, Kankaria J, Agrawal NN. Effectiveness of plain radiography in diagnosing hollow viscus perforation: study of 1,723 patients of perforation peritonitis. Emergency radiology. 2012;19:115-9. [pmid: 22143167].
43 Bansal S, Banever GT, Karrer FM, Partrick DA. Appendicitis in children less than 5 years old: influence of age on presentation and outcome. American journal of surgery. 2012;204:1031-5. discussion 5. [pmid: 23231939].
44 Barker AP, Davey RB. Appendicitis in the first three years of life. The Australian and New Zealand journal of surgery. 1988;58:491-4. [pmid: 3270321].
45 Barreto SG, Tiong L, Thomas T, Travers E, Williams RS. Incidental appendiceal carcinoids: Is surgery affecting their incidence?. World Journal of Oncology. 2012;3:227-30.
46 Bekele A, Mekasha A. Clinical profile and risk factors for perforation of acute appendicitis in children. East African medical journal. 2006;83:434-9. [pmid: 17153656].
47 Bektas F, Eken C, Soyuncu S, Kusoglu L, Cete Y. Contribution of goal-directed ultrasonography to clinical decision-making for emergency physicians. Emergency medicine journal : EMJ. 2009;26:169-72. [pmid: 19234003].
48 Beltran MA, Mendez PE, Barrera RE, Contreras MA, Wilson CS, Cortes VJ, et al. Is hyperbilirubinaemia in appendicitis a better predictor of perforation than C-reactive protein? - a prospective study. The Indian journal of surgery. 2009;71:265-72. [pmid: 23133170].
49 Ben Ely A, Gorelik N, Cohen-Sivan Y, Zissin R, Carpineta L, Osadchy A, Gayer G. Appendicitis in adults with incidental midgut malrotation: CT findings. Clin Radiol. Dec. 2013;68(12):1212-9. [pmid: 23937823].
50 Benjaminov O, Atri M, Hamilton P, Rappaport D. Frequency of visualization and thickness of normal appendix at nonenhanced helical CT. Radiology. 2002;225:400-6. [pmid: 12409572].
51 Bennett GL, Tanpitukpongse TP, Macari M, Cho KC, Babb JS. CT diagnosis of mucocele of the appendix in patients with acute appendicitis. AJR American journal of roentgenology. 2009;192:W103-10. [pmid: 19234237].
52 Bickell NA, Aufses AH Jr, Rojas M, Bodian C. How time affects the risk of rupture in appendicitis. Journal of the American College of Surgeons. 2006;202:401-6. [pmid: 16500243].
53 Bijnen CL, van den Broek WT, Bijnen AB, de Ruiter P, Gouma DJ. Implications of removing a normal appendix. Digestive surgery. 2003;20:215-9. discussion 20–1. [pmid: 12759501].
54 Bijnen CL, Van Den Broek WT, Bijnen AB, De Ruiter P, Gouma DJ. Implications of removing a normal appendix. Digestive surgery. 2003;20:115-21. [pmid: 12686778].
55 Bixby SD, Lucey BC, Soto JA, Theysohn JM, Ozonoff A, Varghese JC. Perforated versus nonperforated acute appendicitis: accuracy of multidetector CT detection. Radiology. 2006;241:780-6. [pmid: 17114626].
56 Bjerregaard B, Brynitz S, Holst-Christensen J, Kalaja E, Jess P, Lund-Kristensen J. Evaluation of use of the computer in the differential diagnosis of patients with acute abdominal pain. Ugeskrift for laeger. 1978;140:834-8. [pmid: 347655].
57 Blanco FC, Sandler AD, Nadler EP. Increased incidence of perforated appendicitis in children with obesity. Clinical pediatrics. 2012;51:928-32. [pmid: 22511195].
58 Bleichrodt RP, Tegzess AM, Slooff MJ. Acute abdomen in hemodialysis patients--a diagnostic dilemma. The Netherlands journal of surgery. 1987;39:51-4. [pmid: 3587698].
59 Bliss D, McKee J, Cho D, Krishnaswami S, Zallen G, Harrison M, et al. Discordance of the pediatric surgeon’s intraoperative assessment of pediatric appendicitis with the pathologists report. Journal of pediatric surgery. 2010;45:1398-403. [pmid: 20638515].
60 Block T, Nilsson TK, Bjorck M, Acosta S. Diagnostic accuracy of plasma biomarkers for intestinal ischaemia. Scandinavian journal of clinical and laboratory investigation. 2008;68:242-8. [pmid: 17934974].
61 Blumfield E, Nayak G, Srinivasan R, Muranaka MT, Blitman NM, Blumfield A, et al. Ultrasound for differentiation between perforated and nonperforated appendicitis in pediatric patients. AJR American journal of roentgenology. 2013;200:957-62. [pmid: 23617475].
62 Bogle AM, Hunsel R. What is the efficacy of computed tomography use in patients with suspected nephrolithiasis and a negative urinalysis for blood?. Annals of emergency medicine. 2011;58:S207.
63 Bohner H, Yang Q, Franke C, Verreet PR, Ohmann C. Simple data from history and physical examination help to exclude bowel obstruction and to avoid radiographic studies in patients with acute abdominal pain. The European journal of surgery. Acta chirurgica. 1998;164:777-84. [pmid: 9840308].
64 Bongard F, Landers DV, Lewis F. Differential diagnosis of appendicitis and pelvic inflammatory disease. A prospective analysis. American journal of surgery. 1985;150:90-6. [pmid: 3160252].
65 Boomer L, Freeman J, Landrito E, Feliz A. Perforation in adults with acute appendicitis linked to insurance status, not ethnicity. The Journal of surgical research. 2010;163:221-4. [pmid: 20599222].
66 Boomer LA, Cooper JN, Deans KJ, Minneci PC, Leonhart K, Diefenbach KA, Kenney BD, Besner GE. Does delay in appendectomy affect surgical site infection in children with appendicitis?. J Pediatr Surg. Jun. 2014;49(6):1026-9. [pmid: 24888856].
67 Borushok KF, Jeffrey RB Jr, Laing FC, Townsend RR. Sonographic diagnosis of perforation in patients with acute appendicitis. AJR American journal of roentgenology. 1990;154:275-8. [pmid: 2105013].
68 Branescu C, Serban D, Dascalu AM, Oprescu SM, Savlovschi C. Interleukin 6 and lipopolysaccharide binding protein - markers of inflammation in acute appendicitis. Chirurgia (Bucharest, Romania : 1990). 2013;108:206-14.
69 Branescu C, Serban D, Savlovschi C, Dascalu AM, Kraft A. Lipopolysaccharide binding protein (L.B.P.)--an inflammatory marker of prognosis in the acute appendicitis. Journal of medicine and life. 2012;5:342-7. [pmid: 23125878].
70 Brassart N, Winant C, Tack D, Gevenois PA, De Maertelaer V, Keyzer C. Optimised z-axis coverage at multidetector-row CT in adults suspected of acute appendicitis. The British journal of radiology. 2013;86:20130115. [pmid: 23690436].
71 Brender JD, Marcuse EK, Koepsell TD, Hatch EI. Childhood appendicitis: factors associated with perforation. Pediatrics. 1985;76:301-6. [pmid: 4022704].
72 Broker ME, van Lieshout EM, van der Elst M, Stassen LP, Schepers T. Discriminating between simple and perforated appendicitis. The Journal of surgical research. 2012;176:79-83. [pmid: 22113128].
73 Browder W, Smith JW, Vivoda LM, Nichols RL. Nonperforative appendicitis: a continuing surgical dilemma. The Journal of infectious diseases. 1989;159:1088-94. [pmid: 2656877].
74 Brown JD, Wheeler B. Pyomyositis. Report of 18 cases in Hawaii. Archives of internal medicine. 1984;144:1749-51. [pmid: 6476991].
75 Buchman TG, Zuidema GD. Reasons for delay of the diagnosis of acute appendicitis. Surgery, gynecology & obstetrics. 1984;158:260-6.
76 Burbige EJ, Huang SH, Bayless TM. Clinical manifestations of Crohn’s disease in children and adolescents. Pediatrics. 1975;55:866-71. [pmid: 1079596].
77 Burjonrappa S, Rachel D. Pediatric appendectomy: optimal surgical timing and risk assessment. Am Surg. May. 2014;80(5):496-9. [pmid: 24887730].
78 Bursali A, Arac M, Oner AY, Celik H, Eksioglu S, Gumus T. Evaluation of the normal appendix at low-dose non-enhanced spiral CT. Diagnostic and interventional radiology (Ankara, Turkey). 2005;11:45-50.
79 Butsch DW, Jothi R, Butsch WL, Butsch JL. Recurrent appendicitis: fact not fallacy. Postgraduate medicine. 1973;54:132-7. [pmid: 4580804].
80 Camp M, Chang DC, Zhang Y, Arnold M, Sharpe L, Gabre-Kidan A, et al. Provider density and health system facility factors and their relationship to rates of pediatric perforated appendicitis in US counties. Archives of surgery (Chicago, Ill : 1960). 2010;145:1139-44.
81 Carpenter SG, Chapital AB, Merritt MV, Johnson DJ. Increased risk of neoplasm in appendicitis treated with interval appendectomy: Single-institution experience and literature review. Am Surg. Mar. 2012;78(3):339-43. [pmid: 22524774].
82 Catalano O, Lobianco R, Sandomenico F, Mattace Raso M, Siani A. Real-time, contrast-enhanced sonographic imaging in emergency radiology. La Radiologia medica. 2004;108:454-69. [pmid: 15722992].
83 Chandler NM, Danielson PD. Single-incision laparoscopic appendectomy vs multiport laparoscopic appendectomy in children: a retrospective comparison. Journal of pediatric surgery. 2010;45:2186-90. [pmid: 21034942].
84 Chang HS, Yang SK, Myung SJ, Jung HY, Hong WS, Kim JH, et al. The role of colonoscopy in the diagnosis of appendicitis in patients with atypical presentations. Gastrointestinal endoscopy. 2002;56:343-8. [pmid: 12196770].
85 Chang YJ, Chao HC, Kong MS, Hsia SH, Yan DC. Misdiagnosed acute appendicitis in children in the emergency department. Chang Gung medical journal. 2010;33:551-7. [pmid: 20979706].
86 Chaudhary P, Kumar A, Saxena N, Biswal UC. Hyperbilirubinemia as a predictor of gangrenous/perforated appendicitis: a prospective study. [pmid: 24714371].
87 Chiu CL, Gambach RR. Radiographic ureteral changes with appendicitis. Journal of the Canadian Association of Radiologists. 1974;25:154-60. [pmid: 4854010].
88 Chock A, Seslar S, Stoopen E, Tristan A, Hashish H, Gonzalez JJ, et al. Needlescopic appendectomy. Surgical endoscopy. 2003;17:1451-3. [pmid: 12811662].
89 Chou YH, Pan HB, Tiu CM, Hsu CC, Su CH, Chiang JH, et al. Sonography of appendical abscess. Zhonghua yi xue za zhi. Chinese medical journal; Free China ed. 1987;39:309-16. [pmid: 3331965].
90 Choudhry AJ, Anandalwar SP, Choudhry AJ, Svider PF, Oliver JO, Eloy JA, Chokshi RJ. Uncovering malpractice in appendectomies: a review of 234 cases. J Gastrointest Surg. Oct. 2013;17(10):1796-803. [pmid: 23903929].
91 Chui CH, Chan MY, Tan AM, Low Y, Yap TL, Jacobsen AS. Appendicitis in immunosuppressed children: Still a diagnostic and therapeutic dilemma?. Pediatric blood & cancer. 2008;50:1282-3. [pmid: 18306278].
92 Chung CH, Ng CP, Lai KK. Delays by patients, emergency physicians, and surgeons in the management of acute appendicitis: retrospective study. Hong Kong medical journal/Hong Kong Academy of Medicine. Xianggang yi xue za zhi. 2000;6:254-9. [pmid: 11025842].
93 Chung JL, Kong MS, Lin SL, Lin TY, Huang CS, Lou CC, et al. Diagnostic value of C-reactive protein in children with perforated appendicitis. European journal of pediatrics. 1996;155:529-31. [pmid: 8831071].
94 Coleman C, Thompson JE Jr, Bennion RS, Schmit PJ. White blood cell count is a poor predictor of severity of disease in the diagnosis of appendicitis. The American surgeon. 1998;64:983-5. [pmid: 9764707].
95 Costa-Navarro D, Jimenez-Fuertes M, Illan-Riquelme A. Laparoscopic appendectomy: quality care and cost-effectiveness for today’s economy. [pmid: 24180475].
96 Couture A, Veyrac C, Baud C, Galifer RB, Armelin I. Evaluation of abdominal pain in Henoch-Schonlein syndrome by high frequency ultrasound. Pediatric radiology. 1992;22:12-7. [pmid: 1594303].
97 Cunningham FG, McCubbin JH. Appendicitis complicating pregnancy. Obstetrics and gynecology. 1975;45:415-20. [pmid: 1121371].
98 Dado G, Anania G, Baccarani U, Marcotti E, Donini A, Risaliti A, et al. Application of a clinical score for the diagnosis of acute appendicitis in childhood: a retrospective analysis of 197 patients. Journal of pediatric surgery. 2000;35:1320-2. [pmid: 10999688].
99 Daehlin L. Acute appendicitis during the first three years of life. Acta chirurgica Scandinavica. 1982;148:291-4. [pmid: 7136432].
100 Davies DA, Yanchar NL. Appendicitis in the obese child. Journal of pediatric surgery. 2007;42:857-61. [pmid: 17502199].
101 Deng Y, Chang DC, Zhang Y, Webb J, Gabre-Kidan A, Abdullah F. Seasonal and day of the week variations of perforated appendicitis in US children. Pediatric surgery international. 2010;26:691-6. [pmid: 20524129].
102 Ding Y, Zhou Y, Ji Z, Zhang J, Wang Q. Laparoscopic management of perforated Meckel’s diverticulum in adults. International journal of medical sciences. 2012;9:243-7. [pmid: 22577339].
103 Ditillo MF, Dziura JD, Rabinovici R. Is it safe to delay appendectomy in adults with acute appendicitis?. Annals of surgery. 2006;244:656-60. [pmid: 17060754].
104 Dixon MR, Haukoos JS, Park IU, Oliak D, Kumar RR, Arnell TD, et al. An assessment of the severity of recurrent appendicitis. American journal of surgery. 2003;186:718-22. discussion 22. [pmid: 14672785].
105 Draghici I, Draghici L, Popescu M, Litescu M. Laparoscopic exploration in pediatric surgery emergencies. Journal of medicine and life. 2010;3:90-5. [pmid: 20302204].
106 Dupre MP, Jadavji I, Matshes E, Urbanski SJ. Diverticular disease of the vermiform appendix: a diagnostic clue to underlying appendiceal neoplasm. Human pathology. 2008;39:1823-6. [pmid: 18715614].
107 Eiberg JP, Grantcharov TP, Eriksen JR, Boel T, Buhl C, Jensen D, et al. Ultrasound of the acute abdomen performed by surgeons in training. Minerva chirurgica. 2008;63:17-22. [pmid: 18212723].
108 Ein SH, Langer JC, Daneman A. Nonoperative management of pediatric ruptured appendix with inflammatory mass or abscess: presence of an appendicolith predicts recurrent appendicitis. Journal of pediatric surgery. 2005;40:1612-5. [pmid: 16226993].
109 Ein SH, Miller S, Rutka JT. Appendicitis in the child with a ventriculo-peritoneal shunt: a 30-year review. Journal of pediatric surgery. 2006;41:1255-8. [pmid: 16818058].
110 Ein SH, Wales P, Langer JC, Daneman A. Is there a role for routine abdominal imaging in predicting postoperative intraabdominal abscess formation after appendectomy for pediatric ruptured appendix?. Pediatric surgery international. 2008;24:307-9. [pmid: 18188573].
111 Elechi EN. Acute appendicitis: a clinical pattern in Port Harcourt Nigeria. East African medical journal. 1989;66:328-32. [pmid: 2791930].
112 Emil S, Gaied F, Lo A, Laberge JM, Puligandla P, Shaw K, Baird R, Bernard C, Blumenkrantz M, Nguyen VH. Gangrenous appendicitis in children: A prospective evaluation of definition, bacteriology, histopathology, and outcomes. J Surg Res. Sep. 2012;177(1):123-6. [pmid: 22482763].
113 Engin O, Calik B, Yildirim M, Coskun A, Coskun GA. Gynecologic pathologies in our appendectomy series and literature review. Journal of the Korean Surgical Society. 2011;80:267-71. [pmid: 22066046].
114 England RJ, Crabbe DC. Delayed diagnosis of appendicitis in children treated with antibiotics. Pediatric surgery international. 2006;22:541-5. [pmid: 16736226].
115 Eriksson S, Tisell A, Granstrom L. Ultrasonographic findings after conservative treatment of acute appendicitis and open appendicectomy. Acta radiologica (Stockholm, Sweden : 1987). 1995;36:173-7.
116 Escartin Villacampa R, Elias Pollina J, Esteban Ibarz JA. Primary torsion of the greater omentum. Anales espanoles de pediatria. 2001;54:251-4. [pmid: 11262253].
117 Estrada JJ, Petrosyan M, Barnhart J, Tao M, Sohn H, Towfigh S, et al. Hyperbilirubinemia in appendicitis: a new predictor of perforation. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. 2007;11:714-8. [pmid: 17436050].
118 Evgenikos N, McLaren J, Macleod DA. Menstruation, the oral contraceptive pill, and acute appendicitis. The European journal of surgery. Acta chirurgica. 2000;166:638-41. [pmid: 11003433].
119 Fashina IB, Adesanya AA, Atoyebi OA, Osinowo OO, Atimomo CJ. Acute appendicitis in Lagos: a review of 250 cases. The Nigerian postgraduate medical journal. 2009;16:268-73. [pmid: 20037623].
120 Fefferman NR, Bomsztyk E, Yim AM, Rivera R, Amodio JB, Pinkney LP, et al. Appendicitis in children: low-dose CT with a phantom-based simulation technique--initial observations. Radiology. 2005;237:641-6. [pmid: 16170015].
121 Finch DR, Lee E. Acute appendicitis complicating pregnancy in the Oxford region. The British journal of surgery. 1974;61:129-32. [pmid: 4816241].
122 Fisher JK, Findley T. Diagnosing appendicitis by computed tomography. Missouri medicine. 1988;85:15-20. [pmid: 3340077].
123 Flum DR, McClure TD, Morris A, Koepsell T. Misdiagnosis of appendicitis and the use of diagnostic imaging. Journal of the American College of Surgeons. 2005;201:933-9. [pmid: 16310698].
124 Foley TA, Earnest Ft, Nathan MA, Hough DM, Schiller HJ, Hoskin TL. Differentiation of nonperforated from perforated appendicitis: accuracy of CT diagnosis and relationship of CT findings to length of hospital stay. Radiology. 2005;235:89-96. [pmid: 15749978].
125 Fraser JD, Aguayo P, Sharp SW, Snyder CL, Rivard DC, Cully BE, et al. Accuracy of computed tomography in predicting appendiceal perforation. Journal of pediatric surgery. 2010;45:231-4. discussion 4–4. [pmid: 20105609].
126 Frei SP, Bond WF, Bazuro RK, Richardson DM, Sierzega GM, Wasser TE. Is early analgesia associated with delayed treatment of appendicitis?. The American journal of emergency medicine. 2008;26:176-80. [pmid: 18272097].
127 Gaensler EH, Jeffrey RB Jr, Laing FC, Townsend RR. Sonography in patients with suspected acute appendicitis: value in establishing alternative diagnoses. AJR American journal of roentgenology. 1989;152:49-51. [pmid: 2642363].
128 Galatioto C, Guadagni S, Zocco G, Mazzilo M, Bagnato C, Lippolis PV, et al. Mesoappendix and appendix stump treatment in laparoscopic appendectomy: a retrospective study in 1084 patients. Annali italiani di chirurgia. 2013;84:269-74. [pmid: 23856524].
129 Garst GC, Moore EE, Banerjee MN, Leopold DK, Burlew CC, Bensard DD, et al. Acute appendicitis: a disease severity score for the acute care surgeon. The journal of trauma and acute care surgery. 2013;74:32-6. [pmid: 23271074].
130 Gavela T, Cabeza B, Serrano A, Casado-Flores J. C-reactive protein and procalcitonin are predictors of the severity of acute appendicitis in children. Pediatric emergency care. 2012;28:416-9. [pmid: 22531196].
131 Gibeily GJ, Ross MN, Manning DB, Wherry DC, Kao TC. Late-presenting appendicitis: a laparoscopic approach to a complicated problem. Surgical endoscopy. 2003;17:725-9. [pmid: 12618944].
132 Gilling-Smith C, Panay N, Wadsworth J, Beard RW, Touquet R. Management of women presenting to the accident and emergency department with lower abdominal pain. Annals of the Royal College of Surgeons of England. 1995;77:193-7. [pmid: 7598417].
133 Gofrit ON, Abu-Dalu K. Perforated appendicitis in the child: contemporary experience. The Israel Medical Association journal : IMAJ. 2001;3:262-5. [pmid: 11344838].
134 Gorg C, Egbring J, Bert T. Contrast-enhanced ultrasound of epiploic appendagitis. Ultraschall in der Medizin (Stuttgart, Germany : 1980). 2009;30:163-7.
135 Gosain A, Williams RF, Blakely ML. Distinguishing acute from ruptured appendicitis preoperatively in the pediatric patient. Advances in surgery. 2010;44:73-85. [pmid: 20919515].
136 Graham DF. Computer-aided prediction of gangrenous and perforating appendicitis. British medical journal. 1977;2:1375-7. [pmid: 338108].
137 Grattan-Smith JD, Blews DE, Brand T. Omental infarction in pediatric patients: sonographic and CT findings. AJR American journal of roentgenology. 2002;178:1537-9. [pmid: 12034634].
138 Gregory J, Poonai N, Lim R, Van Osth S, Andrusiak T, Mekhaiel S, et al. Does pelvic ultrasound lead to a significant delay in management of acute pediatric appendicitis?. Canadian Journal of Emergency Medicine. 2012;14:S41-S2.
139 Grigull L, Lechner WM. Supporting diagnostic decisions using hybrid and complementary data mining applications: a pilot study in the pediatric emergency department. Pediatric research. 2012;71:725-31. [pmid: 22441377].
140 Grosfeld JL, Weinberger M, Clatworthy HW Jr. Acute appendicitis in the first two years of life. Journal of pediatric surgery. 1973;8:285-93. [pmid: 4698365].
141 Grosskreutz S, Goff WB 2nd, Balsara Z, Burkhard TK. CT of the normal appendix. Journal of computer assisted tomography. 1991;15:575-7. [pmid: 2061470].
142 Guraya SY, Al-Tuwaijri TA, Khairy GA, Murshid KR. Validity of leukocyte count to predict the severity of acute appendicitis. Saudi medical journal. 2005;26:1945-7. [pmid: 16380778].
143 Guven H, Koc B, Saglam F, Bayram IA, Adas G. Emergency right hemicolectomy for inflammatory cecal masses mimicking acute appendicitis. World J Emerg Surg. Jan. 20. 2014;9(1):7. [pmid: 24438756].
144 Guzman FC. Acute appendicitis and the leucocyte count. Philippine journal of surgery. 1947;2:235-9. [pmid: 18905999].
145 Hajdu N. Mesenteric adenitis in childhood simulating intussusception. Acta radiologica: diagnosis. 1970;10:130-7. [pmid: 4317045].
146 Hajkova H, Zavadova M, Tomiska F. Diagnosis, treatment and complications of appendicitis in childhood. II. Special features in the diagnosis of different forms of appendicitis in children. Acta Universitatis Carolinae Medica. 1986;32:523-84. [pmid: 3324723].
147 Halverson M, Delgado J, Mahboubi S. Extra-appendiceal findings in pediatric abdominal CT for suspected appendicitis. Pediatr Radiol. Jul. 2014;44(7):816-20. [pmid: 24595877].
148 Hamm M, Wawroschek F, Weckermann D, Knopfle E, Hackel T, Hauser H, et al. Unenhanced helical computed tomography in the evaluation of acute flank pain. European urology. 2001;39:460-5. [pmid: 11306887].
149 Hashimoto D, Hirota M, Matsukawa T, Yagi Y, Baba H. Clinical features of strangulated small bowel obstruction. Surg Today. Nov. 2012;42(11):1061-5. [pmid: 22661266].
150 Heinz-Erian P, Gassner I, Klein-Franke A, Jud V, Trawoeger R, Niederwanger C, Mueller T, Meister B, Scholl-Buergi S. Gastric lactobezoar - a rare disorder?. [pmid: 22216886].
151 Herscu G, Kong A, Russell D, Tran CL, Varela JE, Cohen A, et al. Retrocecal appendix location and perforation at presentation. The American surgeon. 2006;72:890-3. [pmid: 17058728].
152 Heselson J. PERITONEOSCOPY; A REVIEW OF 150 CASES. South African medical journal. Suid-Afrikaanse tydskrif vir geneeskunde. 1965;39:371-4. [pmid: 14301267].
153 Hewitt HW. THE VALUE OF THE LEUCOCYTE COUNT IN THE DIAGNOSIS AND PROGNOSIS OF ACUTE APPENDICITIS, AS BASED ON EXPERIENCE IN ONE HUNDRED CASES. Annals of surgery. 1917;66:143-51. [pmid: 17863756].
154 Hiorns MP, Easty M, McHugh K. Inflammatory appendix masses masquerading as pelvic tumours. Clinical radiology. 2002;57:70-3. [pmid: 11798207].
155 Ho CM, Chen Y, Lai HS, Lin WH, Hsu WM, Chen WJ. Comparison of critical conservative treatment versus emergency operation in children with ruptured appendicitis with tumor formation. Journal of the Formosan Medical Association = Taiwan yi zhi. 2004;103:359-63. [pmid: 15216402].
156 Holgersen LO, Stanley-Brown EG. Acute appendicitis with perforation. American journal of diseases of children (1960). 1971;122:288-93. [pmid: 5000497].
157 Hong YR, Chung CW, Kim JW, Kwon CI, Ahn DH, Kwon SW, et al. Hyperbilirubinemia is a significant indicator for the severity of acute appendicitis. Journal of the Korean Society of Coloproctology. 2012;28:247-52. [pmid: 23185704].
158 Hormann M, Puig S, Prokesch SR, Partik B, Helbich TH. MR imaging of the normal appendix in children. European radiology. 2002;12:2313-6. [pmid: 12195487].
159 Horrocks JC. A computer-aided diagnostic system using a small desk-top computer-calculator. Methods of information in medicine. 1974;13:83-8. [pmid: 4219437].
160 Horrow MM, White DS, Horrow JC. Differentiation of perforated from nonperforated appendicitis at CT. Radiology. 2003;227:46-51. [pmid: 12615997].
161 Horwitz JR, Gursoy M, Jaksic T, Lally KP. Importance of diarrhea as a presenting symptom of appendicitis in very young children. American journal of surgery. 1997;173:80-2. [pmid: 9074368].
162 Hsia CY, Chiu JH, Lui WY. Elective interval laparoscopic management for periappendiceal abscess. Zhonghua yi xue za zhi. Chinese medical journal; Free China ed. 1995;56:52-7. [pmid: 7553411].
163 Huang CB, Yu HR, Hung GC, Huang SC, Chuang JH. Clinical features and outcome of appendicitis in children younger than three years of age. Chang Gung medical journal. 2001;24:27-33. [pmid: 11299974].
164 Huang JC, Appelman HD. Another look at chronic appendicitis resembling Crohn’s disease. Modern pathology : an official journal of the United States and Canadian Academy of Pathology, Inc. 1996;9:975-81.
165 Hung MH, Lin LH, Chen DF. Clinical manifestations in children with ruptured appendicitis. Pediatric emergency care. 2012;28:433-5. [pmid: 22531191].
166 Hunt SJ, Coakley FV, Webb EM, Westphalen AC, Poder L, Yeh BM. Computed tomography of the acute abdomen in patients with atrial fibrillation. Journal of computer assisted tomography. 2009;33:280-5. [pmid: 19346859].
167 Hurst AK, Iseri KT, Gill MA, Noguchi JK, Gilman TM, Jelliffe RW. Comparison of four methods for predicting serum gentamicin concentrations in surgical patients with perforated or gangrenous appendicitis. Clinical pharmacy. 1987;6:234-8. [pmid: 3665379].
168 Hussain A, Mahmood H, Nicholls J, El-Hasani S. Prevention of intra-abdominal abscess following laparoscopic appendicectomy for perforated appendicitis: a prospective study. International journal of surgery (London, England). 2008;6:374-7.
169 Imran S. Accuracy of ultrasound in the diagnosis of upper abdominal pain. Journal of Ayub Medical College, Abbottabad : JAMC. 2003;15:59-62. [pmid: 14552253].
170 Imuta M, Awai K, Nakayama Y, Murata Y, Asao C, Matsukawa T, et al. Multidetector CT findings suggesting a perforation site in the gastrointestinal tract: analysis in surgically confirmed 155 patients. Radiation medicine. 2007;25:113-8. [pmid: 17450335].
171 Ingram RR, Mohammed R, Tillman J. C-reactive protein and acute appendicitis. Journal of the Royal College of Surgeons of Edinburgh. 1988;33:115-6. [pmid: 3225791].
172 Iqbal Z, Ali IS, Khan M. Comparison between predicted position of appendix on clinical examination and position of appendix as an intraoperative finding in patients with clinically suspected acute appendicitis. JPMI - Journal of Postgraduate Medical Institute. 2011;25:352-5.
173 Ishiyama M, Yanase F, Taketa T, Makidono A, Suzuki K, Omata F, et al. Significance of size and location of appendicoliths as exacerbating factor of acute appendicitis. Emergency radiology. 2013;20:125-30. [pmid: 23179506].
174 Ishizuka M, Shimizu T, Kubota K. Neutrophil-to-lymphocyte ratio has a close association with gangrenous appendicitis in patients undergoing appendectomy. International surgery. 2012;97:299-304. [pmid: 23294069].
175 Iwahashi N, Kitagawa Y, Mayumi T, Kohno H. Intravenous contrast-enhanced computed tomography in the diagnosis of acute appendicitis. World journal of surgery. 2005;29:83-7. [pmid: 15592916].
176 Jabra AA, Shalaby-Rana EI, Fishman EK. CT of appendicitis in children. Journal of computer assisted tomography. 1997;21:661-6. [pmid: 9216780].
177 Jeffrey RB Jr, Federle MP, Tolentino CS. Periappendiceal inflammatory masses: CT-directed management and clinical outcome in 70 patients. Radiology. 1988;167:13-6. [pmid: 3347712].
178 Johnson PT, Eng J, Moore CJ, Horton KM, Fishman EK. Multidetector-row CT of the appendix in healthy adults. Emergency radiology. 2006;12:248-53. [pmid: 16819637].
179 Johnson PT, Horton KM, Mahesh M, Fishman EK. Multidetector computed tomography for suspected appendicitis: multi-institutional survey of 16-MDCT data acquisition protocols and review of pertinent literature. Journal of computer assisted tomography. 2006;30:758-64. [pmid: 16954924].
180 Joo SM, Lee KH, Kim YH, Kim SY, Kim K, Kim KJ, et al. Detection of the normal appendix with low-dose unenhanced CT: use of the sliding slab averaging technique. Radiology. 2009;251:780-7. [pmid: 19336669].
181 Jordan FT, Mazzeo RJ, Hoshal VL Jr. Primary adenocarcinoma of the appendix. Can preoperative or intraoperative diagnosis be made? The American surgeon. 1983;49:278-81. [pmid: 6846961].
182 Garcia M, Taylor G, Babcock L, Dillman JR, Iqbal V, Quijano CV, Wootton-Gorges SL, Adelgais K, Anupindi SA, Sonavane S, Joshi A, Veeramani M, Atabaki SM, Monroe DJ, Blumberg SJ, Ruzal-Shapiro C, Cook LJ, Dayan PS. Pediatric Emergency Care Applied Research Network (PECARN). Computed tomography with intravenous contrast alone: the role of intra-abdominal fat on the ability to visualize the normal appendix in children.
183 Jung SJ, Lee do K, Kim JH, Kong PS, Kim KH, Bae SW. Appendicitis during pregnancy: The clinical experience of a secondary hospital. [pmid: 22816059].
184 Karabulut N, Boyaci N, Yagci B, Herek D, Kiroglu Y. Computed tomography evaluation of the normal appendix: comparison of low-dose and standard-dose unenhanced helical computed tomography. Journal of computer assisted tomography. 2007;31:732-40. [pmid: 17895785].
185 Karabulut R, Sonmez K, Turkyilmaz Z, Demirogullari B, Ozen IO, Demirtola A, et al. Negative appendectomy experience in children. Irish journal of medical science. 2011;180:55-8. [pmid: 20658324].
186 Kaser SA, Fankhauser G, Willi N, Maurer CA. C-reactive protein is superior to bilirubin for anticipation of perforation in acute appendicitis. Scandinavian journal of gastroenterology. 2010;45:885-92. [pmid: 20334601].
187 Kaser SA, Furler R, Evequoz DC, Maurer CA. Hyponatremia is a specific marker of perforation in sigmoid diverticulitis or appendicitis in patients older than 50 years. Gastroenterology research and practice. 2013;2013:462891. [pmid: 23476637].
188 Kavakli HS, Altintas ND, Cevik Y, Becel S, Tanriverdi F. Diagnostic value of lactate levels in acute appendicitis. JPMA The Journal of the Pakistan Medical Association. 2010;60:913-5. [pmid: 21375193].
189 Kazim SF, Pal KM. Appendicitis in pregnancy: experience of thirty-eight patients diagnosed and managed at a tertiary care hospital in Karachi. International journal of surgery (London, England). 2009;7:365-7.
190 Kelley SR, Engel AM, Hatton EK, Knudson JJ, Clark BJ, Doepker MP, et al. Do basic laboratory tests add value in predicting the severity of appendicitis in an adult patient population and does it make a difference in how severity is defined?. The American surgeon. 2012;78:E175-7. [pmid: 22524753].
191 Kennedy DW. Accuracy of diagnosis in appendicitis. Journal of the Irish Medical Association. 1974;67:271-4. [pmid: 4850384].
192 Kim HC, Yang DM, Jin W. Identification of the normal appendix in healthy adults by 64-slice MDCT: the value of adding coronal reformation images. The British journal of radiology. 2008;81:859-64. [pmid: 18941045].
193 Kim HC, Yang DM, Kim SW, Park SJ. Gastrointestinal tract perforation: Evaluation of MDCT according to perforation site and elapsed time. Eur Radiol. Jun. 2014;24(6):1386-93. [pmid: 24623365].
194 Kim HC, Yang DM, Shin HP. Why can we not see a normal appendix on CT? An evaluation of the factors influencing nonvisualization of a normal appendix by 64-slice MDCT. Clinical imaging. 2009;33:33-8. [pmid: 19135927].
195 Kim MY, Lee YM, Suh CH, Kim JM. Computed tomographic features of appendiceal serositis in pelvic inflammatory disease: comparison with pathological findings. Journal of computer assisted tomography. 2007;31:104-8. [pmid: 17259841].
196 Kim S, Lim HK, Lee JY, Lee J, Kim MJ, Lee AS. Ascending retrocecal appendicitis: clinical and computed tomographic findings. Journal of computer assisted tomography. 2006;30:772-6. [pmid: 16954926].
197 Kim SH, Choi YH, Kim WS, Cheon JE, Kim IO. Acute appendicitis in children: ultrasound and CT findings in negative appendectomy cases. Pediatr Radiol. Oct. 2014;44(10):1243-51. [pmid: 24840768].
198 Kimura Y, Yamauchi M, Inoue H, Kimura S, Yamakage M, Aimono M, Sumita S. Risk factors for gastric distension in patients with acute appendicitis: A retrospective cohort study. [pmid: 22349834].
199 Kisacik B, Kalyoncu U, Erol MF, Karadag O, Yildiz M, Akdogan A, et al. Accurate diagnosis of acute abdomen in FMF and acute appendicitis patients: how can we use procalcitonin?. Clinical rheumatology. 2007;26:2059-62. [pmid: 17415505].
200 Klingler PJ, Wetscher G, Glaser K, Tschmelitsch J, Schmid T, Hinder RA. The use of ultrasound to differentiate rectus sheath hematoma from other acute abdominal disorders. Surgical endoscopy. 1999;13:1129-34. [pmid: 10556453].
201 Kogut KA, Blakely ML, Schropp KP, Deselle W, Hixson SD, Davidoff AM, et al. The association of elevated percent bands on admission with failure and complications of interval appendectomy. Journal of pediatric surgery. 2001;36:165-8. [pmid: 11150458].
202 Koltuksuz U, Uz E, Ozen S, Aydinc M, Karaman A, Akyol O. Plasma superoxide dismutase activity and malondialdehyde level correlate with the extent of acute appendicitis. Pediatric surgery international. 2000;16:559-61. [pmid: 11149393].
203 Kondo NI, Kohno H. Retained appendicolith in an inflamed appendix. Emergency radiology. 2009;16:105-9. [pmid: 18941809].
204 Korhonen K, Lovvorn HN 3rd, Koyama T, Koehler E, Calder C, Manes B, Evans M, Bruce K, Ho RH, Domm J, Frangoul H. Incidence, risk factors, and outcome of pneumatosis intestinalis in pediatric stem cell transplant recipients. Pediatr Blood Cancer. Apr. 2012;58(4):616-20. [pmid: 21721114].
205 Korner H, Sondenaa K, Soreide JA. Perforated and non-perforated acute appendicitis--one disease or two entities?. The European journal of surgery. Acta chirurgica. 2001;167:525-30. [pmid: 11560388].
206 Kovanlikaya A, Rosenbaum D, Mazumdar M, Dunning A, Brill PW. Visualization of the normal appendix with MR enterography in children. Pediatric radiology. 2012;42:959-64. [pmid: 22434554].
207 Kraemer M, Kremer K, Leppert R, Yang Q, Ohmann C, Fuchs KH. Perforating appendicitis: is it a separate disease? Acute Abdominal Pain Study Group. The European journal of surgery. Acta chirurgica. 1999;165:473-80. [pmid: 10391166].
208 Lai HW, Tseng SH, Lee YT, Hsu CH, Chou DA, Wu HS, et al. Impact of AITS laparoscopic training center on surgeons’ preference for appendectomy. Surgical endoscopy. 2010;24:2210-5. [pmid: 20177931].
209 Laurell H, Hansson LE, Gunnarsson U. Acute diverticulitis--clinical presentation and differential diagnostics. Colorectal disease : the official journal of the Association of Coloproctology of Great Britain and Ireland. 2007;9:496-501. discussion -2. [pmid: 17573742].
210 Le J, Kurian J, Cohen HW, Weinberg G, Scheinfeld MH. Do clinical outcomes suffer during transition to an ultrasound-first paradigm for the evaluation of acute appendicitis in children?. AJR Am J Roentgenol. Dec. 2013;201(6):1348-52. [pmid: 24261376].
211 Lee CH, Jeon WJ, Youn SJ, Yun HY, Jang LC, Choi JW, Song YJ, Ryu DH. The experience of transumbilical endoscopic appendectomies. Ann Surg Treat Res. May. 2014;86(5):278-82. [pmid: 24851231].
212 Lee CK, Ahn MS, Lee EY, Shin JH, Cho YS, Ha HK, et al. Acute abdominal pain in systemic lupus erythematosus: focus on lupus enteritis (gastrointestinal vasculitis). Annals of the rheumatic diseases. 2002;61:547-50. [pmid: 12006332].
213 Lee KS, Tang LH, Shia J, Paty PB, Weiser MR, Guillem JG, et al. Goblet cell carcinoid neoplasm of the appendix: clinical and CT features. European journal of radiology. 2013;82:85-9. [pmid: 23088880].
214 Lefrancois M, Lefevre JH, Chafai N, Pitel S, Kerger L, Agostini J, Canard G, Tiret E. Management of Acute Appendicitis in Ambulatory Surgery: Is It Possible? How to Select Patients?. Ann Surg. Jun. 2015;261(6):1167-72. [pmid: 24950287].
215 Levin T, Whyte C, Borzykowski R, Han B, Blitman N, Harris B. Nonoperative management of perforated appendicitis in children: can CT predict outcome?. Pediatric radiology. 2007;37:251-5. [pmid: 17186230].
216 Levine CD, Aizenstein O, Lehavi O, Blachar A. Why we miss the diagnosis of appendicitis on abdominal CT: evaluation of imaging features of appendicitis incorrectly diagnosed on CT. AJR American journal of roentgenology. 2005;184:855-9. [pmid: 15728609].
217 Li J, Liu Y, Yin W, Zhang C, Huang J, Liao C, et al. Alterations of the preoperative coagulation profile in patients with acute appendicitis. Clinical chemistry and laboratory medicine : CCLM/FESCC. 2011;49:1333-9.
218 Liang CC, Hsieh TT, Chang SD. Appendicitis during pregnancy. Changgeng yi xue za zhi/Changgeng ji nian yi yuan. Chang Gung medical journal/Chang Gung Memorial Hospital. 1989;12:208-14.
219 Lim HK, Lee WJ, Lee SJ, Namgung S, Lim JH. Focal appendicitis confined to the tip: diagnosis at US. Radiology. 1996;200:799-801. [pmid: 8756934].
220 Lin CJ, Chen JD, Tiu CM, Chou YH, Chiang JH, Lee CH, et al. Can ruptured appendicitis be detected preoperatively in the ED?. The American journal of emergency medicine. 2005;23:60-6. [pmid: 15672340].
221 Lukish J, Powell D, Morrow S, Cruess D, Guzzetta P. Laparoscopic appendectomy in children: use of the endoloop vs the endostapler. Archives of surgery (Chicago, Ill : 1960). 2007;142:58-61. discussion 2.
222 Maghan J. The value of sedimentation rate in diagnosis of acute appendicitis. The American journal of medical technology. 1948;14:270-4. [pmid: 18884554].
223 Maki AC, Combs B, McClure B, Slack P, Matheson P, Wiesenauer C. Enterobius vermicularis: a cause of acute appendicitis in children. The American surgeon. 2012;78:E523-4. [pmid: 23265108].
224 Mallick MS, Al-Bassam AA. Primary omental torsion in children. The pre-disposing factors and role of laparoscopy in diagnosis and treatment. Saudi medical journal. 2006;27:194-7. [pmid: 16501675].
225 Mangi AA, Berger DL. Stump appendicitis. The American surgeon. 2000;66:739-41. [pmid: 10966030].
226 Marrero RR Jr, Barnwell S, Hoover EL. Appendicitis in children: a continuing clinical challenge. Journal of the National Medical Association. 1992;84:850-2. [pmid: 1404459].
227 McGann Donlan S, Mycyk MB. Is female sex associated with ED delays to diagnosis of appendicitis in the computed tomography era?. The American journal of emergency medicine. 2009;27:856-8. [pmid: 19683117].
228 McNeeley MF, Vo NJ, Prabhu SJ, Vergnani J, Shaw DW. Percutaneous drainage of intra-abdominal abscess in children with perforated appendicitis. [pmid: 22246413].
229 Merine DS, Fishman EK, Jones B, Nussbaum AR, Simmons T. Right lower quadrant pain in the immunocompromised patient: CT findings in 10 cases. AJR American journal of roentgenology. 1987;149:1177-9. [pmid: 3500605].
230 Minutolo V, Licciardello A, Di Stefano B, Arena M, Arena G, Antonacci V. Outcomes and cost analysis of laparoscopic versus open appendectomy for treatment of acute appendicitis: 4-years experience in a district hospital. [pmid: 24646120].
231 Molander P, Paavonen J, Sjoberg J, Savelli L, Cacciatore B. Transvaginal sonography in the diagnosis of acute appendicitis. Ultrasound in obstetrics & gynecology : the official journal of the International Society of Ultrasound in Obstetrics and Gynecology. 2002;20:496-501.
232 Moon HM, Park BS, Moon DJ. Diagnostic Value of C-reactive Protein in Complicated Appendicitis. Journal of the Korean Society of Coloproctology. 2011;27:122-6. [pmid: 21829766].
233 Moon KS, Jung YH, Lee EH, Hwang YH. Clinical Characteristics and Surgical Safety in Patients with Acute Appendicitis Aged over 80. Journal of the Korean Society of Coloproctology. 2012;28:94-9. [pmid: 22606649].
234 Mori Y, Yamasaki M, Furukawa A, Takahashi M, Murata K. Enhanced CT in the diagnosis of acute appendicitis to evaluate the severity of disease: comparison of CT findings and histological diagnosis. Radiation medicine. 2001;19:197-202. [pmid: 11550720].
235 Moriwaki Y, Sugiyama M, Mochizuki Y, Yamazaki Y, Suda T, Hasegawa S, et al. A pitfall of the diagnostic process of differentiating bile peritonitis from acute appendicitis. Hepato-gastroenterology. 2004;51:353-6. [pmid: 15086157].
236 Mortellaro VE, Juang D, Fike FB, Saites CG, Potter DD Jr, Iqbal CW, et al. Treatment of appendicitis in neutropenic children. The Journal of surgical research. 2011;170:14-6. [pmid: 21514602].
237 Moteki T, Ohya N, Horikoshi H. Computed tomography criterion for the diagnosis of appendicitis without periappendiceal inflammation in children using the maximum depth of intraluminal appendiceal fluid. Journal of computer assisted tomography. 2010;34:907-14. [pmid: 21084908].
238 Muensterer OJ, Puga Nougues C, Adibe OO, Amin SR, Georgeson KE, Harmon CM. Appendectomy using single-incision pediatric endosurgery for acute and perforated appendicitis. Surgical endoscopy. 2010;24:3201-4. [pmid: 20490556].
239 Mukherjee A, Schlenker E, LaMasters T, Johnson M, Brunz J, Thomas E. Periappendicitis: is it a clinical entity?. The American surgeon. 2002;68:913-6. [pmid: 12412725].
240 Mukhopadhyay A, Dey R, Bhattacharya U. Tuberculosis with an acute abdomen: Our clinical experience. [pmid: 25177599].
241 Muqim R, Khan M, Zarin M. Experience of laparoscopic appendecectomies versus open appendecectomies. Pak J Med Sci. 2010:324-8.
242 Murray A, Madigan MR. The leucocyte count and histological appearance in acute appendicitis. The British journal of surgery. 1984;71:319. [pmid: 6704689].
243 Murray JG, Evans SJ, Jeffrey PB, Halvorsen RA Jr. Cytomegalovirus colitis in AIDS: CT features. AJR American journal of roentgenology. 1995;165:67-71. [pmid: 7785636].
244 Nadler EP, Reblock KK, Qureshi FG, Hackam DJ, Gaines BA, Kane TD. Laparoscopic appendectomy in children with perforated appendicitis. Journal of laparoendoscopic & advanced surgical techniques Part A. 2006;16:159-63. [pmid: 16646709].
245 Nadler EP, Reblock KK, Vaughan KG, Meza MP, Ford HR, Gaines BA. Predictors of outcome for children with perforated appendicitis initially treated with non-operative management. Surgical infections. 2004;5:349-56. [pmid: 15744126].
246 Naiditch JA, Lautz TB, Daley S, Pierce MC, Reynolds M. The Implications of Missed Opportunities to Diagnose Appendicitis in Children. Acad Emerg Med. Jun. 2013;20(6):592-6. [pmid: 23758306].
247 Naidu VV, Kate V, Koner BC, Ananthakrishnan N. Diagnostic peritoneal lavage (DPL)--is it useful decision making process for management of the equivocal acute abdomen?. Tropical gastroenterology : official journal of the Digestive Diseases Foundation. 2003;24:140-3. [pmid: 14978990].
248 Naik KS, Ness LM, Bowker AM, Robinson PJ. Is computed tomography of the body overused? An audit of 2068 attendances in a large acute hospital. The British journal of radiology. 1996;69:126-31. [pmid: 8785639].
249 Narci A, Karaman I, Karaman A, Erdogan D, Cavusoglu YH, Aslan MK, et al. Is peritoneal drainage necessary in childhood perforated appendicitis?--a comparative study. Journal of pediatric surgery. 2007;42:1864-8. [pmid: 18022437].
250 Narsule CK, Kahle EJ, Kim DS, Anderson AC, Luks FI. Effect of delay in presentation on rate of perforation in children with appendicitis. The American journal of emergency medicine. 2011;29:890-3. [pmid: 20627213].
251 Nazarey PP, Stylianos S, Velis E, Triana J, Diana-Zerpa J, Pasaron R, Stylianos V, Malvezzi L, Knight C, Burnweit C. Treatment of suspected acute perforated appendicitis with antibiotics and interval appendectomy. J Pediatr Surg. Mar. 2014;49(3):447-50. [pmid: 24650475].
252 Nelson DS, Bateman B, Bolte RG. Appendiceal perforation in children diagnosed in a pediatric emergency department. Pediatric emergency care. 2000;16:233-7. [pmid: 10966339].
253 Ng KS, Tan AG, Chen KK, Wong SK, Tan HM. CT features of primary epiploic appendagitis. European journal of radiology. 2006;59:284-8. [pmid: 16580806].
254 Ng SP, Cheng SM, Yang FS, Tzen CY, Huang JK. Hyperdense appendix on unenhanced CT: a sign of acute appendicitis. Abdominal imaging. 2007;32:701-4. [pmid: 17632752].
255 Nguyen LK, Wong DD, Fatovich DM, Yeung JM, Persaud J, Wood CJ, et al. Low-dose computed tomography versus plain abdominal radiography in the investigation of an acute abdomen. ANZ journal of surgery. 2012;82:36-41. [pmid: 22507493].
256 Nicola Z, Gabriella S, Alberto M, Saverio CF. Transumbilical laparoscopic-assisted appendectomy in children: Clinical and surgical outcomes. World J Gastrointest Endosc. Apr. 16. 2014;6(4):101-4. [pmid: 24748916].
257 Nicolau AE, Merlan V, Veste V, Micu B, Beuran M. Laparoscopic suture repair of perforated duodenal peptic ulcer for patients without risk factors. Chirurgia (Bucharest, Romania : 1990). 2008;103:629-33.
258 Nikolaidis P, Hammond N, Marko J, Miller FH, Papanicolaou N, Yaghmai V. Incidence of visualization of the normal appendix on different MRI sequences. Emergency radiology. 2006;12:223-6. [pmid: 16721554].
259 Nmadu PT. Appendicitis in older African patients: 10 year review and report of 84 cases. The Central African journal of medicine. 1995;41:196-9. [pmid: 7664325].
260 Noguchi T, Yoshimitsu K, Yoshida M. Periappendiceal hyperechoic structure on sonography: a sign of severe appendicitis. Journal of ultrasound in medicine : official journal of the American Institute of Ultrasound in Medicine. 2005;24:323-7. quiz 8–30. [pmid: 15723844].
261 Noh H, Chang SJ, Han A. The diagnostic values of preoperative laboratory markers in children with complicated appendicitis. Journal of the Korean Surgical Society. 2012;83:237-41. [pmid: 23091796].
262 Nomura S, Watanabe M, Komine O, Shioya T, Toyoda T, Bou H, et al. Serum total bilirubin elevation is a predictor of the clinicopathological severity of acute appendicitis. Surgery today. 2014;44:1104-8. [pmid: 23880964].
263 North F, Odunukan O, Varkey P. The value of telephone triage for patients with appendicitis. Journal of telemedicine and telecare. 2011;17:417-20. [pmid: 22052965].
264 Norton VC, Schriger DL. Effect of transfer on outcome in patients with appendicitis. Annals of emergency medicine. 1997;29:467-73. [pmid: 9095006].
265 Oguro S, Funabiki T, Hosoda K, Inoue Y, Yamane T, Sato M, et al. 64-Slice multidetector computed tomography evaluation of gastrointestinal tract perforation site: detectability of direct findings in upper and lower GI tract. European radiology. 2010;20:1396-403. [pmid: 19997849].
266 Okafor PI, Orakwe JC, Chianakwana GU. Management of appendiceal masses in a peripheral hospital in Nigeria: review of thirty cases. World journal of surgery. 2003;27:800-3. [pmid: 14509509].
267 Old O. C-Reactive protein estimation does not improve accuracy in the diagnosis of acute appendicitis in pediatric patients. International journal of surgery (London, England). 2011;9:440.
268 Oliak D, Yamini D, Udani VM, Lewis RJ, Vargas H, Arnell T, et al. Nonoperative management of perforated appendicitis without periappendiceal mass. American journal of surgery. 2000;179:177-81. [pmid: 10827313].
269 Orient JM. Evaluation of abdominal pain: clinicians’ performance compared with three protocols. Southern medical journal. 1986;79:793-9. [pmid: 3523767].
270 Osada H, Ohno H, Saiga K, Watanabe W, Okada T, Honda N. Appendiceal diverticulitis: multidetector CT features. Japanese journal of radiology. 2012;30:242-8. [pmid: 22190074].
271 Otaghvar, Baniahmad M, Pashazadeh AM, Nabipour I, Javadi H, Rezaei L, Assadi M. The role of 99mTc-Ubiquicidin (UBI) and 99mTc-IgG scintigraphies in diagnosis of acute appendicitis: A preliminary result.
272 Otero HJ, Ondategui-Parra S, Erturk SM, Ochoa RE, Gonzalez-Beicos A, Ros PR. Imaging utilization in the management of appendicitis and its impact on hospital charges. Emergency radiology. 2008;15:23-8. [pmid: 17972120].
273 Ozel A, Orhan UP, Akdana B, Disli C, Erturk SM, Basak M, et al. Sonographic appearance of the normal appendix in children. Journal of clinical ultrasound : JCU. 2011;39:183-6. [pmid: 21425275].
274 Ozturk ZA, Koklu S, Erol MF, Yilmaz FM, Basar O, Yuksel O, et al. Serum adenosine deaminase levels in diagnosis of acute appendicitis. Emergency medicine journal : EMJ. 2008;25:583-5. [pmid: 18723708].
275 Paik PS, Towson JA, Anthone GJ, Ortega AE, Simons AJ, Beart RW Jr. Intra-abdominal abscesses following laparoscopic and open appendectomies. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. 1997;1:188-92. discussion 92–3. [pmid: 9834347].
276 Pal KM, Khan A. Appendicitis: a continuing challenge. JPMA The Journal of the Pakistan Medical Association. 1998;48:189-92. [pmid: 10067019].
277 Palanivelu C, Rangarajan M, Shetty AR, Jani K. Intestinal malrotation with midgut volvulus presenting as acute abdomen in children: value of diagnostic and therapeutic laparoscopy. Journal of laparoendoscopic & advanced surgical techniques Part A. 2007;17:490-2. [pmid: 17705733].
278 Papandria D1, Goldstein SD, Rhee D, Salazar JH, Arlikar J, Gorgy A, Ortega G, Zhang Y, Abdullah F. Risk of perforation increases with delay in recognition and surgery for acute appendicitis. J Surg Res. Oct. 2013;184(2):723-9. [pmid: 23290595].
279 Paquette IM, Zuckerman R, Finlayson SR. Perforated appendicitis among rural and urban patients: implications of access to care. Annals of surgery. 2011;253:534-8. [pmid: 21209586].
280 Partecke LI, Thiele A, Schmidt-Wankel F, Kessler W, Wodny M, Dombrowski F, et al. Appendicopathy--a clinical and diagnostic dilemma. International journal of colorectal disease. 2013;28:1081-9. [pmid: 23516073].
281 Peck JJ. Management of carcinoma discovered unexpectedly at operation for acute appendicitis. American journal of surgery. 1988;155:683-5. [pmid: 3369624].
282 Pecoraro AP, Cacchione RN, Sayad P, Williams ME, Ferzli GS. The routine use of diagnostic laparoscopy in the intensive care unit. Surgical endoscopy. 2001;15:638-41. [pmid: 11591958].
283 Peltokallio P, Jauhiainen K. Acute appendicitis in the aged patient. Study of 300 cases after the age of 60. Archives of surgery (Chicago, Ill : 1960). 1970;100:140-3.
284 Pennington C, Dunn J, Li C, Ha T, Browder W. Nuclear factor kappaB activation in acute appendicitis: a molecular marker for extent of disease?. The American surgeon. 2000;66:914-8. discussion 8–9. [pmid: 11261616].
285 Pfister SA, Deckart A, Laschke S, Dellas S, Otto U, Buitrago C, et al. Unenhanced helical computed tomography vs intravenous urography in patients with acute flank pain: accuracy and economic impact in a randomized prospective trial. European radiology. 2003;13:2513-20. [pmid: 12898174].
286 Pickhardt PJ, Levy AD, Rohrmann CA Jr, Kende AI. Primary neoplasms of the appendix manifesting as acute appendicitis: CT findings with pathologic comparison. Radiology. 2002;224:775-81. [pmid: 12202713].
287 Pokharel N, Sapkota P, Kc B, Rimal S, Thapa S, Shakya R. Acute appendicitis in elderly patients: a challenge for surgeons. Nepal Medical College journal : NMCJ. 2011;13:285-8. [pmid: 23016482].
288 Poon RT, Chu KW. Inflammatory cecal masses in patients presenting with appendicitis. World journal of surgery. 1999;23:713-6. discussion 6. [pmid: 10390592].
289 Premaratna R, Bailey MS, Ratnasena BG, de Silva HJ. Dengue fever mimicking acute appendicitis. Transactions of the Royal Society of Tropical Medicine and Hygiene. 2007;101:683-5. [pmid: 17368695].
290 Puri G, Leung Alexander, Kovach Fran E. What clinical presentations and inflammatory markers can be used in the clinical diagnosis of appendicitis in adults?. Evidence-Based Practice. 2014;17:E-15.
291 Quillin SP, Siegel MJ, Coffin CM. Acute appendicitis in children: value of sonography in detecting perforation. AJR American journal of roentgenology. 1992;159:1265-8. [pmid: 1442398].
292 Quillin SP, Siegel MJ. Diagnosis of appendiceal abscess in children with acute appendicitis: value of color Doppler sonography. AJR American journal of roentgenology. 1995;164:1251-4. [pmid: 7717241].
293 Raines A, Garwe T, Wicks R, Palmer M, Wood F, Adeseye A, Tuggle D. Pediatric appendicitis: the prevalence of systemic inflammatory response syndrome upon presentation and its association with clinical outcomes. J Pediatr Surg. Dec. 2013;48(12):2442-5. [pmid: 24314184].
294 Ramdial PK, Madiba TE, Kharwa S, Clarke B, Zulu B. Isolated amoebic appendicitis. Virchows Archiv : an international journal of pathology. 2002;441:63-8. [pmid: 12111202].
295 Rana F, Shaikh MM, Rajyaguru P. A life-threatening cause of abdominal pain. Acute Med. 97. 2014;13(2):77-8. [pmid: 25073201].
296 Rao PM, Rhea JT, Novelline RA. Distal appendicitis: CT appearance and diagnosis. Radiology. 1997;204:709-12. [pmid: 9280247].
297 Rao PM, Rhea JT, Novelline RA. Sensitivity and specificity of the individual CT signs of appendicitis: experience with 200 helical appendiceal CT examinations. Journal of computer assisted tomography. 1997;21:686-92. [pmid: 9294553].
298 Rao PM, Rhea JT, Wittenberg J, Warshaw AL. Misdiagnosis of primary epiploic appendagitis. American journal of surgery. 1998;176:81-5. [pmid: 9683140].
299 Rao PM, Wittenberg J, Lawrason JN. Primary epiploic appendagitis: evolutionary changes in CT appearance. Radiology. 1997;204:713-7. [pmid: 9280248].
300 Rashid A, Nazir S, Kakroo SM, Chalkoo MA, Razvi SA, Wani AA. Laparoscopic interval appendectomy versus open interval appendectomy: A prospective randomized controlled trial. Surg Laparosc Endosc Percutan Tech. Feb. 2013;23(1):93-6. [pmid: 23386160].
301 Reich JD, Brogdon B, Ray WE, Eckert J, Gorell H. Use of CT scan in the diagnosis of pediatric acute appendicitis. Pediatric emergency care. 2000;16:241-3. [pmid: 10966341].
302 Riesenman PJ, Riesenman KP, Stone TJ, Beidler SK, Douillet CD, Rich PB. Nonfocused enhanced CT evaluation of acute appendicitis increases length of stay in the emergency department but does not increase perforation rate. The American surgeon. 2008;74:488-92. discussion 92–3. [pmid: 18556990].
303 Rimon A, Daneman A, Gerstle JT, Ratnapalan S. Omental infarction in children. The Journal of pediatrics. 2009;155:427-31.e1. [pmid: 19540514].
304 Ringl H, Schernthaner RE, Kulinna-Cosentini C, Weber M, Schaefer-Prokop C, Herold CJ, et al. Lossy three-dimensional JPEG2000 compression of abdominal CT images: assessment of the visually lossless threshold and effect of compression ratio on image quality. Radiology. 2007;245:467-74. [pmid: 17890355].
305 Rioux M, Langis P. Primary epiploic appendagitis: clinical, US, and CT findings in 14 cases. Radiology. 1994;191:523-6. [pmid: 8153333].
306 Rivera-Chavez FA, Peters-Hybki DL, Barber RC, Lindberg GM, Jialal I, Munford RS, et al. Innate immunity genes influence the severity of acute appendicitis. Annals of surgery. 2004;240:269-77. [pmid: 15273551].
307 Rivera-Chavez FA, Wheeler H, Lindberg G, Munford RS, O’Keefe GE. Regional and systemic cytokine responses to acute inflammation of the vermiform appendix. Annals of surgery. 2003;237:408-16. [pmid: 12616126].
308 Roach JP, Partrick DA, Bruny JL, Allshouse MJ, Karrer FM, Ziegler MM. Complicated appendicitis in children: a clear role for drainage and delayed appendectomy. American journal of surgery. 2007;194:769-72. discussion 72–3. [pmid: 18005769].
309 Roosevelt GE, Reynolds SL. Does the use of ultrasonography improve the outcome of children with appendicitis?. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. 1998;5:1071-5. [pmid: 9835468].
310 Rose JS, Becker JA, Staiano SJ, Campos E. Proceedings: B-mode sonographic evaluation of abdominal masses in the pediatric patient. The American journal of roentgenology, radium therapy, and nuclear medicine. 1974;120:691-8.
311 Rothrock SG, Skeoch G, Rush JJ, Johnson NE. Clinical features of misdiagnosed appendicitis in children. Annals of emergency medicine. 1991;20:45-50. [pmid: 1984727].
312 Roviaro GC, Vergani C, Varoli F, Francese M, Caminiti R, Maciocco M. Videolaparoscopic appendectomy: the current outlook. Surgical endoscopy. 2006;20:1526-30. [pmid: 16897293].
313 Sabbagh C, Brehant O, Dupont H, Browet F, Pequignot A, Regimbeau JM. The feasibility of short-stay laparoscopic appendectomy for acute appendicitis: a prospective cohort study. Surgical endoscopy. 2012;26:2630-8. [pmid: 22441976].
314 Sand M, Bechara FG, Holland-Letz T, Sand D, Mehnert G, Mann B. Diagnostic value of hyperbilirubinemia as a predictive factor for appendiceal perforation in acute appendicitis. American journal of surgery. 2009;198:193-8. [pmid: 19306980].
315 Sand M, Gelos M, Bechara FG, Sand D, Wiese TH, Steinstraesser L, et al. Epiploic appendagitis--clinical characteristics of an uncommon surgical diagnosis. BMC surgery. 2007;7:11. [pmid: 17603914].
316 Sasmal PK, Tantia O, Patle N, Khanna S. Omental torsion and infarction: a diagnostic dilemma and its laparoscopic management. Journal of laparoendoscopic & advanced surgical techniques Part A. 2010;20:225-9. [pmid: 20180656].
317 Schlinkert RT, Sarr MG, Donohue JH, Thompson GB. General surgical laparoscopic procedures for the “nonlaparologist”. Mayo Clinic proceedings. 1995;70:1142-7. [pmid: 7490914].
318 Scott JH 3rd, Amin M, Harty JI. Abnormal urinalysis in appendicitis. The Journal of urology. 1983;129:1015. [pmid: 6854742].
319 Seah MD, Ng KC. Pitfalls in paediatric appendicitis: Highlighting common clinical features of missed cases. Asian journal of surgery/Asian Surgical Association. 2006;29:262-6. [pmid: 17098660].
320 See CC, Glassman M, Berezin S, Inamdar S, Newman LJ. Emergency ultrasound in the evaluation of acute-onset abdominal pain in children. Pediatric emergency care. 1988;4:169-71. [pmid: 3054822].
321 Shapira SC, Weiss DB, Jersky Y. Quantitative peritoneal lavage in evaluating acute abdominal pain of gynecological origin. International surgery. 1983;68:171-3. [pmid: 6885300].
322 Shen GK, Wong R, Daller J, Melcer S, Tsen A, Awtrey S, et al. Does the retrocecal position of the vermiform appendix alter the clinical course of acute appendicitis? A prospective analysis. Archives of surgery (Chicago, Ill : 1960). 1991;126:569-70.
323 Sheu BF, Chiu TF, Chen JC, Tung MS, Chang MW, Young YR. Risk factors associated with perforated appendicitis in elderly patients presenting with signs and symptoms of acute appendicitis. ANZ journal of surgery. 2007;77:662-6. [pmid: 17635280].
324 Shindoh J, Niwa H, Kawai K, Ohata K, Ishihara Y, Takabayashi N, et al. Predictive factors for negative outcomes in initial non-operative management of suspected appendicitis. Journal of gastrointestinal surgery : official journal of the Society for Surgery of the Alimentary Tract. 2010;14:309-14. [pmid: 19936849].
325 Shindoh J, Niwa H, Kawai K, Ohata K, Ishihara Y, Takabayashi N, et al. Diagnostic power of inflammatory markers in predicting severity of appendicitis. Hepato-gastroenterology. 2011;58:2003-6. [pmid: 22234068].
326 Siewert B, Raptopoulos V, Liu SI, Hodin RA, Davis RB, Rosen MP. CT predictors of failed laparoscopic appendectomy. Radiology. 2003;229:415-20. [pmid: 14595145].
327 Simeone JF, Novelline RA, Ferrucci JT Jr, DeLuca SA, McCabe CJ, Mueller PR, et al. Comparison of sonography and plain films in evaluation of the acute abdomen. AJR American journal of roentgenology. 1985;144:49-52. [pmid: 3880628].
328 Singh KJ. Acute appendicitis and the leucocyte count. The Medical journal of Malaysia. 1980;34:314-6. [pmid: 7412672].
329 Sirvanci M, Tekelioglu MH, Duran C, Yardimci H, Onat L, Ozer K. Primary epiploic appendagitis: CT manifestations. Clinical imaging. 2000;24:357-61. [pmid: 11368937].
330 Sleem R, Fisher S, Gestring M, Cheng J, Sangosanya A, Stassen N, et al. Perforated appendicitis: is early laparoscopic appendectomy appropriate?. Surgery. 2009;146:731-7. discussion 7–8. [pmid: 19789033].
331 Slotboom T, Hamminga JT, Hofker HS, Heineman E, Haveman JW. Apple Study Group Appendicitis and Laparoscopic Evaluation. Intraoperative Motive for Performing a Laparoscopic Appendectomy on a Postoperative Histological Proven Normal Appendix. Scand J Surg. Dec. 2014;103(4):245-8. [pmid: 24737848].
332 Smith F. THE RELATIVE VALUE OF THE DIFFERENT ESSENTIAL PHASES IN THE WHITE CELL AND DIFFERENTIAL COUNT IN THE DIAGNOSIS OF APPENDICITIS. Canadian Medical Association journal. 1939;41:138-40. [pmid: 20321428].
333 Soyer P, Dohan A, Eveno C, Naneix AL, Pocard M, Pautrat K, et al. Pitfalls and mimickers at 64-section helical CT that cause negative appendectomy: an analysis from 1057 appendectomies. Clinical imaging. 2013;37:895-901. [pmid: 23845254].
334 St Peter SD, Sharp SW, Holcomb GW 3rd, Ostlie DJ. An evidence-based definition for perforated appendicitis derived from a prospective randomized trial. Journal of pediatric surgery. 2008;43:2242-5. [pmid: 19040944].
335 Storm-Dickerson TL, Horattas MC. What have we learned over the past 20 years about appendicitis in the elderly?. American journal of surgery. 2003;185:198-201. [pmid: 12620555].
336 Strauther GR, Longo WE, Virgo KS, Johnson FE. Appendicitis in patients with previous spinal cord injury. American journal of surgery. 1999;178:403-5. [pmid: 10612537].
337 Suh SW, Choi YS, Park JM, Kim BG, Cha SJ, Park SJ, et al. Clinical factors for distinguishing perforated from nonperforated appendicitis: a comparison using multidetector computed tomography in 528 laparoscopic appendectomies. Surgical laparoscopy, endoscopy & percutaneous techniques. 2011;21:72-5.
338 Suthikeeree W, Lertdomrongdej L, Charoensak A. Diagnostic performance of CT findings in differentiation of perforated from nonperforated appendicitis. Journal of the Medical Association of Thailand. Chotmaihet thangphaet. 2010;93:1422-9. [pmid: 21344805].
339 Takada T, Yasuda H, Uchiyama K, Hasegawa H, Shikata J. Ultrasonographic diagnosis of acute appendicitis in surgical indication. International surgery. 1986;71:9-13. [pmid: 3522471].
340 Taourel P, Baron MP, Pradel J, Fabre JM, Seneterre E, Bruel JM. Acute abdomen of unknown origin: impact of CT on diagnosis and management. Gastrointestinal radiology. 1992;17:287-91. [pmid: 1426841].
341 Thereaux J, Veyrie N, Corigliano N, Servajean S, Czernichow S, Bouillot JL. Is laparoscopy a safe approach for diffuse appendicular peritonitis? Feasibility and determination of risk factors for post-operative intra-abdominal abscess. Surg Endosc. Jun. 2014;28(6):1908-13. [pmid: 24414463].
342 Todd RD, Sarosi GA, Nwariaku F, Anthony T. Incidence and predictors of appendiceal tumors in elderly males presenting with signs and symptoms of acute appendicitis. American journal of surgery. 2004;188:500-4. [pmid: 15546558].
343 Towfigh S, Chen F, Mason R, Katkhouda N, Chan L, Berne T. Laparoscopic appendectomy significantly reduces length of stay for perforated appendicitis. Surgical endoscopy. 2006;20:495-9. [pmid: 16437274].
344 Trent SA, Valley MA, Brookler K, Haukoos JS, Zerzan JT. Potential barriers associated with increased prevalence of perforated appendicitis in Colorado’s pediatric Medicaid population. [pmid: 23347715].
345 Trout AT1, Towbin AJ, Zhang B. Journal club: The pediatric appendix: defining normal. AJR Am J Roentgenol. May. 2014;202(5):936-45. [pmid: 24758645].
346 Tsai HM, Shan YS, Lin PW, Lin XZ, Chen CY. Clinical and imaging characteristics relating to surgical outcomes of perforated appendicitis. Hepato-gastroenterology. 2008;55:127-32. [pmid: 18507091].
347 Tsioplis C, Brockschmidt C, Sander S, Henne-Bruns D, Kornmann M. Factors influencing the course of acute appendicitis in adults and children. Langenbeck’s archives of surgery/Deutsche Gesellschaft fur Chirurgie. 2013;398:857-67.
348 Tsuboi M, Takase K, Kaneda I, Ishibashi T, Yamada T, Kitami M, et al. Perforated and nonperforated appendicitis: defect in enhancing appendiceal wall--depiction with multi-detector row CT. Radiology. 2008;246:142-7. [pmid: 18096535].
349 Tsukada K, Miyazaki T, Katoh H, Masuda N, Ojima H, Fukuchi M, et al. CT is useful for identifying patients with complicated appendicitis. Digestive and liver disease : official journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2004;36:195-8.
350 Tsukada K, Miyazaki T, Katoh H, Masuda N, Ojima H, Fukuchi M, et al. Clinical factors influencing CT findings in patients with acute appendicitis. Hepato-gastroenterology. 2005;52:1748-51. [pmid: 16334771].
351 Tsze DS, Asnis LM, Merchant RC, Amanullah S, Linakis JG. Increasing computed tomography use for patients with appendicitis and discrepancies in pain management between adults and children: an analysis of the NHAMCS. Annals of emergency medicine. 2012;59:395-403. [pmid: 21802777].
352 Tuladhar AS, Adhikari RC, Shrestha S, Sharma SK, Pradhan S, Shrestha A, Tuladhar AG. Role of USG guided FNAC in diagnosis of abdominal and thoracic lesions. Nepal Med Coll J. Dec. 2012;14(4):271-4. [pmid: 24579532].
353 van Breda Vriesman AC, Lohle PN, Coerkamp EG, Puylaert JB. Infarction of omentum and epiploic appendage: diagnosis, epidemiology and natural history. European radiology. 1999;9:1886-92. [pmid: 10602970].
354 Vaughan-Shaw P, Richardson C, Lewis M. White cell count and C-reactive protein measurement in patients with possible appendicitis. Annals of the Royal College of Surgeons of England. 2011;93:183. [pmid: 22041163].
355 Vaziri M, Pazouki A, Tamannaie Z, Maghsoudloo F, Pishgahroudsari M, Chaichian S. Comparison of pre-operative bilirubin level in simple appendicitis and perforated appendicitis. [pmid: 24791119].
356 Vazquez BJ, Thomas R, Pfluke J, Doski J, Cofer B, Robertson F, et al. Clinical presentation and treatment considerations in children with acute omental torsion: a retrospective review. The American surgeon. 2010;76:385-8. [pmid: 20420248].
357 Victoria T, Mahboubi S. Normal appendiceal diameter in children: does choice of CT oral contrast (VoLumen versus Gastrografin) make a difference?. Emergency radiology. 2010;17:397-401. [pmid: 20461432].
358 Westwood DA, Eglinton TW. Antibiotics may not improve short-term or long-term outcomes in acute uncomplicated diverticulitis. [pmid: 22723593].
359 Walker A, Hatch Q, Drake T, Nelson DW, Fitzpatrick E, Bingham J, Black G, Maykel JA, Steele SR. Predictors of appendiceal perforation in an equal access system.
360 Walsh PF, Crawford D, Crossling FT, Sutherland GR, Negrette JJ, Shand J. The value of immediate ultrasound in acute abdominal conditions: a critical appraisal. Clinical radiology. 1990;42:47-9. [pmid: 2202538].
361 Walsh RM, Popovich MJ, Hoadley J. Bedside diagnostic laparoscopy and peritoneal lavage in the intensive care unit. Surgical endoscopy. 1998;12:1405-9. [pmid: 9822467].
362 Wang CC, Tu CC, Wang PC, Lin HC, Wei PL. Outcome Comparison between Laparoscopic and Open Appendectomy: Evidence from a Nationwide Population-Based Study. PLoS One. Jul. 12. 2013;8(7):e68662. [pmid: 23874710].
363 Wang YB, Ba CF, Li DN, Liu JH. Is it safe to delay appendectomy overnight?. Am Surg. Feb. 2013;79(2):217-9. [pmid: 23336666].
364 Watters JM, Blakslee JM, March RJ, Redmond ML. The influence of age on the severity of peritonitis. Canadian journal of surgery Journal canadien de chirurgie. 1996;39:142-6. [pmid: 8769925].
365 Wen SW, Demissie K, August D, Rhoads GG. Level of aggregation for optimal epidemiological analysis: the case of time to surgery and unnecessary removal of the normal appendix. Journal of epidemiology and community health. 2001;55:198-203. [pmid: 11160175].
366 Wong CH, Trinh TM, Robbins AN, Rowen SJ, Cohen AJ. Diagnosis of appendicitis: imaging findings in patients with atypical clinical features. AJR American journal of roentgenology. 1993;161:1199-203. [pmid: 8249725].
367 Woodward MN, Griffiths DM. Use of dipsticks for routine analysis of urine from children with acute abdominal pain. BMJ (Clinical research ed). 1993;306:1512.
368 Wu CT, Lim KE. A retrospective study of CT findings in cases undergoing appendectomy at a single hospital. Clinical imaging. 2007;31:239-43. [pmid: 17599617].
369 Wu HS, Lai HW, Kuo SJ, Lee YT, Chen DR, Chi CW, Huang MH. Competitive edge of laparoscopic appendectomy versus open appendectomy: a subgroup comparison analysis (Provisional abstract). Journal of Laparoendoscopic and Advanced Surgical Techniques. 2011:197-202. [pmid: 21284519].
370 Wu KL, Changchien CS, Kuo CH, Chiu KW, Lu SN, Kuo CM, et al. Early abdominal sonographic findings in patients with dengue fever. Journal of clinical ultrasound : JCU. 2004;32:386-8. [pmid: 15372445].
371 Yaghmai V, Aghaei-Lasboo A, Brandwein WM, Tochetto S, Mafi JN, Miller FH, et al. MDCT appearance of the appendix: how does the low-density barium sulfate oral contrast agent affect it?. Emergency radiology. 2011;18:11-5. [pmid: 20683631].
372 Yamamoto M, Ando T, Kanai S, Natsume H, Miyake K, Mitsuya H. Abnormal urinalysis in acute appendicitis. Hinyokika kiyo Acta urologica Japonica. 1985;31:1723-5. [pmid: 4091121].
373 Yeung KW, Chang MS, Hsiao CP. Evaluation of perforated and nonperforated appendicitis with CT. Clinical imaging. 2004;28:422-7. [pmid: 15531143].
374 Yokoyama S, Takifuji K, Hotta T, Matsuda K, Nasu T, Nakamori M, et al. C-Reactive protein is an independent surgical indication marker for appendicitis: a retrospective study. World journal of emergency surgery : WJES. 2009;4:36. [pmid: 19878592].
375 Yoon DY, Chu J, Chandler C, Hiyama S, Thompson JE, Hines OJ. Human cytokine levels in nonperforated versus perforated appendicitis: molecular serum markers for extent of disease?. The American surgeon. 2002;68:1033-7. [pmid: 12516803].
376 Zaninotto G, Rossi M, Anselmino M, Costantini M, Pianalto S, Baldan N, Pizzato D, Ancona E. Laparoscopic versus conventional surgery for suspected appendicitis in women (Structured abstract). Surgical Endoscopy - Ultrasound and Interventional Techniques. 1995:337-40.
377 Zhang WF, Xu CX, Liu YH, Huang GJ. A randomized controlled study in the appendectomy of 103 cases with laparoscope or mini incision. Modern Journal of Physicians. 1998:8-9.
378 Zhang Y, Zhao YY, Qiao J, Ye RH. Diagnosis of appendicitis during pregnancy and perinatal outcome in the late pregnancy. Chinese medical journal. 2009;122:521-4. [pmid: 19323901].
379 Zissin R, Gayer G, Kots E, Apter S, Peri M, Shapiro-Feinberg M. Imaging of mucocoele of the appendix with emphasis on the CT findings: a report of 10 cases. Clinical radiology. 1999;54:826-32. [pmid: 10619300].
380 Zyluk A, Ostrowski P. An analysis of factors influencing accuracy of the diagnosis of acute appendicitis. Polski przeglad chirurgiczny. 2011;83:135-43. [pmid: 22166315].