# Search Strategies

## A-1 PubMed/MEDLINE^®^

Date run 7/31/2013), citations retrieved 21,650.

1. ("0001/01/01"[PDAT] : "2013/07/31"[PDAT])
  AND
2. (("Computerized tomography" OR "Computed tomography" OR "CT" or enhancement* ) OR (Ultrasonography OR Sonography OR US OR ultrasound OR ultra-sound) OR ("MR" OR magnetic resonance OR MRI OR "magnetic resonance imaging"[MeSH] ) OR (Radiography[MeSH] OR Tomography, x-ray computed[MeSH] OR Tomography scanners, x-ray computed[MeSH] OR Tomography, spiral computed[MeSH] ) OR ("radionuclide imaging"[Subheading] OR (radionuclide* AND imaging) ) OR laparoscop* OR "laparoscopy"[MeSH Terms] OR skin temperature OR fever OR temperature OR ((McBurney OR obturator OR psoas OR rovsing*) AND (sign OR point) ) OR (rectal AND exam*) OR "acute-phase proteins"[MeSH Terms] OR ("c reactive protein" OR crp ) OR (urine test OR white blood cell count OR WBC OR leukocyte* OR acute phase proteins) OR (DT OR decision* tools OR decision* support system OR algorithm OR scoring system) OR ((Alvarado OR Mantrels) AND ( test OR tests OR score OR scores )) OR checklist* OR algorith* OR (slide rule*) OR calculator* OR (score OR scores) OR (practice AND guideline* ) OR (progno* AND (model OR modeling OR models)) OR (decision support system* ) OR computer* OR (decision tree*) OR (decision analy*) OR (decision aid*) OR (decision tool*) OR (advisory AND (system OR systems)) OR nomogram* OR expert system$ OR neural network* OR artificial intellig* OR machine learning OR Bayes* OR "decision support systems, clinical"[MeSH] OR "decision support systems, management"[MeSH] OR "decision support techniques"[MeSH] OR "artificial intelligence"[MeSH] OR "decision making, computer assisted"[MeSH] OR "medical informatics"[MeSH] OR "information systems"[MeSH] OR "decision making"[MeSH] OR "Reminder Systems"[MeSH] OR "Hospital Information Systems"[MeSH] OR "Management Information Systems"[MeSH] OR "Medical Records Systems, Computerized"[MeSH] OR "Computers"[MeSH] OR (information system*) OR informatic* OR (predict*[tiab] OR predictive value of tests[mh] OR (score[tiab] OR scores[tiab] OR scoring[tiab])) OR "clinical prediction" OR "clinical model*" OR "clinical score*" OR "decision rule*" OR "diagnostic accuracy" OR "diagnostic rule*" OR "diagnostic score*" OR "diagnostic value" OR "predictive outcome*" OR "predictive rule*" OR "predictive score*" OR "predictive value" OR "predictive risk*" OR "prediction outcome*" OR "prediction rule*" OR "prediction score*" OR "prediction value*" OR "prediction risk*" OR "risk assessment" OR "risk score*" OR (clinical[tiab] AND predict*[tiab]) OR (clinical[tiab] AND model*[tiab]) OR (clinical[tiab] AND (score [tiab] OR scores[tiab] OR scoring[tiab])) OR (decision [tiab] AND rule*[tiab]) OR (derive*[tiab] AND validat*[tiab]) OR ( (diagnosi*[tiab] OR diagnost*[tiab] OR diagnose*[tiab]) AND accura*[tiab]) OR ((diagnosi*[tiab] OR diagnost*[tiab] OR diagnose*[tiab]) AND rule*[tiab]) OR ((diagnosi*[tiab] OR diagnost*[tiab] OR diagnose*[tiab]) AND (score [tiab] OR scores[tiab] OR scoring[tiab])) OR ((diagnosi*[tiab] OR diagnost*[tiab] OR diagnose*[tiab]) AND value[tiab]) OR (predict*[tiab] AND outcome*[tiab]) OR (predict*[tiab] AND rule*[tiab]) OR (predict*[tiab] AND (score[tiab] OR scores[tiab] OR scoring[tiab]))OR (risk*[tiab] AND assessment*[tiab]) OR (risk[tiab] AND (score[tiab] OR scores[tiab] OR scoring[tiab])))
  AND
3. ("abdomen, acute"[MeSH] OR "appendicitis"[MeSH] OR "appendectomy"[MeSH] OR "appendix"[MeSH] OR (acute AND (abdome* OR abdomi*) AND pain) OR appendic* OR appendec* OR appendicec* OR appendix OR ( (non?specific) AND (abdome* OR abdomi*) AND pain) OR nsap OR RLQ pain OR (right AND lower AND (quarter OR quadrant) AND pain) OR (acute AND abdominal AND pain) OR AAP)

## A-2 Embase^®^

Because the search strategy developed for MEDLINE, initially retrieved an overwhelming number of citations, it was decided in consultation with the TEP to limit that strategy to the years 2008-present and develop a less sensitive strategy for the older articles. The two strategies are listed below.

### EMBASE search 1 (more sensitive and limited to 2008-present, run 8/23/13; citations retrieved: 7200)

1. #13: #11 NOT 'case report'/de AND [humans]/lim AND [embase]/lim AND [2008–2013]/py
2. #11: #8 AND #10
3. #10: sensitivity OR specificity OR (predictive AND value) OR 'diagnosis'/exp OR (roc AND curve) OR diagnostic OR (reference AND values) OR (false AND (negative OR positive)) OR (diagnostic ANDerrors) OR 'accuracy'/exp OR 'screening'/exp OR 'prediction'/exp OR identify OR identification OR tests OR outcome
4. #8: #1 AND #6 and #7
5. #7: #2 OR #5
6. #6: 'accuracy'/exp OR accurate OR 'diagnosis'/exp OR diagnostic OR diagnose
7. #5: 'checklist'/exp OR 'algorithm'/exp OR (slide AND rule) OR 'calculator'/exp OR score OR scores OR (practice AND guideline) OR ('prognosis'/exp AND 'model'/exp) OR (decision AND (support ANDsystem OR 'tree'/exp OR 'analysis'/exp OR aid OR tool OR support AND 'technique'/exp OR making)) OR 'nomogram'/exp OR 'nomograms'/exp OR (expert OR experts OR advisory AND (systemOR systems)) OR (neural AND (network OR networks)) OR (artificial AND 'intelligence'/exp) OR 'machine'/exp AND 'learning'/exp OR bayes OR bayesian OR (predictive AND (value OR outcome)) OR (decision AND support AND systems) OR (diagnostic AND ('accuracy'/exp OR rule OR score OR value)) OR (clinical AND predicition) OR ('risk'/exp AND (prediciton OR assesment OR score))
8. #2: 'tomography'/exp OR 'ultrasonography'/exp OR (magnetic AND resonance AND 'imaging'/exp) OR 'laparoscopy'/exp OR laparoscopic OR 'ultrasound'/exp OR 'ultra sound'/exp OR 'sonography'/exp OR 'mri'/exp OR 'x ray'/exp OR ('radionuclide'/exp AND 'imaging'/exp) OR 'radiography'/exp OR ('skin'/exp AND 'temperature'/exp) OR 'fever'/exp OR mcburney OR 'obturator'/exp OR psoas ORrovsing OR ('rectal'/exp AND (exam OR exams)) OR ('acute phase' AND 'proteins'/exp) OR (c AND reactive AND 'protein'/exp) OR 'crp'/exp OR 'leukocytes'/exp OR (acute AND phase AND'proteins'/exp) OR ('urine'/exp AND test) OR (white AND 'blood'/exp AND 'cell'/exp AND count) OR 'wbc'/exp OR 'leukocyte'/exp OR alvarado OR mantrels
9. #1: 'appendicitis'/exp OR 'appendix'/exp OR ('abdomen'/exp AND acute) OR 'appendectomy'/exp OR (acute AND (abdominal OR abdomenal) AND 'pain'/exp) OR (nonspecific OR 'non specific' OR nonAND specific AND (abdominal OR abdomenal) AND 'pain'/exp) OR (rlq OR (right AND lower AND quadrant) AND 'pain'/exp) OR aap OR nsap AND [humans]/lim AND [embase]/lim

### EMBASE search 2 (less sensitive no date limit, run 9/4/13; citations retrieved: 1213)

1. #4 #1 AND #3
2. #3 abdomen, AND acute OR 'appendicitis'/exp OR 'appendectomy'/exp OR (acute AND (abdome* OR abdomi*) AND 'pain'/exp) OR appendic* OR appendec* OR appendicec* OR 'appendix'/exp OR (non?specificAND (abdome* OR abdomi*) AND 'pain'/exp) OR nsap OR rlq AND 'pain'/exp OR (right AND lower AND (quarter OR quadrant) AND 'pain'/exp) OR (acute AND abdominal AND 'pain'/exp) OR aap AND [humans]/lim AND [embase]/lim
3. #1 'computerized tomography'/exp OR 'computed tomography'/exp OR 'ct' OR enhancement* OR 'ultrasonography'/exp OR 'sonography'/exp OR us OR 'ultrasound'/exp OR 'ultra sound'/exp OR ('mr'/exp ORmagnetic AND resonance) OR 'mri'/exp OR 'magnetic resonance imaging'/exp OR ('radiography'/exp OR tomography, AND 'x ray'/exp AND computed OR 'tomography'/exp AND scanners, AND 'x ray'/exp ANDcomputed OR tomography, AND spiral AND computed) OR 'radionuclide imaging'/exp OR (radionuclide* AND 'imaging'/exp) OR laparoscop* OR 'laparoscopy'/exp OR 'skin'/exp AND 'temperature'/exp OR'fever'/exp OR 'temperature'/exp OR (mcburney OR 'obturator'/exp OR psoas OR rovsing* AND (sign OR point)) OR ('rectal'/exp AND exam*) OR 'acute phase' AND 'proteins'/exp OR 'c reactive protein'/exp OR'crp'/exp OR ('urine'/exp AND test OR white AND 'blood'/exp AND 'cell'/exp AND count OR 'wbc'/exp OR leukocyte* OR acute AND phase AND 'proteins'/exp) OR (dt OR decision* AND tools OR decision* ANDsupport AND system OR 'algorithm'/exp OR scoring AND system) OR (alvarado OR mantrels AND (test OR tests OR score OR scores)) AND [humans]/lim AND [embase]/lim

## A-3 Cochrane Central Register of Controlled Trials

(run 8/23/13; citations retrieved 1127)

1. (abdomen, acute OR appendicitis OR appendectomy OR appendix OR (acute AND (abdome* OR abdomi*) AND pain) OR appendic* OR appendec* OR appendicec* OR appendix OR ( (non?specific) AND (abdome* OR abdomi*) AND pain) OR nsap OR RLQ pain OR (right AND lower AND (quarter OR quadrant) AND pain) OR (acute AND abdominal AND pain) OR AAP)
  AND
2. (("Computerized tomography" OR "Computed tomography" OR CT or enhancement* ) OR (Ultrasonography OR Sonography OR US OR ultrasound OR ultra-sound) OR ("MR" OR magnetic resonance OR MRI OR magnetic resonance imaging ) OR (Radiography OR Tomography, x-ray computed OR Tomography scanners, x-ray computed OR Tomography, spiral computed ) OR (radionuclide imaging OR (radionuclide* AND imaging) ) OR laparoscop* OR laparoscopy OR skin temperature OR fever OR temperature OR ((McBurney OR obturator OR psoas OR rovsing*) AND (sign OR point) ) OR (rectal AND exam*) OR acute-phase proteins OR ("c reactive protein" OR crp ) OR (urine test OR white blood cell count OR WBC OR leukocyte* OR acute phase proteins) OR (DT OR decision* tools OR decision* support system OR algorithm OR scoring system) OR ( (Alvarado OR Mantrels) AND ( test OR tests OR score OR scores )) OR checklist* OR algorith* OR (slide rule*) OR calculator* OR (score OR scores) OR (practice AND guideline* ) OR (progno* AND (model OR modeling OR models)) OR (decision support system* ) OR computer* OR (decision tree*) OR (decision analy*) OR (decision aid*) OR (decision tool*) OR (advisory AND (system OR systems)) OR nomogram* OR expert system$ OR neural network* OR artificial intellig* OR machine learning OR Bayes* OR "decision support systems, clinical" OR "decision support systems, management" OR "decision support techniques" OR "artificial intelligence" OR "decision making, computer assisted" OR "medical informatics" OR "information systems" OR "decision making" OR "Reminder Systems" OR "Hospital Information Systems" OR "Management Information Systems" OR "Medical Records Systems, Computerized" OR "Computers" OR (information system*) OR informatic* OR (predict* OR predictive value of tests OR (score OR scores OR scoring)) OR "clinical prediction" OR "clinical model*" OR "clinical score*" OR "decision rule*" OR "diagnostic accuracy" OR "diagnostic rule*" OR "diagnostic score*" OR "diagnostic value" OR "predictive outcome*" OR "predictive rule*" OR "predictive score*" OR "predictive value" OR "predictive risk*" OR "prediction outcome*" OR "prediction rule*" OR "prediction score*" OR "prediction value*" OR "prediction risk*" OR "risk assessment" OR "risk score*" OR (clinical AND predict*) OR (clinical AND model*) OR (clinical AND (score OR scores OR scoring)) OR (decision AND rule*) OR (derive* AND validat*) OR ( (diagnosi* OR diagnost* OR diagnose*) AND accura*) OR ((diagnosi* OR diagnost* OR diagnose*) AND rule*) OR ((diagnosi* OR diagnost* OR diagnose*) AND (score OR scores OR scoring)) OR ((diagnosi* OR diagnost* OR diagnose*) AND value) OR (predict* AND outcome*) OR (predict* AND rule*) OR (predict* AND (score OR scores OR scoring))OR (risk* AND assessment*) OR (risk AND (score OR scores OR scoring)))

## A-4 Cumulative Index to Nursing and Allied Health Literature (CINAHL^®^)

(run 8/23/13; citations retrieved: 93)

1. S105: S102 AND S103
2. S104: S102 AND S103
3. S103: ((MH "Tomography, Spiral Computed") OR (MH "Tomography, Emission-Computed") OR (MH "Tomography, X-Ray Computed") OR (MH "Multidetector Computed Tomography") or (MH "Radiography") OR (MH "Ultrasonography") OR (MH "Magnetic Resonance Imaging") OR (MH "Laparoscopy") OR (MH "Surgery, Laparoscopic") OR (MH "Fever") OR Computerized tomography OR Computed tomography OR CT OR ultrasonography or ultrasound or ultra-sound or sonography OR mri or magnetic resonance OR x-ray computed OR (MH "Tomography, X-Ray Computed") OR (MH "Tomography, X-Ray") OR (MH "X-Ray Film") OR radionuclide imaging or radiography or tomography scanners or tomography spiral computed OR laparascopic or laparascopy OR laparoscopic or laparoscopy OR skin temperature or fever or temperature OR McBurney OR obturator or psoas OR rovsing OR rectal and (exam or exams) OR acute-phase proteins OR (MH "Acute-Phase Proteins") OR c reactive protein or crp OR urine test OR white blood cell count OR WBC OR leukocyte or leukocytes OR acute phase proteins OR Alvarado OR Mantrels or computer OR checklist or algorithm or slide rule or calculator or score or scores or practice guideline or prognosis model OR decision and (support system or tree or analysis or aid or tool or support technique or making) OR nomogram or nomograms OR expert system or expert systems or advisory system or advisory systems OR neural network OR neural networks OR artificial intelligence OR machine learning OR Bayes OR Bayesian OR medical informatics or information systems or reminder systems or hospital information systems or management information systems or medical records or information system OR (MH "Predictive Value of Tests") OR (MH "Predictive Validity") OR (MH "Decision Support Systems, Clinical") OR (MH "Clinical Assessment Tools") OR predictive outcome or predictive value or clinical predicition or clinical model or clinical score or decision rule or diagnostic accuracy or diagnosis or diagnostic rule or diagnostic score or diagnostic value OR predictive risk or prediction value or prediction risk OR risk assessment OR risk score OR accuracy or accurate or diagnosis or diagnostic or diagnose)
4. S102: (MH "Appendicitis") OR (MH "Appendix")OR (MH "Appendectomy")OR (MH "Abdomen, Acute") OR acute abdomenOR appendicitisOR appendectomyOR appendix or (MH "appendix") OR acute abdominal pain or acute abdomenal pain OR (nonspecific or non-specific or non specific) and (abdominal or abdomenal) and pain OR RLQ pain OR right lower quadrant pain OR right lower quarter pain OR AAP or nsap
5. S52: S50 AND S51
6. S51: ((MH "Tomography, Spiral Computed") OR (MH "Tomography, Emission-Computed") OR (MH "Tomography, X-Ray Computed") OR (MH "Multidetector Computed Tomography") or (MH "Radiography")OR (MH "Ultrasonography") OR (MH "Magnetic Resonance Imaging") OR (MH "Laparoscopy") OR (MH "Surgery, Laparoscopic") OR (MH "Fever") OR Computerized tomography OR Computed tomography OR CT OR ultrasonography or ultrasound or ultra-sound or sonography OR mri or magnetic resonance OR x-ray computed OR (MH "Tomography, X-Ray Computed") OR (MH "Tomography, X-Ray") OR (MH "X-Ray Film") OR radionuclide imaging or radiography or tomography scanners or tomography spiral computed OR laparascopic or laparascopy OR laparoscopic or laparoscopy OR skin temperature or fever or temperature OR McBurney OR obturator or psoas OR rovsing OR rectal and (exam or exams) OR acute-phase proteins OR (MH "Acute-Phase Proteins") OR c reactive protein or crp OR urine test OR white blood cell count OR WBC OR leukocyte or leukocytes OR acute phase proteins OR Alvarado OR Mantrels or computerOR checklist or algorithm or slide rule or calculator or score or scores or practice guideline or prognosis model OR decision and (support system or tree or analysis or aid or tool or support technique or making) OR nomogram or nomograms OR expert system or expert systems or advisory system or advisory systems OR neural network OR neural networks OR artificial intelligence OR machine learning OR Bayes OR Bayesian OR medical informatics or information systems or reminder systems or hospital information systems or management information systems or medical records or information system OR (MH "Predictive Value of Tests") OR (MH "Predictive Validity") OR (MH "Decision Support Systems, Clinical") OR (MH "Clinical Assessment Tools") OR predictive outcome or predictive value or clinical predicition or clinical model or clinical score or decision rule or diagnostic accuracy or diagnosis or diagnostic rule or diagnostic score or diagnostic value OR predictive risk or prediction value or prediction risk OR risk assessment OR risk score OR accuracy or accurate or diagnosis or diagnostic or diagnose)
7. S50: (MH "Appendicitis") OR (MH "Appendix") OR (MH "Appendectomy") OR (MH "Abdomen, Acute") OR acute abdomen OR appendicitis OR appendectomy OR appendix or (MH "appendix") OR acute abdominal pain or acute abdomenal pain OR (nonspecific or non-specific or non specific) and (abdominal or abdomenal) and pain OR RLQ pain OR right lower quadrant pain OR right lower quarter pain OR AAP or nsap