# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CI: Confidence interval
CrI: Credible interval
CT: Computed tomography
EPC: Evidence-based Practice Center
FN: False negative
FP: False positive
MRI: Magnetic resonance imaging
NRCS: Nonrandomized comparative study
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
QUADAS: Quality Assessment of Diagnostic Accuracy Studies
ROC: Received operating characteristic
SRDR: Systematic Review Data Repository
STARD: Standards for Reporting of Diagnostic Accuracy
TEP: Technical Expert Panel
TOO: Task Order Officer
TN: True negative
TP: True positive
US: Ultrasound