# Results

## Results of the Literature Search

The literature search identified 11,768 unique citations. We excluded 9758 citations during title screening and excluded an additional 1568 during abstract screening. During article screening, we excluded an additional 400 (see Appendix D, List of excluded articles) articles that did not meet one or more of the inclusion criteria. We included 29 RCTs and 10 observational studies (Figure 2). We assessed the following outcomes: contrast-induced nephropathy (CIN), need for renal replacement therapy, cardiovascular outcomes, mortality, adverse events, image quality, and diagnostic accuracy. We did not find any studies that examined how the benefits or harms of contrast media differ according to the type of strategy used to prevent CIN.

Figure 2 Results of the literature search

RCT = randomized controlled trial

* Grey literature was not factored into the total number of studies for title screening.

† Sum of excluded abstracts exceeds 1,568 because reviewers were not required to agree on reasons for exclusion.

‡ Sum of excluded articles exceeds 403 because reviewers were not required to agree on reasons for exclusion.

Figure 2 describes the screening and review processes for our literature search results. 11,768 unique citations were identified. During the title and abstract screening process, 11,326 citations were excluded. In the full-text article screening process, a further 403 citations were excluded. A total of 39 studies were included in the report.

## Key Question: What are the comparative benefits and harms of different contrast media in patients receiving imaging studies requiring intravenous or intra-arterial administration?

a. How do benefits or harms of contrast media differ by patient characteristics (known risk factors such as age, comorbidity, glomerular filtration rate, or creatinine clearance)? How do benefits or harms differ by the dose of contrast medium (i.e., by volume of dose and number of doses)?
b. How do benefits or harms of contrast media differ according to the type of preventive strategy used?

### Key Points

- No study comparing one LOCM to another LOCM reported a statistically significant or clinically important difference between study arms, and the overall analysis did not suggest that any one LOCM was superior to another (low strength of evidence).
- In our meta-analysis of RCTs comparing IOCM to a heterogeneous collection of LOCMs, we found a slight reduction in CIN risk for IOCM that just reached statistical significance; the point estimate of this reduction did not exceed a minimally important relative risk difference of 25 percent and is unlikely to be clinically important. This finding was associated with moderate strength of evidence overall, moderate strength of evidence for intra-arterial administration, and low strength of evidence for intravenous administration.
- We found no evidence that the CIN incidence with IOCM or LOCM varies according to patient characteristics or contrast dose.
- For outcomes other than CIN (need for renal replacement therapy, cardiovascular outcomes, mortality, adverse events, image quality, or diagnostic accuracy), we found no difference between IOCM and LOCM. However, these secondary outcomes occurred uncommonly and/or were not reported for all studies; the strength of evidence of no difference was low. The strength of evidence was insufficient for determining whether outcomes other than CIN differed between LOCMs.

### Overall Study Characteristics

We identified five trials that compared two or more LOCMs,20-24 and 25 that compared IOCM with one or more LOCMs.20,25-48 One trial, which compared IOCM to two LOCMs20, was included in both groups. The individual components in the assessment for risk of bias in these 29 RCTs are shown in Appendix F.

No consistent definition of renal impairment was used among studies enrolling patients with chronic renal disease, so we did not attempt to refine the classification of renal impairment in these patient populations. Contrast concentration and administered volume were not consistently reported across studies, thereby precluding meaningful comparisons with respect to contrast dose. None of the studies formally examined the interaction between the primary outcomes and other factors such as demographic characteristics, comorbid conditions, or baseline renal function. The studies were inconsistent about reporting on any measures that may have been used to prevent CIN, and often did not provide any details.

In addition to the RCTs, we identified three observational studies with a total study population of 59,740 that compared two or more LOCMs.49-51 We identified seven studies with a total study population of 108,119 that compared IOCM with one or more LOCMs.52-58 All of the observation studies involved intra-arterial contrast administration except for one (Appendix E, Evidence Table E-12).56

### Low-Osmolar Contrast Media Versus Low-Osmolar Contrast Media

#### Study Characteristics

Of the five trials in the LOCM versus LOCM group (Appendix E, Evidence Tables E-1–E-4), two studies involved intra-arterial injections of the contrast media, and two studies involved intravenous injections. One study reported data on both intra-arterial and intravenous injections.22 One study reported change in GFR as the primary outcome.20 Only one study21 included CIN incidence as a primary outcome. The other studies included changes in serum creatinine as a primary outcome. The five studies had a total of only 429 patients, well below the optimum information size for detecting a minimally important difference in the risk of CIN.

#### Contrast-Induced Nephropathy

In the LOCM versus LOCM group, none of the five studies addressing CIN found a statistically significant difference between the LOCMs that were compared.20-24 Two studies reported serum creatinine or creatinine changes numerically for the entire study population.20-22,24 These two studies reported the following point estimates for the difference in serum creatinine change between LOCMs: 0.02 mg/dl (intravenous),21 0.09 mg/dl (intravenous),22 and 0.01 mg/dl (intra-arterial).22 Corresponding CI's were not reported, but none of these point estimates exceeded the defined minimally important difference. These two studies were also the only ones in the group reporting outcomes that were defined similarly enough to be compared numerically (Appendix E, Evidence Tables E-5a and b). Therefore, we did not attempt further quantitative analysis. This group of studies included three intravenous administration studies and three intra-arterial administration studies (one study looked at both routes of administration). All of the intravenous studies had one or more problems with the risk of bias items included in our assessment of study quality. All of the intra-arterial studies had problems with two or more of the items in our assessment of the risk of bias (Table 3; Appendix F, Appendix G).

Table 3 Summary of the strength of evidence: low-osmolar contrast media versus low-osmolar contrast media

Outcome | No. of RCTs (n) | Study Limitations | Directness | Consistency | Precision | Strength of Evidence^*^ | Summary of Key Outcomes
Development of CIN | 5 (429) | Medium | Direct | Consistent | Imprecise | Low | Low strength of evidence supporting no differences in CIN incidence between LOCMs.
Mortality | 1 (320) | High | Direct | Unknown | Imprecise | Insufficient | Insufficient evidence that any one LOCM lowers the risk of death over another LOCM.
Adverse events | 1 (320) | High | Direct | Unknown | Imprecise | Insufficient | Insufficient evidence that any one LOCM lowers the risk of adverse events over another LOCM.

CIN = contrast induced nephropathy; IOCM = iso-osmolar contrast medium; LOCM = low-osmolar contrast medium; NA = not assessed; RCT = randomized controlled trial; RRT = renal replacement therapy

* Due to heterogeneity in the study limitations across studies, the median study limitation value was chosen when distribution across studies was normal. In the instance where there is a split between study limitation scores, the more conservative study limitation designation was chosen.

The risk of bias was high in these studies because the randomization was inadequately described and/or incomplete outcome data were not adequately addressed. The strength of evidence was low to support a conclusion that different LOCMs have equivalent effects on the incidence of CIN (Table 3; see Appendix G for study limitations). The strength of evidence was low mainly due to the small number of studies and low event rates, with heterogeneous reporting of renal outcomes. Given the small number of studies in this group and the low strength of evidence, it was not meaningful to stratify these results by route of administration.

The results of the 3 applicable observational studies49-51 were similar to those reported in the RCTs; although these observational studies had a large number of patients, we did not upgrade the strength of evidence because of the high risk of bias in the observational studies on the comparison of LOCMs (Appendix E, Evidence Table E-12).

#### Mortality

One study23 reported on mortality, where eight patients out of the total study population of 320 died between a few days and weeks of contrast administration. Contrast nephrotoxicity contributed to or caused three of these deaths (Appendix E, Evidence Table E-5b). The study had a high risk of bias because of inadequately described randomization and incomplete data were not adequately addressed. There was insufficient evidence to support a conclusion about the difference between LOCMs in their effects on mortality (Table 3; see Appendix G for study limitations).

#### Adverse Events

One study23 reported on adverse events. Five percent of the total population of 320 had mild hypersensitivity reactions of nausea, vomiting, or hives (Ioxaglate arm: 20 participants, Iopamidol arm: 7 participants) (Appendix E, Evidence Table E-5b). There were no severe reactions. This study had a high risk of bias because of inadequately described randomization and incomplete data were not adequately addressed. There was insufficient evidence to support a conclusion about the difference between LOCMs in the incidence of adverse events (Table 3; see Appendix G for study limitations).

#### Image Quality and Diagnostic Accuracy

Our search did not identify any studies comparing LOCM to LOCM that reported on image quality or diagnostic accuracy.

#### Benefits or Harms by Patient Characteristics, Dose of Contrast Media, and Type of Preventive Strategy

No studies indicated that a difference existed for a selected subgroup of patients, or for a given dose of contrast media, or for use of a given type of strategy for preventing CIN.

### Iso-Osmolar Contrast Media Versus Low-Osmolar Contrast Media

#### Study Characteristics

Of the 25 trials in the IOCM versus LOCM comparison (Appendix E, Evidence Table E-7), 18 studies involved intra-arterial contrast, and seven studies involved intravenous contrast. These studies involved seven LOCMs (in order of frequency): iopromide (9 studies), iopamidol (7 studies), iohexol (4 studies), iobitridol (2 studies), ioversol (2 studies), ioxaglate (2 studies), and iomeprol (1 study). All but one study20 included CIN incidence or peak change in serum creatinine as a primary outcome. A substantial majority of these studies (19) involved patients with renal impairment and/or diabetes, and more than half (16) involved patients undergoing coronary catheterization. In studies reporting CIN as an outcome, nearly all defined CIN according to one or both of the following criteria: increase in serum creatinine greater than 25 percent or 0.5 mg/dl above baseline within 48-72 hours following contrast injection. Most studies also reported numerical changes in serum creatinine as either the mean or percent maximal difference between baseline and post-procedural values.

#### Contrast-Induced Nephropathy

Twenty-five studies addressed CIN as an outcome in the comparison of IOCM with LOCM.20,25-48 These 25 studies randomized a total of 5097 patients (which is above the optimum information size that we specified) and reported an overall CIN rate of 11.0 percent (270/2449) for IOCM and 13.4 percent (326/2431) for LOCM. For these numbers of patients and event rates, we considered a relative risk difference of 25 percent to be a minimally important difference, that is, a relative risk outside the range from 0.75 to 1.25. Four of 25 studies reported reductions in CIN with IOCM compared to LOCM that were greater than a minimally important difference and statistically significant. Five studies reported reductions in CIN greater than a minimally important difference but not statistically significant. Four studies reported a greater incidence of CIN with IOCM that exceeded a minimally important difference but was not statistically significant. However, no study reported a statistically significant greater CIN incidence with IOCM compared to LOCM.

In meta-analyses including 23 of the IOCM studies reporting CIN incidence, there was a borderline significant reduction in the incidence of CIN with IOCM compared with a diverse group of LOCMs. The extent of reduction was consistent with or without stratification by route of administration (Figure 3). Statistical heterogeneity was relatively low, as indicated by the I-squared results displayed in Figure 3. The combined estimate of pooled relative risk was 0.80; (95% CI: 0.65 to 0.99), which corresponds to a number-needed-to-treat of 42 for the point estimate. The estimated relative risk did not exceed a minimally important difference. One study only reported on GFR and was not included in the meta-analysis. That study20 did not report on a significant change in GFR between groups (Appendix E, Evidence Table E-8). Also excluded from the meta-analyses was one study48 that reported no CIN in either comparison group but did not explicitly state the CIN criteria. Using Harbord's modified test for small study effects, we did not find evidence of asymmetry in results by study precision (bias coefficient of −0.44, standard error of 0.61, p=0.47).

Figure 3 Graphical summary of randomized controlled trials comparing iso-osmolar and low-osmolar contrast media with contrast-induced nephropathy as a primary outcome

CI = confidence interval; CIN = contrast induced nephropathy; IA = intra-arterial; IV = intravenous; IOCM = iso-osmolar contrast media; LOCM = low-osmolar contrast media; N = sample size; P = p-value; RR = risk ratio

Figure 3 shows a graphical summary of randomized controlled trials that compare iso-osmolar and low osmolar contrast media with contrast-induced nephropathy as a primary outcome

We performed simple meta-regression analyses between CIN incidence and each of the following covariates: age, baseline creatinine, diabetes, gender, and route of administration. No statistically significant associations were found, although the statistical power was limited by the small number of studies.

When we considered study results by year of publication, we saw no trend over time in the results of studies comparing IOCM with LOCM for either route of administration.

When the meta-analysis was stratified by the two most studied LOCMs, the aggregate estimate of the pooled relative risk was 0.82 (95% CI: 0.53 to 1.25) for the eight studies comparing IOCM with iopromide (using either route of administration) and 1.05 (95% CI: 0.75 to 1.47) for the five studies comparing IOCM with iopamidol (using either route of administration). The results were similar when we included only studies using intra-arterial administration (6 for iopromide, and three for iopamidol). When we explored the differences in results between these trials, we found no apparent pattern associated with procedure type or study location.

The strength of the overall body of evidence included in the meta-analysis was moderate. For the studies including only intravenous administration of contrast media, the strength of evidence was low that IOCM had a slightly lower risk of CIN than LOCM that was not clinically important (with only borderline statistical significance), and for intra-arterial administration of contrast media, the strength of evidence was moderate that IOCM had a slightly lower risk of CIN than LOCM that was not clinically important (with only borderline statistical significance) (Table 4; see Appendix G for study limitations).

Table 4 Summary of the strength of evidence: iso-osmolar contrast media versus low-osmolar contrast media

Outcome | RCTs (N) | Study Limitations | Directness | Consistency | Precision | Strength of Evidence^*^ | Summary of Key Outcomes
Development of CIN | 25 (5,097) | Medium | Direct | Consistent | Precise | Moderate | Moderate strength of evidence that IOCM had a slightly lower risk of CIN than LOCM; the point estimate of this reduction did not exceed a minimally important relative risk difference of 25% and is unlikely to be clinically important.
Development of CIN (IV administration) | 6 (790) | Medium | Direct | Consistent | Imprecise | Low | Low strength of evidence that IV IOCM had a slightly lower risk of CIN than IV LOCM; the point estimate of this reduction did not exceed a minimally important relative risk difference of 25% and is unlikely to be clinically important.
Development of CIN (IA administration) | 18 (4,194) | Medium | Direct | Consistent | Precise | Moderate | Moderate strength of evidence that IA IOCM had a slightly lower risk of CIN than IA LOCM; the point estimate of this reduction did not exceed a minimally important relative risk difference of 25% and is unlikely to be clinically important.
Need for RRT | 5 (1,740) | Medium | Direct | Consistent | Imprecise | Low | Low strength of evidence that the need for RRT does not differ between IOCM and LOCM.
Cardiovascular outcomes | 7 (2,258) | Medium | Direct | Consistent | Imprecise | Low | Low strength of evidence that cardiovascular outcomes do not differ between IOCM and LOCM.
Mortality | 8 (2,028) | Medium | Direct | Consistent | Imprecise | Low | Low strength of evidence that mortality does not differ between IOCM and LOCM.
Adverse events | 12 (3,363) | Medium | Direct | Consistent | Imprecise | Low | Low strength of evidence that adverse event rates do not differ between IOCM and LOCM.

CIN = contrast induced nephropathy; IA = intra-arterial; IOCM = iso-osmolar contrast medium; IV = intravenous; LOCM = low-osmolar contrast medium; NA = not assessed; RCT = randomized controlled trial; RRT = renal replacement therapy

* Due to heterogeneity in the study limitations across studies, the median study limitation value was chosen when distribution across studies was normal. In the instance where there is a split between study limitation scores, the more conservative study limitation designation was chosen.

The results of the seven applicable observational studies52-58 were similar to those reported in the RCTs. We did not make any changes in the grading of the overall strength of evidence based on the observational studies of the comparison of IOCM versus LOCM (Appendix E, Evidence Table E-12).

#### Need for Renal Replacement Therapy

Five studies reported on the need for hemodialysis or hemofiltration which ranged from 0 to 1.9 percent (Appendix E, Evidence Table E-9). Four involved intra-arterial administration26,33,35,44 and one involved intravenous administration.37 Differences between groups were either not reported or not statistically significant regardless of administration route. The studies reporting on the need for renal replacement therapy had a total of 1740 patients (well below the optimum information size we specified for this relatively rare event). Confidence intervals for relative risks were wide because of the low event rates in studies reporting need for renal replacement therapy. The strength of the overall body of evidence was low, based on the studies included in the overall meta-analysis (Table 4; see Appendix G for study limitations).

#### Cardiovascular Outcomes

Seven studies reporting on IOCM versus LOCM addressed cardiovascular outcomes. All involved intra-arterial administration (Appendix E, Evidence Table E-9). 26,28,32,34,35,39,41 All studies with the exception of one reported no statistically significant differences between groups (in Nie et al., the composite cardiovascular event rate (percent of sample size) was: IOCM arm = 0.1%, LOCM arm = 5.9%, p-value = 0.025).39 This study39 had a medium risk of bias, and we could find no explanation for why its results differed from the other six studies. The studies reporting on cardiovascular outcomes included a total of 2,258 patients (again below the optimum information size for this relatively rare type of adverse outcome). Confidence intervals for relative risks were generally wide because of the low event rates. The strength of the overall body of evidence was low (Table 4; see Appendix G for study limitations).

#### Mortality

Eight studies reporting on IOCM versus LOCM addressed mortality as an outcome (Appendix E, Evidence Table E-9). Two reported on intravenous administration37,38 and six reported on intra-arterial administration.26,27,33-35,38,39 Differences between groups were either not reported or not statistically significant regardless of administration route. The studies reporting on mortality had a total of 2028 patients (below the optimum information size). Confidence intervals for relative risks were generally wide because of the low mortality rates, most of which ranged from 0 to 2.7 percent. One study reported a 9-percent mortality rate across the entire population with 4 percent dying in the LOCM group and 3 percent in the ICOM group (p=0.63).26 The strength of the overall body of evidence was low (Table 4; see Appendix G for study limitations).

#### Adverse Events

Twelve studies reported on adverse events, with a total of 3363 patients, well below the optimum information size for rare events (Appendix E, Evidence Table E-9). Ten reported on intra-arterial administration 26,28,32-36,39,41,44 and two reported on intravenous administration.29,30 Differences between groups were either not reported or not statistically significant regardless of administration route. The overall strength of evidence on adverse events was low (Table 4; see Appendix G for study limitations).

#### Image Quality and Diagnostic Accuracy

Two studies reporting on IOCM versus LOCM addressed imaging quality as an outcome (Appendix E, Evidence Table E-9).29,39 One reported using intra-arterial administration of contrast and reported on image quality,39 while the other study used intravenous contrast administration and reported on diagnostic efficacy.29 Differences between groups were not statistically significant regardless of outcome measure in either study. The intra-arterial administration study had medium risk of bias. The intravenous administration study had low risk of bias. We were unable to grade the body of evidence on image quality due to the differences in the contrast media administration and the difference in outcomes reported.

#### Benefits or Harms by Patient Characteristics, Dose of Contrast Media, and Type of Preventive Strategy

Few studies reported on how differences in outcomes between contrast media varied according to selected study population characteristics such as age, baseline renal function, and presence or absence of diabetes mellitus. Six studies reported outcomes based on subgroups. Rudnick et al. (2008)40 reported that there was no significant difference in outcomes between patients with and without diabetes mellitus and co-administration of N-acetylcysteine. Jo et al. (2006)44 found the incidence of CIN was higher in patients with severe baseline renal impairment. Hernandez et al. (2009)31 reported that baseline GFR and contrast media acted as independent predictors of CIN. Limbruno et al. (2014)25 reported a dose-dependent effect of contrast media on renal function. Solomon et al. (2007)41 showed no significant difference between groups with and without diabetes mellitus.

When we looked at how study populations varied between studies, we found that the vast majority of study populations had a mean age greater than 60 years, with only one done on a young population.29 When we examined forest plots of results ordered by mean age of study patients, mean baseline renal function, or proportion of patients with diabetes mellitus, we did not see any notable trend in the results for groups receiving intravenous contrast media or intra-arterial contrast media. In the absence of any such trend, we did not include a meta-regression by any of these variables.