# References

1 Kitajima K, Maeda T, Watanabe S, et al. (2011). Recent issues in contrast-induced nephropathy. Int J Urol.
2 Bellomo R, Ronco C, Kellum JA, et al. (2004). Acute renal failure - definition, outcome measures, animal models, fluid therapy and information technology needs: the Second International Consensus Conference of the Acute Dialysis Quality Initiative (ADQI) Group. Crit Care.
3 Mehta RL, Kellum JA, Shah SV, et al. (2007). Acute Kidney Injury Network: report of an initiative to improve outcomes in acute kidney injury. Crit Care.
4 Heyman SN, Rosenberger C, Rosen S. (2005). Regional alterations in renal haemodynamics and oxygenation: a role in contrast medium-induced nephropathy. Nephrol Dial Transplant.
5 Persson PB, Hansell P, Liss P. (2005). Pathophysiology of contrast medium-induced nephropathy. Kidney Int.
6 McDonald RJ, McDonald JS, Bida JP, et al. (2013). Intravenous contrast material-induced nephropathy: causal or coincident phenomenon?. Radiology.
7 Fountaine H, Harnish P, Andrew E, et al. (1996). Safety, tolerance, and pharmacokinetics of iodixanol injection, a nonionic, isosmolar, hexa-iodinated contrast agent. Acad Radiol.
8 Swick M. (1966). The discovery of intravenous urography: historical and developmental aspects of the urographic media and their role in other diagnostic and therapeutic areas. Bull N Y Acad Med.
9 Niendorf H. (1996). Delayed allergy-like reactions to X-ray contrast media. European Radiology.
10 Kidney Disease: Improving Global Outcomes (KDIGO) Acute Kidney Injury Work Group. (2012). KDIGO Clinical Practice Guideline for Acute Kidney Injury. Kidney inter, Suppl.
11 McDonald JS, McDonald RJ, Comin J, et al. (2013). Frequency of acute kidney injury following intravenous contrast medium administration: a systematic review and meta-analysis. Radiology.
12 Davenport MS, Khalatbari S, Dillman JR, et al. (2013). Contrast material-induced nephrotoxicity and intravenous low-osmolality iodinated contrast material. Radiology.
13 Cochrane Bias Method Group. (2013). Assessing Risk of Bias in Included Studies.
14 DerSimonian R, Laird N. (1986). Meta-analysis in clinical trials. Control Clin Trials.
15 Higgins JP, Thompson SG, Deeks JJ, et al. (2003). Measuring inconsistency in meta-analyses. BMJ.
16 Selvin E, Juraschek SP, Eckfeldt J, et al. (2013). Within-person variability in kidney measures. Am J Kidney Dis.
17 Toffaletti JG, McDonnell EH. (2008). Variation of serum creatinine, cystatin C, and creatinine clearance tests in persons with normal renal function. Clin Chim Acta.
18 Guyatt GH, Oxman AD, Kunz R, et al. (2011). GRADE guidelines 6. Rating the quality of evidence--imprecision. J Clin Epidemiol.
19 (2014). Methods Guide for Effectiveness and Comparative Effectiveness Reviews.
20 Becker J, Babb J, Serrano M. (2013). Glomerular filtration rate in evaluation of the effect of iodinated contrast media on renal function. AJR Am J Roentgenol.
21 Dillman JR, al-Hawary M, Ellis JH, et al. (2012). Comparative investigation of i.v. iohexol and iopamidol: effect on renal function in low-risk outpatients undergoing CT. AJR Am J Roentgenol.
22 Koutsikos D, Konstadinidou I, Mourikis D, et al. (1992). Contrast media nephrotoxicity: comparison of diatrizoate, ioxaglate, and iohexol after intravenous and renal arterial administration. Ren Fail.
23 Campbell DR, Flemming BK, Mason WF, et al. (1990). A comparative study of the nephrotoxicity of iohexol, iopamidol and ioxaglate in peripheral angiography. Can Assoc Radiol J.
24 Jevnikar AM, Finnie KJ, Dennis B, et al. (1988). Nephrotoxicity of high- and low-osmolality contrast media. Nephron.
25 Limbruno U, Picchi A, Micheli A, et al. (2014). Refining the assessment of contrast-induced acute kidney injury: the load-to-damage relationship. J Cardiovasc Med (Hagerstown).
26 Bolognese L, Falsini G, Schwenke C, et al. (2012). Impact of iso-osmolar versus low-osmolar contrast agents on contrast-induced nephropathy and tissue reperfusion in unselected patients with ST-segment elevation myocardial infarction undergoing primary percutaneous coronary intervention (from the Contrast Media and Nephrotoxicity Following Primary Angioplasty for Acute Myocardial Infarction [CONTRAST-AMI] Trial). Am J Cardiol.
27 Serafin Z, Karolkiewicz M, Gruszka M, et al. (2011). High incidence of nephropathy in neurosurgical patients after intra-arterial administration of low-osmolar and iso-osmolar contrast media. Acta Radiol.
28 Shin DH, Choi DJ, Youn TJ, et al. (2011). Comparison of contrast-induced nephrotoxicity of iodixanol and iopromide in patients with renal insufficiency undergoing coronary angiography. Am J Cardiol.
29 Zo'o M, Hoermann M, Balassy C, et al. (2011). Renal safety in pediatric imaging: randomized, double-blind phase IV clinical trial of iobitridol 300 versus iodixanol 270 in multidetector CT. Pediatr Radiol.
30 Chuang FR, Chen TC, Wang IK, et al. (2009). Comparison of iodixanol and iohexol in patients undergoing intravenous pyelography: a prospective controlled study. Ren Fail.
31 Hernandez F, Mora L, Garcia-Tejada J, et al. (2009). Comparison of iodixanol and ioversol for the prevention of contrast-induced nephropathy in diabetic patients after coronary angiography or angioplasty. Rev Esp Cardiol.
32 Juergens CP, Winter JP, Nguyen-Do P, et al. (2009). Nephrotoxic effects of iodixanol and iopromide in patients with abnormal renal function receiving N-acetylcysteine and hydration before coronary angiography and intervention: a randomized trial. Intern Med J.
33 Laskey W, Aspelin P, Davidson C, et al. (2009). Nephrotoxicity of iodixanol versus iopamidol in patients with chronic kidney disease and diabetes mellitus undergoing coronary angiographic procedures. Am Heart J.
34 Mehran R, Nikolsky E, Kirtane AJ, et al. (2009). Ionic low-osmolar versus nonionic iso-osmolar contrast media to obviate worsening nephropathy after angioplasty in chronic renal failure patients: the ICON (Ionic versus non-ionic Contrast to Obviate worsening Nephropathy after angioplasty in chronic renal failure patients) study. JACC Cardiovasc Interv.
35 Wessely R, Koppara T, Bradaric C, et al. (2009). Choice of contrast medium in patients with impaired renal function undergoing percutaneous coronary intervention. Circulation Cardiovascular interventions.
36 Hardiek KJ, Katholi RE, Robbs RS, et al. (2008). Renal effects of contrast media in diabetic patients undergoing diagnostic or interventional coronary angiography. J Diabetes Complications.
37 Kuhn MJ, Chen N, Sahani DV, et al. (2008). The PREDICT study: a randomized double-blind comparison of contrast-induced nephropathy after low- or isoosmolar contrast agent exposure. AJR Am J Roentgenol.
38 Nguyen SA, Suranyi P, Ravenel JG, et al. (2008). Iso-osmolality versus low-osmolality iodinated contrast medium at intravenous contrast-enhanced CT: effect on kidney function. Radiology.
39 Nie B, Cheng WJ, Li YF, et al. (2008). A prospective, double-blind, randomized, controlled trial on the efficacy and cardiorenal safety of iodixanol vs. iopromide in patients with chronic kidney disease undergoing coronary angiography with or without percutaneous coronary intervention. Catheter Cardiovasc Interv.
40 Rudnick MR, Davidson C, Laskey W, et al. (2008). Nephrotoxicity of iodixanol versus ioversol in patients with chronic kidney disease: the Visipaque Angiography/Interventions with Laboratory Outcomes in Renal Insufficiency (VALOR) Trial. Am Heart J.
41 Solomon RJ, Natarajan MK, Doucet S, et al. (2007). Cardiac Angiography in Renally Impaired Patients (CARE) study: a randomized double-blind trial of contrast-induced nephropathy in patients with chronic kidney disease. Circulation.
42 Barrett BJ, Katzberg RW, Thomsen HS, et al. (2006). Contrast-induced nephropathy in patients with chronic kidney disease undergoing computed tomography: a double-blind comparison of iodixanol and iopamidol. Invest Radiol.
43 Feldkamp T, Baumgart D, Elsner M, et al. (2006). Nephrotoxicity of iso-osmolar versus low-osmolar contrast media is equal in low risk patients. Clin Nephrol.
44 Jo SH, Youn TJ, Koo BK, et al. (2006). Renal toxicity evaluation and comparison between visipaque (iodixanol) and hexabrix (ioxaglate) in patients with renal insufficiency undergoing coronary angiography: the RECOVER study: a randomized controlled trial. J Am Coll Cardiol.
45 Aspelin P, Aubry P, Fransson SG, et al. (2003). Nephrotoxic effects in high-risk patients undergoing angiography. N Engl J Med.
46 Carraro M, Malalan F, Antonione R, et al. (1998). Effects of a dimeric vs a monomeric nonionic contrast medium on renal function in patients with mild to moderate renal insufficiency: a double-blind, randomized clinical trial. Eur Radiol.
47 Jakobsen JA, Berg KJ, Kjaersgaard P, et al. (1996). Angiography with nonionic X-ray contrast media in severe chronic renal failure: renal function and contrast retention. Nephron.
48 Semerci T, Cuhadar S, Akcay FA, et al. (2014). Comparing the renal safety of isoosmolar versus low-osmolar contrast medium by renal biomarkers N-acetyl-beta-D-glucosaminidase and endothelin. Angiology.
49 Donadio C, Lucchesi A, Ardini M, et al. (2001). Renal effects of cardiac angiography with different low-osmolar contrast media. Ren Fail.
50 Ajami G, Derakhshan A, Amoozgar H, et al. (2010). Risk of nephropathy after consumption of nonionic contrast media by children undergoing cardiac angiography: a prospective study. Pediatr Cardiol. Pediatr Cardiol.
51 LaBounty TM, Shah M, Raman SV, et al. (2012). Within-hospital and 30-day outcomes in 107,994 patients undergoing invasive coronary angiography with different low-osmolar iodinated contrast media. Am J Cardiol.
52 Briguori C, Colombo A, Airoldi F, et al. (2005). Nephrotoxicity of low-osmolality versus iso-osmolality contrast agents: impact of N-acetylcysteine. Kidney Int.
53 Hsieh YC, Liu TJ, Liang KW, et al. (2006). Iso-osmolar contrast medium better preserves short- and long-term renal function after cardiovascular catheterizations in patients with severe baseline renal insufficiency. Int J Cardiol.
54 Liss P, Persson PB, Hansell P, et al. (2006). Renal failure in 57 925 patients undergoing coronary procedures using iso-osmolar or low-osmolar contrast media. Kidney Int.
55 Valente S, Lazzeri C, Giglioli C, et al. (2006). Contrast-induced nephropathy in urgent coronary interventions. J Cardiovasc Med (Hagerstown).
56 From AM, Bartholmai BJ, Williams AW, et al. (2008). Iodixanol compared to iohexol for contrast procedures: a case-matched retrospective cohort study. Acta Radiol.
57 Karlsberg RP, Dohad SY, Sheng R. (2010). Contrast-induced acute kidney injury (CI-AKI) following intra-arterial administration of iodinated contrast media. J Nephrol.
58 Kanei Y, Ayabe K, Ratcliffe J, et al. (2011). The impact of iso-osmolar contrast use in emergent percutaneous coronary intervention for ST-segment elevation myocardial infarction. J Invasive Cardiol.
59 Katzberg RW, Newhouse JH. (2010). Intravenous contrast medium-induced nephrotoxicity: is the medical risk really as great as we have come to believe?. Radiology.
60 Zhang BC, Wu Q, Wang C, et al. (2014). A meta-analysis of the risk of total cardiovascular events of isosmolar iodixanol compared with low-osmolar contrast media. J Cardiol.
61 Subramaniam RM, Wilson RF, Turban S, et al. Contrast-induced Nephropathy: Comparative Effectiveness of Prevention Measures.
62 From AM, Al Badarin FJ, McDonald FS, et al. (2010). Iodixanol versus low-osmolar contrast media for prevention of contrast induced nephropathy: meta-analysis of randomized, controlled trials. Circ Cardiovasc Interv.
63 Heinrich MC, Haberle L, Muller V, et al. (2009). Nephrotoxicity of iso-osmolar iodixanol compared with nonionic low-osmolar contrast media: meta-analysis of randomized controlled trials. Radiology.
64 Reed M, Meier P, Tamhane UU, et al. (2009). The relative renal safety of iodixanol compared with low-osmolar contrast media: a meta-analysis of randomized controlled trials. JACC Cardiovasc Interv.
65 Dong M, Jiao Z, Liu T, et al. (2012). Effect of administration route on the renal safety of contrast agents: a meta-analysis of randomized controlled trials. J Nephrol.
66 Hill JA, Winniford M, Cohen MB, et al. (1993). Multicenter trial of ionic versus nonionic contrast media for cardiac angiography. Am J Cardiol.
67 Chalmers N, Jackson RW. (1999). Comparison of iodixanol and iohexol in renal impairment. Br J Radiol.
68 Biondi-Zoccai G, Lotrionte M, Thomsen HS, et al. (2014). Nephropathy after administration of iso-osmolar and low-osmolar contrast media: evidence from a network meta-analysis. Int J Cardiol.
69 Sharma SK, Kini A. (2005). Effect of nonionic radiocontrast agents on the occurrence of contrast-induced nephropathy in patients with mild-moderate chronic renal insufficiency: pooled analysis of the randomized trials. Catheter Cardiovasc Interv.
70 McCullough PA, Bertrand ME, Brinker JA, et al. (2006). A meta-analysis of the renal safety of isosmolar iodixanol compared with low-osmolar contrast media. J Am Coll Cardiol.
71 McCullough PA, Brown JR. (2011). Effects of intra-arterial and intravenous iso-asmolar contrast medium (iodixanol) on the risk of contrast-induced acute kidney injury: a meta-analysis. Cardiorenal Med.
72 Newhouse JH, Roy Choudhury A. (2013). Quantitating contrast medium-induced nephropathy: controlling the controls. Radiology.
73 Mills EJ, Thorlund K, Ioannidis JP. (2013). Demystifying trial networks and network meta-analysis. BMJ.