# Methods

## Topic Refinement and Protocol Review

We developed the Key Question with the input of a key informant panel that included: experts in nephrology, radiology, cardiology, and primary care; patient advocates; representatives from the Food and Drug Administration; and oversight by our Task Order Officer from the Agency for Health Care Research and Quality (AHRQ). We recruited a Technical Expert Panel that provided input to the Evidence-based Practice Center during our development of the protocol for the comparative effectiveness review. The protocol for our review is posted on the AHRQ Web site (http://www.effectivehealthcare.ahrq.gov/).

## Literature Search Strategy

We searched the following databases for primary studies: MEDLINE^®^, EMBASE^®^, and the Cochrane Library through October 1, 2014 (see Appendix B for detailed search strategy). We did not add any date limits to the search. We developed a search strategy for MEDLINE, accessed via PubMed^®^, based on medical subject headings (MeSH^®^) terms and text words of key articles that we identified a priori. We reviewed the Scopus database and the reference lists of relevant review articles and related systematic reviews to identify articles that the database searches might have missed. We searched ClinicalTrials.gov to identify studies for which results have not yet been published. Scientific Information Packages (SIP) were requested from a number of industry representatives. We requested data from the manufacturers of contrast media and searched the U. S. Food and Drug Administration Adverse Event Reporting System (AERS).

We uploaded the articles into DistillerSR (Evidence Partners, Ottawa, Ontario, Canada), a Web-based service for systematic review and data management. We used this database to track the search results at the levels of title review, abstract review, article inclusion/exclusion, and data abstraction.

## Study Selection

We followed the PICOTS (Table 1) framework in developing the criteria for inclusion of studies in the review. We included studies of patients of all ages having low, moderate, or high risk of developing CIN. We anticipated heterogeneity in the baseline risk assessment or stratification, and reported on the baseline assessment as it was defined by studies. To be included, studies had to report the incidence of CIN based on serum creatinine or GFR prior to and after (up to 72 hours) contrast media injection. The studies also had to have an intervention group receiving either IOCM or LOCM via intravenous or intra-arterial injection. The possible comparisons that we considered are listed in Table 1 and detailed in Table 2. We focused on RCTs that addressed the Key Question, but we also looked for relevant observational studies to see if their results were similar to the RCTs. Article inclusion was not restricted by publication date, language was only a restriction at the article screening level. We also evaluated existing systematic reviews on the topic to determine the extent to which they addressed our Key Question and PICOTS and whether they could be updated.

Table 1 PICOTS (populations, interventions, comparisons, outcomes, timing, and setting) criteria for including studies in the review

PICOTS | Criteria
Populations | - All patients (including adults and children) undergoing procedures requiring the administration of contrast media.; - High or moderate risk patients (as defined by clinical or demographic risk factors such as age, cardiovascular and other comorbidities, creatinine level, etc.) vs. low risk or normal patients.; - Patients using contrast media for multiple imaging studies.
Interventions | - IOCM (including dose/volume and number of doses); - LOCM (including dose/volume and number of doses)
Comparators | - LOCM vs. LOCM; - LOCM vs. IOCM; - IOCM vs. IOCM (although only 1 IOCM is available for use)
Outcomes | Short-term:; a. Renal function measures; - Development of CIN as defined by change in creatinine or change in GFR; b. Renal disease-specific outcomes; - Need for RRT (dialysis or hemofiltration); c. Other clinical outcomes; - Mortality (in hospital or within 7 days); - Cardiac outcomes; - Anaphylaxis; d. Prolonged hospital stay; e. Benefits of radiographic imaging with contrast media; - Intermediate outcomes; – Image quality (resolution, contrast); – Diagnostic performance (test characteristics); - Clinical benefits of image quality; – Improved morbidity; – Improved mortality; – Minimization of other imaging tests and procedures; Long-term:; a. Renal function measures; - Development of CKD, including ESRD; - Rate of conversion to CKD at 3 and 6 months; - Chronic change in kidney function; b. Renal disease-specific outcomes; - Need for RRT (dialysis, hemofiltration, or kidney transplant); c. Other clinical outcomes; - Cardiac outcomes; - Mortality in hospital or at 3 or 6 months; - Long-term clinical benefits of image quality; - Improved morbidity; - Improved mortality; - Minimization of other imaging tests
Timing | - Short-term: inpatient or within 7 days of procedure.; - Long-term: at least 30 days after procedure. For observational studies, the follow-up should be at least 2 years.
Setting | Inpatient and outpatient populations

CIN = contrast induced nephropathy; CKD = chronic kidney disease; ESRD = end stage renal disease; GFR = glomerular infiltration rate; IOCM = iso-osmolar contrast media; LOCM = low-osmolar contrast media; RRT = renal replacement therapy

Table 2 Low-osmolar and iso-osmolar contrast media

Name | Trade Name | Manufacturer | Classification
iohexol | Omnipaque | GE Healthcare | LOCM
iopamidol | Isovue | Bracco | LOCM
ioversol | Optiray | Mallinckrodt | LOCM
ioxaglate | Hexabrix | Guerbet | LOCM
iopromide | Ultravist | Bayer | LOCM
iobitridol | Xenetix | Guerbet | LOCM
iomeprol | Imeron | Bracco | LOCM
ioxilan | Oxilan | Guerbet | LOCM
iodixanol | Visipaque | GE Healthcare | IOCM

LOCM = low-osmolar contrast media, IOCM = iso-osmolar contrast media

## Data Extraction

We screened titles first, then abstracts for relevance to the Key Question. Titles and abstracts were screened independently by two reviewers. Inclusion at the title screening level was liberal; if a single reviewer believed an article may contain relevant information, the article moved to the next level (abstract) for further screening. Abstracts were included for further review only if both reviewers agreed on inclusion. Disagreements that could not be resolved by the two reviewers were resolved by the internal experts (See Appendix C for screening forms.)

Full text articles included after the review of abstracts were reviewed independently by two reviewers and required agreement between the reviewers for either inclusion or exclusion. Disagreements that could not be resolved by the two reviewers were resolved by a third member of the team. At random intervals during screening, quality checks by senior team members were performed to ensure that screening was consistent with inclusion/exclusion criteria.

## Quality (Risk of Bias) Assessment of Individual Studies

Two reviewers independently assessed each study's risk of bias using five items from the Cochrane Risk of Bias tool for randomized studies:13

- Was the allocation sequence adequately generated?
- Was allocation adequately concealed?
- Was knowledge of the allocated intervention adequately prevented during the study?
- Were incomplete outcome data adequately addressed?
- Are reports of the study free of suggestion of selective outcome reporting?

When assessing the risk of bias, we focused on the main outcome of interest, CIN, an outcome that is objectively measured by laboratory testing.

## Data Synthesis

For primary studies, as defined by our inclusion criteria and Key Question, we sought to perform de novo meta-analyses. Before conducting a meta-analysis, the review team discussed differences in the study design and reporting to identify characteristics that would limit the clinical meaningfulness of pooled results, such as variability in patient characteristics, contrast media used, or outcome definitions. Differences in these characteristics either prevented statistical pooling or were used to stratify the meta-analysis. Pooled risks were calculated using a random effects model using the method of DerSimonian and Laird.14

Statistical heterogeneity was assessed using the I-squared statistic.15 When the I-squared value was greater than or equal to 50 percent, or the p-value was 0.2 or less, the clinicians were asked to re-evaluate the studies for clinical heterogeneity and decide if the meta-analysis should be reported despite statistical heterogeneity. We did not plan to perform network meta-analyses because we anticipated a high degree of clinical heterogeneity among the studies.

We assessed both short- and long-term outcomes. We extracted data on short-term outcomes defined as within 7 days post-procedure. We also extracted data on long-term outcomes, looking particularly for outcomes at least 30 days post-procedure.

## Minimally Important Difference

In comparing post-administration changes in numerical indicators of renal function between two contrast agents, we considered a minimally important difference to be approximately the coefficient of variation associated with the measurement. For serum creatinine, the short-term coefficient of variation within individuals has been reported to be 8 percent.16 Assuming a normal serum creatinine of approximately 1.0 mg/dl, we assumed a minimally important difference of 0.1 mg/dl (approximately 8% of 1.0 mg/dl). For creatinine clearance, we assumed a minimally important difference of 20 percent, which is rounded from a reported estimate of 19 percent for the coefficient of variation within individuals.17

In comparing changes in risk of CIN, a binary outcome, we followed published guidelines for selecting a minimally important difference based on overall observed event rate in the studies.18 Taking into consideration the potential effect of CIN on a patient's overall health and well-being, the clinical experts on our team decided that a relative risk reduction of 25 percent would be clinically important, which is consistent with the guidance suggesting a relative risk reduction of 20 percent to 30 percent in determining optimal information size.

## Strength of the Body of Evidence

The team graded the strength of evidence on comparisons of interest for the key outcomes. We used the grading scheme recommended in the Methods Guide19 and considered all domains: study limitations, directness, consistency, precision, reporting bias, and magnitude of effect.19

Study limitations were determined for each comparison group for CIN and other reported outcomes. A body of evidence was assessed as having high study limitations if greater than 50 percent of the studies scored negative (–) in one or more of the criteria. A body of evidence was assessed as having low study limitations if most (51% or greater) of the studies scored positive (+) in all 5 domains. Bodies of evidence not meeting one of the above criteria were assessed as having medium study limitations.

Following the guidance of the GRADE Working Group18, we rated evidence as precise if the total number of patients exceeded an optimum information size, and the 95% confidence interval (CI) excluded a risk ratio of 1.0. If the total number of patients exceeded the optimum information size, and the 95% CI did not exclude the possibility of no difference (i.e., risk ratio of 1.0), we only rated the evidence as precise if the 95% CI excluded the possibility of a clinically important benefit or harm (i.e., risk ratio less than 0.75 or greater than 1.25). For the main outcome of interest, CIN, we used an optimum information size of 2000 based on an expected 0.1 probability of CIN in the comparison group and a minimally important relative difference of 25 percent. For less frequent adverse outcomes, we used an optimum information size of 10,000 based on an expected 0.02 probability in the comparison group and a minimally important relative difference of 25 percent. If only one study was available for a given comparison, we downgraded the evidence for having unknown consistency. We classified the strength of evidence pertaining to each comparison into four category grades: high, moderate, low, and insufficient. The body of evidence was considered high grade if study limitations were low and there were no problems in any of the other domains, and subsequently downgraded for each domain in which a problem was identified. If the magnitude of effect was very large, the strength of evidence could be upgraded.

Observational studies were considered in grading a comparison's overall strength of evidence if the overall results of the observational studies were not similar to the RCTs applicable to the comparison.

## Applicability

We considered elements of the PICOTS framework when evaluating the applicability of evidence to answer our Key Question as recommended in the Methods Guide.19 We considered important population characteristics, treatment characteristics, and settings that may cause heterogeneity of treatment effects and limit applicability of the findings.