# Peer Reviewers

Prior to publication of the final evidence report, the EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Marta Heilbrun, M.D.
  University of Utah
  Salt Lake City, UT
- Charles Herzog, M.D., FACC, FAHA
  Chronic Disease Research Group
  Minneapolis Medical Research Foundation
  Minneapolis, MN
  Cardiology Division, Department of Internal Medicine
  Hennepin County Medical Center
  Minneapolis, MN
  Professor of Medicine, University of Minnesota
- Peter A. McCullough, M.D., M.P.H., FACC, FACP, FAHA, FCCP, FNKF
  Baylor University Medical Center
  Baylor Heart and Vascular Institute
  Baylor Jack and Jane Hamilton Heart and Vascular Hospital
  Dallas, TX
  The Heart Hospital
  Plano, TX