# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Lakhmir Chawla, M.D.
  George Washington University Medical Center
  Washington, DC
- Robert T. Chow, M.D.
  University of Maryland Medical Center Midtown Campus
  Baltimore, MD
- Matthew S. Davenport, M.D.
  University of Michigan Health System
  Ann Arbor, MI
- Chester H. Fox, M.D.
  University at Buffalo, SUNY
  Buffalo, NY
- Robert McDonough, M.D., J.D., M.P.P.
  Aetna
  Hartford, CT
- Roxana Mehran, M.D., FACC, FSCAI, FAHA
  Professor of Medicine
  Icahn School of Medicine at Mount Sinai
  New York, NY
- Aliza M. Thompson, M.D.
  Food and Drug Administration Silver Spring, MD