# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Martin Bledsoe
  Johns Hopkins University
  Baltimore, MD
- Somjot S. Brar, M.D.
  Kaiser Permanente
  Los Angeles, CA
- Lakhmir Chawla, M.D.
  George Washington University Medical Center
  Washington, DC
- Robert T. Chow, M.D.
  University of Maryland Medical Center
  Midtown Campus
  Baltimore, MD
- Matthew S. Davenport, M.D.
  University of Michigan Health System
  Ann Arbor, MI
- Virna Elly
  Patient Advocate
  Baltimore, MD
- Chester H. Fox, M.D.
  University at Buffalo, SUNY
  Buffalo, NY
- Ira P. Krefting, M.D.
  Food and Drug Administration
  Washington, DC
- Robert McDonough, M.D., J.D., M.P.P.
  Aetna
  Hartford, CT
- Roxana Mehran, M.D., FACC, FSCAI, FAHA
  Professor of Medicine
  Icahn School of Medicine at Mount Sinai
  New York, NY
- Paul M. Palevsky, M.D.
  University of Pittsburgh School of Medicine
  Pittsburgh, PA
- William Peckham, M.D.
  Patient Advocate
  Seattle, WA
- Michael Rudnick, M.D.
  University of Pennsylvania
  Philadelphia, PA
- Richard Solomon, M.D.
  University of Virginia Medical Center
  Charlottesville, VA
- Aliza M. Thompson, M.D.
  Food and Drug Administration
  Silver Spring, MD