# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Jonathan Aboagye, Elisabeth Nannes, Oluwaseun Shogbesan, Yohalakshmi Chelladurai, Greg Weaver, and Molly Merkel. Additional thanks to Jeffrey Brinker, M.D., Paul Scheel, M.D., M.B.A., and Matthews Chacko, M.D., for their input and advice on refining the study protocol and draft report.