# Appendix G Study Limitation Figures

Figure G-1 IOCM versus LOCM study limitations

Appendix G figures show the study limitation domains (random sequence generation, allocation concealment, blinding of participants and personnel, incomplete outcome data, and selective reporting) for each outcome in studies comparing iso-osmolar versus low osmolar contrast media. The figure displays how many studies satisfied the limitation domain, how many did not and how many were unclear.