# Appendix E Evidence Tables

Evidence Table E-1 Participant characteristics for studies comparing contrast media for the prevention of contrast-induced nephropathy

Evidence Table E-2 Study characteristics for studies comparing contrast media for the prevention of contrast-induced nephropathy

Evidence Table E-3 Interventions for studies comparing contrast media for the prevention of contrast-induced nephropathy

Evidence Table E-4 Summary of randomized controlled trials comparing low-osmolar contrast media with contrast-induced nephropathy as an outcome

Evidence Table E-5a Comparison between low-osmolar contrast media: prevention of contrast-induced nephropathy (categorical data)

Evidence Table E-5b Comparison between low-osmolar contrast media reporting on other outcomes

Evidence Table E-6a Comparison between iso- and low-osmolar contrast media: prevention of contrast-induced nephropathy (categorical data)

EvidenceTable E-6b Comparison between iso- and low-osmolar contrast media: prevention of contrast-induced nephropathy (continuous data)

Evidence Table E-7 Comparison between iso- and low-osmolar contrast media: need for renal replacement therapy

Evidence Table E-8 Comparison between iso- and low-osmolar contrast media: cardiovascular outcomes

Evidence Table E-9 Comparison between iso- and low-osmolar contrast media: mortality

Evidence Table E-10 Comparison between iso- and low-osmolar contrast media: adverse events

Evidence Table E-11 Comparison between iso- and low-osmolar contrast media: Image quality and diagnostic accuracy

Evidence Table E-12 Summary of observational studies comparing contrast media for the prevention of contrast-induced nephropathy

## References for Appendix E

1 Alexopoulos E, Spargias K, Kyrzopoulos S, et al. (2010). Contrast-induced acute kidney injury in patients with renal dysfunction undergoing a coronary procedure and receiving non-ionic low-osmolar versus iso-osmolar contrast media. Am J Med Sci.
2 Aspelin P, Aubry P, Fransson SG, et al. (2003). Nephrotoxic effects in high-risk patients undergoing angiography. N Engl J Med.
3 Barrett BJ, Katzberg RW, Thomsen HS, et al. (2006). Contrast-induced nephropathy in patients with chronic kidney disease undergoing computed tomography: a double-blind comparison of iodixanol and iopamidol. Invest Radiol.
4 Becker J, Babb J, Serrano M. (2013). Glomerular filtration rate in evaluation of the effect of iodinated contrast media on renal function. AJR Am J Roentgenol.
5 Bolognese L, Falsini G, Schwenke C, et al. (2012). Impact of iso-osmolar versus low-osmolar contrast agents on contrast-induced nephropathy and tissue reperfusion in unselected patients with ST-segment elevation myocardial infarction undergoing primary percutaneous coronary intervention (from the Contrast Media and Nephrotoxicity Following Primary Angioplasty for Acute Myocardial Infarction [CONTRAST-AMI] Trial). Am J Cardiol.
6 Campbell DR, Flemming BK, Mason WF, et al. (1990). A comparative study of the nephrotoxicity of iohexol, iopamidol and ioxaglate in peripheral angiography. Can Assoc Radiol J.
7 Carraro M, Malalan F, Antonione R, et al. (1998). Effects of a dimeric vs a monomeric nonionic contrast medium on renal function in patients with mild to moderate renal insufficiency: a double-blind, randomized clinical trial. Eur Radiol.
8 Chuang FR, Chen TC, Wang IK, et al. (2009). Comparison of iodixanol and iohexol in patients undergoing intravenous pyelography: a prospective controlled study. Ren Fail.
9 Dillman JR, al-Hawary M, Ellis JH, et al. (2012). Comparative investigation of i.v. iohexol and iopamidol: effect on renal function in low-risk outpatients undergoing CT. AJR Am J Roentgenol.
10 Feldkamp T, Baumgart D, Elsner M, et al. (2006). Nephrotoxicity of iso-osmolar versus low-osmolar contrast media is equal in low risk patients. Clin Nephrol.
11 Hardiek KJ, Katholi RE, Robbs RS, et al. (2008). Renal effects of contrast media in diabetic patients undergoing diagnostic or interventional coronary angiography. J Diabetes Complications.
12 Hernandez F, Mora L, Garcia-Tejada J, et al. (2009). Comparison of iodixanol and ioversol for the prevention of contrast-induced nephropathy in diabetic patients after coronary angiography or angioplasty. Rev Esp Cardiol.
13 Jakobsen JA, Berg KJ, Kjaersgaard P, et al. (1996). Angiography with nonionic X-ray contrast media in severe chronic renal failure: renal function and contrast retention. Nephron.
14 Jevnikar AM, Finnie KJ, Dennis B, et al. (1988). Nephrotoxicity of high- and low-osmolality contrast media. Nephron.
15 Jo SH, Youn TJ, Koo BK, et al. (2006). Renal toxicity evaluation and comparison between visipaque (iodixanol) and hexabrix (ioxaglate) in patients with renal insufficiency undergoing coronary angiography: the RECOVER study: a randomized controlled trial. J Am Coll Cardiol.
16 Juergens CP, Winter JP, Nguyen-Do P, et al. (2009). Nephrotoxic effects of iodixanol and iopromide in patients with abnormal renal function receiving N-acetylcysteine and hydration before coronary angiography and intervention: a randomized trial. Intern Med J.
17 Koutsikos D, Konstadinidou I, Mourikis D, et al. (1992). Contrast media nephrotoxicity: comparison of diatrizoate, ioxaglate, and iohexol after intravenous and renal arterial administration. Ren Fail.
18 Kuhn MJ, Chen N, Sahani DV, et al. (2008). The PREDICT study: a randomized double-blind comparison of contrast-induced nephropathy after low- or isoosmolar contrast agent exposure. AJR Am J Roentgenol.
19 Laskey W, Aspelin P, Davidson C, et al. (2009). Nephrotoxicity of iodixanol versus iopamidol in patients with chronic kidney disease and diabetes mellitus undergoing coronary angiographic procedures. Am Heart J.
20 Limbruno U, Picchi A, Micheli A, et al. (2013). Refining the assessment of contrast-induced acute kidney injury: The load-to-damage relationship. Journal of Cardiovascular Medicine.
21 Mehran R, Nikolsky E, Kirtane AJ, et al. (2009). Ionic low-osmolar versus nonionic iso-osmolar contrast media to obviate worsening nephropathy after angioplasty in chronic renal failure patients: the ICON (Ionic versus non-ionic Contrast to Obviate worsening Nephropathy after angioplasty in chronic renal failure patients) study. JACC Cardiovasc Interv.
22 Millward SF, Burbridge BE, Hartman NG, et al. (1996). Nephrotoxicity of ioxaglate and ioversol assessed by glomerular filtration rate: A pilot study. Canadian Association of Radiologists Journal.
23 Nguyen SA, Suranyi P, Ravenel JG, et al. (2008). Iso-osmolality versus low-osmolality iodinated contrast medium at intravenous contrast-enhanced CT: effect on kidney function. Radiology.
24 Nie B, Cheng WJ, Li YF, et al. (2008). A prospective, double-blind, randomized, controlled trial on the efficacy and cardiorenal safety of iodixanol vs. iopromide in patients with chronic kidney disease undergoing coronary angiography with or without percutaneous coronary intervention. Catheter Cardiovasc Interv.
25 Rudnick MR, Davidson C, Laskey W, et al. (2008). Nephrotoxicity of iodixanol versus ioversol in patients with chronic kidney disease: the Visipaque Angiography/Interventions with Laboratory Outcomes in Renal Insufficiency (VALOR) Trial. Am Heart J.
26 Semerci T, Cuhadar S, Akcay FA, et al. (2014). Comparing the renal safety of isoosmolar versus low-osmolar contrast medium by renal biomarkers N-acetyl-beta-D-glucosaminidase and endothelin. Angiology.
27 Serafin Z, Karolkiewicz M, Gruszka M, et al. (2011). High incidence of nephropathy in neurosurgical patients after intra-arterial administration of low-osmolar and iso-osmolar contrast media. Acta Radiol.
28 Shin DH, Choi DJ, Youn TJ, et al. (2011). Comparison of contrast-induced nephrotoxicity of iodixanol and iopromide in patients with renal insufficiency undergoing coronary angiography. Am J Cardiol.
29 Solomon RJ, Natarajan MK, Doucet S, et al. (2007). Cardiac Angiography in Renally Impaired Patients (CARE) study: a randomized double-blind trial of contrast-induced nephropathy in patients with chronic kidney disease. Circulation.
30 Solomon RJ, Mehran R, Natarajan MK, et al. (2009). Contrast-induced nephropathy and long-term adverse events: cause and effect?. Clin J Am Soc Nephrol.
31 Wessely R, Koppara T, Bradaric C, et al. (2009). Choice of contrast medium in patients with impaired renal function undergoing percutaneous coronary intervention. Circulation. Cardiovascular interventions.
32 Zo'o M, Hoermann M, Balassy C, et al. (2011). Renal safety in pediatric imaging: randomized, double-blind phase IV clinical trial of iobitridol 300 versus iodixanol 270 in multidetector CT. Pediatr Radiol.
33 Ajami G, Derakhshan A, Amoozgar H, et al. (2010). Risk of nephropathy after consumption of nonionic contrast media by children undergoing cardiac angiography: a prospective study. Pediatr Cardiol.
34 Briguori C, Colombo A, Airoldi F, et al. (2005). Nephrotoxicity of low-osmolality versus iso-osmolality contrast agents: impact of N-acetylcysteine. Kidney Int.
35 Donadio C, Lucchesi A, Ardini M, et al. (2001). Renal effects of cardiac angiography with different low-osmolar contrast media. Ren Fail.
36 From AM, Bartholmai BJ, Williams AW, et al. (2008). Iodixanol compared to iohexol for contrast procedures: a case-matched retrospective cohort study. Acta Radiol.
37 Hsieh YC, Liu TJ, Liang KW, et al. (2006). Iso-osmolar contrast medium better preserves short- and long-term renal function after cardiovascular catheterizations in patients with severe baseline renal insufficiency. Int J Cardiol.
38 Kanei Y, Ayabe K, Ratcliffe J, et al. (2011). The impact of iso-osmolar contrast use in emergent percutaneous coronary intervention for ST-segment elevation myocardial infarction. J Invasive Cardiol.
39 Karlsberg RP, Dohad SY, Sheng R. (2010). Contrast-induced acute kidney injury (CI-AKI) following intra-arterial administration of iodinated contrast media. J Nephrol.
40 LaBounty TM, Shah M, Raman SV, et al. (2012). Within-hospital and 30-day outcomes in 107,994 patients undergoing invasive coronary angiography with different low-osmolar iodinated contrast media. Am J Cardiol.
41 Liss P, Persson PB, Hansell P, et al. (2006). Renal failure in 57 925 patients undergoing coronary procedures using iso-osmolar or low-osmolar contrast media. Kidney Int.
42 Valente S, Lazzeri C, Giglioli C, et al. (2006). Contrast-induced nephropathy in urgent coronary interventions. J Cardiovasc Med (Hagerstown).