# Appendix D Excluded Studies

## Exclusion: Abstract Only

Gandhi MR, Brown P, Romanowski CA, Morcos SK, Campbell S, el Nahas AM, Gray TA. (1992). The use of theophylline, an adenosine antagonist in the prevention of contrast media induced nephrotoxicity. Br J Radiol.
Davenport MS, Khalatbari S, Dunnick NR, Dillman JR, Ellis JH. (2013). Contrast-induced nephrotoxicity: Risk of intravenous low osmolality iodinated contrast material stratified by estimated glomerular filtration rate. Abdominal Imaging.
Sugioka J, Inagaki M, Fukuzawa S, Ikeda A, Okino S, Maekawa J, Maekawa S, Ichikawa S, Kuroiwa N, Okamoto S. (2013). Risk prediction of contrast-induced nephropathy in diabetic patients undergoing primary percutaneous coronary intervention for acute myocardial infarction. Cardiology (Switzerland).
Fujimoto M, Waseda K, Takashima H, Maeda K, Asai K, Kuroda Y, Kosaka T, Kurita A, Kuhara Y, Ando H, Sakurai S, Kato D, Suzuki A, Nakano Y, Niwa T, Mukai K, Sato S, Mizuno T, Amano T. (2013). Effect of oral hydration on renal function after coronary catheterization. American Journal of Cardiology.
Habib M, Hillis A, Hamad A. (2013). The role of ascorbic acid or n-acetylcysteine or combination in prevention of contrast-induced nephropathy in high-risk patients with ischemic heart disease. International Journal of Cardiology.
Habib M, Hillis A, Hamad A. (2013). Low dose of N-acetylcysteine plus ascorbic acid versus hydration with (saline 0.9%) for prevention of contrast-induced nephropathy in patients undergoing coronary angiography. International Journal of Cardiology.
Hamdi S, Selmi W, Hraiech A, Jomaa W, Hamda KB, Maatouk F. (2013). Prevention of patients undergoing coronarography with ascorbic acid. JACC: Cardiovascular Interventions.
Samide J, Saad N, Abraham T, Balmir E. (2012). A retrospective evaluation on the usage of iodinated contrast media in an Urban hospital setting. Critical Care Medicine.
Kooiman J, Sijpkens YW, Brulez HC, De Vries JPP, Hamming JF, Van Der Molen AJ, Aarts NJ, Cannegieter SC, Rabelink TJ, Huisman MV. (2012). Randomized study of short prehydration with sodium bicarbonate versus standard pre- and posthydration with sodium chloride to prevent contrast induced acute kidney injury: The Salina trial. Circulation.
Fayed AM. (2012). Human albumin versus isotonic sodium bicarbonate in prevention of contrast induced nephropathy in critically ill patients. Intensive Care Medicine.
Qun X, Shijuan L. (2012). Protection of n-acetylcysteine for patients with contrast induced nephropathy after percutaneous coronary intervention treatment. Heart.
Li R, Chen H. (2012). Prevention of contrast-induced nephropathy with ascorbic acid. Heart.
Juch J, Le Noble J, Foudraine N. (2012). Incidence and prevention of contrast induced nephropathy (CIN) in the ICU: Preventive administration of Na+ bicarbonate is not effective. Single dose amino-glycoside is a major risk factor. Intensive Care Medicine.
Deray G, Marti-Bonmati L, Rouviere O, Bacigalupo B, Maes L, Hannedouche T, Vrtovsnik F, Rigothier C, Billiouw J, Campioni P. (2012). Renal safety evaluation after Gd-DOTA-enhanced-MRI compared with non-enhanced-MRI in patients at high risk of developing contrast medium induced nephropathy. Journal of Medical Imaging and Radiation Oncology.
Erturk M, Akbay E, Kurtulus G, Isiksacan N, Gul M, Akturk IF, Surgit O, Uzun F, Yildirim A, Uslu N. (2012). Effect of iv or oral N-acetylcysteine in the prevention of contrast-induced nephropathy in patients with moderate to severe renal insufficiency. European Heart Journal.
Singh AK, Kari JA. (2012). 24-hour isotonic sodium choloride was better than 7-hour sodium bicarbonate for preventing CIN. Annals of Internal Medicine.
Brulotte V, Leblond FA, Elkouri S, Therasse E, Pichette V, Beaulieu P. (2012). Impact of sodium bicarbonate administration and N-acetylcysteine on the prevention of contrast media-induced nephropathy in endovascular aortic aneurysm repair. European Journal of Anaesthesiology.
Gu G, Lu R, Cui W, Liu F, Zhang Y, Yang X. (2012). Low-dose furosemide administered with adequate hydration prevents contrast-induced nephropathy in patients undergoing coronary angiography. Circulation.
Chatani K, Abdel-Wahab M, Toelg R, Geist V, Marwan M, Mostafa AE, Richardt G. (2012). Impact of iso-osmolar versus low-osmolar contrast agents on contrast-induced acute kidney injury in unselected patients undergoing TAVI. EuroIntervention.
Lacquaniti A, Donato V, RosariaFazio M, Lucisano S, Cernaro V, Lupica R, Buemi M. (2012). Contrast media, nephrotoxicity and neutrophil-gelatinase associated lipocalin: Between doubts and certainties. Nephrology Dialysis Transplantation.
Traub S, Mitchell A, Jones AE, Tang A, O'Connor J, Kellum J, Shapiro N. (2012). A randomized trial of N-acetyl cysteine and saline versus normal saline alone to prevent contrast nephropathy in emergency department patients undergoing contrast enhanced computed tomography. Academic Emergency Medicine.
Chua BC, Aprjanto AS, Hamada N, Sultan S. (2012). Contrast Induced Nephropathy and Chronic Kidney Disease (CIN/CKD) as a consequence of utilising non ionic Iso-Osmolar Contrast Media (IOCM) versus Low- Osmolar Contrast Media (LOCM) following lower extremity endovascular revascularisation (EvR): A 5 years parallel group observational study. Irish Journal of Medical Science.
Ebisawa S, Saigusa T, Odagiri K, Aso S, Aizawa K, Koshikawa M, Kasai H, Izawa A, Tomita T, Miyashita Y, Kumazaki S, Yaguchi T, Hioki H, Koyama J, Ikeda U, Kurita T, Kimura M, Suzuki T. (2011). Impact of minimum contrast media on percutaneous coronary intervention for preventing contrast induced nephropathy in patients with coronary artery disease. Circulation.
Mayaud N, Isaaz K, Mariat C, Cerisier A, Lamaud M, Richard L, Da A. (2011). Contrast induced nephropathy in patients with normal renal function undergoing complex PCI with high dose of contrast media: Predictive value of Cystatin C. Journal of the American College of Cardiology.
Elshawadfy M, Oraby MA, Ismail HM, Maklady FA. (2011). Effectiveness of theophylline in prevention of contrast-induced nephropathy in risky Egyptian patients undergoing elective coronary angiography or percutaneous intervention: A randomized controlled trial. Journal of the American College of Cardiology.
Menozzi M, Magnavacchi P, Puggioni E, Valgimigli M, Vignali L, Guiducci V, Pignatelli G, Giacometti P, Manari A. (2011). Contrast induced acute kidney injury in patients undergoing primary angioplasty for acute myocardial infarction. a randomized trial on hydration with saline or bicarbonate. Journal of the American College of Cardiology.
Momeni A, Ebrahimi A, Khaledi A. (2011). Comparison of three methods of contrast nephropathy prophylaxis in azotemic patients. Iranian Journal of Kidney Diseases.
Bajaj S, Sharma M, Parikh R, Patel S, Gupta N, Chandran C, Hamdan A, Shamoon F, Bikkina M. (2011). Contrast induced nephropathy in patients with chronic kidney disease undergoing coronary angiography. Chest.
Li W, Li D, Xu T, Zhang Y, Zhu H, Han F. (2011). Prevention of contrast-induced acute kidney injury with ascorbic acid and prostaglandin e1 in high risk factors patients undergoing PCI. Heart.
Miao Y, Yu-Jie Z. (2011). Efficacy of short-term high-dose atorvastatin for prevention of contrastinduced nephropathy in patients with st segment elevation myocardial infarction undergoing percutaneous coronary intervention. Heart.
Hou X, Wang YJ, Yin QX, Miao JL, Jiang H. (2011). Prevention of contrast-induced nephropathy comparison of two hydration regimens in elderly patients undergoing percutaneous coronary intervention. Heart.
Bertelli L, Sgura FA, Manicardi M, Campioli A, Spadafora G, Leuzzi C, Rossi R, Biondi-Zoccai G, Sangiorgi GM, Modena MG. (2011). Mid-term outcomes of iodixanol versus iomeprol contrast medium after primary angioplasty for st elevation myocardial infarction. European Heart Journal.
Brueck M, Cengiz H, Boening A. (2011). Comparison of N-acetylcysteine or ascorbic acid versus placebo to prevent contrast-induced nephropathy in patients with renal insufficiency undergoing elective cardiac catheterization. European Heart Journal.
Mockel M, Dumichen MJ, Friedrich K, Kuhnle Y, Vollert JO, Searle J, Combe V, Schwenke C, Schroder M. (2011). Invasive renal hemodynamics after left ventricular and coronary angiography with randomised use of different contrast media. EuroIntervention.
Li X, Wang Y, Fu N, Zhao R, Xiao J, Li Z, Cong H. (2011). Atorvastatin combining probucol can reduce the renal impairment induced with contrast-medium. EuroIntervention.
Chen Y, Hu S, Liu Y, Wang L, Fu G, He Q. (2011). A randomised, double-blinded comparison of lopromide and lodixanol in renally impaired patients undergoing cardiac catheterisation (DIRECT study). EuroIntervention.
Min J, Ryan A, Spalding J. (2010). Renal morbidity, mortality, and costs in individuals undergoing invasive cardiac catheterization procedures with low-osmolar contrast media: A large retrospective database analysis. Value in Health.
Han Y, Wang S, Wang X, Li F, Zhao X, Jing Q. (2010). Contrast-induced nephropathy following coronary intervention in elderly, renally impaired patients: A randomised comparison of the renal safety of iodixanol and iopromide. EuroIntervention.
Rastelli S, Zanoli L, Marcantoni C, Blanco J, Tamburino C, Castellino P. (2010). Contrast media related risk of contrast induced nephropathy. NDT Plus.
El-Fishawy H, Shaheen N, Soliman A. (2010). Ascorbic acid and acetylcysteine for prevention of acute deterioration of renal function following elective aorto-iliac and coronary angioplasty. NDT Plus.
Brar SS, Shen A-J, Jorgensen MB, Aharonian VJ, Koshkaryan V, Shah AI. (2010). A randomized controlled trial for the prevention of contrast induced nephropathy with sodium bicarbonate vs. sodium chloride in patients undergoing coronary angiography: 2-year results from the MEENA Trial.
Lavenberg JG, Umscheid CA. (2011). Prevention of contrast-induced nephropathy: acetylcysteine, sodium bicarbonate, or saline.

## Exclusion: Followup Less Than 1 Year

McGillicuddy EA, Schuster KM, Kaplan LJ, Maung AA, Lui FY, Maerz LL, Johnson DC, Davis KA. (2010). Contrast-induced nephropathy in elderly trauma patients. J Trauma.
Nozue T, Michishita I, Iwaki T, Mizuguchi I, Miura M. (2009). Contrast medium volume to estimated glomerular filtration rate ratio as a predictor of contrast-induced nephropathy developing after elective percutaneous coronary intervention. J Cardiol.
Khanal S, Attallah N, Smith DE, Kline-Rogers E, Share D, O'Donnell MJ, Moscucci M. (2005). Statin therapy reduces contrast-induced nephropathy: an analysis of contemporary percutaneous interventions. Am J Med.

## Exclusion: Unobtainable

Rahman MM, Haque SS, Rokeya B, Siddique MA, Banerjee SK, Ahsan SA, Rahman F, Mahmood M, Ahmed K, Bhuiyan MM, Joarder AI, Debnath RC. (2012). Trimetazidine in the prevention of contrast induced nephropathy after coronary angiogram. Mymensingh Med J.

## Exclusion: No Comparison Group of Interest

Abe D, Sato A, Hoshi T, Kakefuda Y, Watabe H, Ojima E, Hiraya D, Harunari T, Takeyasu N, Aonuma K. (2013). Clinical Predictors of Contrast-Induced Acute Kidney Injury in Patients Undergoing Emergency Versus Elective Percutaneous Coronary Intervention. Circ J.
Tan N, Liu Y, Chen JY, Zhou YL, Li X, Li LW, Yu DQ, Chen ZJ, Liu XQ, Huang SJ. (2013). Use of the contrast volume or grams of iodine-to-creatinine clearance ratio to predict mortality after percutaneous coronary intervention. Am Heart J.
Burchardt P, Guzik P, Tabaczewski P, Synowiec T, Bogdan M, Faner P, Chmielarz-Sobocinska A, Palasz A. (2013). Early renal dysfunction after contrast media administration despite prophylactic hydration. Int J Cardiovasc Imaging.
Raposeiras-Roubin S, Abu-Assi E, Ocaranza-Sanchez R, Alvarez-Alvarez B, Cambeiro-Gonzalez C, Fandino-Vaquero R, Garcia-Castelo A, Garcia-Acuna JM, Gonzalez-Juanatey JR. (2013). Dosing of iodinated contrast volume: A new simple algorithm to stratify the risk of contrast-induced nephropathy in patients with acute coronary syndrome: A New Simple Algorithm to Stratify the Risk of Contrast-Induced Nephropathy in Patients With Acute Coronary Syndrome. Catheter Cardiovasc Interv.
Morabito S, Pistolesi V, Benedetti G, Di Roma A, Colantonio R, Mancone M, Sardella G, Cibelli L, Ambrosino M, Polistena F, Pierucci A. (2012). Incidence of contrast-induced acute kidney injury associated with diagnostic or interventional coronary angiography. J Nephrol.
Kanei Y, Ayabe K, Ratcliffe J, Vales L, Nakra N, Friedman P, Fox J. (2011). The impact of iso-osmolar contrast use in emergent percutaneous coronary intervention for ST-segment elevation myocardial infarction. J Invasive Cardiol.
Gurm HS, Dixon SR, Smith DE, Share D, Lalonde T, Greenbaum A, Moscucci M. (2011). Renal function-based contrast dosing to define safe limits of radiographic contrast media in patients undergoing percutaneous coronary interventions. J Am Coll Cardiol.
Yoon HJ, Hur SH. (2011). Determination of safe contrast media dosage to estimated glomerular filtration rate ratios to avoid contrast-induced nephropathy after elective percutaneous coronary intervention. Korean Circ J.
Wang XC, Fu XH, Wang YB, Jia XW, Wu WL, Gu J, Zhang XS, Su JL, Hao GZ, Jiang YF, Fan WZ, Li SQ. (2011). Prediction of contrast-induced nephropathy in diabetics undergoing elective percutaneous coronary intervention: role of the ratio of contrast medium volume to estimated glomerular filtration rate. Chin Med J (Engl).
Liu Y, Tan N, Zhou YL, He PC, Luo PC, Chen JY. (2012). The contrast medium volume to estimated glomerular filtration rate ratio as a predictor of contrast-induced nephropathy after primary percutaneous coronary intervention. Int Urol Nephrol.
Ribichini F, Graziani M, Gambaro G, Pasoli P, Pighi M, Pesarini G, Abaterusso C, Yabarek T, Brunelleschi S, Rizzotti P, Lupo A, Vassanelli C. (2010). Early creatinine shifts predict contrast-induced nephropathy and persistent renal damage after angiography. Am J Med.
Trivedi H, Foley WD. (2010). Contrast-induced nephropathy after a second contrast exposure. Ren Fail.
Brown JR, Robb JF, Block CA, Schoolwerth AC, Kaplan AV, O'Connor GT, Solomon GT, Malenka DJ. (2010). Does safe dosing of iodinated contrast prevent contrast-induced acute kidney injury?. Circ Cardiovasc Interv.
Worasuwannarak S, Pornratanarangsi S. (2010). Prediction of contrast-induced nephropathy in diabetic patients undergoing elective cardiac catheterization or PCI: role of volume-to-creatinine clearance ratio and iodine dose-to-creatinine clearance ratio. J Med Assoc Thai.
McGillicuddy EA, Schuster KM, Kaplan LJ, Maung AA, Lui FY, Maerz LL, Johnson DC, Davis KA. (2010). Contrast-induced nephropathy in elderly trauma patients. J Trauma.
Kim SM, Cha RH, Lee JP, Kim DK, Oh KH, Joo KW, Lim CS, Kim S, Kim YS. (2010). Incidence and outcomes of contrast-induced nephropathy after computed tomography in patients with CKD: a quality improvement report. Am J Kidney Dis.
Kiski D, Stepper W, Brand E, Breithardt G, Reinecke H. (2010). Impact of renin-angiotensin-aldosterone blockade by angiotensin-converting enzyme inhibitors or AT-1 blockers on frequency of contrast medium-induced nephropathy: a post-hoc analysis from the Dialysis-versus-Diuresis (DVD) trial. Nephrol Dial Transplant.
Shamkhalova M, Zaitseva NV, Kurumova KO, Shestakova MV, Deev AD, Matskeplishvili ST, Tugeeva EF, Buziashvili Iu I. (2009). Ter Arkh.
Nozue T, Michishita I, Iwaki T, Mizuguchi I, Miura M. (2009). Contrast medium volume to estimated glomerular filtration rate ratio as a predictor of contrast-induced nephropathy developing after elective percutaneous coronary intervention. J Cardiol.
Chong E, Poh KK, Shen L, Chai P, Tan HC. (2009). Diabetic patients with normal baseline renal function are at increased risk of developing contrast-induced nephropathy post-percutaneous coronary intervention. Singapore Med J.
From AM, Bartholmai BJ, Williams AW, Cha SS, McDonald FS. (2008). Mortality associated with nephropathy after radiographic contrast exposure. Mayo Clin Proc.
La Manna G, Pancaldi L, Dalmastri V, Cuna V, Capecchi A, Comai G, Persici E, Bacchi G, Cianciolo G, Lombardi A, Marrozzini C, Coli L, Stefoni S. (2008). Post-coronarography application of continuous veno-venous hemofiltration in the prevention of contrast nephropathy in patients with complex multisystem deficiency. In Vivo.
Huber W, Jeschke B, Page M, Weiss W, Salmhofer H, Schweigart U, Ilgmann K, Reichenberger J, Neu B, Classen M. (2001). Reduced incidence of radiocontrast-induced nephropathy in ICU patients under theophylline prophylaxis: a prospective comparison to series of patients at similar risk. Intensive Care Med.
Madyoon H, Croushore L, Weaver D, Mathur V. (2001). Use of fenoldopam to prevent radiocontrast nephropathy in high-risk patients. Catheter Cardiovasc Interv.
Mikkonen R, Kontkanen T, Kivisaari L. (1995). Acute and late adverse reactions to low-osmolal contrast media. Acta Radiol.
Davidson CJ, Hlatky M, Morris KG, Pieper K, Skelton TN, Schwab SJ, Bashore TM. (1989). Cardiovascular and renal toxicity of a nonionic radiographic contrast agent after cardiac catheterization. A prospective trial. Ann Intern Med.
Laskey WK, Jenkins C, Selzer F, Marroquin OC, Wilensky RL, Glaser R, Cohen HA, Holmes DR. (2007). Volume-to-Creatinine Clearance Ratio. A Pharmacokinetically Based Risk Factor for Prediction of Early Creatinine Increase After Percutaneous Coronary Intervention. Journal of the American College of Cardiology.
Drobnie-Kovac D, Cerne A, Kranjec I, Globokar-Zajec M. (1996). Effects of nonionic radiographic contrast media on renal function after cardiac catheterisation. Radiology and Oncology.
Katholi RE, Taylor GJ, Woods WT, Womack KA, Katholi CR, McCann WP, Moses HW, Dove JT, Mikell FL, Woodruff RC, Miller BD, Schneider JA. (1993). Nephrotoxicity of nonionic low-osmolality versus ionic high-osmolality contrast media: A prospective double-blind randomized comparison in human beings. Radiology.
Conen D, Buerkle G, Perruchoud AP, Buettner HJ, Mueller C. (2006). Hypertension is an independent risk factor for contrast nephropathy after percutaneous coronary intervention.

## Exclusion: No Intervention of Interest

Rahman MM, Haque SS, Rokeya B, Siddique MA, Banerjee SK, Ahsan SA, Rahman F, Mahmood M, Ahmed K, Bhuiyan MM, Joarder AI, Debnath RC. (2012). Trimetazidine in the prevention of contrast induced nephropathy after coronary angiogram. Mymensingh Med J.
Xu RH, Ma GZ, Cai ZX, Chen P, Zhu ZD, Wang WL. (2013). Combined use of hydration and alprostadil for preventing contrast-induced nephropathy following percutaneous coronary intervention in elderly patients. Exp Ther Med.
Abe D, Sato A, Hoshi T, Kakefuda Y, Watabe H, Ojima E, Hiraya D, Harunari T, Takeyasu N, Aonuma K. (2013). Clinical Predictors of Contrast-Induced Acute Kidney Injury in Patients Undergoing Emergency Versus Elective Percutaneous Coronary Intervention. Circ J.
Capodanno D, Ministeri M, Cumbo V, Dalessandro S, Tamburino C. (2013). Volume-to-creatinine clearance ratio in patients undergoing coronary angiography with or without percutaneous coronary intervention: Implications of varying definitions of contrast-induced nephropathy. Catheter Cardiovasc Interv.
Yamamoto M, Hayashida K, Mouillet G, Chevalier B, Meguro K, Watanabe Y, Dubois-Rande JL, Morice MC, Lefevre T, Teiger E. (2013). Renal function-based contrast dosing predicts acute kidney injury following transcatheter aortic valve implantation. JACC Cardiovasc Interv.
Markota D, Markota I, Starcevic B, Tomic M, Prskalo Z, Brizic I. (2013). Prevention of contrast-induced nephropathy with Na/K citrate. Eur Heart J.
Markota D, Markota I, Starcevic B, Tomic M, Prskalo Z, Brizic I. (2013). Prevention of contrast-induced nephropathy with Na/K citrate. Eur Heart J.
Geng W, Fu XH, Gu XS, Wang YB, Wang XC, Li W, Jiang YF, Hao GZ, Fan WZ, Xue L. (2012). Preventive effects of anisodamine against contrast-induced nephropathy in type 2 diabetics with renal insufficiency undergoing coronary angiography or angioplasty. Chin Med J (Engl).
Geng W, Fu XH, Gu XS, Wang YB, Wang XC, Li W, Jiang YF, Hao GZ, Fan WZ, Xue L. (2012). Preventive effects of anisodamine against contrast-induced nephropathy in type 2 diabetics with renal insufficiency undergoing coronary angiography or angioplasty. Chin Med J (Engl).
Wang YB, Fu XH, Gu XS, Wang XC, Zhao YJ, Hao GZ, Jiang YF, Fan WZ, Wu WL, Li SQ, Xue L. (2012). Safety and efficacy of anisodamine on prevention of contrast induced nephropathy in patients with acute coronary syndrome. Chin Med J (Engl).
Wang YB, Fu XH, Gu XS, Wang XC, Zhao YJ, Hao GZ, Jiang YF, Fan WZ, Wu WL, Li SQ, Xue L. (2012). Safety and efficacy of anisodamine on prevention of contrast induced nephropathy in patients with acute coronary syndrome. Chin Med J (Engl).
Kitzler TM, Jaberi A, Sendlhofer G, Rehak P, Binder C, Petnehazy E, Stacher R, Kotanko P. (2012). Efficacy of vitamin E and N-acetylcysteine in the prevention of contrast induced kidney injury in patients with chronic kidney disease: a double blind, randomized controlled trial. Wien Klin Wochenschr.
Wang XC, Fu XH, Wang YB, Jia XW, Wu WL, Gu XS, Zhang J, Su JL, Hao GZ, Jiang YF, Fan WZ, Li SQ. (2011). Prediction of contrast-induced nephropathy in diabetics undergoing elective percutaneous coronary intervention: role of the ratio of contrast medium volume to estimated glomerular filtration rate. Chin Med J (Engl).
Liu Y, Tan N, Zhou YL, He PC, Luo JF, Chen JY. (2012). The contrast medium volume to estimated glomerular filtration rate ratio as a predictor of contrast-induced nephropathy after primary percutaneous coronary intervention. Int Urol Nephrol.
Saitoh T, Satoh H, Nobuhara M, Machii M, Tanaka T, Ohtani H, Saotome M, Urushida T, Katoh H, Hayashi H. (2011). Intravenous glutathione prevents renal oxidative stress after coronary angiography more effectively than oral N-acetylcysteine. Heart Vessels.
Saitoh T, Satoh H, Nobuhara M, Machii M, Tanaka T, Ohtani H, Saotome M, Urushida T, Katoh H, Hayashi H. (2011). Intravenous glutathione prevents renal oxidative stress after coronary angiography more effectively than oral N-acetylcysteine. Heart Vessels.
Trivedi H, Foley WD. (2010). Contrast-induced nephropathy after a second contrast exposure. Ren Fail.
Yoshida S, Kamihata H, Nakamura S, Senoo T, Manabe K, Motohiro M, Sugiura T, Iwasaka T. (2009). Prevention of contrast-induced nephropathy by chronic pravastatin treatment in patients with cardiovascular disease and renal insufficiency. J Cardiol.
Yoshida S, Kamihata H, Nakamura S, Senoo T, Manabe K, Motohiro M, Sugiura T, Iwasaka T. (2009). Prevention of contrast-induced nephropathy by chronic pravastatin treatment in patients with cardiovascular disease and renal insufficiency. J Cardiol.
Chong E, Poh KK, Shen L, Chai P, Tan HC. (2009). Diabetic patients with normal baseline renal function are at increased risk of developing contrast-induced nephropathy post-percutaneous coronary intervention. Singapore Med J.
Jo SH, Koo BK, Park JS, Kang HJ, Kim YJ, Kim HL, Chae IH, Choi DJ, Sohn DW, Oh BH, Park YB, Choi YS, Kim HS. (2009). N-acetylcysteine versus AScorbic acid for preventing contrast-Induced nephropathy in patients with renal insufficiency undergoing coronary angiography NASPI study-a prospective randomized controlled trial. Am Heart J.
Bouzas-Mosquera A, Vazquez-Rodriguez JM, Calvino-Santos R, Vazquez-Gonzalez N, Castro-Beiras A. (2009). Statin therapy and contrast-induced nephropathy after primary angioplasty. Int J Cardiol.
Patti G, Nusca A, Chello M, Pasceri V, D'Ambrosio A, Vetrovec GW, Di Sciascio G. (2008). Usefulness of statin pretreatment to prevent contrast-induced nephropathy and to improve long-term outcome in patients undergoing percutaneous coronary intervention. Am J Cardiol.
Patti G, Nusca A, Chello M, Pasceri V, D'Ambrosio A, Vetrovec GW, Di Sciascio G. (2008). Usefulness of statin pretreatment to prevent contrast-induced nephropathy and to improve long-term outcome in patients undergoing percutaneous coronary intervention. Am J Cardiol.
Haase M, Haase-Fielitz A, Ratnaike S, Reade MC, Bagshaw SM, Morgera S, Dragun D, Bellomo R. (2008). N-Acetylcysteine does not artifactually lower plasma creatinine concentration. Nephrol Dial Transplant.
Cheruvu B, Henning K, Mulligan J, Klippenstein D, Lawrence D, Gurtoo L, Gottlieb RH. (2007). Iodixanol: risk of subsequent contrast nephropathy in cancer patients with underlying renal insufficiency undergoing diagnostic computed tomography examinations. J Comput Assist Tomogr.
Coyle LC, Rodriguez A, Jeschke RE, Simon-Lee A, Abbott KC, Taylor AJ. (2006). Acetylcysteine In Diabetes (AID): a randomized study of acetylcysteine for the prevention of contrast nephropathy in diabetics. Am Heart J.
Clavijo LC, Pinto TL, Kuchulakanti PK, Torguson R, Chu WW, Satler LF, Kent KM, Suddath WO, Waksman R, Pichard AD. (2006). Effect of a rapid intra-arterial infusion of dextrose 5% prior to coronary angiography on frequency of contrast-induced nephropathy in high-risk patients. Am J Cardiol.
Assadi F. (2006). Acetazolamide for prevention of contrast-induced nephropathy: a new use for an old drug. Pediatr Cardiol.
Balderramo DC, Verdu MB, Ramacciotti CF, Cremona LS, Lemos PA, Orias M, Eduardo M. (2004). Renoprotective effect of high periprocedural doses of oral N-acetylcysteine in patients scheduled to undergo a same-day angiography. Rev Fac Cien Med Univ Nac Cordoba.
Khanal S, Attallah N, Smith DE, Kline-Rogers E, Share D, O'Donnell MJ, Moscucci M. (2005). Statin therapy reduces contrast-induced nephropathy: an analysis of contemporary percutaneous interventions. Am J Med.
Gill NK, Piccione EA, Vido DA, Clark BA, Shannon RP. (2004). Gender as a risk factor for contrast nephropathy: effects of hydration and N-acetylcysteine. Clin Cardiol.
Gill NK, Piccione EA, Vido DA, Clark BA, Shannon RP. (2004). Gender as a risk factor for contrast nephropathy: effects of hydration and N-acetylcysteine. Clin Cardiol.
Bartholomew BA, Harjai KJ, Dukkipati S, Boura JA, Yerkey MW, Glazier S, Grines CL, O'Neill WW. (2004). Impact of nephropathy after percutaneous coronary intervention and a method for risk stratification. Am J Cardiol.
Weisbord SD, Bruns FJ, Saul MI, Palevsky PM. (2004). Provider use of preventive strategies for radiocontrast nephropathy in high-risk patients. Nephron Clin Pract.
Kapoor A, Kumar S, Gulati S, Gambhir S, Sethi RS, Sinha N. (2002). The role of theophylline in contrast-induced nephropathy: a case-control study. Nephrol Dial Transplant.
Kolonko A, Wiecek A, Kokot F. (1998). The nonselective adenosine antagonist theophylline does prevent renal dysfunction induced by radiographic contrast agents. J Nephrol.
Kapoor A, Sinha N, Sharma RK, Shrivastava S, Radhakrishnan S, Goel PK, Bajaj R. (1996). Use of dopamine in prevention of contrast induced acute renal failure--a randomised study. Int J Cardiol.
Weisberg LS, Kurnik PB, Kurnik BR. (1993). Dopamine and renal blood flow in radiocontrast-induced nephropathy in humans. Ren Fail.
Harris KG, Smith TP, Cragg AH, Lemke JH. (1991). Nephrotoxicity from contrast material in renal insufficiency: ionic versus nonionic agents. Radiology.
Deray G, Bellin MF, Boulechfar H, Baumelou B, Koskas F, Baumelou A, Grellet J, Jacobs C. (1991). Nephrotoxicity of contrast media in high-risk patients with renal insufficiency: comparison of low- and high-osmolar contrast agents. Am J Nephrol.
Deray G, Bellin MF, Boulechfar H, Baumelou B, Koskas F, Baumelou A, Grellet J, Jacobs C. (1991). Nephrotoxicity of contrast media in high-risk patients with renal insufficiency: comparison of low- and high-osmolar contrast agents. Am J Nephrol.
Cigarroa RG, Lange RA, Williams RH, Hillis LD. (1989). Dosing of contrast material to prevent contrast nephropathy in patients with renal disease. Am J Med.
Cigarroa RG, Lange RA, Williams RH, Hillis LD. (1989). Dosing of contrast material to prevent contrast nephropathy in patients with renal disease. Am J Med.
Parfrey PS, Griffiths SM, Barrett BJ, Paul MD, Genge M, Withers J, Farid N, McManamon PJ. (1989). Contrast material-induced renal failure in patients with diabetes mellitus, renal insufficiency, or both. A prospective controlled study. N Engl J Med.
Davidson CJ, Hlatky M, Morris KG, Pieper K, Skelton TN, Schwab SJ. (1989). Cardiovascular and renal toxicity of a nonionic radiographic contrast agent after cardiac catheterization. A prospective trial. Ann Intern Med.
Neumayer HH, Junge W, Kufner A, Wenning A. (1989). Prevention of radiocontrast-media-induced nephrotoxicity by the calcium channel blocker nitrendipine: a prospective randomised clinical trial. Nephrol Dial Transplant.
Donadio C, Tramonti G, Giordani R, Lucchetti A, Calderazzi A, Sbragia P, Bianchi C. (1988). Glomerular and tubular effects of ionic and nonionic contrast media (diatrizoate and iopamidol). Contrib Nephrol.
Cramer BC, Parfrey PS, Hutchinson TA, Baran D, Melanson DM, Ethier RE, Seely JF. (1985). Renal function following infusion of radiologic contrast material. A prospective controlled study. Arch Intern Med.
Eisenberg RL, Bank WO, Hedgock MW. (1981). Renal failure after major angiography can be avoided with hydration. AJR Am J Roentgenol.
Metys R, Hornych A, Burianova B, Jirka J. (1971). Influence of tri-iodinated contrast media on renal function. Nephron.
Metys R, Hornych A, Burianova B, Jirka J. (1971). Influence of tri-iodinated contrast media on renal function. Nephron.
Miao Y, Zhong Y, Yan H, Li W, Wang BY, Jin J. (2013). Alprostadil plays a protective role in contrast-induced nephropathy in the elderly. International Urology and Nephrology.
Miao Y, Zhong Y, Yan H, Li W, Wang BY, Jin J. (2013). Alprostadil plays a protective role in contrast-induced nephropathy in the elderly. International Urology and Nephrology.
Baris N, Ozpelit E, Bilgin Dogan N, Kangul H, Gul S, Akdeniz B, Guneri S. (2013). The effects of chronic usage of enzyme inhibitors and angiotensin receptor blockers on contrast-induced nephropathy in low-risk patients. Anadolu Kardiyoloji Dergisi.
Habib M, Hillis A, Hamad A. (2013). The role of ascorbic acid or n-acetylcysteine or combination in prevention of contrast-induced nephropathy in high-risk patients with ischemic heart disease. International Journal of Cardiology.
Albabtain MA, Almasood A, Alshurafah H, Alamri H, Tamim H. (2013). Efficacy of ascorbic acid, N-acetylcysteine, or combination of both on top of saline hydration versus saline hydration alone on prevention of contrast-induced nephropathy: A prospective randomized study. Journal of Interventional Cardiology.
Albabtain MA, Almasood A, Alshurafah H, Alamri H, Tamim H. (2013). Efficacy of ascorbic acid, N-acetylcysteine, or combination of both on top of saline hydration versus saline hydration alone on prevention of contrast-induced nephropathy: A prospective randomized study. Journal of Interventional Cardiology.
Li R, Chen H. (2012). Prevention of contrast-induced nephropathy with ascorbic acid. Heart.
Sadeghi MM, Gharipour M, Nilforoush P, Shamsolkotabi H, Sadeghi HM, Kiani A, Sadeghi PM, Farahmand N. (2011). Influence of the timing of cardiac catheterization and amount of contrast media on acute renal failure after cardiac surgery. Journal of Research in Medical Sciences.
Uyarel H, Cam N, Ergelen M, Akkaya E, Ayhan E, Isik T, Cicek G, Gunaydin ZY, Osmonov D, Gul M, Demirci D, Guney MR, Ozturk R, Yekeler I. (2009). Contrast-induced nephropathy in patients undergoing primary angioplasty for acute myocardial infarction: Incidence, a simple risk score, and prognosis. Archives of Medical Science.
Kim U, Kim YJ, Lee WJ, Lee SH, Hong GR, Park JS, Shin DG, Shim BS. (2008). The estimated glomerular filtration rate with using the mayo clinic quadratic equation as a new predictor for developing contrast induced nephropathy in patients with angina pectoris. Korean Circulation Journal.
Spargias K, Alexopoulos E, Kyrzopoulos S, Iacovis P, Greenwood DC, Manginas A, Voudris V, Pavlides G, Buller CE, Kremastinos D, Cokkinos DV. (2004). Ascorbic acid prevents contrast-mediated nephropathy in patients with renal dysfunction undergoing coronary angiography or intervention. Circulation.
Katholi RE, Taylor GJ, McCann WP, Woods WT, Womack KA, McCoy CD, Katholi CR, Moses HW, Mishkel GJ, Lucore CL, Holloway RM, Miller BD, Woodruff RC, Dove JT, Mikell FL, Schneider JA. (1995). Nephrotoxicity from contrast media: Attenuation with theophylline. Radiology.
Katholi RE, Taylor GJ, Woods WT, Womack KA, Katholi CR, McCann WP, Moses HW, Dove JT, Mikell FL, Woodruff RC, Miller BD, Schneider JA. (1993). Nephrotoxicity of nonionic low-osmolality versus ionic high-osmolality contrast media: A prospective double-blind randomized comparison in human beings. Radiology.
Taliercio CP, Vlietstra RE, Ilstrup DM, Burnett JC, Menke KK, Stensrud SL, Holmes DR. (1991). A randomized comparison of the nephrotoxicity of iopamidol and diatrizoate in high risk patients undergoing cardiac angiography. Journal of the American College of Cardiology.
Lufft V, Hoogestraat-Lufft L, Fels LM, Egbeyong-Baiyee D, Tusch G, Galanski M, Olbricht CJ. (2002). Contrast media nephropathy: intravenous CT angiography versus intraarterial digital subtraction angiography in renal artery stenosis: a prospective randomized trial.
Conen D, Buerkle G, Perruchoud AP, Buettner HJ, Mueller C. (2006). Hypertension is an independent risk factor for contrast nephropathy after percutaneous coronary intervention.

## Exclusion: Does Not Apply to Key Questions

Rosenstock JL, Gilles E, Geller AB, Panagopoulos G, Mathew S, Malieckal D, DeVita MV, Michelis MF. (2010). Impact of heart failure on the incidence of contrast-induced nephropathy in patients with chronic kidney disease. Int Urol Nephrol.
Rosenstock JL, Gilles E, Geller AB, Panagopoulos G, Mathew S, Malieckal D, DeVita MV, Michelis MF. (2010). Impact of heart failure on the incidence of contrast-induced nephropathy in patients with chronic kidney disease. Int Urol Nephrol.
Kiski D, Stepper W, Breithardt G, Reinecke H. (2010). Impact of female gender on frequency of contrast medium-induced nephropathy: post hoc analysis of dialysis versus diuresis trial. J Womens Health (Larchmt).
Haase M, Haase-Fielitz A, Ratnaike S, Reade MC, Bagshaw SM, Morgera S, Dragun D, Bellomo R. (2008). N-Acetylcysteine does not artifactually lower plasma creatinine concentration. Nephrol Dial Transplant.
Kapoor A, Kumar S, Gulati S, Gambhir S, Sethi RS, Sinha N. (2002). The role of theophylline in contrast-induced nephropathy: a case-control study. Nephrol Dial Transplant.
Kapoor A, Sinha N, Sharma RK, Shrivastava S, Radhakrishnan S, Goel PK, Bajaj R. (1996). Use of dopamine in prevention of contrast induced acute renal failure--a randomised study. Int J Cardiol.
Kjaersgaard P, Jakobsen JA, Nossen JO, Berg KJ. (1996). Determination of glomerular filtration rate with Visipaque in patients with severely reduced renal function. Eur Radiol.
Donadio C, Tramonti G, Giordani R, Lucchetti A, Calderazzi A, Sbragia P, Bianchi C. (1988). Glomerular and tubular effects of ionic and nonionic contrast media (diatrizoate and iopamidol). Contrib Nephrol.
Baris N, Ozpelit E, Bilgin Dogan N, Kangul H, Gul S, Akdeniz B, Guneri S. (2013). The effects of chronic usage of enzyme inhibitors and angiotensin receptor blockers on contrast-induced nephropathy in low-risk patients. Anadolu Kardiyoloji Dergisi.
Karlsberg RP, Dohad SY, Sheng R. (2011). Contrast mediuminduced acute kidney injury: Comparison of intravenous and intraarterial administration of iodinated contrast medium. Journal of Vascular and Interventional Radiology.
Karlsberg RP, Dohad SY, Sheng R. (2011). Contrast mediuminduced acute kidney injury: Comparison of intravenous and intraarterial administration of iodinated contrast medium. Journal of Vascular and Interventional Radiology.
Laskey WK, Jenkins C, Selzer F, Marroquin OC, Wilensky RL, Glaser R, Cohen HA, Holmes DR. (2007). Volume-to-Creatinine Clearance Ratio. A Pharmacokinetically Based Risk Factor for Prediction of Early Creatinine Increase After Percutaneous Coronary Intervention. Journal of the American College of Cardiology.
Taliercio CP, Vlietstra RE, Ilstrup DM, Burnett JC, Menke KK, Stensrud SL, Holmes DR. (1991). A randomized comparison of the nephrotoxicity of iopamidol and diatrizoate in high risk patients undergoing cardiac angiography. Journal of the American College of Cardiology.
Boucek P, Havrdova T, Oliyarnyk O, Skibova J, Pecenkova V, Pucelikova T, Sarkady D. (2013). Prevention of contrast-induced nephropathy in diabetic patients with impaired renal function: A randomized, double blind trial of sodium bicarbonate versus sodium chloride-based hydration. Diabetes Res Clin Pract.
Brueck M, Cengiz H, Hoeltgen R, Wieczorek M, Boedeker RH, Scheibelhut C, Boening A. (2013). Usefulness of N-acetylcysteine or ascorbic acid versus placebo to prevent contrast-induced acute kidney injury in patients undergoing elective cardiac catheterization: a single-center, prospective, randomized, double-blind, placebo-controlled trial. J Invasive Cardiol.
Chousterman BG, Bouadma L, Moutereau S, Loric S, Alvarez-Gonzalez A, Mekontso-Dessap A, Laissy JP, Rahmouni A, Katsahian S, Brochard L, Schortgen F. (2013). Prevention of contrast-induced nephropathy by N-acetylcysteine in critically ill patients: different definitions, different results. J Crit Care.
Spini V, Cecchi E, Chiostri M, Landi D, Romano SM, Mattesini A, Gensini GF, Giglioli C. (2013). Effects of two different treatments with continuous renal replacement therapy in patients with chronic renal dysfunction submitted to coronary invasive procedures. J Invasive Cardiol.
Kong DG, Hou YF, Ma LL, Yao DK, Wang LX. (2012). Comparison of oral and intravenous hydration strategies for the prevention of contrast-induced nephropathy in patients undergoing coronary angiography or angioplasty: a randomized clinical trial. Acta Cardiol.
Leone AM, De Caterina AR, Sciahbasi A, Aurelio A, Basile E, Porto I, Trani C, Burzotta F, Niccoli G, Mongiardo R, Mazzari MA, Buffon A, Panocchia N, Romagnoli E, Lioy E, Rebuzzi AG, Crea F. (2012). Sodium bicarbonate plus N-acetylcysteine to prevent contrast-induced nephropathy in primary and rescue percutaneous coronary interventions: the BINARIO (BIcarbonato e N-Acetil-cisteina nell'infaRto mIocardico acutO) study. EuroIntervention.
Quintavalle C, Fiore D, De Micco F, Visconti G, Focaccio A, Golia B, Ricciardelli B, Donnarumma E, Bianco A, Zabatta MA, Troncone G, Colombo A, Briguori C, Condorelli G. (2012). Impact of a high loading dose of atorvastatin on contrast-induced acute kidney injury. Circulation.
Shemirani H, Pourrmoghaddas M. (2012). A randomized trial of saline hydration to prevent contrast-induced nephropathy in patients on regular captopril or furosemide therapy undergoing percutaneous coronary intervention. Saudi J Kidney Dis Transpl.
Klima T, Christ A, Marana I, Kalbermatter S, Uthoff H, Burri E, Hartwiger S, Schindler C, Breidthardt T, Marenzi G, Mueller C. (2012). Sodium chloride vs. sodium bicarbonate for the prevention of contrast medium-induced nephropathy: a randomized controlled trial. Eur Heart J.
Gurm HS, Smith DE, Berwanger O, Share D, Schreiber T, Moscucci M, Nallamothu BK. (2012). Contemporary use and effectiveness of N-acetylcysteine in preventing contrast-induced nephropathy among patients undergoing percutaneous coronary intervention. JACC Cardiovasc Interv.
Maioli M, Toso A, Leoncini M, Micheletti C, Bellandi F. (2011). Effects of hydration in contrast-induced acute kidney injury after primary angioplasty: a randomized, controlled trial. Circ Cardiovasc Interv.
Ludwig U, Riedel MK, Backes M, Imhof A, Muche R, Keller F. (2011). MESNA (sodium 2-mercaptoethanesulfonate) for prevention of contrast medium-induced nephrotoxicity - controlled trial. Clin Nephrol.
Malhis M, Al-Bitar S, Al-Deen Zaiat K. (2010). The role of theophylline in prevention of radiocontrast media-induced nephropathy. Saudi J Kidney Dis Transpl.
Pakfetrat M, Nikoo MH, Malekmakan L, Tabandeh M, Roozbeh J, Nasab MH, Ostovan MA, Salari S, Kafi M, Vaziri NM, Adl F, Hosseini M, Khajehdehi P. (2009). A comparison of sodium bicarbonate infusion versus normal saline infusion and its combination with oral acetazolamide for prevention of contrast-induced nephropathy: a randomized, double-blind trial. Int Urol Nephrol.
Weisbord SD, Mor MK, Resnick AL, Hartwig KC, Sonel AF, Fine MJ, Palevsky PM. (2008). Prevention, incidence, and outcomes of contrast-induced acute kidney injury. Arch Intern Med.
Jo SH, Koo BK, Park JS, Kang HJ, Cho YS, Kim YJ, Youn TJ, Chung WY, Chae IH, Choi DJ, Sohn DW, Oh BH, Park YB, Choi YS, Kim HS. (2008). Prevention of radiocontrast medium-induced nephropathy using short-term high-dose simvastatin in patients with renal insufficiency undergoing coronary angiography (PROMISS) trial--a randomized controlled study. Am Heart J.
From AM, Bartholmai BJ, Williams AW, Cha SS, Pflueger A, McDonald FS. (2008). Sodium bicarbonate is associated with an increased incidence of contrast nephropathy: a retrospective cohort study of 7977 patients at mayo clinic. Clin J Am Soc Nephrol.
Lee PT, Chou KJ, Liu CP, Mar GY, Chen CL, Hsu CY, Fang HC, Chung HM. (2007). Renal protection for coronary angiography in advanced renal failure patients by prophylactic hemodialysis. A randomized controlled trial. J Am Coll Cardiol.
Poletti PA, Saudan P, Platon A, Mermillod B, Sautter AM, Vermeulen B, Sarasin FP, Becker CD, Martin PY. (2007). I.v. N-acetylcysteine and emergency CT: use of serum creatinine and cystatin C as markers of radiocontrast nephrotoxicity. AJR Am J Roentgenol.
Briguori C, Airoldi F, D'Andrea D, Bonizzoni E, Morici N, Focaccio A, Michev I, Montorfano M, Carlino M, Cosgrave J, Ricciardelli B, Colombo A. (2007). Renal Insufficiency Following Contrast Media Administration Trial (REMEDIAL): a randomized comparison of 3 preventive strategies. Circulation.
Huber W, Eckel F, Hennig M, Rosenbrock H, Wacker A, Saur D, Sennefelder A, Hennico R, Schenk C, Meining A, Schmelz R, Fritsch R, Weiss W, Hamar P, Heemann U, Schmid RM. (2006). Prophylaxis of contrast material-induced nephropathy in patients in intensive care: acetylcysteine, theophylline, or both? A randomized study. Radiology.
Dussol B, Morange S, Loundoun A, Auquier P, Berland Y. (2006). A randomized trial of saline hydration to prevent contrast nephropathy in chronic renal failure patients. Nephrol Dial Transplant.
Gulel O, Keles T, Eraslan H, Aydogdu S, Diker E, Ulusoy V. (2005). Prophylactic acetylcysteine usage for prevention of contrast nephropathy after coronary angiography. J Cardiovasc Pharmacol.
Bader BD, Berger ED, Heede MB, Silberbaur I, Duda S, Risler T, Erley CM. (2004). What is the best hydration regimen to prevent contrast media-induced nephrotoxicity?. Clin Nephrol.
Fung JW, Szeto CC, Chan WW, Kum LC, Chan AK, Wong JT, Wu EB, Yip GW, Chan JY, Yu CM, Woo KS, Sanderson JE. (2004). Effect of N-acetylcysteine for prevention of contrast nephropathy in patients with moderate to severe renal insufficiency: a randomized trial. Am J Kidney Dis.
Krasuski RA, Beard BM, Geoghagan JD, Thompson CM, Guidera SA. (2003). Optimal timing of hydration to erase contrast-associated nephropathy: the OTHER CAN study. J Invasive Cardiol.
Boccalandro F, Amhad M, Smalling RW, Sdringola S. (2003). Oral acetylcysteine does not protect renal function from moderate to high doses of intravenous radiographic contrast. Catheter Cardiovasc Interv.
Huber W, Ilgmann K, Page M, Hennig M, Schweigart U, Jeschke B, Lutilsky L, Weiss W, Salmhofer H, Classen M. (2002). Effect of theophylline on contrast material-nephropathy in patients with chronic renal insufficiency: controlled, randomized, double-blinded study. Radiology.
Vogt B, Ferrari P, Schonholzer C, Marti HP, Mohaupt M, Wiederkehr M, Cereghetti C, Serra A, Huynh-Do U, Uehlinger D, Frey FJ. (2001). Prophylactic hemodialysis after radiocontrast media in patients with renal insufficiency is potentially harmful. Am J Med.
Erley CM, Duda SH, Rehfuss D, Scholtes B, Bock J, Muller C, Osswald H, Risler T. (1999). Prevention of radiocontrast-media-induced nephropathy in patients with pre-existing renal insufficiency by hydration in combination with the adenosine antagonist theophylline. Nephrol Dial Transplant.
Hall KA, Wong RW, Hunter GC, Camazine BM, Rappaport WA, Smyth SH, Bull DA, McIntyre KE, Bernhard VM, Misiorowski RL. (1992). Contrast-induced nephrotoxicity: the effects of vasodilator therapy. J Surg Res.
Weinstein JM, Heyman S, Brezis M. (1992). Potential deleterious effect of furosemide in radiocontrast nephropathy. Nephron.
Chousterman BG, Bouadma L, Loric S, Alvarez-Gonzalez A, Mekontso-Dessap A, Laissy JP, Rahmouni A, Brochard L, Schortgen F. (2011). Prevention of contrast induced nephropathy (CIN) by N-acetylcystein (NAC) : Different definitions, Different results. Intensive Care Medicine.
Demir M, Kutlucan A, Akin H, Aydin O, Sezer MT. (2008). Comparison of different agents on radiographic contrast agent induced nephropathy. European Journal of General Medicine.
Sterner G, Frennby B, Kurkus J, Nyman U. (2000). Does post-angiographic hemodialysis reduce the risk of contrast-medium nephropathy?.
Hsu TF, Huang MK, Yu SH, Yen DH, Kao WF, Chen YC, Huang MS. (2012). N-acetylcysteine for the prevention of contrast-induced nephropathy in the emergency department. Intern Med.
Burns KE, Priestap F, Martin C. (2010). N-acetylcysteine in critically ill patients undergoing contrast-enhanced computed tomography: a randomized trial. Clin Nephrol.
Sar F, Saler T, Ecebay A, Saglam ZA, Ozturk S, Kazancioglu R. (2010). The efficacy of n-acetylcysteine in preventing contrast-induced nephropathy in type 2 diabetic patients without nephropathy. J Nephrol.
Tepel M, van der Giet M, Schwarzfeld C, Laufer U, Liermann D, Zidek W. (2000). Prevention of radiographic-contrast-agent-induced reductions in renal function by acetylcysteine. N Engl J Med.
Khalili H, Dashti-Khavidaki S, Tabifar H, Ahmadinejad N, Ahmadi F. (2006). N-acetylcysteine in the prevention of contrast agent-induced nephrotoxicity in patients undergoing computed tomography studies. Therapy.
Han Y, Zhu G, Han L, Hou F, Huang W, Liu H, Gan J, Jiang T, Li X, Wang W, Ding S, Jia S, Shen W, Wang D, Sun L, Qiu J, Wang X, Li Y, Deng J, Li J, Xu K, Xu B, Mehran R, Huo Y. (2013). Short-Term Rosuvastatin Therapy for Prevention of Contrast-Induced Acute Kidney Injury in Patients with Diabetes and Chronic Kidney Disease. J Am Coll Cardiol.
Alessandri N, Lanzi L, Garante CM, Tersigni F, Sergiacomi R, Petrassi M, Di Matteo A, Tufano F. (2013). Prevention of acute renal failure post-contrast imaging in cardiology: a randomized study. Eur Rev Med Pharmacol Sci.
Oguzhan N, Cilan H, Sipahioglu M, Unal A, Kocyigit I, Kavuncuoglu F, Arikan T, Akpek M, Elcik D, Sahin O, Gulme E, Pala C, Tokgoz B, Utas C, Oguzhan A, Oymak O. (2013). The lack of benefit of a combination of an angiotensin receptor blocker and calcium channel blocker on contrast-induced nephropathy in patients with chronic kidney disease. Ren Fail.
Gomes VO, Lasevitch R, Lima VC, Brito FS, Perez-Alva JC, Moulin B, Arruda A, Oliveira D, Caramori P. (2012). Hydration with sodium bicarbonate does not prevent contrast nephropathy: a multicenter clinical trial. Arq Bras Cardiol.
Heguilen RM, Liste AA, Payaslian M, Ortemberg MG, Albarracin LM, Bernasconi AR. (2013). N-acethyl-cysteine reduces the occurrence of contrast-induced acute kidney injury in patients with renal dysfunction: a single-center randomized controlled trial. Clin Exp Nephrol.
Chen Y, Hu S, Liu Y, Zhao R, Wang L, Fu G, He Q, Su X, Zheng Y, Qi X, Liu H, Wang J, Gao W, Wang M, Liu S, Zheng X, He B, Yang P, Zhou S, Gao C, Qiu C. (2012). Renal tolerability of iopromide and iodixanol in 562 renally impaired patients undergoing cardiac catheterisation: the DIRECT study. EuroIntervention.
Tamai N, Ito S, Nakasuka K, Morimoto K, Miyata K, Inomata M, Yoshida T, Suzuki S, Murakami Y, Sato K. (2012). Sodium bicarbonate for the prevention of contrast-induced nephropathy: the efficacy of high concentration solution. J Invasive Cardiol.
Li W, Fu X, Wang Y, Li X, Yang Z, Wang X, Geng W, Gu X, Hao G, Jiang Y, Fan W, Wu W, Li S. (2012). Beneficial effects of high-dose atorvastatin pretreatment on renal function in patients with acute ST-segment elevation myocardial infarction undergoing emergency percutaneous coronary intervention. Cardiology.
Rim MY, Ro H, Kang WC, Kim AJ, Park H, Chang JH, Lee HH, Chung W, Jung JY. (2012). The effect of renin-angiotensin-aldosterone system blockade on contrast-induced acute kidney injury: a propensity-matched study. Am J Kidney Dis.
Bilasy ME, Oraby MA, Ismail HM, Maklady FA. (2012). Effectiveness of theophylline in preventing contrast-induced nephropathy after coronary angiographic procedures. J Interv Cardiol.
Talati S, Kirtane AJ, Hassanin A, Mehran R, Leon MB, Moses JW, Weisz G. (2012). Direct infusion of fenoldopam into the renal arteries to protect against contrast-induced nephropathy in patients at increased risk. Clin Exp Pharmacol Physiol.
Aslanger E, Uslu B, Akdeniz C, Polat N, Cizgici Y, Oflaz H. (2012). Intrarenal application of N-acetylcysteine for the prevention of contrast medium-induced nephropathy in primary angioplasty. Coron Artery Dis.
Yin L, Li G, Liu T, Yuan R, Zheng X, Xu G, Xu Y, Che J, Liu X, Ma X, Li F, Liu E, Chen X, Wu L, Fan Z, Ruan Y, He M, Li Y. (2013). Probucol for the prevention of cystatin C-based contrast-induced acute kidney injury following primary or urgent angioplasty: a randomized, controlled trial. Int J Cardiol.
Gunebakmaz O, Kaya MG, Koc F, Akpek M, Kasapkara A, Inanc MT, Yarlioglues M, Calapkorur B, Karadag Z, Oguzhan A. (2012). Does nebivolol prevent contrast-induced nephropathy in humans?. Clin Cardiol.
Marenzi G, Ferrari C, Marana I, Assanelli E, De Metrio M, Teruzzi G, Veglia F, Fabbiocchi F, Montorsi P, Bartorelli AL. (2012). Prevention of contrast nephropathy by furosemide with matched hydration: the MYTHOS (Induced Diuresis With Matched Hydration Compared to Standard Hydration for Contrast Induced Nephropathy Prevention) trial. JACC Cardiovasc Interv.
Alioglu E, Saygi S, Turk U, Kirilmaz B, Tuzun N, Duman C, Tengiz I, Yildiz S, Ercan E. (2013). N-acetylcysteine in preventing contrast-induced nephropathy assessed by cystatin C. Cardiovasc Ther.
Li XM, Cong HL, Li TT, He LJ, Zhou YJ. (2011). Impact of benazepril on contrast-induced acute kidney injury for patients with mild to moderate renal insufficiency undergoing percutaneous coronary intervention. Chin Med J (Engl).
Firouzi A, Eshraghi A, Shakerian F, Sanati HR, Salehi N, Zahedmehr A, Kiani R, Madani M, Pedarzadeh A. (2012). Efficacy of pentoxifylline in prevention of contrast-induced nephropathy in angioplasty patients. Int Urol Nephrol.
Rey JR, Iglesias D, LopezDe Sa E, Armada E, Moreno R, Salvador O, Monedero Mdel C, Blas SG, Iniesta AM, Lopez-Sendon JL. (2011). Prevention of contrast-induced nephropathy with haemofiltration in high-risk patients after percutaneous coronary intervention. Acute Card Care.
(2011). Acetylcysteine for prevention of renal outcomes in patients undergoing coronary and peripheral vascular angiography: main results from the randomized Acetylcysteine for Contrast-induced nephropathy Trial (ACT). Circulation.
Briguori C, Visconti G, Focaccio A, Airoldi F, Valgimigli M, Sangiorgi GM, Golia B, Ricciardelli B, Condorelli G. (2011). Renal Insufficiency After Contrast Media Administration Trial II (REMEDIAL II): RenalGuard System in high-risk patients for contrast-induced acute kidney injury. Circulation.
Jaffery Z, Verma A, White CJ, Grant AG, Collins TJ, Grise MA, Jenkins JS, McMullan PW, Patel RA, Reilly JP, Thornton SN, Ramee SR. (2012). A randomized trial of intravenous n-acetylcysteine to prevent contrast induced nephropathy in acute coronary syndromes. Catheter Cardiovasc Interv.
Hafiz AM, Jan MF, Mori N, Shaikh F, Wallach J, Bajwa T, Allaqaband S. (2012). Prevention of contrast-induced acute kidney injury in patients with stable chronic renal disease undergoing elective percutaneous coronary and peripheral interventions: randomized comparison of two preventive strategies. Catheter Cardiovasc Interv.
Patti G, Ricottini E, Nusca A, Colonna G, Pasceri V, D'Ambrosio A, Montinaro A, Di Sciascio G. (2011). Short-term, high-dose Atorvastatin pretreatment to prevent contrast-induced nephropathy in patients with acute coronary syndromes undergoing percutaneous coronary intervention (from the ARMYDA-CIN [atorvastatin for reduction of myocardial damage during angioplasty--contrast-induced nephropathy] trial. Am J Cardiol.
Awal A, Ahsan SA, Siddique MA, Banerjee S, Hasan MI, Zaman SM, Arzu J, Subedi B. (2011). Effect of hydration with or without n-acetylcysteine on contrast induced nephropathy in patients undergoing coronary angiography and percutaneous coronary intervention. Mymensingh Med J.
Tanaka A, Suzuki Y, Suzuki N, Hirai T, Yasuda N, Miki K, Fujita M, Tanaka T. (2011). Does N-acetylcysteine reduce the incidence of contrast-induced nephropathy and clinical events in patients undergoing primary angioplasty for acute myocardial infarction?. Intern Med.
Lee SW, Kim WJ, Kim YH, Park SW, Park DW, Yun SC, Lee JY, Kang SJ, Lee CW, Lee JH, Choi SW, Seong IW, Suh J, Cho YH, Lee NH, Cheong SS, Yoo SY, Lee BK, Lee SG, Hyon MS, Shin WY, Jang JS, Park SJ. (2011). Preventive strategies of renal insufficiency in patients with diabetes undergoing intervention or arteriography (the PREVENT Trial). Am J Cardiol.
Motohiro M, Kamihata H, Tsujimoto S, Seno T, Manabe K, Isono T, Sutani Y, Yuasa F, Iwasaka T. (2011). A new protocol using sodium bicarbonate for the prevention of contrast-induced nephropathy in patients undergoing coronary angiography. Am J Cardiol.
Ueda H, Yamada T, Masuda M, Okuyama Y, Morita T, Furukawa Y, Koji T, Iwasaki Y, Okada T, Kawasaki M, Kuramoto Y, Naito T, Fujimoto T, Komuro I, Fukunami M. (2011). Prevention of contrast-induced nephropathy by bolus injection of sodium bicarbonate in patients with chronic kidney disease undergoing emergent coronary procedures. Am J Cardiol.
Calabro P, Bianchi R, Crisci M, Caprile M, Bigazzi MC, Palmieri R, Golia E, De Vita A, Romano IJ, Limongelli G, Russo MG, Calabro R. (2011). Use and efficacy of saline hydration and N-acetyl cysteine to prevent contrast-induced nephropathy in low-risk populations undergoing coronary artery angiography. Intern Emerg Med.
Koc F, Ozdemir K, Kaya MG, Dogdu O, Vatankulu MA, Ayhan S, Erkorkmaz U, Sonmez O, Aygul MU, Kalay N, Kayrak M, Karabag T, Alihanoglu Y, Gunebakmaz O. (2012). Intravenous N-acetylcysteine plus high-dose hydration versus high-dose hydration and standard hydration for the prevention of contrast-induced nephropathy: CASIS--a multicenter prospective controlled trial. Int J Cardiol.
Buyukhatipoglu H, Sezen Y, Yildiz A, Bas M, Kirhan I, Ulas T, Turan MN, Taskin A, Aksoy N. (2010). N-acetylcysteine fails to prevent renal dysfunction and oxidative stress after noniodine contrast media administration during percutaneous coronary interventions. Pol Arch Med Wewn.
Acikel S, Muderrisoglu H, Yildirir A, Aydinalp A, Sade E, Bayraktar N, Bal U, Ozin B. (2010). Prevention of contrast-induced impairment of renal function by short-term or long-term statin therapy in patients undergoing elective coronary angiography. Blood Coagul Fibrinolysis.
Reed MC, Moscucci M, Smith DE, Share D, LaLonde T, Mahmood SA, D'Haem C, McNamara R, Greenbaum A, Gurm HS. (2010). The relative renal safety of iodixanol and low-osmolar contrast media in patients undergoing percutaneous coronary intervention. Insights from Blue Cross Blue Shield of Michigan Cardiovascular Consortium (BMC2). J Invasive Cardiol.
Matejka J, Varvarovsky I, Vojtisek P, Herman A, Rozsival V, Borkova V, Kvasnicka J. (2010). Prevention of contrast-induced acute kidney injury by theophylline in elderly patients with chronic kidney disease. Heart Vessels.
Cho R, Javed N, Traub D, Kodali S, Atem F, Srinivasan V. (2010). Oral hydration and alkalinization is noninferior to intravenous therapy for prevention of contrast-induced nephropathy in patients with chronic kidney disease. J Interv Cardiol.
Sadat U, Walsh SR, Norden AG, Gillard JH, Boyle JR. (2011). Does oral N-acetylcysteine reduce contrast-induced renal injury in patients with peripheral arterial disease undergoing peripheral angiography? A randomized-controlled study. Angiology.
Thiele H, Hildebrand L, Schirdewahn C, Eitel I, Adams V, Fuernau G, Erbs S, Linke A, Diederich KW, Nowak M, Desch S, Gutberlet M, Schuler G. (2010). Impact of high-dose N-acetylcysteine versus placebo on contrast-induced nephropathy and myocardial reperfusion injury in unselected patients with ST-segment elevation myocardial infarction undergoing primary percutaneous coronary intervention. The LIPSIA-N-ACC (Prospective, Single-Blind, Placebo-Controlled, Randomized Leipzig Immediate PercutaneouS Coronary Intervention Acute Myocardial Infarction N-ACC) Trial. J Am Coll Cardiol.
Ozhan H, Erden I, Ordu S, Aydin M, Caglar O, Basar C, Yalcin S, Alemdar R. (2010). Efficacy of short-term high-dose atorvastatin for prevention of contrast-induced nephropathy in patients undergoing coronary angiography. Angiology.
Kinbara T, Hayano T, Ohtani N, Furutani Y, Moritani K, Matsuzaki M. (2010). Efficacy of N-acetylcysteine and aminophylline in preventing contrast-induced nephropathy. J Cardiol.
Vasheghani-Farahani A, Sadigh G, Kassaian SE, Khatami SM, Fotouhi A, Razavi SA, Mansournia MA, Kazemisaeid A, Soleimani A, Pourhosseini HR, Alidoosti M, Hajizeinali AM, Hoseini K, Nematipour E. (2010). Sodium bicarbonate in preventing contrast nephropathy in patients at risk for volume overload: a randomized controlled trial. J Nephrol.
Castini D, Lucreziotti S, Bosotti L, Salerno Uriarte D, Sponzilli C, Verzoni A, Lombardi F. (2010). Prevention of contrast-induced nephropathy: a single center randomized study. Clin Cardiol.
Toso A, Maioli M, Leoncini M, Gallopin M, Tedeschi D, Micheletti C, Manzone C, Amato M, Bellandi F. (2010). Usefulness of atorvastatin (80 mg) in prevention of contrast-induced nephropathy in patients with chronic renal disease. Am J Cardiol.
Carbonell N, Sanjuan R, Blasco M, Jorda A, Miguel A. (2010). N-acetylcysteine: short-term clinical benefits after coronary angiography in high-risk renal patients. Rev Esp Cardiol.
Alexopoulos E, Spargias K, Kyrzopoulos S, Manginas A, Pavlides G, Voudris V, Lerakis S, McLean DS, Cokkinos DV. (2010). Contrast-induced acute kidney injury in patients with renal dysfunction undergoing a coronary procedure and receiving non-ionic low-osmolar versus iso-osmolar contrast media. Am J Med Sci.
Tamura A, Goto Y, Miyamoto K, Naono S, Kawano Y, Kotoku M, Watanabe T, Kadota J. (2009). Efficacy of single-bolus administration of sodium bicarbonate to prevent contrast-induced nephropathy in patients with mild renal insufficiency undergoing an elective coronary procedure. Am J Cardiol.
Shavit L, Korenfeld R, Lifschitz M, Butnaru A, Slotki I. (2009). Sodium bicarbonate versus sodium chloride and oral N-acetylcysteine for the prevention of contrast-induced nephropathy in advanced chronic kidney disease. J Interv Cardiol.
Xinwei J, Xianghua F, Jing Z, Xinshun G, Ling X, Weize F, Guozhen H, Yunfa J, Weili W, Shiqiang L. (2009). Comparison of usefulness of simvastatin 20 mg versus 80 mg in preventing contrast-induced nephropathy in patients with acute coronary syndrome undergoing percutaneous coronary intervention. Am J Cardiol.
Vasheghani-Farahani A, Sadigh G, Kassaian SE, Khatami SM, Fotouhi A, Razavi SA, Mansournia MA, Yamini-Sharif A, Amirzadegan A, Salarifar M, Sadeghian S, Davoodi G, Borumand MA, Esfehani FA, Darabian S. (2009). Sodium bicarbonate plus isotonic saline versus saline for prevention of contrast-induced nephropathy in patients undergoing coronary angiography: a randomized controlled trial. Am J Kidney Dis.
Amini M, Salarifar M, Amirbaigloo A, Masoudkabir F, Esfahani F. (2009). N-acetylcysteine does not prevent contrast-induced nephropathy after cardiac catheterization in patients with diabetes mellitus and chronic kidney disease: a randomized clinical trial. Trials.
Ferrario F, Barone MT, Landoni G, Genderini A, Heidemperger M, Trezzi M, Piccaluga E, Danna P, Scorza D. (2009). Acetylcysteine and non-ionic isosmolar contrast-induced nephropathy--a randomized controlled study. Nephrol Dial Transplant.
Baskurt M, Okcun B, Abaci O, Dogan GM, Kilickesmez K, Ozkan AA, Ersanli M, Gurmen T. (2009). N-acetylcysteine versus N-acetylcysteine + theophylline for the prevention of contrast nephropathy. Eur J Clin Invest.
Budhiraja P, Chen Z, Popovtzer M. (2009). Sodium bicarbonate versus normal saline for protection against contrast nephropathy. Ren Fail.
Li G, Yin L, Liu T, Zheng X, Xu G, Xu Y, Yuan R, Che J, Liu H, Zhou L, Chen X, He M, Li Y, Wu L, Liu E. (2009). Role of probucol in preventing contrast-induced acute kidney injury after coronary interventional procedure. Am J Cardiol.
Heng AE, Cellarier E, Aublet-Cuvelier B, Decalf V, Motreff P, Marcaggi X, Deteix P, Souweine B. (2008). Is treatment with N-acetylcysteine to prevent contrast-induced nephropathy when using bicarbonate hydration out of date?. Clin Nephrol.
Holscher B, Heitmeyer C, Fobker M, Breithardt G, Schaefer RM, Reinecke H. (2008). Predictors for contrast media-induced nephropathy and long-term survival: prospectively assessed data from the randomized controlled Dialysis-Versus-Diuresis (DVD) trial. Can J Cardiol.
Adolph E, Holdt-Lehmann B, Chatterjee T, Paschka S, Prott A, Schneider H, Koerber T, Ince H, Steiner M, Schuff-Werner P, Nienaber CA. (2008). Renal Insufficiency Following Radiocontrast Exposure Trial (REINFORCE): a randomized comparison of sodium bicarbonate versus sodium chloride hydration for the prevention of contrast-induced nephropathy. Coron Artery Dis.
Kim BJ, Sung KC, Kim BS, Kang JH, Lee KB, Kim H, Lee MH. (2010). Effect of N-acetylcysteine on cystatin C-based renal function after elective coronary angiography (ENABLE Study): a prospective, randomized trial. Int J Cardiol.
Brar SS, Shen AY, Jorgensen MB, Kotlewski A, Aharonian VJ, Desai N, Ree M, Shah AI, Burchette RJ. (2008). Sodium bicarbonate vs sodium chloride for the prevention of contrast medium-induced nephropathy in patients undergoing coronary angiography: a randomized trial. JAMA.
Masuda M, Yamada T, Okuyama Y, Morita T, Sanada S, Furukawa Y, Tsukamoto Y, Okuda K, Iwasaki Y, Yasui T, Fukunami M. (2008). Sodium bicarbonate improves long-term clinical outcomes compared with sodium chloride in patients with chronic kidney disease undergoing an emergent coronary procedure. Circ J.
Maioli M, Toso A, Leoncini M, Gallopin M, Tedeschi D, Micheletti C, Bellandi F. (2008). Sodium bicarbonate versus saline for the prevention of contrast-induced nephropathy in patients with renal dysfunction undergoing coronary angiography or intervention. J Am Coll Cardiol.
Rosenstock JL, Bruno R, Kim JK, Lubarsky L, Schaller R, Panagopoulos G, DeVita MV, Michelis MF. (2008). The effect of withdrawal of ACE inhibitors or angiotensin receptor blockers prior to coronary angiography on the incidence of contrast-induced nephropathy. Int Urol Nephrol.
Marron B, Ruiz E, Fernandez C, Almeida P, Horcajada C, Navarro F, Caramelo C. (2007). Rev Esp Cardiol.
Lawlor DK, Moist L, DeRose G, Harris KA, Lovell MB, Kribs SW, Elliot J, Forbes TL. (2007). Prevention of contrast-induced nephropathy in vascular surgery patients. Ann Vasc Surg.
Masuda M, Yamada T, Mine T, Morita T, Tamaki S, Tsukamoto Y, Okuda K, Iwasaki Y, Hori M, Fukunami M. (2007). Comparison of usefulness of sodium bicarbonate versus sodium chloride to prevent contrast-induced nephropathy in patients undergoing an emergent coronary procedure. Am J Cardiol.
Ozcan EE, Guneri S, Akdeniz B, Akyildiz IZ, Senaslan O, Baris N, Aslan O, Badak O. (2007). Sodium bicarbonate, N-acetylcysteine, and saline for prevention of radiocontrast-induced nephropathy. A comparison of 3 regimens for protecting contrast-induced nephropathy in patients undergoing coronary procedures. A single-center prospective controlled trial. Am Heart J.
Chen SL, Zhang J, Yei F, Zhu Z, Liu Z, Lin S, Chu J, Yan J, Zhang R, Kwan TW. (2008). Clinical outcomes of contrast-induced nephropathy in patients undergoing percutaneous coronary intervention: a prospective, multicenter, randomized study to analyze the effect of hydration and acetylcysteine. Int J Cardiol.
Seyon RA, Jensen LA, Ferguson IA, Williams RG. (2007). Efficacy of N-acetylcysteine and hydration versus placebo and hydration in decreasing contrast-induced renal dysfunction in patients undergoing coronary angiography with or without concomitant percutaneous coronary intervention. Heart Lung.
Schmidt P, Pang D, Nykamp D, Knowlton G, Jia H. (2007). N-acetylcysteine and sodium bicarbonate versus N-acetylcysteine and standard hydration for the prevention of radiocontrast-induced nephropathy following coronary angiography. Ann Pharmacother.
Reinecke H, Fobker M, Wellmann J, Becke B, Fleiter J, Heitmeyer C, Breithardt G, Hense HW, Schaefer RM. (2007). A randomized controlled trial comparing hydration therapy to additional hemodialysis or N-acetylcysteine for the prevention of contrast medium-induced nephropathy: the Dialysis-versus-Diuresis (DVD) Trial. Clin Res Cardiol.
Ramesh N, Pillai RK, Abraham T, Padmaja NP, Hameed S, Vijayaraghavan G. (2006). Reno-protective effect of N-acetyl cysteine in patients with impaired renal function undergoing coronary angiography and interventions. J Assoc Physicians India.
Carbonell N, Blasco M, Sanjuan R, Perez-Sancho E, Sanchis J, Insa L, Bodi V, Nunez J, Garcia-Ramon R, Miguel A. (2007). Intravenous N-acetylcysteine for preventing contrast-induced nephropathy: a randomised trial. Int J Cardiol.
Marenzi G, Assanelli E, Marana I, Lauri G, Campodonico J, Grazi M, De Metrio M, Galli S, Fabbiocchi F, Montorsi P, Veglia F, Bartorelli AL. (2006). N-acetylcysteine and contrast-induced nephropathy in primary angioplasty. N Engl J Med.
Kawashima S, Takano H, Iino Y, Takayama M, Takano T. (2006). Prophylactic hemodialysis does not prevent contrast-induced nephropathy after cardiac catheterization in patients with chronic renal insufficiency. Circ J.
Sandhu C, Belli AM, Oliveira DB. (2006). The role of N-acetylcysteine in the prevention of contrast-induced nephrotoxicity. Cardiovasc Intervent Radiol.
Marenzi G, Lauri G, Campodonico J, Marana I, Assanelli E, De Metrio M, Grazi M, Veglia F, Fabbiocchi F, Montorsi P, Bartorelli AL. (2006). Comparison of two hemofiltration protocols for prevention of contrast-induced nephropathy in high-risk patients. Am J Med.
Kotlyar E, Keogh AM, Thavapalachandran S, Allada CS, Sharp J, Dias L, Muller D. (2005). Prehydration alone is sufficient to prevent contrast-induced nephropathy after day-only angiography procedures--a randomised controlled trial. Heart Lung Circ.
Briguori C, Colombo A, Airoldi F, Morici N, Sangiorgi GM, Violante A, Focaccio A, Montorfano M, Carlino M, Condorelli G, Ricciardelli B. (2005). Nephrotoxicity of low-osmolality versus iso-osmolality contrast agents: impact of N-acetylcysteine. Kidney Int.
Ng TM, Shurmur SW, Silver M, Nissen LR, O'Leary EL, Rigmaiden RS, Cieciorka M, Porter LL, Ineck BA, Kline ME, Puumala SE. (2006). Comparison of N-acetylcysteine and fenoldopam for preventing contrast-induced nephropathy (CAFCIN). Int J Cardiol.
Hsieh YC, Ting CT, Liu TJ, Wang CL, Chen YT, Lee WL. (2005). Short- and long-term renal outcomes of immediate prophylactic hemodialysis after cardiovascular catheterizations in patients with severe renal insufficiency. Int J Cardiol.
Gomes VO, Poli de Figueredo CE, Caramori P, Lasevitch R, Bodanese LC, Araujo A, Roedel AP, Caramori AP, Brito FS, Bezerra HG, Nery P, Brizolara A. (2005). N-acetylcysteine does not prevent contrast induced nephropathy after cardiac catheterisation with an ionic low osmolality contrast medium: a multicentre clinical trial. Heart.
Azmus AD, Gottschall C, Manica A, Manica J, Duro K, Frey M, Bulcao L, Lima C. (2005). Effectiveness of acetylcysteine in prevention of contrast nephropathy. J Invasive Cardiol.
Shah SJ, Hsu CY. (2004). Has acetylcysteine use changed the incidence of contrast nephropathy in hospitalized patients? A before-after study. Am J Med.
Rashid ST, Salman M, Myint F, Baker DM, Agarwal S, Sweny P, Hamilton G. (2004). Prevention of contrast-induced nephropathy in vascular patients undergoing angiography: a randomized controlled trial of intravenous N-acetylcysteine. J Vasc Surg.
Attallah N, Yassine L, Musial J, Yee J, Fisher K. (2004). The potential role of statins in contrast nephropathy. Clin Nephrol.
Miner SE, Dzavik V, Nguyen-Ho P, Richardson R, Mitchell J, Atchison D, Seidelin P, Daly P, Ross J, McLaughlin PR, Ing D, Lewycky P, Barolet A, Schwartz L. (2004). N-acetylcysteine reduces contrast-associated nephropathy but not clinical events during long-term follow-up. Am Heart J.
Webb JG, Pate GE, Humphries KH, Buller CE, Shalansky S, Al Shamari A, Sutander A, Williams T, Fox RS, Levin A. (2004). A randomized controlled trial of intravenous N-acetylcysteine for the prevention of contrast-induced nephropathy after cardiac catheterization: lack of effect. Am Heart J.
Briguori C, Colombo A, Airoldi F, Violante A, Castelli A, Balestrieri P, PaoloElia P, Golia B, Lepore S, Riviezzo G, Scarpato P, Librera M, Focaccio A, Ricciardelli B. (2004). N-Acetylcysteine versus fenoldopam mesylate to prevent contrast agent-associated nephrotoxicity. J Am Coll Cardiol.
Marenzi G, Bartorelli AL. (2004). Hemofiltration in the prevention of radiocontrast agent induced nephropathy. Minerva Anestesiol.
Merten GJ, Burgess WP, Gray LV, Holleman JH, Roush TS, Kowalchuk GJ, Bersin RM, Van Moore A, Simonton CA, Rittase RA, Norton HJ, Kennedy TP. (2004). Prevention of contrast-induced nephropathy with sodium bicarbonate: a randomized controlled trial. JAMA.
Drager LF, Andrade L, Barros de Toledo JF, Laurindo FR, Machado Cesar LA, Seguro AC. (2004). Renal effects of N-acetylcysteine in patients at risk for contrast nephropathy: decrease in oxidant stress-mediated renal tubular injury. Nephrol Dial Transplant.
Goldenberg I, Shechter M, Matetzky S, Jonas M, Adam M, Pres H, Elian D, Agranat O, Schwammenthal E, Guetta V. (2004). Oral acetylcysteine as an adjunct to saline hydration for the prevention of contrast-induced nephropathy following coronary angiography. A randomized controlled trial and review of the current literature. Eur Heart J.
Briguori C, Colombo A, Violante A, Balestrieri P, Manganelli F, Paolo Elia P, Golia B, Lepore S, Riviezzo G, Scarpato P, Focaccio A, Librera M, Bonizzoni E, Ricciardelli B. (2004). Standard vs double dose of N-acetylcysteine to prevent contrast agent associated nephrotoxicity. Eur Heart J.
Kefer JM, Hanet CE, Boitte S, Wilmotte L, De Kock M. (2003). Acetylcysteine, coronary procedure and prevention of contrast-induced worsening of renal function: which benefit for which patient?. Acta Cardiol.
Oldemeyer JB, Biddle WP, Wurdeman RL, Mooss AN, Cichowski E, Hilleman DE. (2003). Acetylcysteine in the prevention of contrast-induced nephropathy after coronary angiography. Am Heart J.
MacNeill BD, Harding SA, Bazari H, Patton KK, Colon-Hernadez P, DeJoseph D, Jang IK. (2003). Prophylaxis of contrast-induced nephropathy in patients undergoing coronary angiography. Catheter Cardiovasc Interv.
Raven QL, Walton T, Howe AM, Macon EJ. (2003). Role of acetylcysteine in the prevention of contrast-media-induced nephrotoxicity. Am J Health Syst Pharm.
Frank H, Werner D, Lorusso V, Klinghammer L, Daniel WG, Kunzendorf U, Ludwig J. (2003). Simultaneous hemodialysis during coronary angiography fails to prevent radiocontrast-induced nephropathy in chronic renal failure. Clin Nephrol.
Marenzi G, Marana I, Lauri G, Assanelli E, Grazi M, Campodonico J, Trabattoni D, Fabbiocchi F, Montorsi P, Bartorelli AL. (2003). The prevention of radiocontrast-agent-induced nephropathy by hemofiltration. N Engl J Med.
Baker CS, Wragg A, Kumar S, De Palma R, Baker LR, Knight CJ. (2003). A rapid protocol for the prevention of contrast-induced renal dysfunction: the RAPPID study. J Am Coll Cardiol.
Tadros GM, Mouhayar EN, Akinwande AO, Campbell B, Wood C, Blankenship JA. (2003). Prevention of radiocontrast-induced nephropathy with N-acetylcysteine in patients undergoing coronary angiography. J Invasive Cardiol.
Kay J, Chow WH, Chan TM, Lo SK, Kwok OH, Yip A, Fan K, Lee CH, Lam WF. (2003). Acetylcysteine for prevention of acute deterioration of renal function following elective coronary angiography and intervention: a randomized controlled trial. JAMA.
Durham JD, Caputo C, Dokko J, Zaharakis T, Pahlavan M, Keltz J, Dutka P, Marzo K, Maesaka JK, Fishbane S. (2002). A randomized controlled trial of N-acetylcysteine to prevent contrast nephropathy in cardiac angiography. Kidney Int.
Trivedi HS, Moore H, Nasr S, Aggarwal K, Agrawal A, Goel P, Hewett J. (2003). A randomized prospective trial to assess the role of saline hydration on the development of contrast nephrotoxicity. Nephron Clin Pract.
Allaqaband S, Tumuluri R, Malik AM, Gupta A, Volkert P, Shalev Y, Bajwa TK. (2002). Prospective randomized study of N-acetylcysteine, fenoldopam, and saline for prevention of radiocontrast-induced nephropathy. Catheter Cardiovasc Interv.
Shyu KG, Cheng JJ, Kuan P. (2002). Acetylcysteine protects against acute renal damage in patients with abnormal renal function undergoing a coronary procedure. J Am Coll Cardiol.
Briguori C, Manganelli F, Scarpato P, Elia PP, Golia B, Riviezzo G, Lepore S, Librera M, Villari B, Colombo A, Ricciardelli B. (2002). Acetylcysteine and contrast agent-associated nephrotoxicity. J Am Coll Cardiol.
Mueller C, Buerkle G, Buettner HJ, Petersen J, Perruchoud AP, Eriksson U, Marsch S, Roskamm H. (2002). Prevention of contrast media-associated nephropathy: randomized comparison of 2 hydration regimens in 1620 patients undergoing coronary angioplasty. Arch Intern Med.
Shammas NW, Kapalis MJ, Harris M, McKinney D, Coyne EP. (2001). Aminophylline does not protect against radiocontrast nephropathy in patients undergoing percutaneous angiographic procedures. J Invasive Cardiol.
Abizaid AS, Clark CE, Mintz GS, Dosa S, Popma JJ, Pichard AD, Satler LF, Harvey M, Kent KM, Leon MB. (1999). Effects of dopamine and aminophylline on contrast-induced acute renal failure after coronary angioplasty in patients with preexisting renal insufficiency. Am J Cardiol.
Stevens MA, McCullough PA, Tobin KJ, Speck JP, Westveer DC, Guido-Allen DA, Timmis GC, O'Neill WW. (1999). A prospective randomized trial of prevention measures in patients at high risk for contrast nephropathy: results of the P.R.I.N.C.E. Study. Prevention of Radiocontrast Induced Nephropathy Clinical Evaluation. J Am Coll Cardiol.
Hans SS, Hans BA, Dhillon R, Dmuchowski C, Glover J. (1998). Effect of dopamine on renal function after arteriography in patients with pre-existing renal insufficiency. Am Surg.
Lehnert T, Keller E, Gondolf K, Schaffner T, Pavenstadt H, Schollmeyer P. (1998). Effect of haemodialysis after contrast medium administration in patients with renal insufficiency. Nephrol Dial Transplant.
Solomon R, Werner C, Mann D, D'Elia J, Silva P. (1994). Effects of saline, mannitol, and furosemide to prevent acute decreases in renal function induced by radiocontrast agents. N Engl J Med.
Weisberg LS, Kurnik PB, Kurnik BR. (1994). Risk of radiocontrast nephropathy in patients with and without diabetes mellitus. Kidney Int.
Erol T, Tekin A, Katircibasi MT, Sezgin N, Bilgi M, Tekin G, Zumrutdal A, Sezgin AT, Muderrisoglu H. (2013). Efficacy of allopurinol pretreatment for prevention of contrast-induced nephropathy: A randomized controlled trial. International Journal of Cardiology.
Koc F, Ozdemir K, Altunkas F, Celik A, Dogdu O, Karayakali M, Gul EE, Erkorkmaz U, Kadi H, Akpek M, Kaya MG. (2013). Sodium bicarbonate versus isotonic saline for the prevention of contrast-induced nephropathy in patients with diabetes mellitus undergoing coronary angiography and/or intervention: A multicenter prospective randomized study. Journal of Investigative Medicine.
Gu GQ, Lu R, Cui W, Liu F, Zhang Y, Yang XH, Chen XF, Jia WM. (2013). Low-dose furosemide administered with adequate hydration reduces contrast-induced nephropathy in patients undergoing coronary angiography. Cardiology (Switzerland).
Berwanger O, Cavalcanti AB, Sousa AMG, Buehler A, Castello-Junior HJ, Cantarelli MJC, Mangione JA, Bergo RR, Sao Thiago LEK, Nunes PMS, Da Motta PAM, Kodama A, Victor E, Carvalho VO, Sousa JE. (2013). Acetylcysteine for the prevention of renal outcomes in patients with diabetes mellitus undergoing coronary and peripheral vascular angiography: A substudy of the acetylcysteine for contrast-induced nephropathy trial. Circulation: Cardiovascular Interventions.
Rashid H, Tufail Q, Shafi T. (2011). Role of N - Acetylcysteine in prevention of contrast induced nephropathy. Pakistan Journal of Medical and Health Sciences.
Hassan Y, Zainal ZA, Aziz NA, Al-Jabi SW, Ismail O. (2011). Prevention of radiocontrast-induced nephropathy after coronary angiography: N-acetylcysteine plus saline hydration versus saline hydration. Tropical Journal of Pharmaceutical Research.
Hassan Y, Zainal ZA, Aziz NA, Al-Jabi SW, Ismail O. (2011). Prevention of radiocontrast-induced nephropathy after coronary angiography: N-acetylcysteine plus saline hydration versus saline hydration. Tropical Journal of Pharmaceutical Research.
Ratcliffe JA, Thiagarajah P, Chen J, Kavala G, Kanei Y, Fox J, Gowda R, Schmitz SJ, Friedmann P, Bergmann S. (2009). Prevention of contrast-induced nephropathy: A randomized controlled trial of sodium bicarbonate and N-acetylcysteine. International Journal of Angiology.
Staniloae CS, Doucet S, Sharma SK, Katholi RE, Mody KR, Coppola JT, Solomon R. (2009). N-acetylcysteine added to volume expansion with sodium bicarbonate does not further prevent contrast-induced nephropathy: Results from the cardiac angiography in renally impaired patients study. Journal of Interventional Cardiology.
Izani Wan Mohamed WM, Darus Z, Yusof Z. (2008). Oral N-acetylcysteine in prevention of contrast induced nephropathy following coronary angiogram. International Medical Journal.
Wang JH, Subeq YM, Tsai WC, Lee RP, Hsu BG. (2008). Intravenous N-acetylcysteine with saline hydration improves renal function and ameliorates plasma total homocysteine in patients undergoing cardiac angiography. Renal Failure.
Kimmel M, Butscheid M, Brenner S, Kuhlmann U, Klotz U, Alscher DM. (2008). Improved estimation of glomerular filtration rate by serum cystatin C in preventing contrast induced nephropathy by N-acetylcysteine or zinc - Preliminary results. Nephrology Dialysis Transplantation.
Hsu CH, Lee JD, Lo PH, Lin JJ, Chang HW, Chou HT. (2007). Prevention of radiocontrast-induced nephropathy with N-acetylcysteine after cardiac angiography in diabetic patients with renal dysfunction. Mid-Taiwan Journal of Medicine.
Baranska-Kosakowska A, Zakliczynski M, Przybylski R, Zembala M. (2007). Role of N-Acetylcysteine on Renal Function in Patients After Orthotopic Heart Transplantation Undergoing Coronary Angiography. Transplantation Proceedings.
Recio-Mayoral A, Chaparro M, Prado B, Cozar R, Mendez I, Banerjee D, Kaski JC, Cubero J, Cruz JM. (2007). The Reno-Protective Effect of Hydration With Sodium Bicarbonate Plus N-Acetylcysteine in Patients Undergoing Emergency Percutaneous Coronary Intervention. The RENO Study. Journal of the American College of Cardiology.
Rezkalla SH, Benz M. (2004). Effectiveness of Acetylcysteine on Preventing Renal Dysfunction in Patients Undergoing Coronary Procedures. Wisconsin Medical Journal.
Ochoa A, Pellizzon G, Addala S, Grines C, Isayenko Y, Boura J, Rempinski D, O'Neill W, Kahn J. (2004). Abbreviated dosing of N-acetylcysteine prevents contrast-induced nephropathy after elective and urgent coronary angiography and intervention.
Hashemi M, Kharazi A, Shahidi S. (2005). Captopril for prevention of contrast induced nephropathy in patients undergoing coronary angioplasty: a double blind placebo controlled clinical trial.

## Exclusion: Non-English

Suzuki H. (2011). Nihon Rinsho.
Su JZ, Xue Y, Cai WQ, Huang QY, Chai DJ, Chen GL, Wang FB, Chen XP, Zhang DS. (2011). Zhonghua Xin Xue Guan Bing Za Zhi.
Shamkhalova M, Zaitseva NV, Kurumova KO, Shestakova MV, Deev AD, Matskeplishvili ST, Tugeeva EF, Buziashvili IuI. (2009). Ter Arkh.
Zhou X, Jin YZ, Wang Q, Min R, Zhang XY. (2009). Zhonghua Xin Xue Guan Bing Za Zhi.
Yin L, Li GP, Liu T, Liu HM, Chen X, He M, Zheng XT, Liu EZ, Zhou LJ. (2009). Zhonghua Xin Xue Guan Bing Za Zhi.
Kamiyama N, Ogawa R, Hamada H, Ohno T, Asano R, Umemura J, Yoshida H. (2008). Preventive effect of N-acetylcysteine on contrast-induced nephropathy following coronary angiography and angioplasty. Yakugaku Zasshi.
Sulimov VA, Udovichenko AE. (2008). Kardiologiia.
Shavit L, Lifschitz M, Lachish T, Rosenmann D, Balkin J, Slotki I. (2007). Harefuah.
Shavit L, Lifschitz M, Lachish T, Rosenmann D, Balkin J, Slotki I. (2007). Harefuah.
Hoshino A, Enomoto S, Kawahito H, Kurata H, Nakahara Y, Nakamura T. (2007). J Cardiol.
Hoshino A, Enomoto S, Kawahito H, Kurata H, Nakahara Y, Nakamura T. (2007). J Cardiol.
Chen CY, Cao L, Chen DK, Chu M, Tu J. (2006). Zhonghua Er Ke Za Zhi.
Chen CY, Cao L, Chen DK, Chu M, Tu J. (2006). Zhonghua Er Ke Za Zhi.
El Mahmoud R, Le Feuvre C, Le Quan Sang KH, Helft G, Beygui F, Batisse JP, Metzger JP. (2003). Arch Mal Coeur Vaiss.
Vallero A, Cesano G, Pozzato M, Garbo R, Minelli M, Quarello F, Formica M. (2002). G Ital Nefrol.
Vallero A, Cesano G, Pozzato M, Garbo R, Minelli M, Quarello F, Formica M. (2002). G Ital Nefrol.
Berger ED, Bader BD, Bosker J, Risler T, Erley CM. (2001). Dtsch Med Wochenschr.
Berger ED, Bader BD, Bosker J, Risler T, Erley CM. (2001). Dtsch Med Wochenschr.
Usutani S. (2000). Nihon Jinzo Gakkai Shi.
Usutani S. (2000). Nihon Jinzo Gakkai Shi.
Diez T, Bagilet D, Ramos M, Jolly H, Diab M, Marcucci R, Rojo L. (1999). Medicina (B Aires).
Diez T, Bagilet D, Ramos M, Jolly H, Diab M, Marcucci R, Rojo L. (1999). Medicina (B Aires).
Porst H, Mayer R, Clauss W. (1986). Urologe A.
Prinseau J, Jardin F, Sanchez A, Baglin A, Domart M, Lubetzki J, Margairaz A, Fritel D. (1977). Ann Med Interne (Paris).
Stage P, Brix E, Folke K, Karle A. (1971). Ugeskr Laeger.
Stage P, Brix E, Folke K, Karle A. (1971). Ugeskr Laeger.
Grazi S, Leonetti G, Romano S, Bonazzi O, Ligresti A. (1967). Atti Accad Fisiocrit Siena Med Fis.
Grazi S, Leonetti G, Romano S, Bonazzi O, Ligresti A. (1967). Atti Accad Fisiocrit Siena Med Fis.
Hornych A, Prat V, Hejl Z, Dejdar R. (1963). Cas Lek Cesk.
Hornych A, Prat V, Hejl Z, Dejdar R. (1963). Cas Lek Cesk.
Zhang BC, Zhang YD, Zhao K, Wang XY, Jiang XX. (2013). A prospective study on the risk of contrast induced nephropathy in the patients who underwent contrast-enhanced CT examination. Chinese Journal of Radiology (China).
Zhang BC, Zhang YD, Zhao K, Wang XY, Jiang XX. (2013). A prospective study on the risk of contrast induced nephropathy in the patients who underwent contrast-enhanced CT examination. Chinese Journal of Radiology (China).
Pan JW, Lu ZG, Zhang JY, Xuan CY, Qi S, Wang NS, Wei M. (2013). Delayed contrast-induced nephropathy occurring after percutaneous coronary intervention. Journal of Interventional Radiology (China).
Pan JW, Lu ZG, Zhang JY, Xuan CY, Qi S, Wang NS, Wei M. (2013). Delayed contrast-induced nephropathy occurring after percutaneous coronary intervention. Journal of Interventional Radiology (China).
Gul M, Turan B, Ugur M, Turer A, Findikcioglu U, Ergelen M, Uyarel H. (2013). Nephrotoxicity of iodixanol versus iopamidol in patients with acute coronary syndrome. Turk Kardiyoloji Dernegi Arsivi.
Gul M, Turan B, Ugur M, Turer A, Findikcioglu U, Ergelen M, Uyarel H. (2013). Nephrotoxicity of iodixanol versus iopamidol in patients with acute coronary syndrome. Turk Kardiyoloji Dernegi Arsivi.
Sanadgol H, Abdani S, Tabatabaiee P, Mohammadi M, Baradaran A. (2012). Comparison between the efficacy of high dose short-term statin therapy and normal saline in prevention of contrast-induced nephropathy among patients receiving iodixanol. Journal of Isfahan Medical School.
Sanadgol H, Abdani S, Tabatabaiee P, Mohammadi M, Baradaran A. (2012). Comparison between the efficacy of high dose short-term statin therapy and normal saline in prevention of contrast-induced nephropathy among patients receiving iodixanol. Journal of Isfahan Medical School.
Campanale CM, Nusca A, Contuzzi R, Patti G, D'Ambrosio A, Di Sciascio G. (2011). GIK and N-Acetyl-cysteine in prevention of CIN in diabetic and/or with chronic renal failure patients undergoing PCI: Preliminary results from a randomized trial. Giornale Italiano di Cardiologia.
Yu DJ, Su JZ, Chen GL, Cai WQ, Jin XQ, Chai DJ. (2010). Effect of different doses of Atorvastatin in contrast-induced nephropathy. Chinese Journal of Interventional Imaging and Therapy.
Yu DJ, Su JZ, Chen GL, Cai WQ, Jin XQ, Chai DJ. (2010). Effect of different doses of Atorvastatin in contrast-induced nephropathy. Chinese Journal of Interventional Imaging and Therapy.
Negita K, Miura T, Katsumi A, Tamai H, Takemoto K, Watarai M. (2008). Protective effect orally administered N-acetylcysteine on Contrast media-induced nephropathy: evaluation in acute and chronic phases. Japanese Journal of Interventional Cardiology.
Negita K, Miura T, Katsumi A, Tamai H, Takemoto K, Watarai M. (2008). Protective effect orally administered N-acetylcysteine on Contrast media-induced nephropathy: evaluation in acute and chronic phases. Japanese Journal of Interventional Cardiology.
Li YH, Zhang LL, Zhao CY. (2008). Influences of an iso-osmolar versus a low-osmolar contrast media on radiographic contrast nephropathy in high-risk patients. Journal of Clinical Rehabilitative Tissue Engineering Research.
Li YH, Zhang LL, Zhao CY. (2008). Influences of an iso-osmolar versus a low-osmolar contrast media on radiographic contrast nephropathy in high-risk patients. Journal of Clinical Rehabilitative Tissue Engineering Research.
Funada R, Oikawa Y, Yajima J, Nagashima K, Kirigaya H, Shiraiwa O, Goda A, Shiratori Y, Ikeno K, Aizawa T. (2006). The prevention of radiocontrast-agent induced nephropathy in renal dysfunction patients: A comparison between perioperative, postoperative hemodialysis and hydration. Japanese Journal of Interventional Cardiology.
Funada R, Oikawa Y, Yajima J, Nagashima K, Kirigaya H, Shiraiwa O, Goda A, Shiratori Y, Ikeno K, Aizawa T. (2006). The prevention of radiocontrast-agent induced nephropathy in renal dysfunction patients: A comparison between perioperative, postoperative hemodialysis and hydration. Japanese Journal of Interventional Cardiology.
Sugaya K, Nishizawa O, Noto H, Suzuki T, Shimoda N, Miyagata S, Harada T, Tsuchida S. (1992). Comparative study on nephrotoxicity of ionic and non-ionic contrast agents for drip infused urography. Acta Urologica Japonica.
Sugaya K, Nishizawa O, Noto H, Suzuki T, Shimoda N, Miyagata S, Harada T, Tsuchida S. (1992). Comparative study on nephrotoxicity of ionic and non-ionic contrast agents for drip infused urography. Acta Urologica Japonica.
Mannella P, Tataranni G, Benea G. (1983). Renal investigation by means of contrast medium in hypertensive patients: Nephrotoxicity comparison between ionic and non-ionic contrast media. Radiologia Medica.
Mannella P, Tataranni G, Benea G. (1983). Renal investigation by means of contrast medium in hypertensive patients: Nephrotoxicity comparison between ionic and non-ionic contrast media. Radiologia Medica.
Esplugas E, Molina C, Romero R. (1983). Nephrotoxicity of contrast medium in cardiac catheterization. A prospective study. Revista Espanola de Cardiologia.
Esplugas E, Molina C, Romero R. (1983). Nephrotoxicity of contrast medium in cardiac catheterization. A prospective study. Revista Espanola de Cardiologia.
Hobikoglu GF, Norgaz T, Aksu H, Ozer O, Sari I, Karabulut A, Onturk E, Narin A. (2007).

## Exclusion: No Outcome of Interest

Bartholomew BA, Harjai KJ, Dukkipati S, Boura JA, Yerkey MW, Glazier S, Grines CL, O'Neill WW. (2004). Impact of nephropathy after percutaneous coronary intervention and a method for risk stratification. Am J Cardiol.
Kolonko A, Wiecek A, Kokot F. (1998). The nonselective adenosine antagonist theophylline does prevent renal dysfunction induced by radiographic contrast agents. J Nephrol.
Furukawa T, Ueda J, Takahashi S, Sakaguchi K. (1996). Elimination of low-osmolality contrast media by hemodialysis. Acta Radiol.
Hayami S, Ishigooka M, Suzuki Y, Hashimoto T, Nakada T, Mitobe K. (1996). Comparison of the nephrotoxicity between ioversol and iohexol. Int Urol Nephrol.
Kjaersgaard P, Jakobsen JA, Nossen JO, Berg KJ. (1996). Determination of glomerular filtration rate with Visipaque in patients with severely reduced renal function. Eur Radiol.
Mikkonen R, Kontkanen T, Kivisaari L. (1995). Acute and late adverse reactions to low-osmolal contrast media. Acta Radiol.
Fujimoto M, Waseda K, Takashima H, Maeda K, Asai K, Kuroda Y, Kosaka T, Kurita A, Kuhara Y, Ando H, Sakurai S, Kato D, Suzuki A, Nakano Y, Niwa T, Mukai K, Sato S, Mizuno T, Amano T. (2013). Effect of oral hydration on renal function after coronary catheterization. American Journal of Cardiology.
Sadeghi MM, Gharipour M, Nilforoush P, Shamsolkotabi H, Sadeghi HM, Kiani A, Sadeghi PM, Farahmand N. (2011). Influence of the timing of cardiac catheterization and amount of contrast media on acute renal failure after cardiac surgery. Journal of Research in Medical Sciences.
Schild HH, Kuhl CK, Hubner-Steiner U, Bohm I, Speck U. (2006). Adverse events after unenhanced and monomeric and dimeric contrast-enhanced CT: A prospective randomized controlled trial. Radiology.
Oi H, Yamazaki H, Matsushita M. (1997). Delayed vs. immediate adverse reactions to ionic and non-ionic low- osmolality contrast media. Radiation Medicine - Medical Imaging and Radiation Oncology.

## Exclusion: No Original Data

Briguori C. (2012). Renalguard system in high-risk patients for contrast-induced acute kidney injury. Minerva Cardioangiol.
Silva RG, Silva NG, Lucchesi F, Burdmann EA. (2010). Prevention of contrast-induced nephropathy by use of bicarbonate solution: preliminary results and literature review. J Bras Nefrol.
Silva RG, Silva NG, Lucchesi F, Burdmann EA. (2010). Prevention of contrast-induced nephropathy by use of bicarbonate solution: preliminary results and literature review. J Bras Nefrol.
Bolognese L, Falsini G, Grotti S, Limbruno U, Liistro F, Carrera A, Angioli P, Picchi A, Ducci K, Pierli C. (2010). The contrast media and nephrotoxicity following coronary revascularization by primary angioplasty for acute myocardial infarction study: design and rationale of the CONTRAST-AMI study. J Cardiovasc Med (Hagerstown).
Thomsen HS, Morcos SK. (2009). Risk of contrast-medium-induced nephropathy in high-risk patients undergoing MDCT--a pooled analysis of two randomized trials. Eur Radiol.
Goldenberg I, Chonchol M, Guetta V. (2009). Reversible acute kidney injury following contrast exposure and the risk of long-term mortality. Am J Nephrol.
Goldenberg I, Chonchol M, Guetta V. (2009). Reversible acute kidney injury following contrast exposure and the risk of long-term mortality. Am J Nephrol.
Bouzas-Mosquera A, Vazquez-Rodriguez JM, Calvino-Santos R, Vazquez-Gonzalez N, Castro-Beiras A. (2009). Statin therapy and contrast-induced nephropathy after primary angioplasty. Int J Cardiol.
Gandhi MR, Brown P, Romanowski CA, Morcos SK, Campbell S, el Nahas AM, Gray TA. (1992). The use of theophylline, an adenosine antagonist in the prevention of contrast media induced nephrotoxicity. Br J Radiol.
Teruel JL, Marcen R, Herrero JA, Felipe C, Ortuno J. (1989). An easy and effective procedure to prevent radiocontrast agent nephrotoxicity in high-risk patients. Nephron.
Teruel JL, Marcen R, Herrero JA, Felipe C, Ortuno J. (1989). An easy and effective procedure to prevent radiocontrast agent nephrotoxicity in high-risk patients. Nephron.
Uyarel H, Cam N, Ergelen M, Akkaya E, Ayhan E, Isik T, Cicek G, Gunaydin ZY, Osmonov D, Gul M, Demirci D, Guney MR, Ozturk R, Yekeler I. (2009). Contrast-induced nephropathy in patients undergoing primary angioplasty for acute myocardial infarction: Incidence, a simple risk score, and prognosis. Archives of Medical Science.
Erley CM. (1998). Prevention of contrast-media-induced renal impairment by adenosine antagonists in humans. Drug Development Research.
Berns JS, Rudnick MR. (1992). Radiocontrast media associated nephrotoxicity. Kidney.
Davidson CJ, Bashore TM. (1991). Comparison of ionic and low-osmolar contrast media during cardiac catheterization. Trends in Cardiovascular Medicine.

## Exclusion: Qualitative Study

Oi H, Yamazaki H, Matsushita M. (1997). Delayed vs. immediate adverse reactions to ionic and non-ionic low- osmolality contrast media. Radiation Medicine - Medical Imaging and Radiation Oncology.

## Exclusion: Study Compared an Intervention of Interest to a Comparator of Interest, but the Patient Groups Being Compared Were Fundamentally Different

Calabr P, Bianchi R, Caprile M, Sordelli C, Cappelli Bigazzi M, Palmieri R, Gigantino G, Umongelli G, Capozzi G, Cuomo S, Calabro R. (2010). Use of NaCl saline hydration and N-Acetyl Cysteine to prevent contrast induced nephropathy in different populations of patients at high and low risk undergoing coronary artery angiography. Minerva Cardioangiologica.