# Appendix C Screening and Data Abstraction Forms

Title

This is the screening and data abstraction form for titles and abstracts.

Abstract Screening – NO

This is the screening and data abstraction form for titles and abstracts that do not apply to the Key Questions.

Abstract Screening – YES

This is the screening and data abstraction form for titles and abstracts that do apply to the Key Questions.

Abstract Screening – Unclear

This is the screening and data abstraction form for titles and abstracts with an unclear application to the Key Questions.

Article Screening – NO

This is the article screening form for articles that do not apply to the Key Questions.

Article Screening – YES

This is the article screening form for articles that do apply to the Key Questions.

Participant Characteristics

This is the participant characteristics form.

Study Characteristics

This is the study characteristics form.

Intervention Description

This is the intervention description form.

Clinical Outcomes, Continuous

This is the clinical outcomes, continuous form.

Clinical Outcomes, Categorical

This is the clinical outcomes, categorical form.

Adverse Events

This is the adverse events form.

Cochrane Risk of Bias

This is the Cochrane Risk of Bias form.