# Appendix B Detailed Search Strategy

Database | Search | Included returns | Notes
PubMed | ((“Kidney diseases”[mh] OR “Kidney disease”[tiab] OR “kidney diseases”[tiab] OR Nephropathy[tiab] OR “acute kidney injury”[mh] OR “acute kidney injury”[tiab] OR “acute renal injury”[tiab] OR “renal disease”[tiab] OR “renal diseases”[tiab]) AND (“contrast media”[mh] OR “contrast media”[tiab] OR “contrast medium”[tiab] OR “contrast material”[tiab])) NOT (animal[mh] NOT human[mh]) | 5308
Embase | (‘contrast medium’/exp OR ‘contrast medium’:ab,ti OR ‘contrast media’:ab,ti OR ‘contrast material’:ab,ti) AND (‘kidney disease’/exp OR ‘kidney disease’:ab,ti OR ‘kidney diseases’:ab,ti OR nephropathy:ab,ti OR ‘acute kidney injury’:ab,ti OR ‘renal disease’:ab,ti OR ‘acute renal failure’:ab,ti OR ‘acute renal injury’:ab,ti) | 8952 | 12151 Limit to humans (study type): 9972 Limit to Article, Review, Conference Abstract, Conference Paper, Short Survey, Article in Press, Conference review (Publication type): 8952
Cochrane | ID Search #1 MeSH descriptor: [Kidney Diseases] explode all trees #2 “kidney disease”:ti,ab,kw (Word variations have been searched) #3 nephropathy:ti,ab,kw (Word variations have been searched) #4 “acute kidney injury”:ti,ab,kw (Word variations have been searched) #5 “renal disease”:ti,ab,kw (Word variations have been searched) #6 “acute renal injury”:ti,ab,kw #7 “renal diseases”:ti,ab,kw #8 #1 or #2 or #3 or #4 or #5 or #6 or #7 #9 MeSH descriptor: [Contrast Media] explode all trees #10 “contrast media”:ti,ab,kw (Word variations have been searched) #11 “contrast material”:ti,ab,kw (Word variations have been searched) #12 “contrast medium”:ti,ab,kw #13 #9 or #10 or #11 or #12 #14 #8 and #13 | 429 | Other reviews: 52 Trials: 368 Technology assessments: 4 Economic evaluations: 5
Total | | 14,689