# Appendix A Acronyms

AHRQ: Agency for Healthcare Research and Quality
AKI: Acute kidney injury
CI: Confidence Interval
CIN: Contrast induced nephropathy
CKD: Chronic kidney disease
CV: Cardiovascular
EPC: Evidence-based Practice Center
ESRD: End stage renal disease
GFR: Glomular filtration rate
HD: Hemodialysis
HF: Heart failure
HOCM: High osmolar contrast media
IA: Intra-arterial
IOCM: Iso-osmolar contrast media
ITT: Intention to treat
IV: Intravenous
IVU: Intravenous urography
KDIGO: Kidney Disease: Improving Global Outcomes
KQ: Key Questions
LOCM: Low osmolar contrast media
MACE: Major adverse cardiac events
MeSH: Medical subject heading
MI: Myocardial infarction
NA: Not applicable
NR: Not reported
NS: Not significant
PCI: Percutaneous coronary intervention
PICOTS: Population, interventions, comparators, outcomes, timing, setting
PP: Protocol population
RCT: Randomized controlled trial
RRT: Renal replacement therapy
SOE: Strength of evidence
SIP: Scientific information package
TOO: Task Order Officer