# References

1 Lahey BB, Loeber R, Burke J, et al. Adolescent outcomes of childhood conduct disorder among clinic-referred boys: predictors of improvement. J Abnorm Child Psychol. Aug. 2002;30(4):333-48. [pmid: 12108765].
2 The Chance of a Lifetime: Preventing Early Conduct Problems and Reducing Crime. London. Sainsbury Centre for Mental Health. 2009. Available at: http://www.centreformentalhealth.org.uk/pdfs/chance_of_a_lifetime.pdf. April 2, 2015.
3 Loeber R. Oppositional defiant disorder and conduct disorder. Hosp Community Psychiatry. Nov. 1991;42(11):1099-100. 102. [pmid: 1743634].
4 Frick PJ, Kamphaus RW, Lahey BB, et al. Academic underachievement and the disruptive behavior disorders. J Consult Clin Psychol. Apr. 1991;59(2):289-94. [pmid: 2030190].
5 Loeber R. Antisocial behavior: more enduring than changeable?. J Am Acad Child Adolesc Psychiatry. May. 1991;30(3):393-7. [pmid: 2055875].
6 Loeber R, Green SM, Lahey BB, et al. Differences and similarities between children, mothers, and teachers as informants on disruptive child behavior. J Abnorm Child Psychol. Feb. 1991;19(1):75-95. [pmid: 2030249].
7 Loeber R, Lahey BB, Thomas C. Diagnostic conundrum of oppositional defiant disorder and conduct disorder. J Abnorm Psychol. Aug. 1991;100(3):379-90. [pmid: 1918617].
8 Meier MH, Slutske WS, Heath AC, et al. Sex differences in the genetic and environmental influences on childhood conduct disorder and adult antisocial behavior. J Abnorm Psychol. May. 2011;120(2):377-88. [pmid: 21319923].
9 Murrihy RC, Kidman AD, Ollendick TH. Clinical handbook of assessing and treating conduct problems in youth. New York. Springer Science Business Media. 2010.
10 Kutcher S, Aman M, Brooks SJ, et al. International consensus statement on attention-deficit/hyperactivity disorder (ADHD) and disruptive behaviour disorders (DBDs): clinical implications and treatment practice suggestions. Eur Neuropsychopharmacol. Jan. 2004;14(1):11-28. [pmid: 14659983].
11 Lahey BB, Miller TL, Gordon RA, et al. Developmental epidemiology of the disruptive behavior disorders. Quay HC, Hogan AE, editors. Handbook of Disruptive Behavior Disorder. Dordrecht, Netherlands. Kluwer Academic Publishers. 1999.
12 Maughan B, Rowe R, Messer J, et al. Conduct disorder and oppositional defiant disorder in a national sample: developmental epidemiology. J Child Psychol Psychiatry. Mar. 2004;45(3):609-21. [pmid: 15055379].
13 Loeber R, Burke JD, Lahey BB, et al. Oppositional defiant and conduct disorder: a review of the past 10 years, part I. J Am Acad Child Adolesc Psychiatry. Dec. 2000;39(12):1468-84. [pmid: 11128323].
14 Burke JD, Loeber R, Birmaher B. Oppositional defiant disorder and conduct disorder: a review of the past 10 years, part II. J Am Acad Child Adolesc Psychiatry. Nov. 2002;41(11):1275-93. [pmid: 12410070].
15 Perou R, Bitsko RH, Blumberg SJ, et al. Mental health surveillance among children--United States, 2005-2011. MMWR Surveill Summ. May. 17. Suppl 2. 2013;62:1-35. [pmid: 23677130].
16 American Psychiatric Association. Task Force on DSM-IV. Diagnostic and statistical manual of mental disorders : DSM-IV. Fourth edition. Washington, D.C. American Psychiatric Association. 1994.
17 American Psychiatric Association. Diagnostic and statistical manual of mental disorders: DSM-V. Fifth edition. Arlington, VA. American Psychiatric Association. 2013.
18 Bonin EM, Stevens M, Beecham J, et al. Costs and longer-term savings of parenting programmes for the prevention of persistent conduct disorder: a modelling study. BMC Public Health. 2011;11:803. [pmid: 21999434].
19 Kessler RC, Berglund P, Demler O, et al. Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. Jun. 2005;62(6):593-602. [pmid: 15939837].
20 Russo MF, Loeber R, Lahey BB, et al. Oppositional Defiant and Conduct Disorders - Validation of the DSMIII-R and an Alternative Diagnostic Option. Journal of Clinical Child Psychology. Mar. 1994;23(1):56-68.
21 Russo MF, Beidel DC. Comorbidity of Childhood Anxiety and Externalizing Disorders - Prevalence, Associated Characteristics, and Validation Issues. Clinical Psychology Review. 1994;14(3):199-221.
22 U. S. Department of Health and Human Services. Mental Health: A Report of the Surgeon General. Rockville, MD. U. S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration, Center for Mental Health Services, National Institutes of Health, National Institute of Mental Health. 1999.
23 McKinney C, Morse M. Assessment of Disruptive Behavior Disorders: Tools and Recommendations. Professional Psychology-Research and Practice. Dec. 2012;43(6):641-9.
24 van Goozen SH, Matthys W, Cohen-Kettenis PT, et al. Salivary cortisol and cardiovascular activity during stress in oppositional-defiant disorder boys and normal controls. Biol Psychiatry. Apr. 1. 1998;43(7):531-9. [pmid: 9547933].
25 Loeber R, Green SM, Lahey BB, et al. Findings on disruptive behavior disorders from the first decade of the Developmental Trends Study. Clin Child Fam Psychol Rev. Mar. 2000;3(1):37-60. [pmid: 11228766].
26 Latimer K, Wilson P, Kemp J, et al. Disruptive behaviour disorders: a systematic review of environmental antenatal and early years risk factors. Child Care Health Dev. Sep. 2012;38(5):611-28. [pmid: 22372737].
27 Loeber R, Burke JD, Pardini DA. Development and etiology of disruptive and delinquent behavior. Annu Rev Clin Psychol. 2009;5:291-310. [pmid: 19154139].
28 August GJ, Bloomquist ML, Lee SS, et al. Can evidence-based prevention programs be sustained in community practice settings? The Early Risers' Advanced-Stage Effectiveness Trial. Prev Sci. Jun. 2006;7(2):151-65. [pmid: 16555143].
29 Bloomquist ML, August GJ, Horowitz JL, et al. Moving from science to service: transposing and sustaining the Early Risers prevention program in a community service system. J Prim Prev. Jul. 2008;29(4):307-21. [pmid: 18581235].
30 Knapp M, McDaid D, Parsonage M, editors. Mental health promotion and mental illness prevention: The economic case. London. Department of Health. 2011.
31 Cooper WO, Arbogast PG, Ding H, et al. Trends in prescribing of antipsychotic medications for US children. Ambul Pediatr. 2006;6:79-83. [pmid: 16530143].
32 Cooper WO, Federspiel CF, Griffin MR, et al. New use of anticonvulsant medications among children enrolled in the Tennessee Medicaid Program. Arch Pediatr Adolesc Med. 1997;151(12):1242-6. [pmid: 9412601].
33 Cooper WO, Hickson GB, Fuchs C, et al. New users of antipsychotic medications among children enrolled in TennCare. Arch Pediatr Adolesc Med. 2004;158:753-9. [pmid: 15289247].
34 Henggeler SW, Melton GB, Smith LA. Family preservation using multisystemic therapy: an effective alternative to incarcerating serious juvenile offenders. J Consult Clin Psychol. Dec. 1992;60(6):953-61. [pmid: 1460157].
35 Alexander J, Parsons BV. Functional Family Therapy. Monterey, CA. Brooks/Cole. 1982.
36 Wells KC, Egan J. Social learning and systems family therapy for childhood oppositional disorder: comparative treatment outcome. Compr Psychiatry. Mar-Apr. 1988;29(2):138-46. [pmid: 3370964].
37 Hembree-Kigin TL, McNeil CB. Parent-Child Interaction Therapy. New Yotk. Plenum Press. 1995.
38 Kazdin AE, Siegel TC, Bass D. Cognitive problem-solving skills training and parent management training in the treatment of antisocial behavior in children. J Consult Clin Psychol. Oct. 1992;60(5):733-47. [pmid: 1401389].
39 Cunningham NR, Ollendick TH. Comorbidity of anxiety and conduct problems in children: implications for clinical research and practice. Clin Child Fam Psychol Rev. Dec. 2010;13(4):333-47. [pmid: 20809124].
40 Kolko DJ, Pardini DA. ODD dimensions, ADHD, and callous-unemotional traits as predictors of treatment response in children with disruptive behavior disorders. J Abnorm Psychol. Nov. 2010;119(4):713-25. [pmid: 21090875].
41 Goldstein AP, Glick B, Gibbs JC. Aggression replacement training: A comprehensive intervention for aggressive youth. Revised Edition. Champaign, IL. Research Press. 1998.
42 Tcheremissine OV, Lieving LM. Pharmacological aspects of the treatment of conduct disorder in children and adolescents. CNS Drugs. 2006;20(7):549-65. [pmid: 16800715].
43 Newcorn JH, Ivanov I. Psychopharmacologic treatment of attention-deficit/hyperactivity disorder and disruptive behavior disorders. Pediatr Ann. Sep. 2007;36(9):564-74. [pmid: 17910204].
44 Connor DF, Glatt SJ, Lopez ID, et al. Psychopharmacology and aggression. I: A meta-analysis of stimulant effects on overt/covert aggression-related behaviors in ADHD. J Am Acad Child Adolesc Psychiatry. Mar. 2002;41(3):253-61. [pmid: 11886019].
45 Linton D, Barr AM, Honer WG, et al. Antipsychotic and psychostimulant drug combination therapy in attention deficit/hyperactivity and disruptive behavior disorders: a systematic review of efficacy and tolerability. Curr Psychiatry Rep. May. 2013;15(5):355. [pmid: 23539465].
46 Duhig MJ, Saha S, Scott JG. Efficacy of risperidone in children with disruptive behavioural disorders. J Paediatr Child Health. Jan. 2013;49(1):19-26. [pmid: 22050179].
47 Hanwella R, Senanayake M, de Silva V. Comparative efficacy and acceptability of methylphenidate and atomoxetine in treatment of attention deficit hyperactivity disorder in children and adolescents: a meta-analysis. BMC Psychiatry. 2011;11:176. [pmid: 22074258].
48 Hazell PL, Kohn MR, Dickson R, et al. Core ADHD symptom improvement with atomoxetine versus methylphenidate: a direct comparison meta-analysis. J Atten Disord. Nov. 2011;15(8):674-83. [pmid: 20837981].
49 Loy JH, Merry SN, Hetrick SE, et al. Atypical antipsychotics for disruptive behaviour disorders in children and youths. Cochrane Database Syst Rev. 2012;9. CD008559. [pmid: 22972123].
50 McKinney C, Renk K. Atypical antipsychotic medications in the management of disruptive behaviors in children: safety guidelines and recommendations. Clinical Psychology Review. Apr. 2011;31(3):465-71. [pmid: 21130552].
51 Pringsheim T, Gorman D. Second-generation antipsychotics for the treatment of disruptive behaviour disorders in children: a systematic review. Can J Psychiatry. Dec. 2012;57(12):722-7. [pmid: 23228230].
52 Seida JC, Schouten JR, Boylan K, et al. Antipsychotics for children and young adults: a comparative effectiveness review. Pediatrics. Mar. 2012;129(3):e771-84. [pmid: 22351885].
53 van Wyk GW, Hazell PL, Kohn MR, et al. How oppositionality, inattention, and hyperactivity affect response to atomoxetine versus methylphenidate: a pooled meta-analysis. J Atten Disord. May. 2012;16(4):314-24. [pmid: 21289234].
54 Bloch MH, Qawasmi A. Omega-3 fatty acid supplementation for the treatment of children with attention-deficit/hyperactivity disorder symptomatology: systematic review and meta-analysis. J Am Acad Child Adolesc Psychiatry. Oct. 2011;50(10):991-1000. [pmid: 21961774].
55 Dretzke J, Davenport C, Frew E, et al. The clinical effectiveness of different parenting programmes for children with conduct problems: a systematic review of randomised controlled trials. Child Adolesc Psychiatry Ment Health. 2009;3(1):7. [pmid: 19261188].
56 Furlong M, McGilloway S, Bywater T, et al. Cochrane review: behavioural and cognitive-behavioural group-based parenting programmes for early-onset conduct problems in children aged 3 to 12 years (Review). Evid Based Child Health. Mar. 7. 2012;8(2):318-692. [pmid: 23877886].
57 Lee MS, Choi TY, Kim JI, et al. Acupuncture for treating attention deficit hyperactivity disorder: a systematic review and meta-analysis. Chin J Integr Med. Apr. 2011;17(4):257-60. [pmid: 21509667].
58 Lee PC, Niew WI, Yang HJ, et al. A meta-analysis of behavioral parent training for children with attention deficit hyperactivity disorder. Res Dev Disabil. Nov-Dec. 2012;33(6):2040-9. [pmid: 22750360].
59 Michelson D, Davenport C, Dretzke J, et al. Do evidence-based interventions work when tested in the “real world?” a systematic review and meta-analysis of parent management training for the treatment of child disruptive behavior. Clin Child Fam Psychol Rev. Mar. 2013;16(1):18-34. [pmid: 23420407].
60 Sonuga-Barke EJ, Brandeis D, Cortese S, et al. Nonpharmacological interventions for ADHD: systematic review and meta-analyses of randomized controlled trials of dietary and psychological treatments. Am J Psychiatry. Mar. 1. 2013;170(3):275-89. [pmid: 23360949].
61 Storebo OJ, Skoog M, Damm D, et al. Social skills training for Attention Deficit Hyperactivity Disorder (ADHD) in children aged 5 to 18 years. Cochrane Database Syst Rev. 2011;(12). CD008223. [pmid: 22161422].
62 Weisz JR, Kuppens S, Eckshtain D, et al. Performance of evidence-based youth psychotherapies compared with usual clinical care: a multilevel meta-analysis. JAMA Psychiatry. Jul. 2013;70(7):750-61. [pmid: 23754332].
63 Zwi M, Jones H, Thorgaard C, et al. Parent training interventions for Attention Deficit Hyperactivity Disorder (ADHD) in children aged 5 to 18 years. Cochrane Database Syst Rev. 2011;(12). CD003018. [pmid: 22161373].
64 Knapp P, Chait A, Pappadopulos E, et al. Treatment of maladaptive aggression in youth: CERT guidelines I. Engagement, assessment, and management. Pediatrics. Jun. 2012;129(6):e1562-76. [pmid: 22641762].
65 Scotto Rosato N, Correll CU, Pappadopulos E, et al. Treatment of maladaptive aggression in youth: CERT guidelines II. Treatments and ongoing management. Pediatrics. Jun. 2012;129(6):e1577-86. [pmid: 22641763].
66 Vitiello B, Correll C, van Zwieten-Boot B, et al. Antipsychotics in children and adolescents: increasing use, evidence for efficacy and safety concerns. Eur Neuropsychopharmacol. Sep. 2009;19(9):629-35. [pmid: 19467582].
67 Seida JC, Schouten JR, Mousavi SS, et al. First- and Second-Generation Antipsychotics for Children and Young Adults. Comparative Effectiveness Review. AHRQ Publication No: 11(12)-EHC077-EF. Rockville, MD. Agency for Healthcare Research and Quality. Feb. 2012;39. http://effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction= displayproduct&productID=835. April 2, 2015.
68 Burns B, Fisher S, Ganju V, et al. Evidence-based and promising practices: Interventions for disruptive behavior disorders. Substance Abuse and Mental Health Services Administration. 2011. http://store.samhsa.gov/shin/content/SMA11-4634CD-DVD/EBPsPromisingPractices-IDBD.pdf. April 2, 2015.
69 Charach A, Dashti B, Carson P, et al. Attention Deficit Hyperactivity Disorder: Effectiveness of Treatment in At-Risk Preschoolers; Long-Term Effectiveness in All Ages; and Variability in Prevalence, Diagnosis, and Treatment. Comparative Effectiveness Review. AHRQ Report No: 12-EHC003-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2011;44. http://www.ncbi.nlm.nih.gov/books/NBK82368/. April 2, 2015.
70 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. AHRQ Publication No. 12-EHC047-EF. Rockville MD. Agency for Healthcare Research and Quality. 2012.
71 Higgins JP, Altman DG, Sterne JA. Chapter 8: Assessing the risk of bias in included studies. Higgins JP, Green S, editors. Cochrane handbook for systematic reviews of interventions. The Cochrane Collaboration. 2011.
72 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. Feb. 2012;65(2):163-78. [pmid: 21959223].
73 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. Oct. 2009;62(10):1013-20. [pmid: 19230606].
74 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
75 Shea BJ, Bouter LM, Peterson J, et al. External validation of a measurement tool to assess systematic reviews (AMSTAR). PLoS One. 2007;2(12):e1350. [pmid: 18159233].
76 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):502-12. [pmid: 18823754].
77 Lu G, Ades AE. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. Oct. 30. 2004;23(20):3105-24. [pmid: 15449338].
78 Wei Y, Higgins JP. Bayesian multivariate meta-analysis with multiple outcomes. Stat Med. Jul. 30. 2013;32(17):2911-34. [pmid: 23386217].
79 Lumley T. Network meta-analysis for indirect treatment comparisons. Stat Med. Aug. 30. 2002;21(16):2313-24. [pmid: 12210616].
80 Brooks S, Gelman A, Jones G, et al. Handbook of Markov Chain Monte Carlo. CRC Press. 2011.
81 Patil A, Huard D, Fonnesbeck CJ. PyMC: Bayesian Stochastic Modelling in Python. J Stat Softw. Jul. 2010;35(4):1-81. [pmid: 21603108].
82 Berkman ND, Lohr KN, Ansari MT, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Comparative Effectiveness Reviews. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No 290-2007-10056-I). AHRQ Publication No. 13(14)-EHC 130-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2013. http://effectivehealthcare.ahrq.gov/ehc/products/457/1752/methods-guidance-grading-evidence-131118.pdf. April 2, 2015.
83 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
84 Berkman ND, Lohr KN, Ansari M, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD). 2008.
85 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate health care interventions: explanation and elaboration. J Clin Epidemiol. Oct. 2009;62(10):e1-34. [pmid: 19631507].
86 van der Put CE, Asscher JJ, Stams GJ, et al. Recidivism after treatment in a forensic youth-psychiatric setting: the effect of treatment characteristics. Int J Offender Ther Comp Criminol. Sep. 2013;57(9):1120-39. [pmid: 22811475].
87 Posthumus JA, Raaijmakers MA, Maassen GH, et al. Sustained effects of incredible years as a preventive intervention in preschool children with conduct problems. J Abnorm Child Psychol. May. 2012;40(4):487-500. [pmid: 22006348].
88 Coughlin M, Sharry J, Fitzpatrick C, et al. A controlled clinical evaluation of the parents plus children's programme: a video-based programme for parents of children aged 6 to 11 with behavioural and developmental problems. Clin Child Psychol Psychiatry. Oct. 2009;14(4):541-58. [pmid: 19759073].
89 Lipman EL, Kenny M, Sniderman C, et al. Evaluation of a community-based program for young boys at-risk of antisocial behaviour: results and issues. J Can Acad Child Adolesc Psychiatry. 2008;17(1):12-9. [pmid: 18392161].
90 Shapiro JP, Youngstrom JK, Youngstrom EA, et al. Transporting a manualized treatment for children's disruptive behavior to a community clinic. Journal of Contemporary Psychotherapy. 2012;42(4):215-25.
91 Costin J, Lichte C, Hill-Smith A, et al. Parent group treatments for children with Oppositional Defiant Disorder. AeJAMH (Australian e-Journal for the Advancement of Mental Health). 2004;3(1).
92 Masi G, Milone A, Paciello M, et al. Efficacy of a multimodal treatment for disruptive behavior disorders in children and adolescents: focus on internalizing problems. Psychiatry Res. Nov. 30. 2014;219(3):617-24. [pmid: 25060833].
93 Perrin EC, Sheldrick RC, McMenamy JM, et al. Improving Parenting Skills for Families of Young Children in Pediatric Settings: A Randomized Clinical Trial. JAMA Pediatr. 2013. Nov. 4. [pmid: 24190691].
94 Weiss B, Han S, Harris V, et al. An Independent Randomized Clinical Trial of Multisystemic Therapy With Non-Court-Referred Adolescents With Serious Conduct Problems. J Consult Clin Psychol. 2013. Aug. 12. [pmid: 23937347].
95 Jones DJ, Forehand R, Cuellar J, et al. Technology-Enhanced Program for Child Disruptive Behavior Disorders: Development and Pilot Randomized Control Trial. J Clin Child Adolesc Psychol. 2013. Aug. 7. [pmid: 23924046].
96 Boylan K, Macpherson HA, Fristad MA. Examination of disruptive behavior outcomes and moderation in a randomized psychotherapy trial for mood disorders. J Am Acad Child Adolesc Psychiatry. Jul. 2013;52(7):699-708. [pmid: 23800483].
97 Kolko DJ, Campo JV, Kelleher K, et al. Improving access to care and clinical outcome for pediatric behavioral problems: a randomized trial of a nurse-administered intervention in primary care. J Dev Behav Pediatr. Jun. 2010;31(5):393-404. [pmid: 20495474].
98 Bagner DM, Sheinkopf SJ, Vohr BR, et al. Parenting intervention for externalizing behavior problems in children born premature: an initial examination. J Dev Behav Pediatr. Apr. 2010;31(3):209-16. [pmid: 20375736].
99 McCabe K, Yeh M. Parent-child interaction therapy for Mexican Americans: a randomized clinical trial. J Clin Child Adolesc Psychol. Sep. 2009;38(5):753-9. [pmid: 20183659].
100 Jouriles EN, McDonald R, Rosenfield D, et al. Reducing conduct problems among children exposed to intimate partner violence: a randomized clinical trial examining effects of Project Support. J Consult Clin Psychol. Aug. 2009;77(4):705-17. [pmid: 19634963].
101 Kolko DJ, Dorn LD, Bukstein OG, et al. Community vs. clinic-based modular treatment of children with early-onset ODD or CD: a clinical trial with 3-year follow-up. J Abnorm Child Psychol. Jul. 2009;37(5):591-609. [pmid: 19221871].
102 Lavigne JV, Lebailly SA, Gouze KR, et al. Treating oppositional defiant disorder in primary care: a comparison of three models. J Pediatr Psychol. Jun. 2008;33(5):449-61. [pmid: 17956932].
103 Greene RW, Ablon JS, Goring JC, et al. Effectiveness of collaborative problem solving in affectively dysregulated children with oppositional-defiant disorder: initial findings. J Consult Clin Psychol. Dec. 2004;72(6):1157-64. [pmid: 15612861].
104 Rohde P, Clarke GN, Mace DE, et al. An efficacy/effectiveness study of cognitive-behavioral treatment for adolescents with comorbid major depression and conduct disorder. J Am Acad Child Adolesc Psychiatry. Jun. 2004;43(6):660-8. [pmid: 15167082].
105 Webster-Stratton C, Reid MJ, Hammond M. Treating children with early-onset conduct problems: intervention outcomes for parent, child, and teacher training. J Clin Child Adolesc Psychol. Mar. 2004;33(1):105-24. [pmid: 15028546].
106 Santisteban DA, Coatsworth JD, Perez-Vidal A, et al. Efficacy of brief strategic family therapy in modifying Hispanic adolescent behavior problems and substance use. J Fam Psychol. Mar. 2003;17(1):121-33. [pmid: 12666468].
107 Jouriles EN, McDonald R, Spiller L, et al. Reducing conduct problems among children of battered women. J Consult Clin Psychol. Oct. 2001;69(5):774-85. [pmid: 11680554].
108 Kolko DJ. Efficacy of cognitive-behavioral treatment and fire safety education for children who set fires: initial and follow-up outcomes. J Child Psychol Psychiatry. Mar. 2001;42(3):359-69. [pmid: 11321205].
109 Schuhmann EM, Foote RC, Eyberg SM, et al. Efficacy of parent-child interaction therapy: interim report of a randomized trial with short-term maintenance. J Clin Child Psychol. Mar. 1998;27(1):34-45. [pmid: 9561935].
110 Webster-Stratton C, Hammond M. Treating children with early-onset conduct problems: a comparison of child and parent training interventions. J Consult Clin Psychol. Feb. 1997;65(1):93-109. [pmid: 9103739].
111 Borduin CM, Mann BJ, Cone LT, et al. Multisystemic treatment of serious juvenile offenders: long-term prevention of criminality and violence. J Consult Clin Psychol. Aug. 1995;63(4):569-78. [pmid: 7673534].
112 Eyberg SM, Boggs SR, Algina J. Parent-child interaction therapy: a psychosocial model for the treatment of young children with conduct problem behavior and their families. Psychopharmacol Bull. 1995;31(1):83-91. [pmid: 7675994].
113 Webster-Stratton C. Advancing videotape parent training: a comparison study. J Consult Clin Psychol. Jun. 1994;62(3):583-93. [pmid: 8063985].
114 Brestan EV, Eyberg SM, Boggs SR, et al. Parent–child interaction therapy: Parents' perceptions of untreated siblings. Child Fam Behav Ther. 1997;19(3):13-28.
115 Azrin NH, Donohue B, Teichner GA, et al. A controlled evaluation and description of individual-cognitive problem solving and family-behavior therapies in dually-diagnosed conduct-disordered and substance-dependent youth. J Child Adolesc Subst Abuse. 2001;11(1):1-43.
116 Sells SP, Early KW, Smith TE. Reducing Adolescent Oppositional and Conduct Disorders: An Experimental Design Using the Parenting with Love and Limits^®^ Model. Professional Issues in Criminal Justice. 2011;6(3).
117 Kjobli J, Ogden T. A randomized effectiveness trial of brief parent training in primary care settings. Prev Sci. Dec. 2012;13(6):616-26. [pmid: 22956303].
118 Axberg U, Broberg AG. Evaluation of “the incredible years” in Sweden: the transferability of an American parent-training program to Sweden. Scand J Psychol. Jun. 2012;53(3):224-32. [pmid: 22621727].
119 Somech LY, Elizur Y. Promoting self-regulation and cooperation in pre-kindergarten children with conduct problems: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Apr. 2012;51(4):412-22. [pmid: 22449647].
120 Butler S, Baruch G, Hickey N, et al. A randomized controlled trial of multisystemic therapy and a statutory therapeutic intervention for young offenders. J Am Acad Child Adolesc Psychiatry. Dec. 2011;50(12):1220-35 e2. [pmid: 22115143].
121 McGrath PJ, Lingley-Pottie P, Thurston C, et al. Telephone-based mental health interventions for child disruptive behavior or anxiety disorders: randomized trials and overall analysis. J Am Acad Child Adolesc Psychiatry. Nov. 2011;50(11):1162-72. [pmid: 22024004].
122 Kling A, Forster M, Sundell K, et al. A randomized controlled effectiveness trial of parent management training with varying degrees of therapist support. Behav Ther. Dec. 2010;41(4):530-42. [pmid: 21035616].
123 Scott S, Sylva K, Doolan M, et al. Randomised controlled trial of parent groups for child antisocial behaviour targeting multiple risk factors: the SPOKES project. J Child Psychol Psychiatry. Jan. 2010;51(1):48-57. [pmid: 19732250].
124 Sundell K, Hansson K, Lofholm CA, et al. The transportability of multisystemic therapy to Sweden: short-term results from a randomized trial of conduct-disordered youths. J Fam Psychol. Aug. 2008;22(4):550-60. [pmid: 18729669].
125 Ogden T, Hagen KA. Treatment effectiveness of Parent Management Training in Norway: a randomized controlled trial of children with conduct problems. J Consult Clin Psychol. Aug. 2008;76(4):607-21. [pmid: 18665689].
126 Larsson B, Fossum S, Clifford G, et al. Treatment of oppositional defiant and conduct problems in young Norwegian children : results of a randomized controlled trial. Eur Child Adolesc Psychiatry. Jan. 2009;18(1):42-52. [pmid: 18563473].
127 Cummings JG, Wittenberg JV. Supportive expressive therapy--Parent child version: An exploratory study. Psychotherapy (Chic). Jun. 2008;45(2):148-64. [pmid: 22122414].
128 van de Wiel NM, Matthys W, Cohen-Kettenis PT, et al. The effectiveness of an experimental treatment when compared to care as usual depends on the type of care as usual. Behav Modif. May. 2007;31(3):298-312. [pmid: 17438344].
129 Hutchings J, Gardner F, Bywater T, et al. Parenting intervention in Sure Start services for children at risk of developing conduct disorder: pragmatic randomised controlled trial. BMJ. Mar. 31. 2007;334(7595):678. [pmid: 17350966].
130 Gardner F, Burton J, Klimes I. Randomised controlled trial of a parenting intervention in the voluntary sector for reducing child conduct problems: outcomes and mechanisms of change. J Child Psychol Psychiatry. Nov. 2006;47(11):1123-32. [pmid: 17076751].
131 Drugli MB, Larsson B. Children aged 4-8 years treated with parent training and child therapy because of conduct problems: generalisation effects to day-care and school settings. Eur Child Adolesc Psychiatry. Oct. 2006;15(7):392-9. [pmid: 16614786].
132 van Manen TG, Prins PJ, Emmelkamp PM. Reducing aggressive behavior in boys with a social cognitive group treatment: results of a randomized, controlled trial. J Am Acad Child Adolesc Psychiatry. Dec. 2004;43(12):1478-87. [pmid: 15564817].
133 Nixon RD, Sweeney L, Erickson DB, et al. Parent-child interaction therapy: a comparison of standard and abbreviated treatments for oppositional defiant preschoolers. J Consult Clin Psychol. Apr. 2003;71(2):251-60. [pmid: 12699020].
134 Cabiya JJ, Padilla-Cotto L, González K, et al. Effectiveness of a cognitive-behavioral intervention for Puerto Rican children. Revista Interamericana de Psicología. 2008;42(2):195-202.
135 Markie-Dadds C, Sanders MR. A Controlled Evaluation of an Enhanced Self-Directed Behavioural Family Intervention for Parents of Children With Conduct Problems in Rural and Remote Areas. Behaviour Change. 2006;23(1):55-72.
136 Asscher JJ, Deković M, Manders WA, et al. A randomized controlled trial of the effectiveness of multisystemic therapy in the Netherlands: Post-treatment changes and moderator effects. J Exp Criminol. 2013;9(2):169-87.
137 Augimeri LK, Farrington DP, Koegl CJ, et al. The SNAPTM Under 12 Outreach Project: Effects of a community based program for children with conduct problems. J Child Fam Stud. 2007;16(6):799-807.
138 McGilloway S, Mhaille GN, Bywater T, et al. A parenting intervention for childhood behavioral problems: A randomized controlled trial in disadvantaged community-based settings. J Consult Clin Psychol. 2012;80(1):116-27. [pmid: 22148879].
139 Markie-Dadds C, Sanders MR. Self-Directed Triple P (Positive Parenting Program) for Mothers with Children at-Risk of Developing Conduct Problems. Behav Cogn Psychother. 2006;34(3):259-75.
140 Sanders MR, Markie-Dadds C, Tully LA, et al. The triple P-positive parenting program: a comparison of enhanced, standard, and self-directed behavioral family intervention for parents of children with early onset conduct problems. J Consult Clin Psychol. Aug. 2000;68(4):624-40. [pmid: 10965638].
141 Connell S, Sanders MR, Markie-Dadds C. Self-directed behavioral family intervention for parents of oppositional children in rural and remote areas. Behav Modif. Oct. 1997;21(4):379-408. [pmid: 9337598].
142 Nickel M, Luley J, Krawczyk J, et al. Bullying girls - changes after brief strategic family therapy: a randomized, prospective, controlled trial with one-year follow-up. Psychother Psychosom. 2006;75(1):47-55. [pmid: 16361874].
143 Nickel MK, Krawczyk J, Nickel C, et al. Anger, interpersonal relationships, and health-related quality of life in bullying boys who are treated with outpatient family therapy: a randomized, prospective, controlled trial with 1 year of follow-up. Pediatrics. Aug. 2005;116(2):e247-54. [pmid: 16061577].
144 Nickel MK, Muehlbacher M, Kaplan P, et al. Influence of family therapy on bullying behaviour, cortisol secretion, anger, and quality of life in bullying male adolescents: A randomized, prospective, controlled study. Can J Psychiatry. May. 2006;51(6):355-62. [pmid: 16786816].
145 Sanders MR, Baker S, Turner KM. A randomized controlled trial evaluating the efficacy of Triple P Online with parents of children with early-onset conduct problems. Behav Res Ther. Nov. 2012;50(11):675-84. [pmid: 22982082].
146 Shechtman Z, Birani-Nasaraladin D. Treating mothers of aggressive children: a research study. Int J Group Psychother. Jan. 2006;56(1):93-112. [pmid: 16555426].
147 Hutchings J, Appleton P, Smith M, et al. Evaluation of two treatments for children with severe behaviour problems: Child behaviour and maternal mental health outcomes. Behav Cogn Psychother. Jul. 2002;30(3):279-95.
148 Webster-Stratton C. Randomized trial of two parent-training programs for families with conduct-disordered children. J Consult Clin Psychol. Aug. 1984;52(4):666-78. [pmid: 6470293].
149 Funderburk B, Eyberg S. History of parent-child interaction therapy. Norcross JC, VandenBos GR, Freedheim DK, American Psychological Association, editors. History of psychotherapy : continuity and change. 2nd ed. Washington, DC. American Psychological Association. 2011.
150 Sanders MR. Development, evaluation, and multinational dissemination of the triple P-Positive Parenting Program. Annu Rev Clin Psychol. 2012;8:345-79. [pmid: 22149480].
151 Henggeler SW. Efficacy studies to large-scale transport: the development and validation of multisystemic therapy programs. Annu Rev Clin Psychol. 2011;7:351-81. [pmid: 21443449].
152 Szapocznik J, Williams RA. Brief Strategic Family Therapy: twenty-five years of interplay among theory, research and practice in adolescent behavior problems and drug abuse. Clin Child Fam Psychol Rev. Jun. 2000;3(2):117-34. [pmid: 11227062].
153 Nixon RDV. Changes in hyperactivity and temperament in behaviourally disturbed preschoolers after parent-child interaction therapy (PCIT). Behaviour Change. 2001;18(3):168-76.
154 Sanders MR, McFarland M. Treatment of depressed mothers with disruptive children: A controlled evaluation of cognitive behavioral family intervention. Behav Ther. Winter. 2000;31(1):89-112.
155 Havighurst SS, Wilson KR, Harley AE, et al. “Tuning into Kids”: reducing young children's behavior problems using an emotion coaching parenting program. Child Psychiatry Hum Dev. Apr. 2013;44(2):247-64. [pmid: 22820873].
156 Bagner DM, Graziano PA, Jaccard J, et al. An initial investigation of baseline respiratory sinus arrhythmia as a moderator of treatment outcome for young children born premature with externalizing behavior problems. Behav Ther. Sep. 2012;43(3):652-65. [pmid: 22697452].
157 McCabe K, Yeh M, Lau A, et al. Parent-child interaction therapy for Mexican Americans: results of a pilot randomized clinical trial at follow-up. Behav Ther. Sep. 2012;43(3):606-18. [pmid: 22697448].
158 Gardner F, Hutchings J, Bywater T, et al. Who benefits and how does it work? Moderators and mediators of outcome in an effectiveness trial of a parenting intervention. J Clin Child Adolesc Psychol. 2010;39(4):568-80. [pmid: 20589567].
159 Lavigne JV, Lebailly SA, Gouze KR, et al. Predictor and moderator effects in the treatment of oppositional defiant disorder in pediatric primary care. J Pediatr Psychol. Jun. 2008;33(5):462-72. [pmid: 17956931].
160 Sanders MR, Bor W, Morawska A. Maintenance of treatment gains: a comparison of enhanced, standard, and self-directed Triple P-Positive Parenting Program. J Abnorm Child Psychol. Dec. 2007;35(6):983-98. [pmid: 17610061].
161 Nixon RD, Sweeney L, Erickson DB, et al. Parent-child interaction therapy: one- and two-year follow-up of standard and abbreviated treatments for oppositional preschoolers. J Abnorm Child Psychol. Jun. 2004;32(3):263-71. [pmid: 15228175].
162 Bor W, Sanders MR, Markie-Dadds C. The effects of the Triple P-Positive Parenting Program on preschool children with co-occurring disruptive behavior and attentional/hyperactive difficulties. J Abnorm Child Psychol. Dec. 2002;30(6):571-87. [pmid: 12481972].
163 McGilloway S, NiMhaille G, Bywater T, et al. Reducing child conduct disordered behaviour and improving parent mental health in disadvantaged families: a 12-month follow-up and cost analysis of a parenting intervention. Eur Child Adolesc Psychiatry. Sep. 2014;23(9):783-94. [pmid: 25183424].
164 Rugino TA, Samsock TC. Levetiracetam in autistic children: an open-label study. J Dev Behav Pediatr. Aug. 2002;23(4):225-30. [pmid: 12177568].
165 Barrett P, Turner C, Rombouts S, et al. Reciprocal skills training in the treatment of externalising behaviour disorders in childhood: A preliminary investigation. Behaviour Change. 2000;17(4):221-34.
166 Hagen KA, Ogden T, Bjornebekk G. Treatment outcomes and mediators of parent management training: a one-year follow-up of children with conduct problems. J Clin Child Adolesc Psychol. 2011;40(2):165-78. [pmid: 21391015].
167 Hutchings J, Lane E, Kelly J. Comparison of Two Treatments for Children with Severely Disruptive Behaviours: A Four-Year Follow-up. Behav Cogn Psychother. 2004;32(1):15-30.
168 Zonnevylle-Bender MJS, Matthys W, Van De Wiel NMH, et al. Preventive Effects of Treatment of Disruptive Behavior Disorder in Middle Childhood on Substance Use and Delinquent Behavior. Journal of the American Academy of Child & Adolescent Psychiatry. 2007;46(1):33-9. [pmid: 17195727].
169 Manders WA, Dekovic M, Asscher JJ, et al. Psychopathy as predictor and moderator of multisystemic therapy outcomes among adolescents treated for antisocial behavior. J Abnorm Child Psychol. Oct. 2013;41(7):1121-32. [pmid: 23756854].
170 Dekovic M, Asscher JJ, Manders WA, et al. Within-intervention change: mediators of intervention effects during multisystemic therapy. J Consult Clin Psychol. Aug. 2012;80(4):574-87. [pmid: 22563638].
171 Asscher JJ, Deković M, Manders W, et al. Sustainability of the effects of multisystemic therapy for juvenile delinquents in the Netherlands: Effects on delinquency and recidivism. J Exp Criminol. 2014;10(2):227-43.
172 Weiss B, Han SS, Tran NT, et al. Test of “Facilitation” vs. “Proximal Process” Moderator Models for the Effects of Multisystemic Therapy on Adolescents with Severe Conduct Problem. J Abnorm Child Psychol. 2014. Nov. 12. [pmid: 25387903].
173 Gelman A, Shalizi CR. Philosophy and the practice of Bayesian statistics. Br J Math Stat Psychol. Feb. 2013;66(1):8-38. [pmid: 22364575].
174 Achenbach TMR LA. Manual for the ASEBA preschool forms and profiles: An integrated System of Multi-informant assessment. Research Center for Children Youth and Families. 2000.
175 Eyberg S. Parent and teacher behavior inventories for the assessment of conduct problem behaviors in children. Innovations in clinical practice: A source book. 1992;11:261-70.
176 Dittmann RW, Schacht A, Helsberg K, et al. Atomoxetine versus placebo in children and adolescents with attention-deficit/hyperactivity disorder and comorbid oppositional defiant disorder: a double-blind, randomized, multicenter trial in Germany. J Child Adolesc Psychopharmacol. Apr. 2011;21(2):97-110. [pmid: 21488751].
177 Connor DF, Findling RL, Kollins SH, et al. Effects of guanfacine extended release on oppositional symptoms in children aged 6-12 years with attention-deficit hyperactivity disorder and oppositional symptoms: a randomized, double-blind, placebo-controlled trial. CNS Drugs. Sep. 2010;24(9):755-68. [pmid: 20806988].
178 Blader JC, Schooler NR, Jensen PS, et al. Adjunctive divalproex versus placebo for children with ADHD and aggression refractory to stimulant monotherapy. Am J Psychiatry. Dec. 2009;166(12):1392-401. [pmid: 19884222].
179 Dell'Agnello G, Maschietto D, Bravaccio C, et al. Atomoxetine hydrochloride in the treatment of children and adolescents with attention-deficit/hyperactivity disorder and comorbid oppositional defiant disorder: A placebo-controlled Italian study. Eur Neuropsychopharmacol. Nov. 2009;19(11):822-34. [pmid: 19716683].
180 Connor DF, McLaughlin TJ, Jeffers-Terry M. Randomized controlled pilot study of quetiapine in the treatment of adolescent conduct disorder. J Child Adolesc Psychopharmacol. Apr. 2008;18(2):140-56. [pmid: 18439112].
181 Armenteros JL, Lewis JE, Davalos M. Risperidone augmentation for treatment-resistant aggression in attention-deficit/hyperactivity disorder: a placebo-controlled pilot study. J Am Acad Child Adolesc Psychiatry. May. 2007;46(5):558-65. [pmid: 17450046].
182 Spencer TJ, Abikoff HB, Connor DF, et al. Efficacy and safety of mixed amphetamine salts extended release (adderall XR) in the management of oppositional defiant disorder with or without comorbid attention-deficit/hyperactivity disorder in school-aged children and adolescents: A 4-week, multicenter, randomized, double-blind, parallel-group, placebo-controlled, forced-dose-escalation study. Clin Ther. Mar. 2006;28(3):402-18. [pmid: 16750455].
183 Reyes M, Buitelaar J, Toren P, et al. A randomized, double-blind, placebo-controlled study of risperidone maintenance treatment in children and adolescents with disruptive behavior disorders. Am J Psychiatry. Mar. 2006;163(3):402-10. [pmid: 16513860].
184 Steiner H, Petersen ML, Saxena K, et al. Divalproex sodium for the treatment of conduct disorder: a randomized controlled clinical trial. J Clin Psychiatry. Oct. 2003;64(10):1183-91. [pmid: 14658966].
185 Donovan SJ, Stewart JW, Nunes EV, et al. Divalproex treatment for youth with explosive temper and mood lability: a double-blind, placebo-controlled crossover design. Am J Psychiatry. May. 2000;157(5):818-20. [pmid: 10784478].
186 Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry. Apr. 2000;39(4):509-16. [pmid: 10761354].
187 Klein RG, Abikoff H, Klass E, et al. Clinical efficacy of methylphenidate in conduct disorder with and without attention deficit hyperactivity disorder. Arch Gen Psychiatry. Dec. 1997;54(12):1073-80. [pmid: 9400342].
188 Bastiaens L. A non-randomized, open study with aripiprazole and ziprasidone for the treatment of aggressive behavior in youth in a community clinic. Community Ment Health J. Feb. 2009;45(1):73-7. [pmid: 18597173].
189 Padhy R, Saxena K, Remsing L, et al. Symptomatic response to divalproex in subtypes of conduct disorder. Child Psychiatry Hum Dev. Oct. 2011;42(5):584-93. [pmid: 21706221].
190 Wehmeier PM, Schacht A, Dittmann RW, et al. Effect of atomoxetine on quality of life and family burden: results from a randomized, placebo-controlled, double-blind study in children and adolescents with ADHD and comorbid oppositional defiant or conduct disorder. Qual Life Res. Jun. 2011;20(5):691-702. [pmid: 21136299].
191 Munshi KR, Oken T, Guild DJ, et al. The Use of Antiepileptic Drugs (AEDs) for the Treatment of Pediatric Aggression and Mood Disorders. Pharmaceuticals. 2010;3(9):2986-3004. [doi: 10.3390/ph3092986].
192 Strattera (atomoxetine) [package insert]. Indiannapolis, IN. Eli Lilly and Company. 2014.
193 Saxena K, Mora L, Torres E, et al. Divalproex sodium-ER in outpatients with disruptive behavior disorders: a three month open label study. Child Psychiatry Hum Dev. Jun. 2010;41(3):274-84. [pmid: 20043204].
194 Penzner JB, Dudas M, Saito E, et al. Lack of effect of stimulant combination with second-generation antipsychotics on weight gain, metabolic changes, prolactin levels, and sedation in youth with clinically relevant aggression or oppositionality. J Child Adolesc Psychopharmacol. Oct. 2009;19(5):563-73. [pmid: 19877981].
195 Ercan ES, Kutlu A, Cikoglu S, et al. Risperidone in children and adolescents with conduct disorder: A single-center, open-label study. Current Therapeutic Research - Clinical and Experimental. 01. Jan. 2003;64(1):55-64. [pmid: 24944356].
196 Pandina GJ, Zhu Y, Cornblatt B. Cognitive function with long-term risperidone in children and adolescents with disruptive behavior disorder. J Child Adolesc Psychopharmacol. Dec. 2009;19(6):749-56. [pmid: 20035593].
197 Connor DF, Spencer TJ. Short-term cardiovascular effects of mixed amphetamine salts extended release in children and adolescents with oppositional defiant disorder. CNS Spectr. Oct. 2005;10(10 Suppl 15):31-8. [pmid: 15618945].
198 Pringsheim T, Lam D, Ching H, et al. Metabolic and neurological complications of second-generation antipsychotic use in children: a systematic review and meta-analysis of randomized controlled trials. Drug Saf. Aug. 1. 2011;34(8):651-68. [pmid: 21751826].
199 Risperdal (risperidone) [package insert]. Titusville, NJ. Janssen Pharmaceuticals Inc. 2007.
200 Risperdal (risperidone) [package insert]. Titusville, NJ. Janssen Pharmaceuticals Inc. 2014.
201 Risperdal [package insert]. Titusville, NJ. Janssen Pharmaceuticals, Inc. 2014. http://www.accessdata.fda.gov/drugsatfda_docs/label/2014/020272s073,020588s062,021444s048lbl.pdf. April 2, 2015.
202 Risperdal Medical Review - Pediatric Approval 20-272/S045/S046, 20-588/S036/S037, 21-444/S020/S021. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2007. http://www.accessdata.fda.gov/drugsatfda_docs/nda/2007/020272_s046_risperdal_toc.cfm. April 2, 2015.
203 Modafinil: serious skin reactions. Prescrire Int. Apr. 2007;16(88):71. [pmid: 17465032].
204 Abilify (aripiprazole) [package insert]. Rockville, MD. Otsuka America Pharmaceutical I. 2014.
205 Abilify [package insert]. Rockville, MD. Otsuka America Pharmaceutical, Inc. 2013. http://www.accessdata.fda.gov/drugsatfda_docs/label/2013/021436s037,021713s029,021729s021,021866s022lbl.pdf. April 2, 2015.
206 Seroquel Medical Review - QT Prolongation Review 020639Orig1s049. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2011. http://www.accessdata.fda.gov/drugsatfda_docs/nda/2011/020639Orig1s049MedR.pdf. April 2, 2015.
207 Seroquel [package inert]. Wilmington, DE. AstraZeneca Pharmaceuticals LP. October. 2013. http://www.accessdata.fda.gov/drugsatfda_docs/label/2013/020639s061lbl.pdf. April 2, 2015.
208 Geodon [package insert]. New York, NY. Pfizer. October. 2012. http://www.accessdata.fda.gov/drugsatfda_docs/label/2013/020825s049,020919s035lbl.pdf. April 2, 2015.
209 Khanzode LA, Saxena K, Kraemer H, et al. Efficacy profiles of psychopharmacology: divalproex sodium in conduct disorder. Child Psychiatry Hum Dev. Fall. 2006;37(1):55-64. [pmid: 16927177].
210 Depacon (valproate/valproic acid) [package insert]. North Chicago, IL. Inc. A. 2014.
211 Depakote [package insert]. North Chicago, IL. AbbVie Inc. July. 2013. http://www.accessdata.fda.gov/drugsatfda_docs/label/2013/018723s048lbl.pdf. April 2, 2015.
212 Adderall [package insert]. Pomona, NY. Barr Laboratories. 2007. http://www.accessdata.fda.gov/drugsatfda_docs/label/2007/011522s040lbl.pdf. April 2, 2015.
213 Ritalin [package insert]. East Hanover, NJ. Novartis Pharmaceuticals Corporation. 2013. http://www.accessdata.fda.gov/drugsatfda_docs/label/2013/010187s077lbl.pdf. April 2, 2015.
214 Strattera [package insert]. Indianapolis, IN. Eli Lilly and Company. 2014. http://www.accessdata.fda.gov/drugsatfda_docs/label/2014/021411s044lbl.pdf. April 2, 2015.
215 Strattera Medical Review - Original Approval. 21-411. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2002. http://www.accessdata.fda.gov/drugsatfda_docs/nda/2002/21-411_Strattera.cfm. April 2, 2015.
216 Intuniv Medical Review - Original Approval. 22-037. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2009. http://www.accessdata.fda.gov/drugsatfda_docs/nda/2009/022037s000medr.pdf. April 2, 2015.
217 Intuniv [package insert]. Wayne, PA. Shire US Inc. 2013. http://www.accessdata.fda.gov/drugsatfda_docs/label/2013/022037s009lbl.pdf. April 2, 2015.
218 Beauchaine TP, Webster-Stratton C, Reid MJ. Mediators, moderators, and predictors of 1-year outcomes among children treated for early-onset conduct problems: a latent growth curve analysis. J Consult Clin Psychol. Jun. 2005;73(3):371-88. [pmid: 15982136].
219 Fossum S, Morch WT, Handegard BH, et al. Parent training for young Norwegian children with ODD and CD problems: predictors and mediators of treatment outcome. Scand J Psychol. Apr. 2009;50(2):173-81. [pmid: 19170971].
220 Kolko DJ, Pardini DA. ODD dimensions, ADHD, and callous–unemotional traits as predictors of treatment response in children with disruptive behavior disorders. J Abnorm Psychol. 2010;119(4):713-25. [pmid: 21090875].
221 Shenk CE, Dorn LD, Kolko DJ, et al. Prior exposure to interpersonal violence and long-term treatment response for boys with a disruptive behavior disorder. J Trauma Stress. Oct. 2014;27(5):585-92. [pmid: 25270151].
222 Wolff JC, Greene RW, Ollendick TH. Differential responses of children with varying degrees of reactive and proactive aggression to two forms of psychosocial treatment. Child Fam Behav Ther. 2008;30(1):37-50.
223 Lochman JE, Wells KC, Qu L, et al. Three year follow-up of coping power intervention effects: evidence of neighborhood moderation?. Prev Sci. Aug. 2013;14(4):364-76. [pmid: 23065350].
224 Mojtabai R. Serious emotional and behavioral problems and mental health contacts in American and British children and adolescents. J Am Acad Child Adolesc Psychiatry. Oct. 2006;45(10):1215-23. [pmid: 17003667].
225 Bobo WV, Cooper WO, Stein CM, et al. Antipsychotics and the risk of type 2 diabetes mellitus in children and youth. JAMA Psychiatry. Oct. 2013;70(10):1067-75. [pmid: 23965896].
226 Forehand R, Lafko N, Parent J, et al. Is parenting the mediator of change in behavioral parent training for externalizing problems of youth?. Clinical Psychology Review. Dec. 2014;34(8):608-19. [pmid: 25455625].
227 Littell JH, Campbell M, Green S, et al. Multisystemic Therapy for social, emotional, and behavioral problems in youth aged 10-17. Cochrane Database of Systematic Reviews. 2005;(4).
228 Ozabaci N. Cognitive behavioural therapy for violent behaviour in children and adolescents: A meta-analysis. Children and Youth Services. 2011;33(10):1989-93.
229 Nowak C, Heinrichs N. A comprehensive meta-analysis of Triple P-Positive Parenting Program using hierarchical linear modeling: effectiveness and moderating variables. Clin Child Fam Psychol Rev. Sep. 2008;11(3):114-44. [pmid: 18509758].
230 Sanders MR, Kirby JN, Tellegen CL, et al. The Triple P-Positive Parenting Program: a systematic review and meta-analysis of a multi-level system of parenting support. Clinical Psychology Review. Jun. 2014;34(4):337-57. [pmid: 24842549].
231 Thomas R, Zimmer-Gembeck MJ. Behavioral outcomes of Parent-Child Interaction Therapy and Triple P-Positive Parenting Program: a review and meta-analysis. J Abnorm Child Psychol. Jun. 2007;35(3):475-95. [pmid: 17333363].
232 Dretzke J, Frew E, Davenport C, et al. The effectiveness and cost-effectiveness of parent training/education programmes for the treatment of conduct disorder, including oppositional defiant disorder, in children. Health Technol Assess. Dec. ix. 2005;9(50):iii-x. 1. 233. [pmid: 16336845].
233 Bradley MC, Mandell D. Oppositional defiant disorder: A systematic review of evidence of intervention effectiveness. Journal of Experimental Criminology. 2005;1(3):343-65.
234 Maughan DR, Christiansen E, Jenson WR, Olympia D, Clark E. Behavioral parent training as a treatment for externalizing behaviors and disruptive behavior disorders: A meta-analysis. School Psychology Review. 2005;34:267-86.
235 Lundahl BW, Risser HJ, Lovejoy MC. A meta-analysis of parent training: Moderators and follow-up effects. Clinical Psychology Review. 2006;26:86-104. [pmid: 16280191].
236 Fossum S, Handegard BH, Martinussen M, et al. Psychosocial interventions for disruptive and aggressive behaviour in children and adolescents: a meta-analysis. Eur Child Adolesc Psychiatry. Oct. 2008;17(7):438-51. [pmid: 18427863].
237 Comer JS, Chow C, Chan PT, et al. Psychosocial treatment efficacy for disruptive behavior problems in very young children: a meta-analytic examination. J Am Acad Child Adolesc Psychiatry. Jan. 2013;52(1):26-36. [pmid: 23265631].
238 Eyberg SM, Nelson MM, Boggs SR. Evidence-based psychosocial treatments for children and adolescents with disruptive behavior. Journal of Clinical Child and Adolescent Psychology. 2008;37(1):215-37. [pmid: 18444059].
239 McCart MR, Priester PE, Davies WH, et al. Differential effectiveness of behavioral parent-training and cognitive-behavioral therapy for antisocial youth: a meta-analysis. J Abnorm Child Psychol. Aug. 2006;34(4):527-43. [pmid: 16838122].
240 Piquero AR, Farrington DP, Welsh BC, Tremblay R, Jennings WG. Effects of early family/parent training programs on antisocial behavior and delinquency. Journal of Experimental Criminology. 2009;5:83-120.
241 Johnson MH, George P, Armstrong MI, et al. Behavioral Management for Children and Adolescents: Assessing the Evidence. Psychiatr Serv. 2013. Dec. 17. [pmid: 24343339].
242 Reyno SM, McGrath PJ. Predictors of parent training efficacy for child externalizing behavior problems--a meta-analytic review. J Child Psychol Psychiatry. Jan. 2006;47(1):99-111. [pmid: 16405646].
243 Shelleby EC, Shaw DS. Outcomes of Parenting Interventions for Child Conduct Problems: A Review of Differential Effectiveness. Child Psychiatry Hum Dev. 2014. Jan. 4. [pmid: 24390592].
244 Leijten P, Raaijmakers MA, de Castro BO, et al. Does socioeconomic status matter? A meta-analysis on parent training effectiveness for disruptive child behavior. J Clin Child Adolesc Psychol. 2013;42(3):384-92. [pmid: 23461526].
245 Fixsen D, Naoom S, Blase K, et al. Implementation Research: A Synthesis of the Literature. Louis de la Parte Florida Mental Health Institute. The National Implementation Research Network. FMHI Publication #231. Tampa, FL. University of South Florida. 2005.
246 March J, Silva S, Petrycki S, et al. Fluoxetine, cognitive-behavioral therapy, and their combination for adolescents with depression: Treatment for Adolescents With Depression Study (TADS) randomized controlled trial. Jama. Aug. 18. 2004;292(7):807-20. [pmid: 15315995].