# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Barbara J. Burns, Ph.D.
  Professor of Medical Psychology
  Duke University School of Medicine
  Durham, NC
- Karol L. Kumpfer, Ph.D.
  Professor
  Department of Health Promotion and Education
  College of Health, University of Utah
  Salt Lake City, UT
- John E. Lochman, Ph.D.
  University of Alabama
  Tuscaloosa, AL
  Roberto Sassi, M.D.
  McMaster University
  Hamilton, ON, Canada
- Bonnie T. Zima, M.D., M.P.H.
  Professor-in-Residence
  Child & Adolescent Psychiatry
  David Geffen School of Medicine
  University of California at Los Angeles
  Associate Director
  Center for Health Services & Society
  UCLA-Semel Institute for Neuroscience and Human Behavior
  Los Angeles, CA