# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Marc S. Atkins, Ph.D.
  University of Illinois at Chicago
  Chicago, IL
- Susan DosReis, Ph.D.
  University of Maryland
  Baltimore, MD
- Tiffany R. Farchione, M.D.
  Food and Drug Administration
  Silver Spring, MD
- Jeri Fitzpatrick, M.D.
  Private Practice
  Nashville, TN
- Robert J. McMahon, Ph.D.
  Simon Fraser University
  Burnaby, BC, Canada
  Child & Family Research Institute
  Vancouver, BC, Canada
- Erik von Hahn, M.D.
  Tufts University School of Medicine
  Boston, MA