# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Mina Dulcan, M.D.
  Northwestern University Feinberg School of Medicine
  Chicago, IL
- Jeff Feix, Ph.D.
  Tennessee Department of Mental Health and Substance Abuse Services
  Nashville, TN
- Rex Forehand, Ph.D.
  University of Vermont
  Burlington, VT
- Geetha Gopalan, L.C.S.W., Ph.D.
  University of Maryland School of Social Work
  Baltimore, MD
- Ross Greene, Ph.D.
  Harvard Medical School
  Boston, MA
- Penelope K. Knapp, M.D.
  UC Davis MIND Institute
  Sacramento, CA
- David Kolko, Ph.D.
  University of Pittsburgh School of Medicine
  Pittsburgh, PA
- Laurel Leslie, M.D., M.P.H.
  Tufts Clinical and Translational Science Institute (CTSI)
  Boston, MA
- Keith McBurnett, Ph.D.
  University of California San Francisco
  San Francisco, CA
- Ukamaka M. Oruche, Ph.D., R.N.
  Indiana University School of Nursing
  Indianapolis, IN
- Millie Sweeney, M.S.
  Tennessee Voices for Children
  Nashville, TN
- Aaron M. Thompson, M.S.W., Ph.D.
  University of Missouri School of Social Work
  Columbia, MO