# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Sanura Latham, B.S.; William Cooper, M.D., M.P.H.; Rachel Walden, M.L.I.S.; Rebecca Jerome, M.L.I.S., M.P.H.; Sarah Elizabeth Williams, M.D.; and Tanya Surawicz, M.P.H.