# Key Question 1 Evidence Profile

Table J-1 Evidence summary of psychosocial intervention effects on parent-rated disruptive behavior in studies of preschool age children

Studies | N | Risk of Bias | Intervention vs. Control | Head-to-Head Comparison | SOE Comments
Child Only (n=0)
NA | NA | NA | NA | NA | O
Parent Only (n=14)
RCT: 13^1-13^ | (1466) | Low: 1^8^ Moderate: 7^1,3,6,7,9,10,13^ High: 5^2,4,5,11,12^ | Outcomes consistently improved in intervention arms compared with waitlist or treatment as usual controls. Significant: Intervention > WLC or TAU (9)1,3 ,6-12 Nonsignificant: Intervention > TAU (1)13 | Differences between modified versions of the same intervention were typically not significant. Significant: Intervention vs. modified intervention (1)7 Nonsignificant: Intervention vs. modified intervention (4)2,4,5,10 | ++
NRCT: 1^14^ | (144) | Moderate: 1^14^ | Nonsignificant: Intervention > WLC or TAU (1)14 | NA | O
Multicomponent (n=9)
RCT: 9 | (401) | Low: 1^15^ Moderate: 3^16-18^ High: 5^19-23^ | Outcomes consistently improved in intervention arms compared with waitlist or treatment as usual controls. Significant: Intervention > WLC or TAU (8)15-22 | Differences between modified versions of the same intervention were typically not significant. Nonsignificant: Intervention vs. modified intervention (3)15,16,23 | ++

O = Insufficient, + = Low, ++ = Moderate, +++ = High

Table J-2 Evidence summary of psychosocial intervention effects on parent-rated disruptive behavior in studies of school age children

Studies | N | Risk of Bias | Intervention vs. Control | Head-to-Head Comparison | SOE Comments
Child Only (n=1)
RCT: 1^1^ | (97) | Low: 0 Moderate: 1^1^ High: 0 | Outcomes improved in intervention arms compared with waitlist control group Significant: SCIP, SST > WLC (1)1 | Differences between the active intervention groups were not significant Nonsignificant: SCIP > SST (1)1 | O
Parent Only (n=11)
RCT: 8^2-9^ | (995) | Low: 1^4^ Moderate: 5^5-9^ High: 2^2,3^ | Outcomes significantly improved in intervention groups vs. control Significant: (6)2-7 | Differences between modified versions of the same intervention were not significant Nonsignificant: (3)5,8,9 | ++
Cohort: 3^10-12^ | (334) | Low: 0 Moderate: 0 High: 3^10-12^ | Outcomes significantly improved in intervention groups vs. control Significant: Intervention > TAU (1)10 Nonsignificant: Intervention vs. TAU (1)11 | Differences between modified versions of the same intervention were significant Significant: PMT skilled > PMT perceptive (1)12 | +
Multicomponent (n=17)
RCT: 15^13-27^ | (1685) | Low: 1^15^ Moderate: 11^13,14,17-22,24-26^ High: 3^16,23,27^ | Improved from baseline in most active treatment arms but between group changes not consistently significantly different Significant: (4)16,20,24,27 Nonsignificant: (5)13,14,19,23,26 Inconsistent: (2)15,18 | Improved from baseline in most active treatment arms but between group changes not consistently significantly different Significant: (2)20,25 Nonsignificant: (3)17,21,26 Inconsistent: (1)22 | + Inconsistent outcomes reported by different measures/rating scales
Cohort: 2^28,29^ | (474) | Low: 0 Moderate: 1^29^ High: 1^28^ | Outcomes significantly improved in intervention groups vs. WLC or TAU Significant: (2)28,29 | NA | ++

O = Insufficient, + = Low, ++ = Moderate, +++ = High

Table J-3 Evidence summary of psychosocial intervention effects on parent-rated disruptive behavior in studies of teenage children

Studies | N | Risk of Bias | Intervention vs. Control | Head-to-Head Comparison | SOE Comments
Child Only^a^ (n=1)
RCT: 1^1^ | (93) | Low: 0 Moderate: 0 High: 1^1^ | Intervention > Control Significant: (1)1 | NA | O
Parent Only (n=0)
NA | NA | NA | NA | NA | O
Multicomponent (n=13)
RCT: 12^2-13^ | (1294) | Low: 4^3,4,8,9^ Moderate: 5^2,7,10,11,13^ High: 3^5,6,12^ | Most studies reported improved outcomes in treatment arms versus control arms. Significant: (10)2-4,6-11,13 | Differences between interventions were significant. Significant: (2)5,12 | ++
Cohort: 1^14^ | (192) | Low: 0 Moderate: 0 High: 1^14^ | NA | Nonsignificant: CBT vs. FFT vs. CBT + Parent training (1)14 | O Outcome: recidivism

O = Insufficient, + = Low, ++ = Moderate, +++ = High

Table J-4 Evidence profile for studies included in the meta-analysis

Intervention Category (arms) | Total N | Effect measure | Probability of being best | Overall SOE
TAU/WLC (n=50) | 1348 | NA | NA | - Strong evidence that of the 4 arms, this is the inferior
Child only (n=6) | 190 | −1.0 (95% credible interval: −1.6 to −0.4) | 15 | - Strong evidence that each of these are better than TAU; - Weak evidence that of these 3 arms multi-component and parent only are best
Parent only (n=41) | 1540 | −1.2 (95% credible interval: −1.6 to −0.9) | 43 | - Strong evidence that each of these are better than TAU; - Weak evidence that of these 3 arms multi-component and parent only are best
Multicomponent (n=32) | 929 | −1.2 (95% credible interval: −1.6 to −0.9) | 43 | - Strong evidence that each of these are better than TAU; - Weak evidence that of these 3 arms multi-component and parent only are best

Notes: Table represents quantitative mixed effects model of a subset of studies from qualitative review. The model included RCTs that reported baseline and end-of-treatment group mean and standard deviation from ECBI- Intensity, ECBI- Problem, and/or CBCL- Externalizing T-score). For more details on the selection of studies, see the methods in the Full Report.

Includes studies from KQ1 for children of all ages (i.e., psychosocial interventions for preschool age, school age, and teenage participants).The treatment arms of each study were classified as one of the following types: 1) interventions including only a child component; 2) interventions including only a parent component; and 3) multicomponent interventions. Those not identified by any of these three classes were considered either control or treatment-as-usual arms. The number of arms exceeds the number of included studies as studies could contribute data from more than one arm per intervention type.

The effect sizes estimated by the model can be interpreted as the expected change in score for the intervention category relative to treatment as usual or control.

This summary does not include risk of bias ratings, as those assessments are made at the individual study level, and not at the level of a treatment arm.

## References for Appendix J

1 Perrin EC, Sheldrick RC, McMenamy JM, et al. Improving Parenting Skills for Families of Young Children in Pediatric Settings: A Randomized Clinical Trial. JAMA Pediatr. 2013. Nov. 4. [pmid: 24190691].
2 Jones DJ, Forehand R, Cuellar J, et al. Technology-Enhanced Program for Child Disruptive Behavior Disorders: Development and Pilot Randomized Control Trial. J Clin Child Adolesc Psychol. 2013. Aug. 7. [pmid: 23924046].
3 Somech LY, Elizur Y. Promoting self-regulation and cooperation in pre-kindergarten children with conduct problems: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Apr. 2012;51(4):412-22. [pmid: 22449647].
4 Cummings JG, Wittenberg JV. Supportive expressive therapy--Parent child version: An exploratory study. Psychotherapy (Chic). Jun. 2008;45(2):148-64. [pmid: 22122414].
5 Lavigne JV, Lebailly SA, Gouze KR, et al. Treating oppositional defiant disorder in primary care: a comparison of three models. J Pediatr Psychol. Jun. 2008;33(5):449-61. [pmid: 17956932].
6 Hutchings J, Gardner F, Bywater T, et al. Parenting intervention in Sure Start services for children at risk of developing conduct disorder: pragmatic randomised controlled trial. BMJ. Mar. 31. 2007;334(7595):678. [pmid: 17350966].
7 Markie-Dadds C, Sanders MR. A Controlled Evaluation of an Enhanced Self-Directed Behavioural Family Intervention for Parents of Children With Conduct Problems in Rural and Remote Areas. Behaviour Change. 2006;23(1):55-72.
8 McGilloway S, Mhaille GN, Bywater T, et al. A parenting intervention for childhood behavioral problems: A randomized controlled trial in disadvantaged community-based settings. J Consult Clin Psychol. 2012;80(1):116-27. [pmid: 22148879].
9 Markie-Dadds C, Sanders MR. Self-Directed Triple P (Positive Parenting Program) for Mothers with Children at-Risk of Developing Conduct Problems. Behav Cogn Psychother. 2006;34(3):259-75.
10 Sanders MR, Markie-Dadds C, Tully LA, et al. The triple P-positive parenting program: a comparison of enhanced, standard, and self-directed behavioral family intervention for parents of children with early onset conduct problems. J Consult Clin Psychol. Aug. 2000;68(4):624-40. [pmid: 10965638].
11 Connell S, Sanders MR, Markie-Dadds C. Self-directed behavioral family intervention for parents of oppositional children in rural and remote areas. Behav Modif. Oct. 1997;21(4):379-408. [pmid: 9337598].
12 Sanders MR, Baker S, Turner KM. A randomized controlled trial evaluating the efficacy of Triple P Online with parents of children with early-onset conduct problems. Behav Res Ther. Nov. 2012;50(11):675-84. [pmid: 22982082].
13 Havighurst SS, Wilson KR, Harley AE, et al. “Tuning into Kids”: reducing young children's behavior problems using an emotion coaching parenting program. Child Psychiatry Hum Dev. Apr. 2013;44(2):247-64. [pmid: 22820873].
14 Posthumus JA, Raaijmakers MA, Maassen GH, et al. Sustained effects of incredible years as a preventive intervention in preschool children with conduct problems. J Abnorm Child Psychol. May. 2012;40(4):487-500. [pmid: 22006348].
15 McCabe K, Yeh M. Parent-child interaction therapy for Mexican Americans: a randomized clinical trial. J Clin Child Adolesc Psychol. Sep. 2009;38(5):753-9. [pmid: 20183659].
16 Nixon RD, Sweeney L, Erickson DB, et al. Parent-child interaction therapy: a comparison of standard and abbreviated treatments for oppositional defiant preschoolers. J Consult Clin Psychol. Apr. 2003;71(2):251-60. [pmid: 12699020].
17 Schuhmann EM, Foote RC, Eyberg SM, et al. Efficacy of parent-child interaction therapy: interim report of a randomized trial with short-term maintenance. J Clin Child Psychol. Mar. 1998;27(1):34-45. [pmid: 9561935].
18 Brestan EV, Eyberg SM, Boggs SR, et al. Parent–child interaction therapy: Parents' perceptions of untreated siblings. Child Fam Behav Ther. 1997;19(3):13-28.
19 Bagner DM, Sheinkopf SJ, Vohr BR, et al. Parenting intervention for externalizing behavior problems in children born premature: an initial examination. J Dev Behav Pediatr. Apr. 2010;31(3):209-16. [pmid: 20375736].
20 Jouriles EN, McDonald R, Spiller L, et al. Reducing conduct problems among children of battered women. J Consult Clin Psychol. Oct. 2001;69(5):774-85. [pmid: 11680554].
21 Eyberg SM, Boggs SR, Algina J. Parent-child interaction therapy: a psychosocial model for the treatment of young children with conduct problem behavior and their families. Psychopharmacol Bull. 1995;31(1):83-91. [pmid: 7675994].
22 Nixon RDV. Changes in hyperactivity and temperament in behaviourally disturbed preschoolers after parent-child interaction therapy (PCIT). Behaviour Change. 2001;18(3):168-76.
23 Sanders MR, McFarland M. Treatment of depressed mothers with disruptive children: A controlled evaluation of cognitive behavioral family intervention. Behav Ther. Winter. 2000;31(1):89-112.
24 van Manen TG, Prins PJ, Emmelkamp PM. Reducing aggressive behavior in boys with a social cognitive group treatment: results of a randomized, controlled trial. J Am Acad Child Adolesc Psychiatry. Dec. 2004;43(12):1478-87. [pmid: 15564817].
25 Kjobli J, Ogden T. A randomized effectiveness trial of brief parent training in primary care settings. Prev Sci. Dec. 2012;13(6):616-26. [pmid: 22956303].
26 Axberg U, Broberg AG. Evaluation of “the incredible years” in Sweden: the transferability of an American parent-training program to Sweden. Scand J Psychol. Jun. 2012;53(3):224-32. [pmid: 22621727].
27 McGrath PJ, Lingley-Pottie P, Thurston C, et al. Telephone-based mental health interventions for child disruptive behavior or anxiety disorders: randomized trials and overall analysis. J Am Acad Child Adolesc Psychiatry. Nov. 2011;50(11):1162-72. [pmid: 22024004].
28 Kling A, Forster M, Sundell K, et al. A randomized controlled effectiveness trial of parent management training with varying degrees of therapist support. Behav Ther. Dec. 2010;41(4):530-42. [pmid: 21035616].
29 Ogden T, Hagen KA. Treatment effectiveness of Parent Management Training in Norway: a randomized controlled trial of children with conduct problems. J Consult Clin Psychol. Aug. 2008;76(4):607-21. [pmid: 18665689].
30 Gardner F, Burton J, Klimes I. Randomised controlled trial of a parenting intervention in the voluntary sector for reducing child conduct problems: outcomes and mechanisms of change. J Child Psychol Psychiatry. Nov. 2006;47(11):1123-32. [pmid: 17076751].
31 Webster-Stratton C. Advancing videotape parent training: a comparison study. J Consult Clin Psychol. Jun. 1994;62(3):583-93. [pmid: 8063985].
32 Hutchings J, Appleton P, Smith M, et al. Evaluation of two treatments for children with severe behaviour problems: Child behaviour and maternal mental health outcomes. Behav Cogn Psychother. Jul. 2002;30(3):279-95.
33 Coughlin M, Sharry J, Fitzpatrick C, et al. A controlled clinical evaluation of the parents plus children's programme: a video-based programme for parents of children aged 6 to 11 with behavioural and developmental problems. Clin Child Psychol Psychiatry. Oct. 2009;14(4):541-58. [pmid: 19759073].
34 Shapiro JP, Youngstrom JK, Youngstrom EA, et al. Transporting a manualized treatment for children's disruptive behavior to a community clinic. Journal of Contemporary Psychotherapy. 2012;42(4):215-25.
35 Costin J, Lichte C, Hill-Smith A, et al. Parent group treatments for children with Oppositional Defiant Disorder. AeJAMH (Australian e-Journal for the Advancement of Mental Health). 2004;3(1).
36 Boylan K, Macpherson HA, Fristad MA. Examination of disruptive behavior outcomes and moderation in a randomized psychotherapy trial for mood disorders. J Am Acad Child Adolesc Psychiatry. Jul. 2013;52(7):699-708. [pmid: 23800483].
37 Kolko DJ, Campo JV, Kelleher K, et al. Improving access to care and clinical outcome for pediatric behavioral problems: a randomized trial of a nurse-administered intervention in primary care. J Dev Behav Pediatr. Jun. 2010;31(5):393-404. [pmid: 20495474].
38 Scott S, Sylva K, Doolan M, et al. Randomised controlled trial of parent groups for child antisocial behaviour targeting multiple risk factors: the SPOKES project. J Child Psychol Psychiatry. Jan. 2010;51(1):48-57. [pmid: 19732250].
39 Jouriles EN, McDonald R, Rosenfield D, et al. Reducing conduct problems among children exposed to intimate partner violence: a randomized clinical trial examining effects of Project Support. J Consult Clin Psychol. Aug. 2009;77(4):705-17. [pmid: 19634963].
40 Kolko DJ, Dorn LD, Bukstein OG, et al. Community vs. clinic-based modular treatment of children with early-onset ODD or CD: a clinical trial with 3-year follow-up. J Abnorm Child Psychol. Jul. 2009;37(5):591-609. [pmid: 19221871].
41 Larsson B, Fossum S, Clifford G, et al. Treatment of oppositional defiant and conduct problems in young Norwegian children : results of a randomized controlled trial. Eur Child Adolesc Psychiatry. Jan. 2009;18(1):42-52. [pmid: 18563473].
42 van de Wiel NM, Matthys W, Cohen-Kettenis PT, et al. The effectiveness of an experimental treatment when compared to care as usual depends on the type of care as usual. Behav Modif. May. 2007;31(3):298-312. [pmid: 17438344].
43 Drugli MB, Larsson B. Children aged 4-8 years treated with parent training and child therapy because of conduct problems: generalisation effects to day-care and school settings. Eur Child Adolesc Psychiatry. Oct. 2006;15(7):392-9. [pmid: 16614786].
44 Greene RW, Ablon JS, Goring JC, et al. Effectiveness of collaborative problem solving in affectively dysregulated children with oppositional-defiant disorder: initial findings. J Consult Clin Psychol. Dec. 2004;72(6):1157-64. [pmid: 15612861].
45 Webster-Stratton C, Reid MJ, Hammond M. Treating children with early-onset conduct problems: intervention outcomes for parent, child, and teacher training. J Clin Child Adolesc Psychol. Mar. 2004;33(1):105-24. [pmid: 15028546].
46 Cabiya JJ, Padilla-Cotto L, González K, et al. Effectiveness of a cognitive-behavioral intervention for Puerto Rican children. Revista Interamericana de Psicología. 2008;42(2):195-202.
47 Augimeri LK, Farrington DP, Koegl CJ, et al. The SNAPTM Under 12 Outreach Project: Effects of a community based program for children with conduct problems. J Child Fam Stud. 2007;16(6):799-807.
48 Kolko DJ. Efficacy of cognitive-behavioral treatment and fire safety education for children who set fires: initial and follow-up outcomes. J Child Psychol Psychiatry. Mar. 2001;42(3):359-69. [pmid: 11321205].
49 Webster-Stratton C, Hammond M. Treating children with early-onset conduct problems: a comparison of child and parent training interventions. J Consult Clin Psychol. Feb. 1997;65(1):93-109. [pmid: 9103739].
50 Barrett P, Turner C, Rombouts S, et al. Reciprocal skills training in the treatment of externalising behaviour disorders in childhood: A preliminary investigation. Behaviour Change. 2000;17(4):221-34.
51 Lipman EL, Kenny M, Sniderman C, et al. Evaluation of a community-based program for young boys at-risk of antisocial behaviour: results and issues. J Can Acad Child Adolesc Psychiatry. 2008;17(1):12-9. [pmid: 18392161].
52 Masi G, Milone A, Paciello M, et al. Efficacy of a multimodal treatment for disruptive behavior disorders in children and adolescents: focus on internalizing problems. Psychiatry Res. Nov. 30. 2014;219(3):617-24. [pmid: 25060833].
53 Rohde P, Clarke GN, Mace DE, et al. An efficacy/effectiveness study of cognitive-behavioral treatment for adolescents with comorbid major depression and conduct disorder. J Am Acad Child Adolesc Psychiatry. Jun. 2004;43(6):660-8. [pmid: 15167082].
54 Weiss B, Han S, Harris V, et al. An Independent Randomized Clinical Trial of Multisystemic Therapy With Non-Court-Referred Adolescents With Serious Conduct Problems. J Consult Clin Psychol. 2013. Aug. 12. [pmid: 23937347].
55 Butler S, Baruch G, Hickey N, et al. A randomized controlled trial of multisystemic therapy and a statutory therapeutic intervention for young offenders. J Am Acad Child Adolesc Psychiatry. Dec. 2011;50(12):1220-35 e2. [pmid: 22115143].
56 Sundell K, Hansson K, Lofholm CA, et al. The transportability of multisystemic therapy to Sweden: short-term results from a randomized trial of conduct-disordered youths. J Fam Psychol. Aug. 2008;22(4):550-60. [pmid: 18729669].
57 Santisteban DA, Coatsworth JD, Perez-Vidal A, et al. Efficacy of brief strategic family therapy in modifying Hispanic adolescent behavior problems and substance use. J Fam Psychol. Mar. 2003;17(1):121-33. [pmid: 12666468].
58 Asscher JJ, Deković M, Manders WA, et al. A randomized controlled trial of the effectiveness of multisystemic therapy in the Netherlands: Post-treatment changes and moderator effects. J Exp Criminol. 2013;9(2):169-87.
59 Borduin CM, Mann BJ, Cone LT, et al. Multisystemic treatment of serious juvenile offenders: long-term prevention of criminality and violence. J Consult Clin Psychol. Aug. 1995;63(4):569-78. [pmid: 7673534].
60 Nickel M, Luley J, Krawczyk J, et al. Bullying girls - changes after brief strategic family therapy: a randomized, prospective, controlled trial with one-year follow-up. Psychother Psychosom. 2006;75(1):47-55. [pmid: 16361874].
61 Nickel MK, Krawczyk J, Nickel C, et al. Anger, interpersonal relationships, and health-related quality of life in bullying boys who are treated with outpatient family therapy: a randomized, prospective, controlled trial with 1 year of follow-up. Pediatrics. Aug. 2005;116(2):e247-54. [pmid: 16061577].
62 Nickel MK, Muehlbacher M, Kaplan P, et al. Influence of family therapy on bullying behaviour, cortisol secretion, anger, and quality of life in bullying male adolescents: A randomized, prospective, controlled study. Can J Psychiatry. May. 2006;51(6):355-62. [pmid: 16786816].
63 Shechtman Z, Birani-Nasaraladin D. Treating mothers of aggressive children: a research study. Int J Group Psychother. Jan. 2006;56(1):93-112. [pmid: 16555426].
64 Azrin NH, Donohue B, Teichner GA, et al. A controlled evaluation and description of individual-cognitive problem solving and family-behavior therapies in dually-diagnosed conduct-disordered and substance-dependent youth. J Child Adolesc Subst Abuse. 2001;11(1):1-43.
65 Sells SP, Early KW, Smith TE. Reducing Adolescent Oppositional and Conduct Disorders: An Experimental Design Using the Parenting with Love and Limits® Model. Professional Issues in Criminal Justice. 2011;6(3).
66 van der Put CE, Asscher JJ, Stams GJ, et al. Recidivism after treatment in a forensic youth-psychiatric setting: the effect of treatment characteristics. Int J Offender Ther Comp Criminol. Sep. 2013;57(9):1120-39. [pmid: 22811475].