# Pharmacologic Approval Status, Harms, and Indications

The harms data provided in this section were gathered from analyzing available gray literature (i.e. package inserts and FDA review packages). FDA approval packages were limited to those available on the FDA website that contained a “Medical Review” section of the document. Upon further analysis, approval packages that did not assess pediatric safety data were not included. Table I-1 includes the pediatric indication for medications referenced in the clinical studies included in this review. Medications that have not been approved as safe and effective in pediatric patients; therefore are only FDA approved in adults are referenced in Table I-2. Notable boxed warnings, contraindications, and warnings/precautions that would be relevant to consider in the pediatric population were included. As a result, the data provided in this chart is not an all-inclusive list of these package insert sections. For complete data please see the corresponding package insert.

Updated: September 28, 2014

Table I-1 FDA-approved pediatric medications included in literature review

Drug | FDA Approved Pediatric Indication | Boxed Warning | Contraindications | Warnings/ Precautions
Guanfacine 1 | Treatment of Attention Deficit Hyperactivity Disorder (ADHD) as monotherapy and as adjunctive therapy to stimulant medications | --- | --- | - Dose-dependent decreases in blood pressure and heart rate.; - Somnolence and sedation
Divalproex sodium 2 | - Treatment of manic episodes associated with bipolar disorder; - Monotherapy and adjunctive therapy of complex partial seizures and simple and complex absence seizures; adjunctive therapy in patients with multiple seizure types that include absence seizures; - Prophylaxis of migraine headaches | - Hepatotoxicity, including fatalities, usually during the first 6 months of treatment. Children under the age of two years and patients with mitochondrial disorders are at higher risk.; - Pancreatitis, including fatal hemorrhagic cases. | - Hepatic disease or significant hepatic dysfunction,; - Known mitochondrial disorders caused by mutations in mitochondrial DNA polymerase γ (POLG),; - Suspected POLG-related disorder in children under two years of age,; - Urea cycle disorders. | - Suicidal behavior or ideation; - Thrombocytopenia; monitor platelet counts and coagulation test.; - Hyperammonemia and hyperammonemic encephalopathy; measure ammonia level if unexplained lethargy and vomiting or changes in mental status, and also with concomitant topiramate use; consider discontinuation of therapy.; - Hypothermia
Aripiprazole 3 | - Treatment of schizophrenia: Adolescents (ages 13-17); - Acute treatment of manic or mixed episodes associated with bipolar I disorder as monotherapy and as an adjunct to lithium or valproate: Pediatric Patients (ages 10-17); - Treatment of irritability associated with autistic disorder: Pediatric Patients (ages 6-17 years) | - Children, adolescents, and young adults are at increased risk of suicidal thinking and behavior when taking this medication. | --- | - Neuroleptic Malignant Syndrome: Manage with immediate discontinuation and close monitoring.; - Tardive Dyskinesia: Discontinue if clinically appropriate.; - Metabolic Changes: Atypical antipsychotic drugs have been associated with metabolic changes that include hyperglycemia/diabetes mellitus, dyslipidemia, and body weight gain; - Orthostatic Hypotension: Use with caution in patients with known cardiovascular or cerebrovascular disease; - Leukopenia, Neutropenia, and Agranulocytosis: Patients with a history of a clinically significant low white blood cell count (WBC) or a drug-induced leukopenia/neutropenia should have their complete blood count (CBC) monitored frequently during the first few months of therapy and discontinuation of aripiprazole should be considered at the first sign of a clinically significant decline in WBC in the absence of other causative factors.; - Seizures/Convulsions: Use cautiously in patients with a history of seizures or with conditions that lower the seizure threshold.; - Potential for Cognitive and Motor Impairment: Use caution when operating machinery.; - Suicide: The possibility of a suicide attempt is inherent in schizophrenia and bipolar disorder.
Atomoxetine 4 | Treatment of Attention-Deficit/Hyperactivity Disorder (ADHD) | Increased risk of suicidal ideation in children or adolescents | - Atomoxetine use within 2 weeks after discontinuing MAOI or other drugs that affect brain monoamine concentrations.; - Pheochromocytoma or history thereof; - Severe Cardiovascular Disorders that might deteriorate with clinically important increases in HR and BP. | - Severe Liver Injury – Should be discontinued and not restarted in patients with jaundice or laboratory evidence of liver injury.; - Serious Cardiovascular Events – Sudden death, stroke and myocardial infarction have been reported in association with atomoxetine treatment. Patients should have a careful history and physical exam to assess for presence of cardiovascular disease. Atomoxetine generally should not be used in children or adolescents with known serious structural cardiac abnormalities, cardiomyopathy, serious heart rhythm abnormalities, or other serious cardiac problems that may place them at increased vulnerability to its noradrenergic effects.; - Emergent Cardiovascular Symptoms – Patients should undergo prompt cardiac evaluation.; - Effects on Blood Pressure and Heart Rate – Increase in blood pressure and heart rate; orthostasis and syncope may occur. Use with caution in patients with hypertension, tachycardia, or cardiovascular or cerebrovascular disease.; - Emergent Psychotic or Manic Symptoms – Consider discontinuing treatment if such new symptoms occur.; - Bipolar Disorder – Screen patients to avoid possible induction of a mixed/manic episode.; - Aggressive behavior or hostility should be monitored.; - Effects on Urine Outflow – Urinary hesitancy and retention may occur.; - Priapism – Prompt medical attention is required in the event of suspected priapism.; - Growth – Height and weight should be monitored in pediatric patients.; - Concomitant Use of Potent CYP2D6 Inhibitors or Use in patients known to be CYP2D6 PMs – Dose adjustment of atomoxetine may be necessary.
Amphetamine- Dextroamphetamine 5 | Treatment of Attention Deficit Hyperactivity Disorder (ADHD) and Narcolepsy | - Administration of amphetamine for prolonged periods of time may lead to drug dependence due to the high risk of abuse and must be avoided; - Misuse of amphetamine may cause sudden death and serious cardiovascular adverse events. | - Advanced arteriosclerosis, symptomatic cardiovascular disease, moderate to severe hypertension, hyperthyroidism, known hypersensitivity or idiosyncrasy to the sympathomimetic amines, glaucoma.; - Agitated states.; - Patients with a history of drug abuse.; - During or within 14 days following the administration of monoamine oxidase inhibitors (hypertensive crises may result). | - Serious Cardiovascular Events: Sudden Death and Pre Existing Structural Cardiac Abnormalities or Other Serious Heart Problems; ○ Sudden death has been reported in association with CNS stimulant treatment at usual doses in children and adolescents with structural cardiac abnormalities or other serious heart problems.; ○ Hypertension and Other Cardiovascular Conditions: Stimulant medications cause a modest increase in average blood pressure (about 2-4 mmHg) and average heart rate (about 3-6 bpm), and individuals may have larger increases.; ○ Assessing Cardiovascular Status in Patients being Treated with Stimulant Medications: Children, adolescents, or adults who are being considered for treatment with stimulant medications should have a careful history (including assessment for a family history of sudden death or ventricular arrhythmia) and physical exam to assess for the presence of cardiac disease, and should receive further cardiac evaluation if findings suggest such disease (e.g., electrocardiogram and echocardiogram).; - Psychiatric Adverse Events; ○ Preexisting Psychosis: Administration of stimulants may exacerbate symptoms of behavior disturbance and thought disorder in patients with a pre-existing psychotic disorder.; ○ Bipolar Disorder: Particular care should be taken in using stimulants to treat ADHD in patients with comorbid bipolar disorder because of concern for possible induction of a mixed/manic episode in such patients.; ○ Emergence of New Psychotic or Manic Symptoms: Treatment emergent psychotic or manic symptoms, e.g., hallucinations, delusional thinking, or mania in children and adolescents without a prior history of psychotic illness or mania can be caused by stimulants at usual doses.; ○ Aggression: Aggressive behavior or hostility is often observed in children and adolescents with ADHD, and has been reported in clinical trials and the post-marketing experience of some medications indicated for the treatment of ADHD.; ○ Long-Term Suppression of Growth: Careful follow-up of weight and height in children ages 7 to 10 years who were randomized to either methylphenidate or non-medication treatment groups over 14 months, as well as in naturalistic subgroups of newly methylphenidate-treated and non-medication treated children over 36 months (to the ages of 10 to 13 years), suggests that consistently medicated children (i.e., treatment for 7 days per week throughout the year) have a temporary slowing in growth rate (on average, a total of about 2 cm less growth in height and 2.7 kg less growth in weight over 3 years), without evidence of growth rebound during this period of development.; ○ Seizures: there is some clinical evidence that stimulants may lower the convulsive threshold in patients with prior history of seizures, in patients with prior EEG abnormalities in absence of seizures, and, very rarely, in patients without a history of seizures and no prior EEG evidence of seizures.; ○ Visual disturbances: Difficulties with accommodation and blurring of vision have been reported with stimulant treatment.; - Should be used with caution in patients who use other sympathomimetic drugs.; - Amphetamines have been reported to exacerbate motor and phonic tics and Tourette's syndrome.; - Amphetamines may impair the ability of the patient to engage in potentially hazardous activities such as operating machinery or vehicles; the patient should therefore be cautioned accordingly.
Methylphenidate 6 | Attention Deficit Disorders (previously known as Minimal Brain Dysfunction in Children). Other terms being used to describe the behavioral syndrome below include: Hyperkinetic Child Syndrome, Minimal Brain Damage, Minimal Cerebral Dysfunction, Minor Cerebral Dysfunction. | --- | - Marked anxiety, tension, and agitation since the drug may aggravate these symptoms.; - Glaucoma; - Motor tics or with a family history or diagnosis of Tourette's syndrome.; - Treatment with monoamine oxidase inhibitors, and also within a minimum of 14 days following discontinuation of a monoamine oxidase inhibitor (hypertensive crises may result). | - Serious Cardiovascular Events:; ○ Sudden Death and Preexisting Structural Cardiac Abnormalities or Other Serious Heart Problems - Sudden death has been reported in association with CNS stimulant treatment at usual doses in children and adolescents with structural cardiac abnormalities or other serious heart problems.; ○ Hypertension and Other Cardiovascular Conditions Stimulant medications cause a modest increase in average blood pressure (about 2-4 mmHg) and average heart rate (about 3-6 bpm), and individuals may have larger increases.; ○ Assessing Cardiovascular Status in Patients being Treated with Stimulant Medications Children, adolescents, or adults who are being considered for treatment with stimulant medications should have a careful history (including assessment for a family history of sudden death or ventricular arrhythmia) and physical exam to assess for the presence of cardiac disease, and should receive further cardiac evaluation if findings suggest such disease (e.g., electrocardiogram and echocardiogram).; - Psychiatric Adverse Events; ○ Pre-existing Psychosis: Administration of stimulants may exacerbate symptoms of behavior disturbance and thought disorder in patients with a pre-existing psychotic disorder.; ○ Bipolar Disorder: Particular care should be taken in using stimulants to treat ADHD in patients with comorbid bipolar disorder because of concern for possible induction of a mixed/manic episode in such patients.; ○ Emergence of New Psychotic or Manic Symptoms: Treatment emergent psychotic or manic symptoms, e.g., hallucinations, delusional thinking, or mania in children and adolescents without a prior history of psychotic illness or mania can be caused by stimulants at usual doses.; ○ Aggression: Aggressive behavior or hostility is often observed in children and adolescents with ADHD, and has been reported in clinical trials and the post-marketing experience of some medications indicated for the treatment of ADHD.; - Long-term suppression of growth: Careful follow-up of weight and height in children ages 7 to 10 years who were randomized to either methylphenidate or non-medication treatment groups over 14 months, as well as in naturalistic subgroups of newly methylphenidate-treated and non-medication treated children over 36 months (to the ages of 10 to 13 years), suggests that consistently medicated children (i.e., treatment for 7 days per week throughout the year) have a temporary slowing in growth rate (on average, a total of about 2 cm less growth in height and 2.7 kg less growth in weight over 3 years), without evidence of growth rebound during this period of development.; - Seizures: There is some clinical evidence that stimulants may lower the convulsive threshold in patients with prior history of seizures, in patients with prior EEG abnormalities in absence of seizures, and, very rarely, in patients without a history of seizures and no prior EEG evidence of seizures.; - Priapism: Prolonged and painful erections, sometimes requiring surgical intervention, have been reported with methylphenidate products in both pediatric and adult patients.; - Peripheral Vasculopathy, Including Raynaud's Phenomenon: Stimulants, including methylphenidate, used to treat ADHD are associated with peripheral vasculopathy, including Raynaud's phenomenon.; - Visual Disturbance: Difficulties with accommodation and blurring of vision have been reported with stimulant treatment.; - Use in Children Under Six Years of Age: should not be used in children under 6 years, since safety and efficacy in this age group have not been established.; - Drug Dependence methylphenidate should be given cautiously to patients with a history of drug dependence or alcoholism. Chronic abusive use can lead to marked tolerance and psychological dependence with varying degrees of abnormal behavior. Frank psychotic episodes can occur, especially with parenteral abuse. Careful supervision is required during withdrawal from abusive use, since severe depression may occur. Withdrawal following chronic therapeutic use may unmask symptoms of the underlying disorder that may require follow-up.; - Patients with an element of agitation may react adversely; discontinue therapy if necessary.; - Periodic CBC, differential, and platelet counts are advised during prolonged therapy.; - Drug treatment is not indicated in all cases of this behavioral syndrome and should be considered only in light of the complete history and evaluation of the child. The decision to prescribe should depend on the physician's assessment of the chronicity and severity of the child's symptoms and their appropriateness for his/her age. Prescription should not depend solely on the presence of 1 or more of the behavioral characteristics. When these symptoms are associated with acute stress reactions, treatment with methylphenidate is usually not indicated.
Quetiapine 7 | - Schizophrenia; - Bipolar I disorder manic episodes; - Bipolar disorder, depressive episodes | Suicidal Thoughts and Behaviors: Increased risk of suicidal thoughts and behavior in children, adolescents, and young adults taking antidepressants. | --- | - Neuroleptic Malignant Syndrome (NMS): Manage with immediate discontinuation and close monitoring; - Metabolic Changes: Atypical antipsychotics have been associated with metabolic changes. These metabolic changes include hyperglycemia, dyslipidemia, and weight gain.; - Tardive Dyskinesia: Discontinue if clinically appropriate.; - Hypotension: Use with caution in patients with known cardiovascular or cerebrovascular disease.; - Increased Blood Pressure in Children and Adolescents: Monitor blood pressure at the beginning of, and periodically during treatment in children and adolescents; - Leukopenia, Neutropenia and Agranulocytosis: Monitor complete blood count frequently during the first few months of treatment in patients with a preexisting low white cell count or a history of leukopenia/neutropenia and discontinue at the first sign of a decline in WBC in absence of other causative factors.; - Cataracts: Lens changes have been observed in patients during long-term quetiapine treatment. Lens examination is recommended when starting treatment and at 6-month intervals during chronic treatment.; - Hypothyroidism: In controlled trials in children and adolescent patients with schizophrenia or bipolar mania, the incidence of shifts for thyroid function values at any time for quetiapine treated patients and placebo-treated patients for elevated TSH was 2.9% (8/280) vs. 0.7% (1/138), respectively and for decreased total thyroxine was 2.8% (8/289) vs. 0% (0/145, respectively).; - Hyperprolactinemia: In controlled trials in children and adolescent patients with bipolar mania or schizophrenia, the incidence of shifts in prolactin levels to a value (>20 μg/L males; > 26 μg/L females at any time) was 13.4% (18/134) for quetiapine compared to 4% (3/75) for placebo in males and 8.7% (9/104) for quetiapine compared to 0% (0/39) for placebo in females.; - Potential for Cognitive and Motor Impairment - Since quetiapine has the potential to impair judgment, thinking, or motor skills, patients should be cautioned about performing activities requiring mental alertness.
Risperidone 8 | - Treatment of schizophrenia. Efficacy was established in 2 short-term trials in adolescents (ages 13 to 17 years); - Treatment (montherapy) of acute manic or mixed episodes associated with Bipolar I Disorder. Efficacy was established in one short-term trial in children and adolescents (ages 10 to 17 years); - Treatment of irritability associated with autistic disorder, including symptoms of aggression towards others, deliberate selG-injuriousness, temper tantrums, and quickly changing moods. Efficacy was established in 3 short-term trials in children and adolescents (ages 5 to 17 years) | --- | --- | - Neuroleptic Malignant Syndrome: Manage with immediate discontinuation and close monitoring.; - Tardive dyskinesia: Consider discontinuing if clinically indicated.; - Metabolic Changes: Atypical antipsychotic drugs have been associated with metabolic changes that may increase cardiovascular/cerebrovascular risk. These metabolic changes include hyperglycemia, dyslipidemia, and weight gain.; - Hyperprolactinemia: Prolactin elevations occur and persist during chronic administration.; - Orthostatic hypotension: For patients at risk, consider a lower starting dose and slower titration.; - Leukopenia, Neutropenia, and Agranulocytosis: Perform complete blood counts in patients with a history of clinically significant low white blood cell count (WBC). Consider discontinuing if a clinically significant decline in WBC occurs in the absence of other causative factors.; - Potential for cognitive and motor impairment: Use caution when operating machinery.; - Seizures: Use cautiously in patients with a history of seizures or with conditions that lower the seizure threshold.

Table I-2 FDA-approved adult medications (prescribed off label in pediatric patients) included in literature review

Drug | FDA Approved Adult Indication | Boxed Warning | Contraindications | Warnings/ Precautions
Ziprasidone 9 | - Treatment of schizophrenia.; - Acute treatment as monotherapy of manic or mixed episodes associated with bipolar I disorder; - Maintenance treatment of bipolar I disorder as an adjunct to lithium or valproate.; - Acute treatment of agitation in schizophrenic patients. | --- | - Do not use in patients with a known history of QT prolongation.; - Do not use in patients with recent acute myocardial infarction; - Do not use in patients with uncompensated heart failure; - Do not use in combination with other drugs that have demonstrated QT prolongation. | - QT Interval Prolongation: should be avoided in patients with bradycardia, hypokalemia or hypomagnesemia, congenital prolongation of the QT interval, or in combination with other drugs that have demonstrated QT prolongation; - Neuroleptic Malignant Syndrome (NMS): Potentially fatal symptom complex has been reported with antipsychotic drugs. Manage with immediate discontinuation of drug and close monitoring.; - Tardive Dyskinesia - May develop acutely or chronically; - Metabolic Changes: Atypical antipsychotic drugs have been associated with metabolic changes that may increase cardiovascular/cerebrovascular risk. These metabolic changes include hyperglycemia, dyslipidemia, and weight gain.; - Rash: Discontinue in patients who develop a rash without an identified cause; - Orthostatic Hypotension: Use with caution in patients with known cardiovascular or cerebrovascular disease; - Leukopenia, Neutropenia, and Agranulocytosis has been reported with antipsychotics. Patients with a pre-existing low white blood cell count (WBC) or a history of leukopenia/neutropenia should have their complete blood count (CBC) monitored frequently during the first few months of therapy and should discontinue at the first sign of a decline in WBC in the absence of other causative factors.; - Seizures: Use cautiously in patients with a history of seizures or with conditions that lower seizure threshold; - Potential for Cognitive and Motor impairment: Patients should use caution when operating machinery; - Suicide Closely supervise high-risk patients

Table I-3 Serious adverse events reported across medications^*^

| Guanfacine | Divalproex | Aripiprazole | Atomoxetine | Amphetamine / Dextroamphetamine | Methylphenidate | Quetiapine | Risperidone | Ziprasidone
Suicide attempt | | | • | | | | | • | •
Suicidal ideation | | | • | •
QT prolongation | • | | | • | | | • | • | •
Death | • | | | • | • | • | | •
Stroke | | | | • | •
Myocardial Infarction | • | | | • | • | | | | •
Orthostatic hypotension | • | | • | | | | | • | •
Angioedema | | | • | • | • | | | • | •
Cardiac arrest | •
Neuroleptic malignant syndrome | | | • | | | • | • | • | •
Steven-Johnson syndrome | | | | | • | | •
Mania/hypomania | • | | | | • | • | | • | •
Extrapyramidal symptoms/ disorder | | | • | | | | • | • | •
Tardive dyskinesia | | • | • | | | | • | • | •
Abnormal LFTs | | | | •
Respiratory system disorders | | | | | | | | • | •
Pancreatitis | | • | | | | | • | •
Seizures/ convulsions | • | | • | • | • | • | | • | •
Syncope | • | | | • | | | • | | •

* Events gathered from all available harms data including: clinical trial data and post-marketing experience

Table I-4 Selected adverse events observed across medications^*^

| Guanfacine | Divalproex Sodium | Aripiprazole | Atomoxetine | Amphetamine-Dextroamphetamine | Methylphenidate | Quetiapine | Risperidone | Ziprasidone
Somnolence | • | • | • | • | | | • | • | •
Weight Loss | | • | | • | • | •
Weight Gain | • | • | • | | | | • | • | •
Tachycardia | • | • | | • | • | • | • | | •
Decrease alkaline phosphatase | | | | •
Hyperprolactinemia | | | | | | | • | •
Aggression | • | | • | • | • | • | •
Hypotension | • | • | | | | | • | •
Hypertension | • | • | | • | • | •
Decreased heart rate | •
Increased heart rate | | | | • | • | • | • | •
Dyslipidemia | | | • | | | | • | • | •
Hyperglycemia | | | • | | | | • | • | •
Leukopenia | | | • | • | | • | • | • | •
Neutropenia | | | • | | | | • | • | •

* Events gathered from all available harms data including: clinical trial data and post-marketing experience

Table I-5 Pharmacologic agents considered for DBD review

Drug Class Individual agent (proprietary name)
Alpha-agonists; - Clonidine; - Guanfacine (Intuniv®) | First-generation antipsychotics; - Chlorpromazine; - Fluphenazine; - Haloperidol; - Loxapine; - Perphenazine; - Prochlorperazine; - Thiothixene; - Thioridazine; - Trifluoperazine | Selective serotonin reuptake inhibitors (SSRI); - Fluoxetine; - Sertraline; - Citalopram; - Escitalopram; - Paroxetine; - Fluvoxamine
Anticonvulsants; - Carbamazepine (Tegretol®); - Oxcarbazepine (Trileptal®); - Divalproex sodium (Depakote®); - Lamotrigine (Lamictal®); - Valproate/ Valproic acid | First-generation antipsychotics; - Chlorpromazine; - Fluphenazine; - Haloperidol; - Loxapine; - Perphenazine; - Prochlorperazine; - Thiothixene; - Thioridazine; - Trifluoperazine | Selective serotonin reuptake inhibitors (SSRI); - Fluoxetine; - Sertraline; - Citalopram; - Escitalopram; - Paroxetine; - Fluvoxamine
Beta-blockers; - Propranolol; - Metoprolol; - Pindolol; - Nadolol | Second-generation (atypical) antipsychotics; - Aripiprazole (Abilify®); - Asenapine (Saphris®); - Clozapine (Clozaril®); - Iloperidone (Fanapt®); - Lurasidone (Latuda®); - Olanzapine (Zyprexa®); - Olanzapine/Fluoxetine (Symbyax®); - Paliperidone (Invega®); - Quetiapine (Seroquel®); - Risperidone (Risperdal®); - Ziprasidone (Geodon®) | Other (e.g., antihistamines, benzodiazepines, mood stabilizers, non-SSRI antidepressants); - Lithium; - Atomoxetine (Strattera®); - Naltrexone; - Hydroxyzine; - Clonazepam (Klonopin®); - Levetiracetam (Keppra®); - Lorazepam (Ativan®); - Bupropion
Central nervous system (CNS) stimulants; - Amphetamine-Dextroamphetamine (Adderall®); - Methylphenidate (Ritalin®); - Lisdexamfetamine (Vyvanse®)

Table I-6 FDA approval status for drugs included in the DBD review

Generic Name (Trade Name) | Indication(s) | Approved For
Amphetamine Salts (Adderall) | Attention Deficit Hyperactivity Disorder (ADHD) | Children (3 +)
Amphetamine Salts (Adderall) | Narcolepsy | Children (6 +)
Aripiprazole (Abilify)10 | Schizophrenia | Adults and adolescents (13–17 years)
Aripiprazole (Abilify)10 | Bipolar disorder (manic/mixed) monotherapy or adjunctive to lithium or valproate | Adults and children (10–17 years)
Aripiprazole (Abilify)10 | Adjunctive treatment of major depressive disorder | Adults
Aripiprazole (Abilify)10 | Irritability Associated with autistic disorder | Children (6–17 years)
Aripiprazole (Abilify)10 | Acute treatment of agitation | Adults
Atomoxetine (Strattera)11 | Attention Deficit Hyperactivity Disorder (ADHD) | Adults and children (6-18)
Divalproex (Depakote) | Bipolar Disorder (manic episodes) | Adults and children (10 +)
Divalproex (Depakote) | Seizures | Adults and children (10 +)
Divalproex (Depakote) | Migraine Headaches | Adults and children (10 +)
Guanfacine (Intuniv)12 | Attention Deficit Hyperactivity Disorder (ADHD) and adjunctive therapy to stimulant medications | Children and adolescents (6-17)
Methylphenidate (Ritalin) | Attention Deficit Disorders (ADD) | Children and adults (6 + years)
Quetiapine (Seroquel)13 | Schizophrenia | Adults and adolescents (13–17 years)
Quetiapine (Seroquel)13 | Bipolar disorder (acute manic) | Adults, children, and adolescents (10–17 years)
Quetiapine (Seroquel)13 | Bipolar disorder (depression) | Adults
Quetiapine (Seroquel)13 | Bipolar disorder (maintenance) | Adults
Quetiapine (Seroquel)13 | Adjunctive therapy for major depressive disorder | Adults
Risperidone (Risperdal)14 | Schizophrenia | Adults and adolescents (13–17 years)
Risperidone (Risperdal)14 | Bipolar disorder (manic/mixed) | Adults and adolescents (10–17 years)
Risperidone (Risperdal)14 | Irritability associated with autism | Children (5–16 years)
Valproate/Valproic Acid (Depacon) | Epilepsy | Children and adults (10 + years
Ziprasidone (Geodon) | Schizophrenia | Adults
Ziprasidone (Geodon) | Bipolar disorder (manic/mixed) | Adults
Ziprasidone (Geodon) | Bipolar disorder (maintenance) | Adults
Ziprasidone (Geodon) | Acute agitation in patients with schizophrenia | Adults

## References for Appendix I

1 Intuniv [package insert]. Wayne, PA. Shire US Inc. 2013.
2 Depakote [package insert]. North Chicago, IL. AbbVie Inc. July. 2013.
3 Abilify [package insert]. Rockville, MD. Otsuka America Pharmaceutical, Inc. 2013.
4 Strattera [package insert]. Indianapolis, IN. Eli Lilly and Company. 2014.
5 Adderall [package insert]. Pomona, NY. Barr Laboratories. 2007.
6 Ritalin [package insert]. East Hanover, NJ. Novartis Pharmaceuticals Corporation. 2013.
7 Seroquel [package inert]. Wilmington, DE. AstraZeneca Pharmaceuticals LP. October. 2013.
8 Risperdal [package insert]. Titusville, NJ. Janssen Pharmaceuticals, Inc. 2014.
9 Geodon [package insert]. New York, NY. Pfizer. October. 2012.
10 Abilify Medical Review - Schizophrenia in Pediatric Patients. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2007.
11 Strattera Medical Review - Original Approval. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2002.
12 Intuniv Medical Review - Original Approval. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2009.
13 Seroquel Medical Review - QT Prolongation Review. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2011.
14 Risperdal Medical Review - Pediatric Approval. Silver Spring, MD. Food and Drug Administration Center for Drug Evaluation and Research. 2007.