# Reasons for Exclusion

Exclusion Code | Exclusion Reason | Count
X-1 | Not original research | 67
X-2 | Does not measure the relationship between a psychosocial or pharmacologic intervention and an outcome | 158
X-2a | Not an eligible study design | 9
X-3 | Not youth | 30
X-4 | No standardized disruptive behavior disorder classification or symptom assessment meeting a clinical threshold cutoff | 319
X-4a | At-risk population or preventive intervention | 5
X-5 | Not conducted in an outpatient healthcare setting | 177
X-6 | Does not include an alternate treatment or control group for comparison to measure effectiveness | 256
X-7 | Does not report an outcome of interest for the population (youth) with disruptive behavior | 125
X-7a | Does not report data for an outcome of interest by group | 7
X-8 | Does not address a Key Question | 134
X-9 | Duplicate | 7
X-10 | Unavailable | 28
X-11 | Older than 20 years | 198
X-12 | Non-English | 5

## References for Appendix H

Records excluded at full-text level screening; listed alphabetically by first author last name

1 Stereotactic neurosurgery for aggressive behaviour. Med J Aust. Apr. 21. 1973;1(16):779-80. X-11. [pmid: 4575087].
2 A cognitive-ecological approach to preventing aggression in urban settings: initial outcomes for high-risk children. J Consult Clin Psychol. Feb. 2002;70(1):179-94. X-5. [pmid: 11860044].
3 A more compassionate model for treating children with severe mental disturbances. Psychiatr Serv. Nov. 2003;54(11):1529-31. X-1, X-2, X-3, X-5, X-6. [pmid: 14600314].
4 Modafinil: serious skin reactions. Prescrire Int. Apr. 2007;16(88):71. X-1, X-2, X-4. [pmid: 17465032].
5 Fluoxetine: new indication. Depression in children: too many uncertainties. Prescrire Int. Oct. 2008;17(97):186-7. X-1, X-4. [pmid: 19534039].
6 Antisocial Personality Disorder: The NICE Guideline on Treatment, Management and Prevention. The Collaborating Centre for Mental Health. Leicester, UK. The British Psychological Society and The Royal College of Psychiatrists. 2010. X-1.
7 Disruptive behavior disorders. J Okla State Med Assoc. Jul-Aug. 2011;104(7-8):324-5. X-10. [pmid: 22013872].
8 Impact of Early Intervention on Psychopathology, Crime, and Well-Being at Age 25. Am J Psychiatry. 2014. Sep. 15. X-3, X-5. [pmid: 25219348].
9 Abrahamse ME, Junger M, Chavannes EL, et al. Parent-child interaction therapy for preschool children with disruptive behaviour problems in the Netherlands. Child Adolesc Psychiatry Ment Health. 2012;6(1):24. X-2, X-6. [pmid: 22694924].
10 Abrahamse ME, Junger M, Chavannes EL, et al. Parent–child interaction therapy for preschool children with disruptive behaviour problems in the Netherlands. Child and Adolescent Psychiatry and Mental Health. 2012;6. X-6.
11 Abramovitch R, Konstantareas M, Sloman L. An observational assessment of change in two groups of behaviourally disturbed boys. J Child Psychol Psychiatry. Apr. 1980;21(2):133-41. X-11. [pmid: 7372743].
12 Accurso EC, Garland AF. Child, Caregiver, and Therapist Perspectives on Therapeutic Alliance in Usual Care Child Psychotherapy. Psychol Assess. 2014. Oct. 13. X-2, X-6. [pmid: 25314097].
13 Accurso EC, Hawley KM, Garland AF. Psychometric properties of the Therapeutic Alliance Scale for Caregivers and Parents. Psychol Assess. Mar. 2013;25(1):244-52. X-2, X-6. [pmid: 23088205].
14 Acker LE, Acker MA, Pearson D. Generalized imitative affection: relationship to prior kinds of imitation training. J Exp Child Psychol. Aug. 1973;16(1):111-25. X-11. [pmid: 4722555].
15 Adams AL, Meaden P. A 12-Week Comparison Regarding Symptom Improvement in an Urban University-Based Outpatient Child Psychiatry Clinic. Am J Ther. 2013. Jun. 18. X-2a. [pmid: 23782761].
16 Adams D, Allen D. Assessing the need for reactive behaviour management strategies in children with intellectual disability and severe challenging behaviour. J Intellect Disabil Res. Aug. 2001;45(Pt 4):335-43. X-2, X-4, X-6. [pmid: 11489055].
17 al Ansari A, Gouthro S, Ahmad K, et al. Hospital-based behavior modification program for adolescents: evaluation and predictors of outcome. Adolescence. Summer. 1996;31(122):469-76. X-5, X-6, X-8. [pmid: 8726904].
18 Altman K, Hobbs S, Roberts M, et al. Control of disruptive behavior by manipulation of reinforcement density and item difficulty subsequent to errors. Appl Res Ment Retard. 1980;1(3-4):193-208. X-11. [pmid: 7337457].
19 Aman M, Buitelaar J, De Smedt G, et al. Pharmacotherapy of Disruptive Behavior and Item Changes on a Standardized Rating Scale: Pooled Analysis of Risperidone Effects in Children with Subaverage IQ. Journal of Child and Adolescent Psychopharmacology. 2005;15(2):220-32. X-4. [pmid: 15910206].
20 Aman MG, Binder C, Turgay A. Risperidone effects in the presence/absence of psychostimulant medicine in children with ADHD, other disruptive behavior disorders, and subaverage IQ. J Child Adolesc Psychopharmacol. Summer. 2004;14(2):243-54. X-4, X-6. [pmid: 15319021].
21 Aman MG, Bukstein OG, Gadow KD, et al. What does risperidone add to parent training and stimulant for severe aggression in child attention-deficit/hyperactivity disorder?. Journal of the American Academy of Child & Adolescent Psychiatry. 2014;53(1):47-60. X-4. [pmid: 24342385].
22 Aman MG, Hollway JA, Leone S, et al. Effects of risperidone on cognitive-motor performance and motor movements in chronically medicated children. Res Dev Disabil. Mar-Apr. 2009;30(2):386-96. X-4. [pmid: 18768293].
23 Aman MG, Kasper W, Manos G, et al. Line-item analysis of the Aberrant Behavior Checklist: results from two studies of aripiprazole in the treatment of irritability associated with autistic disorder. J Child Adolesc Psychopharmacol. Oct. 2010;20(5):415-22. X-1, X-4, X-7. [pmid: 20973712].
24 Aman MG, McDougle CJ, Scahill L, et al. Medication and parent training in children with pervasive developmental disorders and serious behavior problems: results from a randomized clinical trial. J Am Acad Child Adolesc Psychiatry. Dec. 2009;48(12):1143-54. X-4. [pmid: 19858761].
25 Aman MG, Werry JS. The effects of methylphenidate and haloperidol on the heart rate and blood pressure of hyperactive children with special reference to time of action. Psychopharmacologia. Aug. 21. 1975;43(2):163-8. X-11. [pmid: 1103207].
26 Amaya MM, Reinecke MA, Silva SG, et al. Parental marital discord and treatment response in depressed adolescents. J Abnorm Child Psychol. Apr. 2011;39(3):401-11. X-4. [pmid: 20957515].
27 Amery B, Minichiello MD, Brown GL. Aggression in hyperactive boys: response to d-amphetamine. J Am Acad Child Psychiatry. May. 1984;23(3):291-4. X-11. [pmid: 6736494].
28 Amminger GP, Berger GE, Schafer MR, et al. Omega-3 fatty acids supplementation in children with autism: a double-blind randomized, placebo-controlled pilot study. Biol Psychiatry. Feb. 15. 2007;61(4):551-3. X-4, X-6, X-7, X-8. [pmid: 16920077].
29 Anderson L, Vostanis P, O'Reilly M. Three-year follow-up of a family support service cohort of children with behavioural problems and their parents. Child Care Health Dev. Jul. 2005;31(4):469-77. X-6, X-7, X-8. [pmid: 15948884].
30 Anderson RM, Kauffman JM. Use of state mental health centers in training teachers of children with behavior disorders. J Sch Health. Dec. 1970;40(10):523-5. X-11. [pmid: 5203062].
31 Angrist B, Gershon S. Clinical effects of amphetamine and L-DOPA on sexuality and aggression. Compr Psychiatry. Nov-Dec. 1976;17(6):715-22. X-11. [pmid: 991603].
32 Ansari AA, Gouthro S, Ahmad K, et al. Hospital-based behavior modification program for adolescents: Evaluation and predictors of outcome. Adolescence. 1996;31(122):469-76. X-5, X-6. [pmid: 8726904].
33 Apolito A. Primary prevention: a breakthrough in sight. Am J Psychoanal. Summer. 1978;38(2):121-7. X-11. [pmid: 707672].
34 Apsche JA, Bass CK, Zeiter JS, et al. Family mode deactivation therapy in a residential setting: Treating adolescents with conduct disorder and multi-axial diagnosis. International Journal of Behavioral Consultation and Therapy. 2008;4(4):328-39. X-4, X-7.
35 Armstrong H, Wilks C, McEvoy L, et al. Group therapy for parents of youths with a conduct disorder. Cmaj. Oct. 1. 1994;151(7):939-44. X-2, X-3, X-6. [pmid: 7922930].
36 Arnesen RB, Libby R, Miller PH. Altering the behavior of an aggressive institutionalized boy through paradoxical communication. J Nerv Ment Dis. Jul. 1973;157(1):63-5. X-11. [pmid: 4713308].
37 Arnold LE, Kirilcuk V, Corson SA, et al. Levoamphetamine and dextroamphetamine: differential effect on aggression and hyperkinesis in children and dogs. Am J Psychiatry. Feb. 1973;130(2):165-70. X-11. [pmid: 4568123].
38 Athens ES, Vollmer TR. An investigation of differential reinforcement of alternative behavior without extinction. J Appl Behav Anal. Winter. 2010;43(4):569-89. X-4, X-6, X-7. [pmid: 21541145].
39 Atkins MS, Graczyk PA, Frazier SL, et al. Toward A New Model for Promoting Urban Children's Mental Health: Accessible, Effective, and Sustainable School-Based Mental Health Services. School Psychology Review. 2003;32(4):503-14. X-2, X-4, X-5, X-6.
40 August GJ, Egan EA, Realmuto GM, et al. Parceling component effects of a multifaceted prevention program for disruptive elementary school children. J Abnorm Child Psychol. Oct. 2003;31(5):515-27. X-5, X-6. [pmid: 14561059].
41 August GJ, Hektner JM, Egan EA, et al. The early risers longitudinal prevention trial: examination of 3-year outcomes in aggressive children with intent-to-treat and as-intended analyses. Psychol Addict Behav. Dec. 2002;16(4 Suppl):S27-39. X-5, X-6. [pmid: 12502275].
42 August GJ, Lee SS, Bloomquist ML, et al. Dissemination of an evidence-based prevention innovation for aggressive children living in culturally diverse, urban neighborhoods: the Early Risers effectiveness study. Prev Sci. Dec. 2003;4(4):271-86. X-5. [pmid: 14598999].
43 August GJ, Piehler TF, Bloomquist ML. Being “SMART” About Adolescent Conduct Problems Prevention: Executing a SMART Pilot Study in a Juvenile Diversion Agency. J Clin Child Adolesc Psychol. Sep. 2014;25:1-15. X-1, X-5. [pmid: 25256135].
44 Axberg U, Broberg AG. Evaluation of “the incredible years” in Sweden: The transferability of an American parent-training program to Sweden. Scandinavian Journal of Psychology. 2012;53(3):224-32. X-9. [pmid: 22621727].
45 Axelrad ME, Butler AM, Dempsey J, et al. Treatment effectiveness of a brief behavioral intervention for preschool disruptive behavior. J Clin Psychol Med Settings. Sep. 2013;20(3):323-32. X-6, X-8. [pmid: 23575970].
46 Axelrad ME, Garland BH, Love KB. Brief behavioral intervention for young children with disruptive behaviors. J Clin Psychol Med Settings. Sep. 2009;16(3):263-9. X-6, X-8. [pmid: 19424780].
47 Ayres CM. Serpasil treatment of adolescents with behavior disorders. Dis Nerv Syst. Feb. 1960;21:91-5. X-11. [pmid: 13795365].
48 Azrin NH, Gottlieb L, Hughart L, et al. Eliminating self-injurious behavior by educative procedures. Behav Res Ther. Jun. 1975;13(2-3):101-11. X-11. [pmid: 1164365].
49 Bachmann M, Bachmann CJ, John K, et al. The effectiveness of child and adolescent psychiatric treatments in a naturalistic outpatient setting. World Psychiatry. Jun. 2010;9(2):111-7. X-4, X-7. [pmid: 20671900].
50 Baeza I, de la Serna E, Calvo-Escalona R, et al. Antipsychotic use in children and adolescents: a 1-year follow-up study. J Clin Psychopharmacol. Oct. 2014;34(5):613-9. X-2, X-5, X-6. [pmid: 25154009].
51 Bagner DM, Boggs SR, Eyberg SM. Evidence-Based School Behavior Assessment of Externalizing Behavior in Young Children. Educ Treat Children. Feb. 2010;33(1):65-83. X-2, X-6, X-8. [pmid: 21687781].
52 Bagner DM, Eyberg SM. Father involvement in parent training: when does it matter?. J Clin Child Adolesc Psychol. Dec. 2003;32(4):599-605. X-2, X-6. [pmid: 14710469].
53 Bagner DM, Eyberg SM. Parent-child interaction therapy for disruptive behavior in children with mental retardation: a randomized controlled trial. J Clin Child Adolesc Psychol. Jul-Sep. 2007;36(3):418-29. X-4. [pmid: 17658985].
54 Bagner DM, Graziano PA. Barriers to success in parent training for young children with developmental delay: the role of cumulative risk. Behav Modif. May. 2013;37(3):356-77. X-4. [pmid: 23188886].
55 Bagner DM, Rodriguez GM, Blake CA, et al. Home-Based Preventive Parenting Intervention for at-Risk Infants and Their Families: An Open Trial. Cogn Behav Pract. Aug. 1. 2013;20(3):334-48. X-6. [pmid: 25414568].
56 Bandou N, Koike K, Matuura H. Predictive familial risk factors and pharmacological responses in ADHD with comorbid disruptive behavior disorders. Pediatr Int. Jun. 2010;52(3):415-9. X-4, X-7. [pmid: 19912555].
57 Banerjee S, Ayyash HF. Does atomoxetine increase the risk of aggression and hostility in children with attention deficit hyperactivity disorder?. Arch Dis Child Educ Pract Ed. Aug. 2008;93(4):131-2. X-1, X-2, X-4, X-5, X-6, X-7. [pmid: 18644903].
58 Bangs ME, Hazell P, Danckaerts M, et al. Atomoxetine for the treatment of attention-deficit/hyperactivity disorder and oppositional defiant disorder. Pediatrics. Feb. 2008;121(2):e314-20. X-4. [pmid: 18245404].
59 Bank L, Marlowe JH, Reid JB, et al. A comparative evaluation of parent-training interventions for families of chronic delinquents. J Abnorm Child Psychol. Feb. 1991;19(1):15-33. X-11. [pmid: 2030245].
60 Barbero JAJ, García MP, Galindo FJF, et al. Altemativa psicofamiliar al tratamiento precoz de los problemas de conducta: La escuela de padres. Anales de Psiquiatría. 2009;25(3):142-5. X-1, X-2, X-12.
61 Bardill DR. Behavior contracting and group therapy with preadolescent males in a residential treatment setting. Int J Group Psychother. Jul. 1972;22(3):333-42. X-11. [pmid: 5054380].
62 Barker ED, Vitaro F, Lacourse E, et al. Testing the developmental distinctiveness of male proactive and reactive aggression with a nested longitudinal experimental intervention. Aggress Behav. Mar-Apr. 2010;36(2):127-40. X-4. [pmid: 20052694].
63 Barker P, Fraser IA. A controlled trial of haloperidol in children. Br J Psychiatry. Jul. 1968;114(512):855-7. X-11. [pmid: 4874167].
64 Barkley RA, Shelton TL, Crosswait C, et al. Preliminary findings of an early intervention program with aggressive hyperactive children. Ann N Y Acad Sci. Sep. 20. 1996;794:277-89. X-5. [pmid: 8853609].
65 Barkley RA, Shelton TL, Crosswait C, et al. Multi-method psycho-educational intervention for preschool children with disruptive behavior: preliminary results at post-treatment. J Child Psychol Psychiatry. Mar. 2000;41(3):319-32. X-5. [pmid: 10784079].
66 Barlett CP, Anderson CA. Reappraising the situation and its impact on aggressive behavior. Pers Soc Psychol Bull. Dec. 2011;37(12):1564-73. X-2, X-7. [pmid: 21975949].
67 Barlow J. The Webster Stratton “Incredible Years” parent training programme reduces conduct problems in children. Evid Based Ment Health. Aug. 2007;10(3):86. X-1. [pmid: 17652568].
68 Barmann BC, Croyle-Barmann C. Use of contingent-interrupted music in the treatment of disruptive behavior while riding a bus. Psychol Rep. Aug. 1980;47(1):269-70. X-11. [pmid: 7422768].
69 Barrera M Jr., Biglan A, Taylor TK, et al. Early elementary school intervention to reduce conduct problems: a randomized trial with Hispanic and non-Hispanic children. Prev Sci. Jun. 2002;3(2):83-94. X-4, X-6, X-8. [pmid: 12088139].
70 Bartunkova Z, Cerny L, Drtilova J, et al. Propericiazin, diazepam, chlorpromazine and placebo in a doubleblind trial in pedopsychiatric therapy. Act Nerv Super (Praha). 1972;14(2):83-4. X-11. [pmid: 4402693].
71 Baruch G, Vrouva I, Wells C. Outcome findings from a parent training programme for young people with conduct problems. Child and Adolescent Mental Health. 2011;16(1):47-54. X-6.
72 Bastiaans J, van der Ploeg HM. Contol and regulation of aggression. Psychother Psychosom. 1978;29(1-4):40-8. X-11. [pmid: 724962].
73 Bay-Hinitz AK, Peterson RF, Quilitch HR. Cooperative games: a way to modify aggressive and cooperative behaviors in young children. J Appl Behav Anal. Fall. 1994;27(3):435-46. X-5. [pmid: 7928788].
74 Becker EA, Crismon ML, Shafer A, et al. SSRI Use and Behavioral Disruption Among Children and Adolescents at Austin State Hospital. Tex Med. May. 2009;105(5):e1-5. X-4, X-5. [pmid: 19421919].
75 Beckett PG, Lennox K, Grisell JL. Responsiblity and reward in treatment. A comparative follow-up study of adolesents. J Nerv Ment Dis. Mar. 1968;146(3):257-63. X-11. [pmid: 5645901].
76 Behar LB. The Preschool Behavior Questionnaire. J Abnorm Child Psychol. 1977;5(3):265-75. X-11. [pmid: 903521].
77 Bentovim A. Disobedience and violent behaviour in children: family pathology and family treatment--II. Br Med J. Apr. 24. 1976;1(6016):1004-6. X-11. [pmid: 1268515].
78 Bernal ME, Klinnert MD, Schultz LA. Outcome evaluation of behavioral parent training and client-centered parent counseling for children with conduct problems. J Appl Behav Anal. Winter. 1980;13(4):677-91. X-11. [pmid: 7204284].
79 Biederman J, Mick E, Faraone SV, et al. Risperidone for the Treatment of Affective Symptoms in Children with Disruptive Behavior Disorder: A Post Hoc Analysis of Data from a 6-Week, Multicenter, Randomized, Double-Blind, Parallel-Arm Study. Clinical Therapeutics: The International Peer-Reviewed Journal of Drug Therapy. 2006;28(5):794-800. X-4.
80 Bierman KL, Coie JD, Dodge KA, et al. The effects of the fast track program on serious problem outcomes at the end of elementary school. J Clin Child Adolesc Psychol. Dec. 2004;33(4):650-61. X-5. [pmid: 15498733].
81 Bierman KL, Coie JD, Dodge KA, et al. Using the Fast Track randomized prevention trial to test the early-starter model of the development of serious conduct problems. Dev Psychopathol. Fall. 2002;14(4):925-43. X-2, X-5. [pmid: 12549710].
82 Bierman KL, Nix RL, Heinrichs BS, et al. Effects of Head Start REDI on Children's Outcomes 1 Year Later in Different Kindergarten Contexts. Child Dev. 2013. May. 3. X-4, X-5. [pmid: 23647355].
83 Bierman KL, Nix RL, Maples JJ, et al. Examining clinical judgment in an adaptive intervention design: The fast track program. J Consult Clin Psychol. Jun. 2006;74(3):468-81. X-2. [pmid: 16822104].
84 Bjørknes R, Kjøbli J, Manger T, et al. Parent training among ethnic minorities: Parenting practices as mediators of change in child conduct problems. Family Relations. 2012;61(1):101-14. X-4.
85 Bjorknes R, Manger T. Can parent training alter parent practice and reduce conduct problems in ethnic minority children? A randomized controlled trial. Prev Sci. Feb. 2013;14(1):52-63. X-4. [pmid: 23135877].
86 Blader JC. Pharmacotherapy and postdischarge outcomes of child inpatients admitted for aggressive behavior. J Clin Psychopharmacol. Aug. 2006;26(4):419-25. X-2, X-5. [pmid: 16855463].
87 Blustein J. Intervention with excessively aggressive children. Conceptual and ethical issues. Ann N Y Acad Sci. Sep. 20. 1996;794:308-17. X-2, X-10. [pmid: 8853611].
88 Bodenmann G, Cina A, Ledermann T, et al. The efficacy of the Triple P-Positive Parenting Program in improving parenting and child behavior: a comparison with two other treatment conditions. Behav Res Ther. Apr. 2008;46(4):411-27. X-4. [pmid: 18313033].
89 Boelhouwer C, Henry CE, Glueck BC Jr. Positive spiking: a double-blind control study on its significance in behavior disorders, both diagnostically and therapeutically. Am J Psychiatry. Oct. 1968;125(4):473-81. X-11. [pmid: 4886101].
90 Boggs SR, Eyberg SM, Edwards DL, et al. Outcomes of Parent-Child Interaction Therapy: A Comparison of Treatment Completers and Study Dropouts One to Three Years Later. Child & Family Behavior Therapy. 2004;26(4):1-22. X-2, X-6.
91 Boisjoli R, Vitaro F, Lacourse E, et al. Impact and clinical significance of a preventive intervention for disruptive boys: 15-year follow-up. Br J Psychiatry. Nov. 2007;191:415-9. X-5. [pmid: 17978321].
92 Bolstad OD, Johnson SM. Self-regulation in the modification of disruptive classroom behavior. J Appl Behav Anal. Winter. 1972;5(4):443-54. X-11. [pmid: 16795368].
93 Bolton P, Bass J, Betancourt T, et al. Interventions for depression symptoms among adolescent survivors of war and displacement in northern Uganda: a randomized controlled trial. JAMA. Aug. 1. 2007;298(5):519-27. X-4. [pmid: 17666672].
94 Bonin EM, Stevens M, Beecham J, et al. Costs and longer-term savings of parenting programmes for the prevention of persistent conduct disorder: a modelling study. BMC Public Health. 2011;11:803. X-1, X-7. [pmid: 21999434].
95 Borden LA, Herman KC, Stormont M, et al. Latent profile analysis of observed parenting behaviors in a clinic sample. J Abnorm Child Psychol. Jul. 2014;42(5):731-42. X-1, X-2, X-6. [pmid: 24141708].
96 Borduin CM, Schaeffer CM, Heiblum N. A randomized clinical trial of multisystemic therapy with juvenile sexual offenders: effects on youth social ecology and criminal activity. J Consult Clin Psychol. Feb. 2009;77(1):26-37. X-4. [pmid: 19170451].
97 Borowsky IW, Mozayeny S, Stuenkel K, et al. Effects of a primary care-based intervention on violent behavior and injury in children. Pediatrics. Oct. 2004;114(4):e392-9. X-4. [pmid: 15466063].
98 Borrero CS, Vollmer TR. Experimental analysis and treatment of multiply controlled problem behavior: a systematic replication and extension. J Appl Behav Anal. Fall. 2006;39(3):375-9. X-4, X-5, X-6, X-7, X-8. [pmid: 17020218].
99 Bowers L, Ross J, Nijman H, et al. The scope for replacing seclusion with time out in acute inpatient psychiatry in England. J Adv Nurs. Apr. 2012;68(4):826-35. X-2, X-3, X-4, X-5, X-6, X-7, X-8. [pmid: 21749438].
100 Boyle CL, Sanders MR, Lutzker JR, et al. Erratum to: An Analysis of Training, Generalization, and Maintenance Effects of Primary Care Triple P for Parents of Preschool-Aged Children with Disruptive Behavior. Child Psychiatry Hum Dev. 2014. Oct. 16. X-1. [pmid: 25319510].
101 Bradley C. Benzedrine and dexedrine in the treatment of children's behavior disorders. Pediatrics. Jan. 1950;5(1):24-37. X-11. [pmid: 15404645].
102 Brent DA, Perper JA, Moritz G, et al. Familial risk factors for adolescent suicide: a case-control study. Acta Psychiatr Scand. Jan. 1994;89(1):52-8. X-2. [pmid: 8140907].
103 Brestan EV, Jacobs JR, Rayfield AD, et al. A consumer satisfaction measure for parent–child treatments and its relation to measures of child behavior change. Behavior Therapy. 1999;30(1):17-30. X-6.
104 Broad J, Burke J, Byford SR, et al. Clinical application of the Children's Action Tendency Scale. Psychol Rep. Aug. 1986;59(1):71-4. X-11. [pmid: 3737819].
105 Brookman-Frazee L, Haine RA, Baker-Ericzen M, et al. Factors associated with use of evidence-based practice strategies in usual care youth psychotherapy. Adm Policy Ment Health. May. 2010;37(3):254-69. X-2, X-6, X-7, X-8. [pmid: 19795204].
106 Broota A, Sehgal R. Management of Conduct Disorders through Cognitive Behavioural Intervention. Psychological Studies. 2004;49(1):69-72. X-4.
107 Brotman LM, Dawson-McClure S, Gouley KK, et al. Older siblings benefit from a family-based preventive intervention for preschoolers at risk for conduct problems. J Fam Psychol. Dec. 2005;19(4):581-91. X-4. [pmid: 16402873].
108 Brotman LM, Gouley KK, Chesir-Teran D, et al. Prevention for preschoolers at high risk for conduct problems: immediate outcomes on parenting practices and child social competence. J Clin Child Adolesc Psychol. Dec. 2005;34(4):724-34. X-5, X-7. [pmid: 16232069].
109 Brotman LM, Gouley KK, Huang KY, et al. Effects of a psychosocial family-based preventive intervention on cortisol response to a social challenge in preschoolers at high risk for antisocial behavior. Arch Gen Psychiatry. Oct. 2007;64(10):1172-9. X-4. [pmid: 17909129].
110 Brotman LM, Gouley KK, Huang KY, et al. Preventive intervention for preschoolers at high risk for antisocial behavior: long-term effects on child physical aggression and parenting practices. J Clin Child Adolesc Psychol. Apr. 2008;37(2):386-96. X-5. [pmid: 18470775].
111 Brotman LM, Klein RG, Kamboukos D, et al. Preventive intervention for urban, low-income preschoolers at familial risk for conduct problems: a randomized pilot study. J Clin Child Adolesc Psychol. Jun. 2003;32(2):246-57. X-4, X-6, X-8. [pmid: 12679283].
112 Brotman LM, O'Neal CR, Huang KY, et al. An experimental test of parenting practices as a mediator of early childhood physical aggression. J Child Psychol Psychiatry. Mar. 2009;50(3):235-45. X-4. [pmid: 19220626].
113 Brown TL, Henggeler SW, Schoenwald SK, et al. Multisystemic treatment of substance abusing and dependent juvenile delinquents: Effects on school attendance at posttreatment and 6-month follow-up. Children's Services: Social Policy, Research, & Practice. 1999;2(2):81-93. X-10.
114 Bruggen P, Westland P. Difficult to place adolescents. Are more resources required?. J Adolesc. Sep. 1979;2(3):245-50. X-11. [pmid: 512128].
115 Budman C, Coffey BJ, Shechter R, et al. Aripiprazole in children and adolescents with Tourette disorder with and without explosive outbursts. J Child Adolesc Psychopharmacol. Oct. 2008;18(5):509-15. X-4, X-6. [pmid: 18928415].
116 Budney AJ, Hughes JR, Moore BA, et al. Marijuana abstinence effects in marijuana smokers maintained in their home environment. Arch Gen Psychiatry. Oct. 2001;58(10):917-24. X-2, X-4. [pmid: 11576029].
117 Buitelaar JK, van der Gaag RJ, Cohen-Kettenis P, et al. A randomized controlled trial of risperidone in the treatment of aggression in hospitalized adolescents with subaverage cognitive abilities. J Clin Psychiatry. Apr. 2001;62(4):239-48. X-5. [pmid: 11379837].
118 Bulinski L. Post accessive social policy in the rehabilitation of adolescents following TBI. Med Sci Monit. Jan. 2011;17(1):CR14-25. X-4, X-6. [pmid: 21169906].
119 Burdon AP, Neely JH. Chronic school failure in boys: a short-term group therapy and educational approach. Am J Psychiatry. May. 1966;122(11):1211-9. X-11. [pmid: 5909449].
120 Burke K, Brennan L, Cann W. Promoting protective factors for young adolescents: ABCD Parenting Young Adolescents Program randomized controlled trial. J Adolesc. Oct. 2012;35(5):1315-28. X-4. [pmid: 22677166].
121 Burke RV, Howard MR, Peterson JL, et al. Visual performance feedback: effects on targeted and nontargeted staff. Behav Modif. Sep. 2012;36(5):687-704. X-2, X-3. [pmid: 22457341].
122 Burke RV, Kuhn BR, Peterson JL, et al. “Don't kick me out!”: Day treatment for two preschool children with severe behavior problems. Clinical Case Studies. 2010;9(1):28-40. X-6.
123 Burquest B. The violent girl. Adolescence. Winter. 1981;16(64):749-64. X-11. [pmid: 6120625].
124 Bywater T, Hutchings J, Linck P, et al. Incredible Years parent training support for foster carers in Wales: a multi-centre feasibility study. Child Care Health Dev. Mar. 2011;37(2):233-43. X-4. [pmid: 20854449].
125 Calarge CA, Nicol G, Xie D, et al. Correlates of weight gain during long-term risperidone treatment in children and adolescents. Child Adolesc Psychiatry Ment Health. 2012;6(1):21. X-4, X-6. [pmid: 22643087].
126 Caldwell CH, Rafferty J, Reischl TM, et al. Enhancing parenting skills among nonresident African American fathers as a strategy for preventing youth risky behaviors. Am J Community Psychol. Mar. 2010;45(1-2):17-35. X-4, X-5, X-6. [pmid: 20082239].
127 Caldwell MF, Malterer M, Umstead D, et al. A retrospective evaluation of adjunctive risperidone treatment in severely behaviorally disordered boys receiving psychosocial treatment. J Child Adolesc Psychopharmacol. Feb. 2008;18(1):34-43. X-5. [pmid: 18294087].
128 Calogeras RC, Camp NM. Drug use and aggression. Bull Menninger Clin. Jul. 1975;39(4):329-44. X-11. [pmid: 1156706].
129 Camp BW, Blom GE, Hebert F, et al. “Think aloud”: a program for developing self-control in young aggressive boys. J Abnorm Child Psychol. 1977;5(2):157-69. X-11. [pmid: 886092].
130 Campbell M, Adams PB, Small AM, et al. Lithium in hospitalized aggressive children with conduct disorder: a double-blind and placebo-controlled study. J Am Acad Child Adolesc Psychiatry. Apr. 1995;34(4):445-53. X-5. [pmid: 7751258].
131 Campbell M, Cohen IL, Small AM. Drugs in aggressive behavior. J Am Acad Child Psychiatry. Mar. 1982;21(2):107-17. X-11. [pmid: 7040529].
132 Campbell M, Fish B, Korein J, et al. Lithium and chlorpromazine: a controlled crossover study of hyperactive severely disturbed young children. J Autism Child Schizophr. Jul-Sep. 1972;2(3):234-63. X-11. [pmid: 4567547].
133 Cantwell DP. Hyperactivity and antisocial behavior. J Am Acad Child Psychiatry. Spring. 1978;17(2):252-62. X-11. [pmid: 659744].
134 Carlson GA, Lavelle J, Bromet EJ. Medication treatment in adolescents vs. adults with psychotic mania. J Child Adolesc Psychopharmacol. 1999;9(3):221-31. X-2, X-4. [pmid: 10521014].
135 Carr EG, Durand VM. Reducing behavior problems through functional communication training. J Appl Behav Anal. Summer. 1985;18(2):111-26. X-11. [pmid: 2410400].
136 Carrion VG, Kletter H, Weems CF, et al. Cue-centered treatment for youth exposed to interpersonal violence: a randomized controlled trial. J Trauma Stress. Dec. 2013;26(6):654-62. X-4. [pmid: 24490236].
137 Castellanos-Ryan N, Seguin JR, Vitaro F, et al. Impact of a 2-year multimodal intervention for disruptive 6-year-olds on substance use in adolescence: randomised controlled trial. Br J Psychiatry. 2013;203:188-95. X-4a. [pmid: 23929441].
138 Castillo SC, Holmes GR, Cuccaro ML, et al. Group intervention with second graders at risk for behavioral problems: a pilot study. Psychol Rep. Apr. 1997;80(2):415-8. X-5, X-6, X-7. [pmid: 9129361].
139 Cauce AM, Cruz R, Corona M, et al. The face of the future: risk and resilience in minority youth. Nebr Symp Motiv. 2011;57:13-32. X-1. [pmid: 21166303].
140 Cefai J, Smith D, Pushak RE. Parenting Wisely: Parent Training via CD-ROM with an Australian Sample. Child & Family Behavior Therapy. 2010/03/03. 2010;32(1):17-33. X-4.
141 Celani DP. A structural analysis of the obsessional character: a Fairbairnian perspective. Am J Psychoanal. Jun. 2007;67(2):119-40. X-1, X-2, X-4. [pmid: 17533379].
142 Chamberlain P, Leve LD, Degarmo DS. Multidimensional treatment foster care for girls in the juvenile justice system: 2-year follow-up of a randomized clinical trial. J Consult Clin Psychol. Feb. 2007;75(1):187-93. X-5. [pmid: 17295579].
143 Chamberlain P, Price J, Leve LD, et al. Prevention of behavior problems for children in foster care: outcomes and mediation effects. Prev Sci. Mar. 2008;9(1):17-27. X-4, X-5. [pmid: 18185995].
144 Chaplin JE, Kristrom B, Jonsson B, et al. Improvements in behaviour and self-esteem following growth hormone treatment in short prepubertal children. Horm Res Paediatr. 2011;75(4):291-303. X-4. [pmid: 21304250].
145 Chapple ED. Rehabilitation of character disturbed adolescents through productive participation. Rehabil Rec. Sep-Oct. 1973;14(5):1-7. X-11. [pmid: 4731738].
146 Chessick RD. The psychotherapy of borderland patients. Am J Psychother. Oct. 1966;20(4):600-14. X-11. [pmid: 5972567].
147 Chhangur RR, Weeland J, Overbeek G, et al. ORCHIDS: an observational randomized controlled trial on childhood differential susceptibility. BMC Public Health. 2012;12:917. X-1, X-4, X-7, X-8. [pmid: 23107225].
148 Choi AN, Lee MS, Lee JS. Group Music Intervention Reduces Aggression and Improves Self-esteem in Children with Highly Aggressive Behavior: A Pilot Controlled Trial. Evid Based Complement Alternat Med. Jun. 2010;7(2):213-7. X-5, X-8. [pmid: 18955314].
149 Chorpita BF, Weisz JR, Daleiden EL, et al. Long-Term Outcomes for the Child STEPs Randomized Effectiveness Trial: A Comparison of Modular and Standard Treatment Designs With Usual Care. J Consult Clin Psychol. 2013. Aug. 26. X-8. [pmid: 23978169].
150 Chronis-Tuscano A, O'Brien KA, Johnston C, et al. The relation between maternal ADHD symptoms & improvement in child behavior following brief behavioral parent training is mediated by change in negative parenting. Journal of Abnormal Child Psychology. 2011;39(7):1047-57. X-4, X-6, X-8. [pmid: 21537894].
151 Clark SE, Jerrott S. Effectiveness of Day Treatment for Disruptive Behaviour Disorders: What is the Long-term Clinical Outcome for Children?. J Can Acad Child Adolesc Psychiatry. Aug. 2012;21(3):204-12. X-4, X-6, X-8. [pmid: 22876266].
152 Coats KI. Cognitive self-instructional training approach for reducing disruptive behavior of young children. Psychol Rep. Feb. 1979;44(1):127-34. X-11. [pmid: 461602].
153 Coccaro EF, Kavoussi RJ, Hauger RL. Serotonin function and antiaggressive response to fluoxetine: a pilot study. Biol Psychiatry. Oct. 1. 1997;42(7):546-52. X-3. [pmid: 9376450].
154 Cohen M, Freedman N, Engelhardt DM, et al. Family interaction patterns, drug treatment, and change in social aggression. Arch Gen Psychiatry. Jul. 1968;19(1):50-6. X-11. [pmid: 5661009].
155 Cohen RL. DEVELOPMENTS IN THE ISOLATION THERAPY OF BEHAVIOR DISORDERS OF CHILDREN. Curr Psychiatr Ther. 1963;3:180-7. X-11. [pmid: 14284460].
156 Colmant SA, Merta RJ. Using the sweat lodge ceremony as group therapy for Navajo youth. Journal for Specialists in Group Work. 1999;24(1):55-73. X-2.
157 Conduct Problems Prevention Research G. The Difficulty of Maintaining Positive Intervention Effects: A Look at Disruptive Behavior, Deviant Peer Relations, and Social Skills During the Middle School Years. J Early Adolesc. Aug. 1. 2010;30(4). X-4. [pmid: 24319308].
158 Conduct Problems Prevention Research Group. Initial impact of the Fast Track prevention trial for conduct problems: I. The high-risk sample. Conduct Problems Prevention Research Group. J Consult Clin Psychol. Oct. 1999;67(5):631-47. X-5. [pmid: 10535230].
159 Conduct Problems Prevention Research Group. Evaluation of the first 3 years of the Fast Track prevention trial with children at high risk for adolescent conduct problems. J Abnorm Child Psychol. Feb. 2002;30(1):19-35. X-2, X-5. [pmid: 11930969].
160 Conduct Problems Prevention Research Group. Fast track randomized controlled trial to prevent externalizing psychiatric disorders: findings from grades 3 to 9. J Am Acad Child Adolesc Psychiatry. Oct. 2007;46(10):1250-62. X-5, X-6. [pmid: 17885566].
161 Conduct Problems Prevention Research Group. The effects of the fast track preventive intervention on the development of conduct disorder across childhood. Child Dev. Jan-Feb. 2011;82(1):331-45. X-4. [pmid: 21291445].
162 Connor DF, Findling RL, Kollins SH, et al. Effects of guanfacine extended release on oppositional symptoms in children aged 6-12 years with attention-deficit hyperactivity disorder and oppositional symptoms: A randomized, double-blind, placebo-controlled trial. CNS Drugs. 2010;24(9):755-68. X-4. [pmid: 20806988].
163 Cook MN, Crisostomo PS, Simpson TS, et al. Effectiveness of an intensive outpatient program for disruptive children: initial findings. Community Ment Health J. Feb. 2014;50(2):164-71. X-6. [pmid: 23299227].
164 Cooper LJ, Wacker DP, Sasso GM, et al. Using parents as therapists to evaluate appropriate behavior of their children: application to a tertiary diagnostic clinic. J Appl Behav Anal. Fall. 1990;23(3):285-96. X-11. [pmid: 2249965].
165 Copping VE, Warling DL, Benner DG, et al. A child trauma treatment pilot study. Journal of Child and Family Studies. 2001;10(4):467-75. X-4, X-6.
166 Corr PJ, Kumari V. Effect of D-amphetamine on emotion-potentiated startle in healthy humans: implications for psychopathy and antisocial behaviour. Psychopharmacology (Berl). Jan. 2013;225(2):373-9. X-2, X-3. [pmid: 22864946].
167 Costantino G, Malgady RG, Rogler LH. Storytelling through pictures: Culturally sensitive psychotherapy for Hispanic children and adolescents. Journal of Clinical Child Psychology. 1994;23(1):13-20. X-4, X-10.
168 Costin J, Chambers SM. Parent management training as a treatment for children with oppositional defiant disorder referred to a mental health clinic. Clin Child Psychol Psychiatry. Oct. 2007;12(4):511-24. X-6, X-8, X-10. [pmid: 18095534].
169 Cotter KL, Bacallao M, Smokowski PR, et al. Parenting Interventions Implementation Science: How Delivery Format Impacts the Parenting Wisely Program. Research on Social Work Practice. 2013. 1049731513490811. X-10.
170 Crane DR, Hillin HH, Jakubowski SF. Costs of Treating Conduct Disordered Medicaid Youth with and without Family Therapy. American Journal of Family Therapy. 2005;33(5):403-13. X-2, X-3, X-6, X-8.
171 Cueva JE, Overall JE, Small AM, et al. Carbamazepine in aggressive children with conduct disorder: a double-blind and placebo-controlled study. J Am Acad Child Adolesc Psychiatry. Apr. 1996;35(4):480-90. X-5. [pmid: 8919710].
172 Cunningham CE, Bremner R, Boyle M. Large group community-based parenting programs for families of preschoolers at risk for disruptive behaviour disorders: utilization, cost effectiveness, and outcome. J Child Psychol Psychiatry. Oct. 1995;36(7):1141-59. X-4a. [pmid: 8847377].
173 Cunningham MA, Pillai V, Rogers WJ. Haloperidol in the treatment of children with severe behaviour disorders. Br J Psychiatry. Jul. 1968;114(512):845-54. X-11. [pmid: 4874166].
174 Cunningham PB, Foster SL, Warner SE. Culturally relevant family-based treatment for adolescent delinquency and substance abuse: understanding within-session processes. J Clin Psychol. Aug. 2010;66(8):830-46. X-1, X-2, X-6, X-7, X-8. [pmid: 20564683].
175 Cunningham RM, Whiteside LK, Chermack ST, et al. Dating violence: outcomes following a brief motivational interviewing intervention among at-risk adolescents in an urban emergency department. Acad Emerg Med. Jun. 2013;20(6):562-9. X-4. [pmid: 23758302].
176 Curtis NM, Ronan KR, Borduin CM. Multisystemic treatment: a meta-analysis of outcome studies. J Fam Psychol. Sep. 2004;18(3):411-9. X-1. [pmid: 15382965].
177 Curtis NM, Ronan KR, Heiblum N, et al. Dissemination and effectiveness of multisystemic treatment in New Zealand: a benchmarking study. J Fam Psychol. Apr. 2009;23(2):119-29. X-5, X-6. [pmid: 19364207].
178 Da Fonseca D, Cury F, Santos A, et al. How to increase academic performance in children with oppositional defiant disorder? An implicit theory effect. J Behav Ther Exp Psychiatry. Sep. 2010;41(3):234-7. X-7, X-8. [pmid: 20170904].
179 Dadds MR, Cauchi AJ, Wimalaweera S, et al. Outcomes, moderators, and mediators of empathic-emotion recognition training for complex conduct problems in childhood. Psychiatry Res. Oct. 30. 2012;199(3):201-7. X-4. [pmid: 22703720].
180 Danforth JS. Altering the function of commands presented to boys with oppositional and hyperactive behavior. Anal Verbal Behav. 2002;18:31-49. X-6. [pmid: 22477227].
181 Dangel RF, Deschner JP, Rasp RR. Anger control training for adolescents in residential treatment. Behav Modif. Oct. 1989;13(4):447-58. X-11. [pmid: 2818462].
182 Davis DL, Boster LH. Cognitive-behavioral-expressive interventions with aggressive and resistant youths. Child Welfare. Nov-Dec. 1992;71(6):557-73. X-11. [pmid: 1424948].
183 Davis TN, Dacus S, Strickland E, et al. The effects of a weighted vest on aggressive and self-injurious behavior in a child with autism. Dev Neurorehabil. Jun. 2013;16(3):210-5. X-4, X-5, X-6, X-7, X-8. [pmid: 23278839].
184 Day C, Michelson D, Thomson S, et al. Evaluation of a peer led parenting intervention for disruptive behaviour problems in children: community based randomised controlled trial. BMJ. 2012;344:e1107. X-4. [pmid: 22416059].
185 de Koning P, Mak M, de Vries MH, et al. Eltoprazine in aggressive mentally handicapped patients: a double-blind, placebo- and baseline-controlled multi-centre study. The Eltoprazine Aggression Research Group. Int Clin Psychopharmacol. Sep. 1994;9(3):187-94. X-3, X-4. [pmid: 7814828].
186 Dean AJ, Bor W, Adam K, et al. A randomized, controlled, crossover trial of fish oil treatment for impulsive aggression in children and adolescents with disruptive behavior disorders. J Child Adolesc Psychopharmacol. Apr. 2014;24(3):140-8. X-2, X-8. [pmid: 24689967].
187 Degarmo DS, Forgatch MS. Efficacy of Parent Training for Stepfathers: From Playful Spectator and Polite Stranger to Effective Stepfathering. Parent Sci Pract. Nov. 2007;7(4):331-55. X-4. [pmid: 19173011].
188 DeGarmo DS, Patterson GR, Forgatch MS. How do outcomes in a specified parent training intervention maintain or wane over time?. Prev Sci. Jun. 2004;5(2):73-89. X-4. [pmid: 15134313].
189 Delva-Tauiliili J. Does brief Aikido training reduce aggression of youth?. Percept Mot Skills. Feb. 1995;80(1):297-8. X-8, X-10. [pmid: 7624209].
190 Devlin S, Healy O, Leader G, et al. Comparison of behavioral intervention and sensory-integration therapy in the treatment of challenging behavior. J Autism Dev Disord. Oct. 2011;41(10):1303-20. X-4, X-6, X-7, X-8. [pmid: 21161577].
191 Diego MA, Field T, Hernandez-Reif M, et al. Aggressive adolescents benefit from massage therapy. Adolescence. Fall. 2002;37(147):597-607. X-2. [pmid: 12458696].
192 Dishion TJ, Andrews DW. Preventing escalation in problem behaviors with high-risk young adolescents: immediate and 1-year outcomes. J Consult Clin Psychol. Aug. 1995;63(4):538-48. X-4. [pmid: 7673531].
193 Dishion TJ, Brennan LM, Shaw DS, et al. Prevention of Problem Behavior Through Annual Family Check-Ups in Early Childhood: Intervention Effects From Home to Early Elementary School. J Abnorm Child Psychol. 2013. Sep. 11. X-4. [pmid: 24022677].
194 Dishion TJ, Brennan LM, Shaw DS, et al. Prevention of problem behavior through annual family check-ups in early childhood: intervention effects from home to early elementary school. J Abnorm Child Psychol. 2014;42(3):343-54. X-4. [pmid: 24022677].
195 Dittman CK, Farruggia SP, Palmer ML, et al. Predicting success in an online parenting intervention: the role of child, parent, and family factors. J Fam Psychol. Apr. 2014;28(2):236-43. X-5, X-6. [pmid: 24611694].
196 Dodge KA, Godwin J. Social-information-processing patterns mediate the impact of preventive intervention on adolescent antisocial behavior. Psychol Sci. Apr. 2013;24(4):456-65. X-4a. [pmid: 23406610].
197 Dogra A, Veeraraghavan V. A study of psychological intervention of children with aggressive conduct disorder. Indian Journal of Clinical Psychology. 1994;21(1):28-32. X-10.
198 Donohue B, Azrin NH, Lawson H, et al. Improving initial session attendance of substance abusing and conduct disordered adolescents: A controlled study. Journal of Child & Adolescent Substance Abuse. 1998;8(1):1-13. X-2, X-7.
199 Doob AN, Wood LE. Catharsis and aggression: effects of annoyance and retaliation on aggressive behavior. J Pers Soc Psychol. May. 1972;22(2):156-62. X-11. [pmid: 5024076].
200 Doolittle JC. Immunizing children against possible antisocial effects of viewing television violence: a curricular intervention. Percept Mot Skills. Oct. 1980;51(2):498. X-11. [pmid: 7443368].
201 Dorn LD, Kolko DJ, Shenk CE, et al. Influence of treatment for disruptive behavior disorders on adrenal and gonadal hormones in youth. J Clin Child Adolesc Psychol. 2011;40(4):562-71. X-7. [pmid: 21722028].
202 Drabman R, Spitalnik R. Social isolation as a punishment procedure: a controlled study. J Exp Child Psychol. Oct. 1973;16(2):236-49. X-11. [pmid: 4773588].
203 Dubow EF, Huesmann LR, Eron LD. Mitigating aggression and promoting prosocial behavior in aggressive elementary schoolboys. Behav Res Ther. 1987;25(6):527-31. X-11. [pmid: 3426514].
204 Ducharme JM, Atkinson L, Poulton L. Success-based, noncoercive treatment of oppositional behavior in children from violent homes. J Am Acad Child Adolesc Psychiatry. Aug. 2000;39(8):995-1004. X-6, X-7. [pmid: 10939227].
205 Ducharme JM, Harris K, Milligan K, et al. Sequential evaluation of reinforced compliance and graduated request delivery for the treatment of noncompliance in children with developmental disabilities. J Autism Dev Disord. Oct. 2003;33(5):519-26. X-4. [pmid: 14594331].
206 Ducharme JM, Spencer T, Davidson A, et al. Errorless compliance training: building a cooperative relationship between parents with brain injury and their oppositional children. Am J Orthopsychiatry. Oct. 2002;72(4):585-95. X-4, X-6, X-7, X-8. [pmid: 15792043].
207 Dunbar F, Kusumakar V, Daneman D, et al. Growth and Sexual Maturation During Long-Term Treatment With Risperidone. The American Journal of Psychiatry. 2004;161(5):918-20. X-4. [pmid: 15121661].
208 Dunsmore JC, Booker JA, Ollendick TH. Parental Emotion Coaching and Child Emotion Regulation as Protective Factors for Children with Oppositional Defiant Disorder. Soc Dev. Aug. 1. 2013;22(3). X-2, X-5, X-6, X-7, X-8. [pmid: 24187441].
209 Dura-Vila G, Klasen H, Makatini Z, et al. Mental health problems of young refugees: duration of settlement, risk factors and community-based interventions. Clin Child Psychol Psychiatry. Oct. 2013;18(4):604-23. X-2, X-4, X-6. [pmid: 23104967].
210 Eames C, Daley D, Hutchings J, et al. The impact of group leaders' behaviour on parents acquisition of key parenting skills during parent training. Behav Res Ther. Dec. 2010;48(12):1221-6. X-3, X-7, X-8. [pmid: 20932512].
211 Eddy JM, Reid JB, Stoolmiller M, et al. Outcomes During Middle School for an Elementary School-Based Preventive Intervention for Conduct Problems: Follow-Up Results From a Randomized Trial. Behavior Therapy. 2003;34(4):535-52. X-4, X-5.
212 Edwards VE. Side effects of clonazepam therapy. Proc Aust Assoc Neurol. 1974;11:199-202. X-11. [pmid: 4219957].
213 Effron AS, Freedman AM. The treatment of behavior disorders in children with benadryl. J Pediatr. Feb. 1953;42(2):261-6. X-11. [pmid: 13023526].
214 Eisen P. Levels of psychotherapy: a study of intimacy. Aust N Z J Psychiatry. Sep. 1973;7(3):169-73. X-11. [pmid: 4520538].
215 Eisen P. The infantile roots of adolescent violence. Am J Psychoanal. Fall. 1976;36(3):211-8. X-11. [pmid: 1008101].
216 Elias LC, Marturano EM, Motta AM, et al. Treating boys with low school achievement and behavior problems: comparison of two kinds of intervention. Psychol Rep. Feb. 2003;92(1):105-16. X-4. [pmid: 12674267].
217 Ellis ML, Lindsey MA, Barker ED, et al. Predictors of engagement in a school-based family preventive intervention for youth experiencing behavioral difficulties. Prev Sci. Oct. 2013;14(5):457-67. X-5, X-6, X-7, X-8. [pmid: 23420474].
218 Eme R. Male life-course-persistent antisocial behavior: the most important pediatric mental health problem. Arch Pediatr Adolesc Med. May. 2010;164(5):486-7. X-1, X-2, X-3, X-4, X-5, X-6, X-7, X-8. [pmid: 20439801].
219 Endrass J, Rossegger A, Urbaniok F, et al. Procedures for preventing juvenile violence in Switzerland: the Zurich model. New Dir Youth Dev. Spring. 2011;2011(129):79-87. X-2, X-5, X-6, X-8. [pmid: 21491574].
220 Enebrink P, Hogstrom J, Forster M, et al. Internet-based parent management training: a randomized controlled study. Behav Res Ther. Apr. 2012;50(4):240-9. X-5. [pmid: 22398153].
221 Ercan ES, Akyol Ardic U, Kabukcu Basay B, et al. Atomoxetine response in the inattentive and combined subtypes of attention deficit hyperactivity disorder: a retrospective chart review. Atten Defic Hyperact Disord. Dec. 2013;5(4):377-85. X-4, X-6, X-8. [pmid: 23737214].
222 Ercan ES, Ardic UA, Kutlu A, et al. No Beneficial Effects of Adding Parent Training to Methylphenidate Treatment for ADHD + ODD/CD Children: A 1-Year Prospective Follow-Up Study. J Atten Disord. Apr. 20. 2014;18(2):145-57. X-4. [pmid: 22522574].
223 Ercan ES, Uysal T, Ercan E, et al. Aripiprazole in children and adolescents with conduct disorder: A single-center, open-label study. Pharmacopsychiatry. 2012;45(1):13-9. X-6. [pmid: 21993869].
224 Ercan ES, Varan A, Deniz Ü. Effects of Combined Treatment on Turkish Children Diagnosed with Attention-Deficit/Hyperactivity Disorder: A Preliminary Report. Journal of Child and Adolescent Psychopharmacology. 2005;15(2):203-19. X-4. [pmid: 15910205].
225 Erdogan A, Yurteri N. Aripiprazole treatment in the adolescent patients with inhalants use disorders and conduct disorder: A retrospective case analysis. Yeni Symposium: psikiyatri, nöroloji ve davraniş bilimleri dergisi. 2010;48(3):229-33. X-6, X-8.
226 Evans ME, Boothroyd RA, Greenbaum PE, et al. Outcomes associated with clinical profiles of children in psychiatric crisis enrolled in intensive, in-home interventions. Mental Health Services Research. 2001;3(1):35-44. X-6. [pmid: 11508561].
227 Eyberg S, Boggs S, Jaccard J. Does maintenance treatment matter?. J Abnorm Child Psychol. 2014;42(3):355-66. X-6. [pmid: 24413969].
228 Eyberg SM, Funderburk BW, Hembree-Kigin TL, et al. Parent-child interaction therapy with behavior problem children: One and two year maintenance of treatment effects in the family. Child & Family Behavior Therapy. 2001;23(4):1-20. X-6.
229 Eysbouts Y, Poulton A, Salmelainen P. Stimulant medication in pre-school children in New South Wales. J Paediatr Child Health. Dec. 2011;47(12):870-4. X-4, X-6, X-7. [pmid: 21658150].
230 Faretra G, Dooher L, Dowling J. Comparison of haloperidol and fluphenazine in disturbed children. Am J Psychiatry. May. 1970;126(11):1670-3. X-11. [pmid: 5443653].
231 Farmer CA, Arnold LE, Bukstein OG, et al. The treatment of severe child aggression (TOSCA) study: Design challenges. Child Adolesc Psychiatry Ment Health. 2011;5(1):36. X-1, X-2. [pmid: 22074813].
232 Fayyad JA, Farah L, Cassir Y, et al. Dissemination of an evidence-based intervention to parents of children with behavioral problems in a developing country. Eur Child Adolesc Psychiatry. Aug. 2010;19(8):629-36. X-5, X-6, X-8. [pmid: 20169380].
233 Feil EG, Gordon D, Waldron H, et al. Development and Pilot Testing of an Internet-based Parenting Education Program for Teens and Pre-Teens: Parenting Wisely. The Family Psychologist. 2011;27(22):22-6. X-5, X-6.
234 Fernandez MA, Butler AM, Eyberg SM. Treatment outcome for low socioeconomic status African American families in parent-child interaction therapy: A pilot study. Child & Family Behavior Therapy. 2011;33(1):32-48. X-6.
235 Fernandez MA, Eyberg SM. Predicting treatment and follow-up attrition in parent-child interaction therapy. J Abnorm Child Psychol. Apr. 2009;37(3):431-41. X-8. [pmid: 19096926].
236 Fernandez MA, Eyberg SM. Predicting treatment and follow-up attrition in parent–child interaction therapy. Journal of Abnormal Child Psychology. 2009;37(3):431-41. X-2, X-6, X-7, X-8. [pmid: 19096926].
237 Fernández-Mayoralas DM, Fernández-Jaén A, Muñoz-Jareño N, et al. Treatment with paliperidone in children with behavior disorders previously treated with risperidone: An open-label trial. Clinical Neuropharmacology. 2012;35(5):227-30. X-4, X-6. [pmid: 22935606].
238 Field CE, Nash HM, Handwerk ML, et al. A modification of the token economy for nonresponsive youth in family-style residential care. Behav Modif. May. 2004;28(3):438-57. X-5, X-6, X-8. [pmid: 15104871].
239 Fields EM. The effects of Deanol in children with organic and functional behavior disorders. N Y State J Med. Mar. 15. 1961;61:901-5. X-11. [pmid: 13699373].
240 Findling RL, Aman MG, Eerdekens M, et al. Long-term, open-label study of risperidone in children with severe disruptive behaviors and below-average IQ. Am J Psychiatry. Apr. 2004;161(4):677-84. X-4, X-6. [pmid: 15056514].
241 Findling RL, Kusumakar V, Daneman D, et al. Prolactin levels during long-term risperidone treatment in children and adolescents. J Clin Psychiatry. Nov. 2003;64(11):1362-9. X-4, X-6. [pmid: 14658952].
242 Findling RL, Mankoski R, Timko K, et al. A randomized controlled trial investigating the safety and efficacy of aripiprazole in the long-term maintenance treatment of pediatric patients with irritability associated with autistic disorder. J Clin Psychiatry. Jan. 2014;75(1):22-30. X-4. [pmid: 24502859].
243 Finkelstein JW, Susman EJ, Chinchilli VM, et al. Estrogen or testosterone increases self-reported aggressive behaviors in hypogonadal adolescents. J Clin Endocrinol Metab. Aug. 1997;82(8):2433-8. X-2, X-4. [pmid: 9253313].
244 Fish B. An approach to prevention in infants at risk for schizophrenia. Developmental deviations from birth to 10 years. J Am Acad Child Psychiatry. Winter. 1976;15(1):62-82. X-11. [pmid: 1254848].
245 Fisher DC, Wollersheim JP. Social reinforcement: a treatment component in verbal self-instructional training. J Abnorm Child Psychol. Mar. 1986;14(1):41-8. X-11. [pmid: 3950220].
246 Fisher WW, Thompson RH, Hagopian LP, et al. Facilitating tolerance of delayed reinforcement during functional communication training. Behav Modif. Jan. 2000;24(1):3-29. X-4, X-5, X-6, X-7. [pmid: 10641365].
247 Fleischman MJ. A replication of Patterson's “Intervention for boys with conduct problems”. J Consult Clin Psychol. Jun. 1981;49(3):342-51. X-11. [pmid: 7276323].
248 Fleisher SJ, Berkovitz IH, Briones L, et al. Antisocial behavior, school performance, and reactions to loss: the value of group counseling and communication skills training. Adolesc Psychiatry. 1987;14:546-55. X-11. [pmid: 3618939].
249 Forehand RL, Merchant MJ, Parent J, et al. An examination of a Group Curriculum for parents of young children with disruptive behavior. Behav Modif. May. 2011;35(3):235-51. X-4. [pmid: 21478243].
250 Forgatch MS, DeGarmo DS. Parenting through change: an effective prevention program for single mothers. J Consult Clin Psychol. Oct. 1999;67(5):711-24. X-4. [pmid: 10535238].
251 Forgatch MS, Degarmo DS, Beldavs ZG. An efficacious theory-based intervention for stepfamilies. Behav Ther. 2005;36(4):357-65. X-4. [pmid: 16718303].
252 Forgatch MS, Patterson GR, Degarmo DS, et al. Testing the Oregon delinquency model with 9-year follow-up of the Oregon Divorce Study. Dev Psychopathol. Spring. 2009;21(2):637-60. X-4. [pmid: 19338702].
253 Foster EM, Olchowski AE, Webster-Stratton CH. Is stacking intervention components cost-effective? An analysis of the Incredible Years program. J Am Acad Child Adolesc Psychiatry. Nov. 2007;46(11):1414-24. X-2a, X-7a. [pmid: 18049291].
254 Foster RM. Parenting the child with a behavior disorder: a family approach. Pediatr Ann. Oct. 1977;6(10):637-45. X-11. [pmid: 909733].
255 Fraiberg S. Technical aspects of the analysis of a child with a severe behavior disorder. J Am Psychoanal Assoc. Apr. 1962;10:338-67. X-11. [pmid: 13894444].
256 Frampton I, McArthur C, Crowe B, et al. Beyond parent training: predictors of clinical status and service use two to three years after Scallywags. Clin Child Psychol Psychiatry. Oct. 2008;13(4):593-608. X-4a. [pmid: 18927143].
257 Frankel F, Myatt R, Cantwell DP, et al. Parent-assisted transfer of children's social skills training: effects on children with and without attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. Aug. 1997;36(8):1056-64. X-4. [pmid: 9256585].
258 Fraone G, Wilson S, Casamassimo PS, et al. The effect of orally administered midazolam on children of three age groups during restorative dental care. Pediatr Dent. Jul-Aug. 1999;21(4):235-41. X-4, X-6. [pmid: 10436477].
259 Freedman AM, Kremer MW, Robertiello R, et al. The treatment of behavior disorders in children with tolserol. J Pediatr. Sep. 1955;47(3):369-72. X-11. [pmid: 13252532].
260 Freitag C. Neurobiology and treatment of adolescent female conduct disorder: FemNAT-CD consortium: a new European cooperation. Eur Child Adolesc Psychiatry. Aug. 2014;23(8):723-4. X-1. [pmid: 24682583].
261 Fried RI, Sherman J. Self-help for troubled teens: Delancey Street in the desert. Ohio Med. Mar. 1991;87(3):95-6. X-11. [pmid: 2030889].
262 Frölich J, Döpfner M, Berner W, et al. Behandlungseffekte kombinierter kognitiver Verhaltenstherapie mit Elterntraining bei hyperkinetischen Kindern. Praxis der Kinderpsychologie und Kinderpsychiatrie. 2002;51(6):476-93. X-6, X-10. [pmid: 12235712].
263 Funderburk BW, Eyberg SM, Newcomb K, et al. Parent–child interaction therapy with behavior problem children: Maintenance of treatment effects in the school setting. Child & Family Behavior Therapy. 1998;20(2):17-38. X-6.
264 Fung AL. Intervention for aggressive victims of school bullying in Hong Kong: a longitudinal mixed-methods study. Scand J Psychol. Aug. 2012;53(4):360-7. X-5, X-6. [pmid: 22670574].
265 Furlong M, McGilloway S. The longer term experiences of parent training: a qualitative analysis. Child Care Health Dev. 2014. Sep. 24. X-2, X-7. [pmid: 25256901].
266 Gabel S, Swanson AJ, Shindledecker R. Aggressive children in a day treatment program: changed outcome and possible explanations. Child Abuse Negl. 1990;14(4):515-23. X-11. [pmid: 2289182].
267 Gada SS, Kanumakala S. Helping parents solve stressful life problems enhances the effectiveness of interventions for child aggression and antisocial behaviour. Evid Based Ment Health. Nov. 2003;6(4):120. X-1. [pmid: 14585793].
268 Gadow KD, Arnold LE, Molina BS, et al. Risperidone added to parent training and stimulant medication: effects on attention-deficit/hyperactivity disorder, oppositional defiant disorder, conduct disorder, and peer aggression. J Am Acad Child Adolesc Psychiatry. Sep. 2014;53(9):948-59.e1. X-4. [pmid: 25151418].
269 Gadow KD, Nolan EE. Methylphenidate and comorbid anxiety disorder in children with both chronic multiple tic disorder and ADHD. J Atten Disord. Apr. 2011;15(3):246-56. X-4. [pmid: 20378921].
270 Gadow KD, Nolan EE, Sverd J. Methylphenidate in hyperactive boys with comorbid tic disorder: II. Short-term behavioral effects in school settings. J Am Acad Child Adolesc Psychiatry. May. 1992;31(3):462-71. X-11. [pmid: 1592778].
271 Gadow KD, Nolan EE, Sverd J, et al. Methylphenidate in aggressive-hyperactive boys: I. Effects on peer aggression in public school settings. J Am Acad Child Adolesc Psychiatry. Sep. 1990;29(5):710-8. X-11. [pmid: 2228923].
272 Garcia D, Bagner DM, Pruden SM, et al. Language Production in Children With and At Risk for Delay: Mediating Role of Parenting Skills. J Clin Child Adolesc Psychol. Apr. 2014;30:1-12. X-7, X-8. [pmid: 24787263].
273 Gardner F, Shaw DS, Dishion TJ, et al. Randomized prevention trial for early conduct problems: effects on proactive parenting and links to toddler disruptive behavior. J Fam Psychol. Sep. 2007;21(3):398-406. X-5, X-6. [pmid: 17874925].
274 Gardner FE. Positive interaction between mothers and conduct-problem children: is there training for harmony as well as fighting?. J Abnorm Child Psychol. Jun. 1987;15(2):283-93. X-11. [pmid: 3611525].
275 Gardner HL, Forehand R, Roberts M. Time-out with children. Effects of an explanation and brief parent training on child and parent behaviors. J Abnorm Child Psychol. 1976;4(3):277-88. X-11. [pmid: 972210].
276 Garland AF, Accurso EC, Haine-Schlagel R, et al. Searching for elements of evidence-based practices in children's usual care and examining their impact. J Clin Child Adolesc Psychol. 2014;43(2):201-15. X-6. [pmid: 24555882].
277 Garland EJ, Kutcher S, Virani A. 2008 position paper on using SSRIs in children and adolescents. Journal of the Canadian Academy of Child and Adolescent Psychiatry. 2009;18(2):160-5. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19495439].
278 Garner B, Phillips LJ, Schmidt HM, et al. Pilot study evaluating the effect of massage therapy on stress, anxiety and aggression in a young adult psychiatric inpatient unit. Aust N Z J Psychiatry. May. 2008;42(5):414-22. X-4, X-5. [pmid: 18478478].
279 Garza-Trevino ES, Hollister LE, Overall JE, et al. Efficacy of combinations of intramuscular antipsychotics and sedative-hypnotics for control of psychotic agitation. Am J Psychiatry. Dec. 1989;146(12):1598-601. X-11. [pmid: 2686478].
280 Gauvain M, Perez SM. Mother-child planning and child compliance. Child Dev. May-Jun. 2008;79(3):761-75. X-2, X-4. [pmid: 18489426].
281 Gerra G, Zaimovic A, Giucastro G, et al. Serotonergic function after (+/-)3,4-methylene-dioxymethamphetamine (‘Ecstasy’) in humans. Int Clin Psychopharmacol. Jan. 1998;13(1):1-9. X-2, X-3, X-4. [pmid: 9988361].
282 Gershon ES. Antisocial behavior. Arch Gen Psychiatry. Nov. 1995;52(11):900-1. X-1. [pmid: 7487338].
283 Gersten JC, Langner TS, Eisenberg JG, et al. Stability and change in types of behavioral disturbance of children and adolescents. J Abnorm Child Psychol. 1976;4(2):111-27. X-11. [pmid: 1084892].
284 Gervan S, Granic I, Solomon T, et al. Paternal involvement in Multisystemic Therapy: effects on adolescent outcomes and maternal depression. J Adolesc. Jun. 2012;35(3):743-51. X-2. [pmid: 22104757].
285 Gibbs A, Moor S, Frampton C, et al. Impact of psychosocial interventions on children with disruptive and emotional disorders treated in a health camp. Aust N Z J Psychiatry. Sep. 2008;42(9):789-99. X-5, X-6. [pmid: 18696283].
286 Giovannetti A, Trombetta N. Pretreatment of problem youths with clozapin in preparation for group psychotherapy. Pharmakopsychiatr Neuropsychopharmakol. Sep. 1974;7(5):230-6. X-11. [pmid: 4445196].
287 Gladstone T. Brief, personality-targeted, teacher-delivered CBT interventions reduce depression, anxiety and conduct disorder symptoms in high-risk adolescents. Evid Based Ment Health. 2013. Nov. 28. X-4, X-5, X-8. [pmid: 24288201].
288 Glavin J, Witt PA. Recreation for the conduct disorder child. Except Child. Summer. 1969;35(10):787-91. X-11. [pmid: 5808752].
289 Glennon J, Purper-Ouakil D, Bakker M, et al. Paediatric European Risperidone Studies (PERS): context, rationale, objectives, strategy, and challenges. Eur Child Adolesc Psychiatry. Dec. 2014;23(12):1149-60. X-1. [pmid: 24337449].
290 Glod CA, Teicher MH, Butler M, et al. Modifying quiet room design enhances calming of children and adolescents. J Am Acad Child Adolesc Psychiatry. May. 1994;33(4):558-66. X-5. [pmid: 8005909].
291 Goldbeck L, Schmid K. Effectiveness of autogenic relaxation training on children and adolescents with behavioral and emotional problems. J Am Acad Child Adolesc Psychiatry. Sep. 2003;42(9):1046-54. X-4, X-6, X-8. [pmid: 12960704].
292 Goldstein AP, Sherman M, Gershaw NJ, et al. Training aggressive adolescents in prosocial behavior. J Youth Adolesc. Mar. 1978;7(1):73-92. X-11. [pmid: 24408723].
293 Golubchik P, Sever J, Zalsman G, et al. Methylphenidate in the treatment of female adolescents with cooccurrence of attention deficit/hyperactivity disorder and borderline personality disorder: a preliminary open-label trial. Int Clin Psychopharmacol. Jul. 2008;23(4):228-31. X-4. [pmid: 18446088].
294 Gomez D, Bridges AJ, Andrews AR III, et al. Delivering parent management training in an integrated primary care setting: Description and preliminary outcome data. Cognitive and Behavioral Practice. 2014;21(3):296-309. X-6.
295 Gottfredson D, Kumpfer K, Polizzi-Fox D, et al. The Strengthening Washington D.C. Families project: a randomized effectiveness trial of family-based prevention. Prev Sci. Mar. 2006;7(1):57-74. X-4, X-5, X-8. [pmid: 16555144].
296 Graham-Bermann SA, Howell KH, Lilly M, et al. Mediators and moderators of change in adjustment following intervention for children exposed to intimate partner violence. J Interpers Violence. Jun. 2011;26(9):1815-33. X-4, X-6, X-8. [pmid: 20587468].
297 Granic I, O'Hara A, Pepler D, et al. A dynamic systems analysis of parent-child changes associated with successful “real-world” interventions for aggressive children. J Abnorm Child Psychol. Oct. 2007;35(5):845-57. X-5, X-6. [pmid: 17549621].
298 Grasmann D, Stadler C. VIA—Intensivtherapeutischer behandlungsansatz bei störungen des sozialverhaltens. Zeitschrift für Kinder- und Jugendpsychiatrie und Psychotherapie. 2011;39(1):23-31. X-10, X-12. [pmid: 21267948].
299 Green JM, Wood AJ, Kerfoot MJ, et al. Group therapy for adolescents with repeated self harm: randomised controlled trial with economic evaluation. BMJ. 2011;342:d682. X-4. [pmid: 21459975].
300 Greenbaum PE, Turner C, Cook EW 3rd, et al. Dentists' voice control: effects on children's disruptive and affective behavior. Health Psychol. 1990;9(5):546-58. X-11. [pmid: 2226384].
301 Grizenko N. Outcome of multimodal day treatment for children with severe behavior problems: A five-year follow-up. Journal of the American Academy of Child & Adolescent Psychiatry. 1997;36(7):989-97. X-6. [pmid: 9204678].
302 Grizenko N, Papineau D, Sayegh L. A comparison of day treatment and outpatient treatment for children with disruptive behaviour problems. Can J Psychiatry. Aug. 1993;38(6):432-5. X-11. [pmid: 8402437].
303 Grizenko N, Sayegh L. Evaluation of the effectiveness of a psychodynamically oriented day treatment program for children with behaviour problems: a pilot study. Can J Psychiatry. Aug. 1990;35(6):519-25. X-11. [pmid: 2207986].
304 Groenman AP, Oosterlaan J, Rommelse NN, et al. Stimulant treatment for attention-deficit hyperactivity disorder and risk of developing substance use disorder. Br J Psychiatry. Aug. 2013;203(2):112-9. X-4, X-7, X-8. [pmid: 23846996].
305 Gross D, Fogg L, Webster-Stratton C, et al. Parent training of toddlers in day care in low-income urban communities. J Consult Clin Psychol. Apr. 2003;71(2):261-78. X-4. [pmid: 12699021].
306 Gross DA, Belcher HM, Ofonedu ME, et al. Study protocol for a comparative effectiveness trial of two parent training programs in a fee-for-service mental health clinic: can we improve mental health services to low-income families?. Trials. 2014;15:70. X-1. [pmid: 24581245].
307 Grow LL, Kelley ME, Roane HS, et al. Utility of extinction-induced response variability for the selection of mands. J Appl Behav Anal. Spring. 2008;41(1):15-24. X-4, X-6, X-8. [pmid: 18468276].
308 Guez G, Gill-Lev I. A psychoeducational group for adolescent girls to facilitate egalitarian, non-abusive relationships. Int J Group Psychother. Jul. 2009;59(3):385-405. X-2, X-4. [pmid: 19548786].
309 Gundersen K, Svartdal F. Aggression replacement training in Norway: Outcome evaluation of 11 Norwegian student projects. Scandinavian journal of educational research. 2006;50(1):63-81. X-4.
310 Günther T, Herpertz-Dahlmann B, Jolles J, et al. The Influence of Risperidone on Attentional Functions in Children and Adolescents with Attention-Deficit/Hyperactivity Disorder and Co-Morbid Disruptive Behavior Disorder. Journal of Child and Adolescent Psychopharmacology. 2006;16(6):725-35. X-4, X-6. [pmid: 17201616].
311 Gustafsson PA, Birberg-Thornberg U, Duchen K, et al. EPA supplementation improves teacher-rated behaviour and oppositional symptoms in children with ADHD. Acta Paediatr. Oct. 2010;99(10):1540-9. X-4, X-8. [pmid: 20491709].
312 Gustle LH, Hansson K, Sundell K, et al. Blueprints in Sweden. Symptom load in Swedish adolescents in studies of Functional Family Therapy (FFT), Multisystemic Therapy (MST) and Multidimensional Treatment Foster Care (MTFC). Nord J Psychiatry. 2007;61(6):443-51. X-1, X-2, X-6, X-7. [pmid: 18236311].
313 Gutstein RR. Percutaneous tuberculin therapy in behavior disorders of children. J Indiana State Med Assoc. Mar. 1946;39:113-5. X-11. [pmid: 21016328].
314 Guttman HA. The child's participation in conjoint family therapy. J Am Acad Child Psychiatry. Summer. 1975;14(3):490-9. X-11. [pmid: 1141568].
315 Guzder J, Paisley V, Robertson-Hickling H, et al. Promoting Resilience in High-risk Children in Jamaica: A Pilot Study of a Multimodal Intervention. J Can Acad Child Adolesc Psychiatry. May. 2013;22(2):125-30. X-5. [pmid: 23667358].
316 Gvozdjakova A, Kucharska J, Ostatnikova D, et al. Ubiquinol improves symptoms in children with autism. Oxid Med Cell Longev. 2014;2014:798957. X-4, X-6. [pmid: 24707344].
317 Haas M, Karcher K, Pandina GJ. Treating disruptive behavior disorders with risperidone: a 1-year, open-label safety study in children and adolescents. J Child Adolesc Psychopharmacol. Aug. 2008;18(4):337-45. X-6. [pmid: 18759643].
318 Haas SM, Waschbusch DA, Pelham WE Jr., et al. Treatment response in CP/ADHD children with callous/unemotional traits. J Abnorm Child Psychol. May. 2011;39(4):541-52. X-2, X-4, X-6. [pmid: 21188627].
319 Haine-Schlagel R, Fettes DL, Garcia AR, et al. Consistency with Evidence-Based Treatments and Perceived Effectiveness of Children's Community-Based Care. Community Ment Health J. 2013. Jan. 8. X-2, X-3, X-6, X-8. [pmid: 23296551].
320 Haine-Schlagel R, Fettes DL, Garcia AR, et al. Consistency with evidence-based treatments and perceived effectiveness of children's community-based care. Community Ment Health J. Feb. 2014;50(2):158-63. X-1, X-6. [pmid: 23296551].
321 Hall S, Warren ME. Teaching to improve parent-child interaction: an educational case study. Acad Psychiatry. Nov. 1. 2012;36(6):465-7. X-2, X-3, X-4, X-6, X-7, X-8. [pmid: 23154694].
322 Halldorsdottir T, Ollendick TH, Ginsburg G, et al. Treatment Outcomes in Anxious Youth with and without Comorbid ADHD in the CAMS. J Clin Child Adolesc Psychol. Oct. 2014;13:1-7. X-4. [pmid: 25310142].
323 Hamilton J. Taming the ‘monster child’. Tips for handling behavior problems. Dent Teamwork. Sep-Oct. 1995;8(5):47-9. X-10. [pmid: 9485694].
324 Hamilton JD. The practical search. J Am Acad Child Adolesc Psychiatry. Mar. 2007;46(3):418-22. X-1, X-2. [pmid: 17314728].
325 Hammond JE. DRUGS FOR TREATMENT OF CHILDREN WITH BEHAVIOR DISORDERS: TOWARD A MORE SPECIFIC USE OF THEM. Med Times. May. 1964;92:421-6. X-11. [pmid: 14146040].
326 Handen BL, Hardan AY. Open-label, prospective trial of olanzapine in adolescents with subaverage intelligence and disruptive behavioral disorders. J Am Acad Child Adolesc Psychiatry. Aug. 2006;45(8):928-35. X-4, X-6. [pmid: 16865035].
327 Hanisch C, Freund-Braier I, Hautmann C, et al. Detecting effects of the indicated prevention Programme for Externalizing Problem behaviour (PEP) on child symptoms, parenting, and parental quality of life in a randomized controlled trial. Behav Cogn Psychother. Jan. 2010;38(1):95-112. X-7b. [pmid: 19995467].
328 Hanish LD, Tolan PH. Patterns of change in family-based aggression prevention. J Marital Fam Ther. Apr. 2001;27(2):213-26. X-4. [pmid: 11314554].
329 Hanley GP, Piazza CC, Fisher WW, et al. On the effectiveness of and preference for punishment and extinction components of function-based interventions. J Appl Behav Anal. Spring. 2005;38(1):51-65. X-4, X-5, X-6, X-8. [pmid: 15898474].
330 Hansson K, Olsson M, Cederblad M. A salutogenic investigation and treatment of conduct disorder (CD). Nord J Psychiatry. 2004;58(1):5-16. X-2, X-6. [pmid: 14985149].
331 Harrison-Woolrych M, Garcia-Quiroga J, Ashton J, et al. Safety and usage of atypical antipsychotic medicines in children: a nationwide prospective cohort study. Drug Saf. 2007;30(7):569-79. X-2, X-6. [pmid: 17604408].
332 Harwood MD, Eyberg SM. Therapist verbal behavior early in treatment: relation to successful completion of parent-child interaction therapy. J Clin Child Adolesc Psychol. Sep. 2004;33(3):601-12. X-2, X-3, X-6, X-7. [pmid: 15271617].
333 Harwood MD, Eyberg SM. Child-directed interaction: prediction of change in impaired mother-child functioning. J Abnorm Child Psychol. Jun. 2006;34(3):335-47. X-6. [pmid: 16708275].
334 Hautmann C, Hoijtink H, Eichelberger I, et al. One-year follow-up of a parent management training for children with externalizing behaviour problems in the real world. Behav Cogn Psychother. Jul. 2009;37(4):379-96. X-6, X-8. [pmid: 19619384].
335 Havighurst SS, Duncombe M, Frankling E, et al. An Emotion-Focused Early Intervention for Children with Emerging Conduct Problems. J Abnorm Child Psychol. 2014. Sep. 25. X-5. [pmid: 25249470].
336 Hawes DJ, Dadds MR. The treatment of conduct problems in children with callous-unemotional traits. J Consult Clin Psychol. Aug. 2005;73(4):737-41. X-6, X-8. [pmid: 16173862].
337 Hawes DJ, Dadds MR. Stability and malleability of callous-unemotional traits during treatment for childhood conduct problems. J Clin Child Adolesc Psychol. Jul-Sep. 2007;36(3):347-55. X-6. [pmid: 17658979].
338 Hawes DJ, Dadds MR, Brennan J, et al. Revisiting the treatment of conduct problems in children with callous-unemotional traits. Aust N Z J Psychiatry. Jul. 2013;47(7):646-53. X-2, X-6, X-7, X-8. [pmid: 23574876].
339 Hawkins RO, Axelrod MI. Increasing the on-task homework behavior of youth with behavior disorders using functional behavioral assessment. Behav Modif. Nov. 2008;32(6):840-59. X-6, X-8. [pmid: 18490267].
340 Hazell P, Becker K, Nikkanen EA, et al. Relationship between atomoxetine plasma concentration, treatment response and tolerability in attention-deficit/hyperactivity disorder and comorbid oppositional defiant disorder. Atten Defic Hyperact Disord. Dec. 2009;1(2):201-10. X-7. [pmid: 20234828].
341 Hazell P, Zhang S, Wolańczyk T, et al. Comorbid oppositional defiant disorder and the risk of relapse during 9 months of atomoxetine treatment for attention-deficit/hyperactivity disorder. European Child & Adolescent Psychiatry. 2006;15(2):105-10. X-4. [pmid: 16523251].
342 Heath GA, Gayton WF, Hardesty VA. Childhood firesetting. Can Psychiatr Assoc J. Jun. 1976;21(4):229-37. X-11. [pmid: 963672].
343 Hektner JM, August GJ, Bloomquist ML, et al. A 10-year randomized controlled trial of the Early Risers conduct problems preventive intervention: effects on externalizing and internalizing in late high school. J Consult Clin Psychol. Apr. 2014;82(2):355-60. X-5. [pmid: 24447007].
344 Hemphill SA, Littlefield L. Evaluation of a short-term group therapy program for children with behavior problems and their parents. Behav Res Ther. Jul. 2001;39(7):823-41. X-4. [pmid: 11419613].
345 Hemphill SA, Littlefield L. Child and family predictors of therapy outcome for children with behavioral and emotional problems. Child Psychiatry Hum Dev. Spring. 2006;36(3):329-49. X-2, X-6. [pmid: 16362239].
346 Hemphill SA, Tollit M, Herrenkohl TI. Protective Factors Against the Impact of School Bullying Perpetration and Victimization on Young Adult Externalizing and Internalizing Problems. J Sch Violence. 2014;13(1):125-45. X-2. [pmid: 25419190].
347 Hendriks V, van der Schee E, Blanken P. Matching adolescents with a cannabis use disorder to multidimensional family therapy or cognitive behavioral therapy: treatment effect moderators in a randomized controlled trial. Drug Alcohol Depend. Sep. 1. 2012;125(1-2):119-26. X-4. [pmid: 22560728].
348 Henggeler SW, Letourneau EJ, Chapman JE, et al. Mediators of change for multisystemic therapy with juvenile sexual offenders. J Consult Clin Psychol. Jun. 2009;77(3):451-62. X-4. [pmid: 19485587].
349 Henneberger AK, Varga SM, Moudy A, et al. Family Functioning and High Risk Adolescents' Aggressive Behavior: Examining Effects by Ethnicity. J Youth Adolesc. 2014. Nov. 22. X-2, X-5. [pmid: 25416227].
350 Herbert SD, Harvey EA, Roberts JL, et al. A randomized controlled trial of a parent training and emotion socialization program for families of hyperactive preschool-aged children. Behav Ther. Jun. 2013;44(2):302-16. X-4, X-8. [pmid: 23611079].
351 Herman KC, Borden LA, Reinke WM, et al. The Impact of the Incredible Years Parent, Child, and Teacher Training Programs on Children's Co-Occurring Internalizing Symptoms. Sch Psychol Q. Sep. 2011;26(3):189-201. X-2, X-7. [pmid: 25197205].
352 Herman KC, Reinke WM, Bradshaw CP, et al. Integrating the Family Check-Up and the parent Coping Power program. Adv Sch Ment Health Promot. Jul. 1. 2012;5(3):208-19. X-1. [pmid: 23585776].
353 Hibel LC, Granger DA, Cicchetti D, et al. Salivary biomarker levels and diurnal variation: associations with medications prescribed to control children's problem behavior. Child Dev. May-Jun. 2007;78(3):927-37. X-2, X-4. [pmid: 17517013].
354 Hilton RC, Rengasamy M, Mansoor B, et al. Impact of treatments for depression on comorbid anxiety, attentional, and behavioral symptoms in adolescents with selective serotonin reuptake inhibitor-resistant depression. J Am Acad Child Adolesc Psychiatry. May. 2013;52(5):482-92. X-8. [pmid: 23622849].
355 Hinshaw SP, Owens EB, Wells KC, et al. Family processes and treatment outcome in the MTA: negative/ineffective parenting practices in relation to multimodal treatment. J Abnorm Child Psychol. Dec. 2000;28(6):555-68. X-4. [pmid: 11104317].
356 Hintikka U, Viinamaki H, Pelkonen M, et al. Clinical recovery in cognitive functioning and self-image among adolescents with major depressive disorder and conduct disorder during psychiatric inpatient care. Am J Orthopsychiatry. Apr. 2003;73(2):212-22. X-2, X-5, X-6, X-7, X-8. [pmid: 12769242].
357 Hirschberg W. Sozialtherapie bei Jugendlichen mit Störungen des Sozialverhaltens—Ergebnisse und Katamnesen. Praxis der Kinderpsychologie und Kinderpsychiatrie. 1999;48(4):247-59. X-6, X-10. [pmid: 10409873].
358 Högström J, Enebrink P, Ghaderi A. The moderating role of child callous-unemotional traits in an Internet-based parent-management training program. Journal of Family Psychology. 2013;27(2):314-23. X-5. [pmid: 23458700].
359 Hogstrom J, Enebrink P, Melin B, et al. Eighteen-Month Follow-Up of Internet-Based Parent Management Training for Children with Conduct Problems and the Relation of Homework Compliance to Outcome. Child Psychiatry Hum Dev. 2014. Sep. 19. X-5. [pmid: 25236326].
360 Hogue A, Dauber S. Assessing fidelity to evidence-based practices in usual care: the example of family therapy for adolescent behavior problems. Eval Program Plann. Apr. 2013;37:21-30. X-2, X-7, X-8. [pmid: 23314000].
361 Holtrop K, McNeil Smith S, Scott JC. Associations between Positive Parenting Practices and Child Externalizing Behavior in Underserved Latino Immigrant Families. Fam Process. 2014. Oct. 6. X-2, X-4. [pmid: 25287585].
362 Horner RH, Day HM, Sprague JR, et al. Interspersed requests: a nonaversive procedure for reducing aggression and self-injury during instruction. J Appl Behav Anal. Summer. 1991;24(2):265-78. X-11. [pmid: 1890047].
363 Hornsveld RHJ, Nijman HLI, Hollin CR, et al. Aggression control therapy for violent forensic psychiatric patients: Method and clinical practice. International Journal of Offender Therapy and Comparative Criminology. 2008;52(2):222-33. X-1, X-10. [pmid: 17636205].
364 Horowitz B, Pawel MA, O'Connor P. Frontline reports: the August Aichhorn Center for Adolescent Residential Care. Psychiatr Serv. Oct. 2001;52(10):1391-2. X-1, X-2, X-5, X-6, X-7. [pmid: 11585959].
365 Hudley C, Friday J. Attributional bias and reactive aggression. Am J Prev Med. Sep-Oct. 1996;12(5 Suppl):75-81. X-5. [pmid: 8909627].
366 Huessy HR, Wright AL. The use of imipramine in children's behavior disorders. Acta Paedopsychiatr. Dec. 1970;37(7):194-9. X-11. [pmid: 4927115].
367 Hupp SD, Reitman D, Forde DA, et al. Advancing the assessment of parent-child interactions: development of the Parent Instruction-Giving Game with Youngsters. Behav Ther. Mar. 2008;39(1):91-106. X-2, X-6. [pmid: 18328874].
368 Husted J, Johnson T, Redwing L. Multi-dimensional adolescent treatment with American Indians. Am Indian Alsk Native Ment Health Res. 1995;6(3):23-30. X-4, X-5, X-6. [pmid: 8555351].
369 Hustoft K, Larsen TK, Auestad B, et al. Predictors of involuntary hospitalizations to acute psychiatry. Int J Law Psychiatry. Mar-Apr. 2013;36(2):136-43. X-2, X-4, X-5, X-6. [pmid: 23395506].
370 Hutchings J. Evaluating a behaviourally based parent training group: Outcomes for parents, children and health visitors. Behavioural and Cognitive Psychotherapy. 1996;24(2):149-70. X-6.
371 Hutchings J, Lane E. Parenting and the development and prevention of child mental health problems. Curr Opin Psychiatry. Jul. 2005;18(4):386-91. X-1. [pmid: 16639130].
372 Hutt ML, Dates BG. Reliabilities and interrelationships of two HABGT scales in a male delinquent population. J Pers Assess. Aug. 1977;41(4):353-7. X-11. [pmid: 886427].
373 Hyde LW, Shaw DS, Gardner F, et al. Dimensions of callousness in early childhood: links to problem behavior and family intervention effectiveness. Dev Psychopathol. May. 2013;25(2):347-63. X-4, X-5, X-7, X-8. [pmid: 23627949].
374 Ialongo N, Poduska J, Werthamer L, et al. The distal impact of two first-grade preventive interventions on conduct problems and disorder in early adolescence. Journal of Emotional and Behavioral Disorders. 2001;9(3):146-60. X-5.
375 Iglesias A. Pediatric emotional dysregulation and behavioral disruptiveness treated with hypnosis: a time-series design. Int J Clin Exp Hypn. 2014;62(1):70-83. X-2, X-4, X-6, X-10. [pmid: 24256480].
376 Iglesias A, Iglesias A. Pediatric emotional dysregulation and behavioral disruptiveness treated with hypnosis: a time-series design. Int J Clin Exp Hypn. 2014;62(1):70-83. X-2, X-6. [pmid: 24256480].
377 Ireland JL, Sanders MR, Markie-Dodds C. The impact of parent training on marital functioning: A comparison of two group versions of the Triple P-Positive Parenting Program for parents of children with early-onset conduct problems. Behavioural and Cognitive Psychotherapy. 2003;31(02):127-42. X-4.
378 Irvine AB, Gelatt VA, Hammond M, et al. A Randomized Study of Internet Parent Training Accessed From Community Technology Centers. Prev Sci. 2014. Oct. 29. X-4, X-5. [pmid: 25351866].
379 Ise E, Kierfeld F, Dopfner M. One-Year Follow-Up of Guided Self-Help for Parents of Preschool Children With Externalizing Behavior. J Prim Prev. 2014. Oct. 21. X-4. [pmid: 25331981].
380 Ison MS. Training in social skills: an alternative technique for handling disruptive child behavior. Psychol Rep. Jun. 2001;88(3 Pt 1):903-11. X-5, X-6. [pmid: 11508042].
381 Itil TM, Rizzo AE. Behavior and quantitative EEG correlations during treatment of behavior-disturbed adolescents. Electroencephalogr Clin Neurophysiol. Jul. 1967;23(1):81. X-11. [pmid: 4165577].
382 Jacobs RH, Becker-Weidman EG, Reinecke MA, et al. Treating depression and oppositional behavior in adolescents. J Clin Child Adolesc Psychol. 2010;39(4):559-67. X-4. [pmid: 20589566].
383 Jagers RJ, Morgan-Lopez AA, Flay BR. The impact of age and type of intervention on youth violent behaviors. J Prim Prev. Nov. 2009;30(6):642-58. X-4, X-5, X-8. [pmid: 19953325].
384 Javelot H, Glay-Ribau C, Ligier F, et al. Methylphenidate-risperidone combination in child psychiatry: A retrospective analysis of 44 cases. Ann Pharm Fr. May. 2014;72(3):164-77. X-4. [pmid: 24780832].
385 Jenkins RL. Behavior disorders of childhood. Am Fam Physician GP. May. 1970;1(5):68-73. X-11. [pmid: 5267227].
386 Jensen PS, Hinshaw SP, Swanson JM, et al. Findings from the NIMH Multimodal Treatment Study of ADHD (MTA): implications and applications for primary care providers. J Dev Behav Pediatr. Feb. 2001;22(1):60-73. X-4. [pmid: 11265923].
387 Jenson JM, Dieterich WA. Effects of a skills-based prevention program on bullying and bully victimization among elementary school children. Prev Sci. Dec. 2007;8(4):285-96. X-4, X-5. [pmid: 17968657].
388 Jent JF, Niec LN. Cognitive Behavioral Principles Within Group Mentoring: A Randomized Pilot Study. Child Fam Behav Ther. Jul. 2009;31(3):203-19. X-4. [pmid: 20582243].
389 Jerrell JM. Neurological and cardiovascular adverse events associated with antimanic treatment in children and adolescents. CNS Neurosci Ther. Spring. 2010;16(1):25-31. X-2, X-6, X-7. [pmid: 19769597].
390 Jerrott S, Clark SE, Fearon I. Day treatment for disruptive behaviour disorders: can a short-term program be effective?. J Can Acad Child Adolesc Psychiatry. May. 2010;19(2):88-93. X-2a. [pmid: 20467544].
391 Johnson RJ, Kaplan HB. Gender, aggression, and mental health intervention during early adolescence. J Health Soc Behav. Mar. 1988;29(1):53-64. X-11. [pmid: 3367029].
392 Jones K, Daley D, Hutchings J, et al. Efficacy of the Incredible Years Basic parent training programme as an early intervention for children with conduct problems and ADHD. Child Care Health Dev. Nov. 2007;33(6):749-56. X-4, X-5. [pmid: 17944785].
393 Jones K, Daley D, Hutchings J, et al. Efficacy of the Incredible Years Programme as an early intervention for children with conduct problems and ADHD: long-term follow-up. Child Care Health Dev. May. 2008;34(3):380-90. X-4, X-5, X-7. [pmid: 18410644].
394 Jordans MJ, Tol WA, Ndayisaba A, et al. A controlled evaluation of a brief parenting psychoeducation intervention in Burundi. Soc Psychiatry Psychiatr Epidemiol. Nov. 2013;48(11):1851-9. X-4, X-5. [pmid: 23224723].
395 Joshi PK, Rosenberg LA. Children's behavioral response to residential treatment. J Clin Psychol. Oct. 1997;53(6):567-73. X-5, X-6. [pmid: 9316811].
396 Jurecska DE, Hamilton EB, Peterson MA. Effectiveness of the Coping Power Program in middle-school children with disruptive behaviours and hyperactivity difficulties. Support for Learning. 2011;26(4):168-72. X-4, X-5.
397 Kacir CD, Gordon DA. Parenting adolescents wisely: The effectiveness of an interactive videodisk parent training program in Appalachia. Child & Family Behavior Therapy. 1999;21(4):1-22. X-4.
398 Kalkan Ucar S, Ozbaran B, Demiral N, et al. Clinical overview of children with mucopolysaccharidosis type III A and effect of Risperidone treatment on children and their mothers psychological status. Brain Dev. Feb. 2010;32(2):156-61. X-4. [pmid: 19217229].
399 Kalke T, Glanton A, Cristalli M. Positive behavioral interventions and supports: using strength-based approaches to enhance the culture of care in residential and day treatment education environments. Child Welfare. Sep-Oct. 2007;86(5):151-74. X-5, X-6, X-7, X-8. [pmid: 18422053].
400 Karatzias T, Ferguson S, Chouliara Z, et al. Effectiveness and acceptability of group psychoeducation for the management of mental health problems in survivors of child sexual abuse (CSA). Int J Group Psychother. Oct. 2014;64(4):492-514. X-4. [pmid: 25188564].
401 Karpenko V, Owens JS, Evangelista NM, et al. Clinically significant symptom change in children with attention-deficit/hyperactivity disorder: does it correspond with reliable improvement in functioning?. J Clin Psychol. Jan. 2009;65(1):76-93. X-4, X-6, X-8. [pmid: 19051273].
402 Kayser KH, Wacker DP, Derby KM, et al. A rapid method for evaluating the necessity for both a behavioral intervention and methylphenidate. J Appl Behav Anal. Spring. 1997;30(1):177-80. X-4, X-5, X-6, X-8. [pmid: 9157098].
403 Kazdin AE. Premature termination from treatment among children referred for antisocial behavior. J Child Psychol Psychiatry. Mar. 1990;31(3):415-25. X-11. [pmid: 2318922].
404 Kazdin AE, Bass D, Siegel T, et al. Cognitive-behavioral therapy and relationship therapy in the treatment of children referred for antisocial behavior. J Consult Clin Psychol. Aug. 1989;57(4):522-35. X-11. [pmid: 2768614].
405 Kazdin AE, Durbin KA. Predictors of child–therapist alliance in cognitive–behavioral treatment of children referred for oppositional and antisocial behavior. Psychotherapy. 2012;49(2):202-17. X-6. [pmid: 22642524].
406 Kazdin AE, Esveldt-Dawson K, French NH, et al. Effects of parent management training and problem-solving skills training combined in the treatment of antisocial child behavior. J Am Acad Child Adolesc Psychiatry. May. 1987;26(3):416-24. X-11. [pmid: 3597299].
407 Kazdin AE, Esveldt-Dawson K, French NH, et al. Problem-solving skills training and relationship therapy in the treatment of antisocial child behavior. J Consult Clin Psychol. Feb. 1987;55(1):76-85. X-11. [pmid: 3571662].
408 Kazdin AE, Holland L, Crowley M. Family experience of barriers to treatment and premature termination from child therapy. J Consult Clin Psychol. Jun. 1997;65(3):453-63. X-2, X-6, X-7. [pmid: 9170769].
409 Kazdin AE, Wassell G. Therapeutic changes in children, parents, and families resulting from treatment of children with conduct problems. J Am Acad Child Adolesc Psychiatry. Apr. 2000;39(4):414-20. X-6. [pmid: 10761342].
410 Kazdin AE, Whitley M, Marciano PL. Child-therapist and parent-therapist alliance and therapeutic change in the treatment of children referred for oppositional, aggressive, and antisocial behavior. J Child Psychol Psychiatry. May. 2006;47(5):436-45. X-6. [pmid: 16671927].
411 Kazdin AE, Whitley MK. Treatment of parental stress to enhance therapeutic change among children referred for aggressive and antisocial behavior. J Consult Clin Psychol. Jun. 2003;71(3):504-15. X-7. [pmid: 12795574].
412 Kazdin AE, Whitley MK. Comorbidity, case complexity, and effects of evidence-based treatment for children referred for disruptive behavior. J Consult Clin Psychol. Jun. 2006;74(3):455-67. X-6. [pmid: 16822103].
413 Kazdin AE, Whitley MK. Pretreatment social relations, therapeutic alliance, and improvements in parenting practices in parent management training. J Consult Clin Psychol. Apr. 2006;74(2):346-55. X-3, X-6, X-7, X-8. [pmid: 16649879].
414 Kennedy J, Mitchell JB, Klerman LV, et al. A day school approach to aggressive adolescents. Child Welfare. Dec. 1976;55(10):712-24. X-11. [pmid: 1001075].
415 Kethineni S, Blimling L, Bozarth JM, et al. Youth violence: an exploratory study of a treatment program in a central Illinois county. Int J Offender Ther Comp Criminol. Dec. 2004;48(6):697-720. X-10. [pmid: 15538027].
416 Kettlewell PW, Kausch DF. The generalization of the effects of a cognitive-behavioral treatment program for aggressive children. J Abnorm Child Psychol. Mar. 1983;11(1):101-14. X-11. [pmid: 6853873].
417 Kewley GD. Risperidone in comorbid ADHD and OCC/CD. Journal of the American Academy of Child & Adolescent Psychiatry. 1999;38(11):1327-8. X-1, X-6. [pmid: 10560215].
418 Khantzian EJ. An ego/self theory of substance dependence: a contemporary psychoanalytic perspective. NIDA Res Monogr. Mar. 1980;30:29-33. X-11. [pmid: 6779190].
419 Khanzode LA, Saxena K, Kraemer H, et al. Efficacy profiles of psychopharmacology: divalproex sodium in conduct disorder. Child Psychiatry Hum Dev. Fall. 2006;37(1):55-64. X-6, X-7. [pmid: 16927177].
420 Kierfeld F, Ise E, Hanisch C, et al. Effectiveness of telephone-assisted parent-administered behavioural family intervention for preschool children with externalizing problem behaviour: a randomized controlled trial. Eur Child Adolesc Psychiatry. Sep. 2013;22(9):553-65. X-4. [pmid: 23463180].
421 Killeen MR. Marital conflict management skills, parenting style, and early-onset conduct problems: processes and pathways. J Child Fam Nurs. Mar-Apr. 2000;3(2):110-1. X-2, X-10. [pmid: 11271139].
422 Kim E, Cain KC, Webster-Stratton C. The preliminary effect of a parenting program for Korean American mothers: a randomized controlled experimental study. Int J Nurs Stud. Sep. 2008;45(9):1261-73. X-4. [pmid: 17996239].
423 Kimonis ER, Bagner DM, Linares D, et al. Parent Training Outcomes among Young Children with Callous-Unemotional Conduct Problems with or At-Risk for Developmental Delay. J Child Fam Stud. Feb. 1. 2014;23(2):437-48. X-4. [pmid: 24511217].
424 King B, Zwi K, Nunn K, et al. Use of risperidone in a paediatric population: an observational study. J Paediatr Child Health. Sep-Oct. 2003;39(7):523-7. X-4, X-6, X-8. [pmid: 12969207].
425 Kinnen C, Döpfner M. Zusammenhang von Therapeutischer Beziehungmit Symptomminderung und Behandlungszufriedenheit in der Behandlung von Kindern und Jugendlichen mit ADHS und/oder Störungen des Sozialverhaltens. Zeitschrift für Kinder- und Jugendpsychiatrie und Psychotherapie. 2013;41(2):133-44. X-2, X-6, X-8, X-10. [pmid: 23425615].
426 Kjøbli J, Hukkelberg S, Ogden T. A randomized trial of group parent training: Reducing child conduct problems in real-world settings. Behaviour Research and Therapy. 2013;51(3):113-21. X-4. [pmid: 23318242].
427 Kliman GW. Analyst in the nursery. Experimental application of child analytic techniques in a therapeutic nursery: the cornerstone method. Psychoanal Study Child. 1975;30:477-510. X-11. [pmid: 1197519].
428 Klingsporn MJ, Force RC, Burdsal C. The effectiveness of various degrees and circumstances of program completion of young male offenders in a residential treatment center. J Clin Psychol. Jul. 1990;46(4):491-500. X-11. [pmid: 2212054].
429 Klorman R, Brumaghim JT, Salzman LF, et al. Comparative effects of methylphenidate on attention-deficit hyperactivity disorder with and without aggressive/noncompliant features. Psychopharmacol Bull. 1989;25(1):109-13. X-11. [pmid: 2772109].
430 Knight RA, Ronis ST, Zakireh B. Bootstrapping persistence risk indicators for juveniles who sexually offend. Behav Sci Law. Nov-Dec. 2009;27(6):878-909. X-2, X-4, X-5, X-6, X-7, X-8. [pmid: 19937923].
431 Knox L, Guerra NG, Williams KR, et al. Preventing children's aggression in immigrant Latino families: a mixed methods evaluation of the Families and Schools Together program. Am J Community Psychol. Sep. 2011;48(1-2):65-76. X-4, X-5. [pmid: 21253821].
432 Koda VH, Halperin JM, Newcorn JH, et al. Gender differences in the prolactin response to fenfluramine challenge in children with disruptive behavior disorders. Ann N Y Acad Sci. Sep. 20. 1996;794:369-71. X-2, X-6, X-7, X-10. [pmid: 8853619].
433 Kodak T, Miltenberger RG, Romaniuk C. The effects of differential negative reinforcement of other behavior and noncontingent escape on compliance. J Appl Behav Anal. Fall. 2003;36(3):379-82. X-4, X-5, X-6, X-8. [pmid: 14596581].
434 Kodak T, Northup J, Kelley ME. An evaluation of the types of attention that maintain problem behavior. J Appl Behav Anal. Spring. 2007;40(1):167-71. X-2, X-6, X-7. [pmid: 17471800].
435 Kogan SM, Brody GH, Chen YF. Natural mentoring processes deter externalizing problems among rural African American emerging adults: a prospective analysis. Am J Community Psychol. Dec. 2011;48(3-4):272-83. X-2, X-4, X-5, X-8. [pmid: 21293917].
436 Kohlhoff J, Morgan S. Parent-child interaction therapy for toddlers: A pilot study. Child & Family Behavior Therapy. 2014;36(2):121-39. X-6.
437 Kolko DJ, Lindhiem O, Hart J, et al. Evaluation of a booster intervention three years after acute treatment for early-onset disruptive behavior disorders. J Abnorm Child Psychol. 2014;42(3):383-98. X-9. [pmid: 23494526].
438 Konstantareas MM, Homatidis S. Aggressive and prosocial behaviours before and after treatment in conduct-disordered children and in matched controls. J Child Psychol Psychiatry. Oct. 1984;25(4):607-20. X-11. [pmid: 6480733].
439 Kotsopoulos S, Walker S, Beggs K, et al. A clinical and academic outcome study of children attending a day treatment program. Can J Psychiatry. Aug. 1996;41(6):371-8. X-4, X-5, X-6. [pmid: 8862856].
440 Kuhn DE, Hardesty SL, Luczynski K. Further evaluation of antecedent social events during functional analysis. J Appl Behav Anal. Summer. 2009;42(2):349-53. X-2, X-6, X-7, X-8. [pmid: 19949523].
441 Kumar GV. Impact of rational-emotive behaviour therapy (REBT) on adolescents with conduct disorder (CD). Journal of the Indian Academy of Applied Psychology. 2009;35(spec iss):103-11. X-5, X-6.
442 Kuperman S, Calarge C, Kolar A, et al. An open-label trial of aripiprazole in the treatment of aggression in male adolescents diagnosed with conduct disorder. Ann Clin Psychiatry. Nov. 2011;23(4):270-6. X-6. [pmid: 22073384].
443 Kupfer DJ, Detre T, Jacqueline K. “Deviant” behavior patterns in school children, application of KDS-TM-14. Psychol Rep. Aug. 1974;35(1):183-91. X-11. [pmid: 4420969].
444 Kupietz SS, Balka EB. Alterations in the vigilance performance of children receiving amitriptyline and methylphenidate pharmacotherapy. Psychopharmacology (Berl). Oct. 20. 1976;50(1):29-33. X-11. [pmid: 827759].
445 Lacourse E, Cote S, Nagin DS, et al. A longitudinal-experimental approach to testing theories of antisocial behavior development. Dev Psychopathol. Fall. 2002;14(4):909-24. X-5. [pmid: 12549709].
446 Lahey BB, Loeber R, Burke J, et al. Adolescent outcomes of childhood conduct disorder among clinic-referred boys: predictors of improvement. J Abnorm Child Psychol. Aug. 2002;30(4):333-48. X-2, X-6, X-8. [pmid: 12108765].
447 Laje G, Bernert R, Morse R, et al. Pharmacological treatment of disruptive behavior in Smith-Magenis syndrome. Am J Med Genet C Semin Med Genet. Nov. 15. 2010;154C(4):463-8. X-4, X-8. [pmid: 20981776].
448 Lakes KD, Kettler RJ, Schmidt J, et al. The CUIDAR Early Intervention Parent Training Program for Preschoolers at Risk for Behavioral Disorders: An Innovative Practice for Reducing Disparities in Access to Service. J Early Interv. Mar. 1. 2009;31(2):167-78. X-4, X-6, X-8. [pmid: 23620645].
449 Larson JD, Calamari JE, West JG, et al. Aggression management with disruptive adolescents in the residential setting: Integration of a cognitive–behavioral component. Residential Treatment for Children & Youth. 1998;15(4):1-9. X-5, X-6.
450 Larsson B, Fossum S, Clifford G, et al. Treatment of oppositional defiant and conduct problems in young Norwegian children: Results of a randomized controlled trial. European Child & Adolescent Psychiatry. 2009;18(1):42-52. X-9. [pmid: 18563473].
451 Larzelere RE, Cox RB Jr., Smith GL. Do nonphysical punishments reduce antisocial behavior more than spanking? a comparison using the strongest previous causal evidence against spanking. BMC Pediatr. 2010;10:10. X-2, X-8. [pmid: 20175902].
452 Lavigne JV, Lebailly SA, Gouze KR, et al. Predictors and correlates of completing behavioral parent training for the treatment of oppositional defiant disorder in pediatric primary care. Behav Ther. Jun. 2010;41(2):198-211. X-7, X-8. [pmid: 20412885].
453 Lazerson DB. “I must be good if i can teach!” --- peer tutoring with aggressive and withdrawn children. J Learn Disabil. Mar. 1980;13(3):152-7. X-11. [pmid: 7381310].
454 LeBlanc JC, Binder CE, Armenteros JL, et al. Risperidone reduces aggression in boys with a disruptive behaviour disorder and below average intelligence quotient: analysis of two placebo-controlled randomized trials. Int Clin Psychopharmacol. Sep. 2005;20(5):275-83. X-1, X-4. [pmid: 16096518].
455 Lees DG, Fergusson DM, Frampton CM, et al. A pilot study to evaluate the efficacy of adding a structured home visiting intervention to improve outcomes for high-risk families attending the Incredible Years Parent Programme: study protocol for a randomised controlled trial. Trials. 2014;15:66. X-1. [pmid: 24568271].
456 Leff SS, Gullan RL, Paskewich BS, et al. An initial evaluation of a culturally adapted social problem-solving and relational aggression prevention program for urban African-American relationally aggressive girls. J Prev Interv Community. 2009;37(4):260-74. X-5. [pmid: 19830622].
457 Leijten P, Shaw DS, Gardner F, et al. The Family Check-Up and Service Use in High-Risk Families of Young Children: A Prevention Strategy with a Bridge to Community-Based Treatment. Prev Sci. 2014. Mar. 20. X-4. [pmid: 24643281].
458 Lepanto J. Targeting problem behaviors. Behav Healthc. Nov-Dec. 32. 2009;29(10):4. X-1, X-2, X-5, X-6, X-7, X-8. [pmid: 20063649].
459 Leung C, Sanders MR, Leung S, et al. An outcome evaluation of the implementation of the Triple P-Positive Parenting Program in Hong Kong. Fam Process. Winter. 2003;42(4):531-44. X-4. [pmid: 14979223].
460 Leve LD, Chamberlain P, Reid JB. Intervention outcomes for girls referred from juvenile justice: effects on delinquency. J Consult Clin Psychol. Dec. 2005;73(6):1181-5. X-5. [pmid: 16392991].
461 Levinson BM. Pet psychotherapy: use of household pets in the treatment of behavior disorder in childhood. Psychol Rep. Dec. 1965;17(3):695-8. X-11. [pmid: 5892572].
462 Lewis JA, Young R. Deanol and methylphenidate in minimal brain dysfunction. Clin Pharmacol Ther. May. 1975;17(5):534-40. X-11. [pmid: 1092513].
463 Lewis JC, Glasser N. Evolution of a treatment approach to families: group family therapy. Int J Group Psychother. Oct. 1965;15(4):506-15. X-11. [pmid: 5829258].
464 Lewis RE. The effectiveness of Families First services: An experimental study. Children and Youth Services Review. 5. 2005;27(5):499-509. X-4.
465 Li MH. A model parent group for enhancing aggressive children's social competence in Taiwan. Int J Group Psychother. Jul. 2009;59(3):407-19. X-4, X-5, X-6, X-8. [pmid: 19548787].
466 Liber JM, De Boo GM, Huizenga H, et al. School-based intervention for childhood disruptive behavior in disadvantaged settings: A randomized controlled trial with and without active teacher support. J Consult Clin Psychol. Dec. 2013;81(6):975-87. X-5. [pmid: 23834227].
467 Lichtwarck-Aschoff A, Hasselman F, Cox R, et al. A characteristic destabilization profile in parent-child interactions associated with treatment efficacy for aggressive children. Nonlinear Dynamics Psychol Life Sci. Jul. 2012;16(3):353-79. X-5, X-6. [pmid: 22695153].
468 Liddle HA, Dakof GA, Henderson C, et al. Implementation outcomes of Multidimensional Family Therapy-Detention to Community: a reintegration program for drug-using juvenile detainees. Int J Offender Ther Comp Criminol. Jun. 2011;55(4):587-604. X-4, X-5, X-7, X-8. [pmid: 20427547].
469 Lien-Thorne S, Kamps D. Replication study of the first step to success early intervention program. Behavioral Disorders. 2005;31(1):18-32. X-4, X-5, X-6, X-8.
470 Linares LO, Stovall-McClough KC, Li M, et al. Salivary cortisol in foster children: a pilot study. Child Abuse Negl. Jun. 2008;32(6):665-70. X-2, X-6, X-7. [pmid: 18582935].
471 Lindhiem O, Kolko DJ. Trajectories of symptom reduction and engagement during treatment for childhood behavior disorders: differences across settings. J Abnorm Child Psychol. Oct. 2010;38(7):995-1005. X-2, X-6, X-7. [pmid: 20414715].
472 Lindhiem O, Kolko DJ. Trajectories of symptom reduction during treatment for behavior problems in pediatric primary-care settings. Adm Policy Ment Health. Nov. 2011;38(6):486-94. X-6. [pmid: 21301952].
473 Lindhiem O, Shaffer A, Kolko DJ. Quantifying Discipline Practices Using Absolute Versus Relative Frequencies: Clinical and Research Implications for Child Welfare. J Interpers Violence. 2013. Oct. 7. X-3, X-6, X-7, X-8. [pmid: 24106146].
474 Lindsay G, Strand S. Evaluation of the national roll-out of parenting programmes across England: the parenting early intervention programme (PEIP). BMC Public Health. Oct. 19. 2013;13(1):972. X-4, X-5, X-7, X-8. [pmid: 24138747].
475 Lindsay G, Strand S, Davis H. A comparison of the effectiveness of three parenting programmes in improving parenting skills, parent mental-well being and children's behaviour when implemented on a large scale in community settings in 18 English local authorities: the parenting early intervention pathfinder (PEIP). BMC Public Health. 2011;11:962. X-4. [pmid: 22208676].
476 Lindsay RL, Leone S, Aman MG. Discontinuation of risperidone and reversibility of weight gain in children with disruptive behavior disorders. Clin Pediatr (Phila). Jun. 2004;43(5):437-44. X-2, X-4, X-6. [pmid: 15208748].
477 Lipman EL, Boyle MH, Cunningham C, et al. Testing effectiveness of a community-based aggression management program for children 7 to 11 years old and their families. J Am Acad Child Adolesc Psychiatry. Sep. 2006;45(9):1085-93. X-4. [pmid: 16926616].
478 Livingston R, Taylor JL, Crawford SL. Factors related to length of hospitalization of children with mental disorders. Hosp Community Psychiatry. Feb. 1990;41(2):193-5. X-11. [pmid: 2303224].
479 Lobitz WC. A simple stimulus cue for controlling disruptive classroom behavior. Methodological implications for behavior change procedures. J Abnorm Child Psychol. Jun. 1974;2(2):143-52. X-11. [pmid: 4430817].
480 Lochman JE. Effects of different treatment lengths in cognitive behavioral interventions with aggressive boys. Child Psychiatry Hum Dev. Fall. 1985;16(1):45-56. X-11. [pmid: 4064791].
481 Lochman JE, Baden RE, Boxmeyer CL, et al. Does a Booster Intervention Augment the Preventive Effects of an Abbreviated Version of the Coping Power Program for Aggressive Children?. J Abnorm Child Psychol. 2013. Feb. 16. X-4. [pmid: 23417235].
482 Lochman JE, Baden RE, Boxmeyer CL, et al. Does a booster intervention augment the preventive effects of an abbreviated version of the coping power program for aggressive children?. J Abnorm Child Psychol. 2014;42(3):367-81. X-9. [pmid: 23417235].
483 Lochman JE, Boxmeyer C, Powell N, et al. Masked intervention effects: Analytic methods for addressing low dosage of intervention. New Directions for Evaluation. 2006;2006(110):19-32. X-4.
484 Lochman JE, Lampron LB, Burch PR, et al. Client characteristics associated with behavior change for treated and untreated aggressive boys. J Abnorm Child Psychol. Dec. 1985;13(4):527-38. X-11. [pmid: 4078184].
485 Lochman JE, Wells KC. Contextual social-cognitive mediators and child outcome: a test of the theoretical model in the Coping Power program. Dev Psychopathol. Fall. 2002;14(4):945-67. X-4. [pmid: 12549711].
486 Lochman JE, Wells KC. The Coping Power program at the middle-school transition: universal and indicated prevention effects. Psychol Addict Behav. Dec. 2002;16(4 Suppl):S40-54. X-5. [pmid: 12502276].
487 Lochman JE, Wells KC. Effectiveness of the Coping Power Program and of Classroom Intervention With Aggressive Children: Outcomes at a 1-Year Follow-Up. Behavior Therapy. 2003;34(4):493-515. X-4.
488 Lochman JE, Wells KC. The coping power program for preadolescent aggressive boys and their parents: outcome effects at the 1-year follow-up. J Consult Clin Psychol. Aug. 2004;72(4):571-8. X-4. [pmid: 15301641].
489 Lochman JE, Wells KC, Qu L, et al. Three year follow-up of coping power intervention effects: evidence of neighborhood moderation?. Prev Sci. Aug. 2013;14(4):364-76. X-2a, X-4. [pmid: 23065350].
490 Lochmann J, FitzGerald D, Gage S, et al. Effects of a social-cognitive intervention for aggressive deaf children: The Coping Power Program. JADARA-ROCHESTER NY. 2001;35(2):39-61. X-10.
491 Long P, Forehand R, Wierson M, et al. Does parent training with young noncompliant children have long-term effects?. Behav Res Ther. Jan. 1994;32(1):101-7. X-6, X-8. [pmid: 8135705].
492 Lorandos DA. Adolescents in residential treatment: a six-year comparison. Adolesc Psychiatry. 1990;17:473-8. X-11. [pmid: 2240432].
493 Love AR, Mueller CW, Tolman RT, et al. Frequency, Level, and Rate of Improvement for Treatment Targets in a Children's Mental Health Community-Based Intensive In-Home Therapeutic Setting. Adm Policy Ment Health. 2013. Mar. 9. X-4, X-6, X-7. [pmid: 23474672].
494 Love AR, Mueller CW, Tolman RT, et al. Frequency, level, and rate of improvement for treatment targets in a children's mental health community-based intensive in-home therapeutic setting. Adm Policy Ment Health. Jul. 2014;41(4):421-33. X-1, X-6. [pmid: 23474672].
495 Luce SC, Christian WP, Anderson SR, et al. Development of a continuum of services for children and adults with autism and other severe behavior disorders. Res Dev Disabil. 1992;13(1):9-25. X-11. [pmid: 1585026].
496 Luiselli JK, Pace GM, Dunn EK. Effects of behavior-contingent and fixed-time release contingencies on frequency and duration of therapeutic restraint. Behav Modif. Jul. 2006;30(4):442-55. X-2, X-4, X-5, X-6, X-7, X-8, X-10. [pmid: 16723424].
497 Luk ES, Staiger P, Mathai J, et al. Comparison of treatments of persistent conduct problems in primary school children: a preliminary evaluation of a modified cognitive-behavioural approach. Aust N Z J Psychiatry. Jun. 1998;32(3):379-86. X-4. [pmid: 9672727].
498 Luk ES, Staiger PK, Mathai J, et al. Children with persistent conduct problems who dropout of treatment. Eur Child Adolesc Psychiatry. Mar. 2001;10(1):28-36. X-4. [pmid: 11315533].
499 Luk ESL, Staiger P, Mathai J, et al. Comparison of treatments of persistent conduct problems in primary school children: A preliminary evaluation of a modified cognitive–behavioural approach. Australian and New Zealand Journal of Psychiatry. 1998;32(3):379-86. X-10. [pmid: 9672727].
500 Luk ESL, Staiger P, Mathai J, et al. Evaluation of outcome in child and adolescent mental health services: Children with persistent conduct problems. Clinical Child Psychology and Psychiatry. 2001;6(1):109-24. X-6, X-10.
501 Lytton GJ, Knobel M. Diagnosis and treatment of behavior disorders in children. Dis Nerv Syst. Aug. 1959;20:334-40. X-11. [pmid: 14419219].
502 Maag JW, Howell KW. Serving troubled youth or a troubled society?. Except Child. Sep. 1991;58(1):75-6. discussion 7-9. X-11. [pmid: 1954973].
503 MacMillan CM, Korndorfer SR, Rao S, et al. A comparison of divalproex and oxcarbazepine in aggressive youth with bipolar disorder. J Psychiatr Pract. Jul. 2006;12(4):214-22. X-4. [pmid: 16883146].
504 Madsen PS, Conte JR. Single subject research in occupational therapy: a case illustration. Am J Occup Ther. Apr. 1980;34(4):263-7. X-11. [pmid: 7369087].
505 Maeda E. Activity programming for the aggressive child. Am J Occup Ther. Jul-Aug. 1960;14:223-6. X-11. [pmid: 14419707].
506 Mahoney JL. School extracurricular activity participation as a moderator in the development of antisocial patterns. Child Dev. Mar-Apr. 2000;71(2):502-16. X-2, X-5, X-6. [pmid: 10834480].
507 Malmberg JL, Field CE. Preventative behavioral parent training: A preliminary investigation of strategies for preventing at-risk children from developing later conduct problems. Child & Family Behavior Therapy. 2013;35(3):212-27. X-4, X-6, X-7, X-8.
508 Malone RP, Bennett DS, Luebbert JF, et al. Aggression classification and treatment response. Psychopharmacol Bull. 1998;34(1):41-5. X-5. [pmid: 9564197].
509 Malone RP, Delaney MA, Luebbert JF, et al. A double-blind placebo-controlled study of lithium in hospitalized aggressive children and adolescents with conduct disorder. Arch Gen Psychiatry. Jul. 2000;57(7):649-54. X-5. [pmid: 10891035].
510 Malone RP, Luebbert JF, Delaney MA, et al. Nonpharmacological response in hospitalized children with conduct disorder. J Am Acad Child Adolesc Psychiatry. Feb. 1997;36(2):242-7. X-2, X-5, X-6, X-7. [pmid: 9031577].
511 Mandell DS, Guevara JP, Rostain AL, et al. Economic grand rounds: medical expenditures among children with psychiatric disorders in a Medicaid population. Psychiatr Serv. Apr. 2003;54(4):465-7. X-2. [pmid: 12663833].
512 Marini JL, Sheard MH, Bridges CI, et al. An evaluation of the double-blind design in a study comparing lithium carbonate with placebo. Acta Psychiatr Scand. May. 1976;53(5):343-54. X-11. [pmid: 785950].
513 Marlowe RH, Madsen CH Jr., Bowen CE, et al. Severe classroom behavior problems: teachers or counsellors. J Appl Behav Anal. Spring. 1978;11(1):53-66. X-11. [pmid: 649528].
514 Martens WH. Multisystemic therapy for antisocial juveniles: suggestions for improvement. Int J Offender Ther Comp Criminol. Jun. 2004;48(3):389-94. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 15142315].
515 Martin A, Krieg H, Esposito F, et al. Reduction of restraint and seclusion through collaborative problem solving: a five-year prospective inpatient study. Psychiatr Serv. Dec. 2008;59(12):1406-12. X-2, X-4, X-5, X-6. [pmid: 19033167].
516 Martin CA, Cook C, Woodring JH, et al. Caffeine use: association with nicotine use, aggression, and other psychopathology in psychiatric and pediatric outpatient adolescents. ScientificWorldJournal. 2008;8:512-6. X-2. [pmid: 18516472].
517 Martinez CR Jr., Eddy JM. Effects of culturally adapted parent management training on Latino youth behavioral health outcomes. J Consult Clin Psychol. Oct. 2005;73(5):841-51. X-4. [pmid: 16287384].
518 Masi G, Manfredi A, Milone A, et al. Predictors of nonresponse to psychosocial treatment in children and adolescents with disruptive behavior disorders. J Child Adolesc Psychopharmacol. Feb. 2011;21(1):51-5. X-5, X-6. [pmid: 21309697].
519 Masi G, Milone A, Manfredi A, et al. Effectiveness of lithium in children and adolescents with conduct disorder: a retrospective naturalistic study. CNS Drugs. 2009;23(1):59-69. X-6. [pmid: 19062775].
520 Masi G, Muratori P, Manfredi A, et al. Response to treatments in youth with disruptive behavior disorders. Compr Psychiatry. Oct. 2013;54(7):1009-15. X-7a. [pmid: 23683839].
521 Mast JE, Antonini TN, Raj SP, et al. Web-based parenting skills to reduce behavior problems following abusive head trauma: a pilot study. Child Abuse Negl. Sep. 2014;38(9):1487-95. X-4. [pmid: 24844734].
522 Matos M, Bauermeister JJ, Bernal G. Parent-child interaction therapy for Puerto Rican preschool children with ADHD and behavior problems: a pilot efficacy study. Fam Process. Jun. 2009;48(2):232-52. X-4. [pmid: 19579907].
523 Matos M, Torres R, Santiago R, et al. Adaptation of parent-child interaction therapy for Puerto Rican families: a preliminary study. Fam Process. Jun. 2006;45(2):205-22. X-6. [pmid: 16768019].
524 Mattes JA. Comparative effectiveness of carbamazepine and propranolol for rage outbursts. J Neuropsychiatry Clin Neurosci. Spring. 1990;2(2):159-64. X-11. [pmid: 2136070].
525 Mazaheri R, Eshghi A, Bashardoost N, et al. Assessment of intranasal midazolam administration with a dose of 0.5 mg/kg in behavior management of uncooperative children. J Clin Pediatr Dent. Winter. 2008;32(2):95-9. X-4, X-6, X-10. [pmid: 18389672].
526 McAuley R. Training parents to modify conduct problems in their children. J Child Psychol Psychiatry. Jul. 1982;23(3):335-42. X-11. [pmid: 7107748].
527 McClain DB, Wolchik SA, Winslow E, et al. Developmental cascade effects of the New Beginnings Program on adolescent adaptation outcomes. Dev Psychopathol. Nov. 2010;22(4):771-84. X-4, X-6, X-7, X-8. [pmid: 20883581].
528 McCleary L, Ridley T. Parenting adolescents with ADHD: evaluation of a psychoeducation group. Patient Educ Couns. Sep. 1999;38(1):3-10. X-4. [pmid: 14528566].
529 McClowry SG, Snow DL, Tamis-LeMonda CS. An evaluation of the effects of INSIGHTS on the behavior of inner city primary school children. J Prim Prev. Nov. 2005;26(6):567-84. X-5. [pmid: 16237502].
530 McCord J. Competence in long-term perspective. Psychiatry. Aug. 1991;54(3):227-37. X-11. [pmid: 1946824].
531 McCormick E, Kerns SE, McPhillips H, et al. Training pediatric residents to provide parent education: a randomized controlled trial. Acad Pediatr. Jul-Aug. 2014;14(4):353-60. X-4. [pmid: 24976347].
532 McElroy SL. Recognition and treatment of DSM-IV intermittent explosive disorder. J Clin Psychiatry. Suppl 15. 1999;60:12-6. X-1, X-3. [pmid: 10418808].
533 McKay MM, Harrison ME, Gonzales J, et al. Multiple-family groups for urban children with conduct difficulties and their families. Psychiatr Serv. Nov. 2002;53(11):1467-8. X-1, X-4, X-6, X-7, X-8. [pmid: 12407277].
534 McKee TE, Harvey E, Danforth JS, et al. The relation between parental coping styles and parent-child interactions before and after treatment for children with ADHD and oppositional behavior. J Clin Child Adolesc Psychol. Mar. 2004;33(1):158-68. X-4, X-6, X-8. [pmid: 15028550].
535 McKibbin E, King J. Activity group counseling for learning-disabled children with behavior problems. Am J Occup Ther. Sep. 1983;37(9):617-23. X-11. [pmid: 6624859].
536 McLaughlin M. An experiment. Nurs Times. Jan. 31. 1974;70(5):166-7. X-11. [pmid: 4822646].
537 McMenamy J, Sheldrick RC, Perrin EC. Early intervention in pediatrics offices for emerging disruptive behavior in toddlers. Journal of Pediatric Health Care. 2011;25(2):77-86. X-2, X-6. [pmid: 21320679].
538 McNamara E, Evans M, Hill W. The reduction of disruptive behaviour in two secondary school classes. Br J Educ Psychol. Jun. 1986;56(Pt 2):209-15. X-11. [pmid: 3730274].
539 McNeil CB, Herschell AD, Gurwitch RH, et al. Training foster parents in parent-child interaction therapy. Education & Treatment of Children. 2005;28(2):182-96. X-2, X-6.
540 Mendel S. An adolescent group within a milieu setting. Journal of Child & Adolescent Group Therapy. 1995;5(1):47-51. X-1, X-2, X-6.
541 Menting AT, de Castro BO, Wijngaards-de Meij LD, et al. A trial of parent training for mothers being released from incarceration and their children. J Clin Child Adolesc Psychol. 2014;43(3):381-96. X-4. [pmid: 23915290].
542 Middleton MB, Cartledge G. The effects of social skills instruction and parental involvement on the aggressive behaviors of African American males. Behav Modif. Apr. 1995;19(2):192-210. X-5, X-6. [pmid: 7726817].
543 Milani A, Nikmanesh Z, Farnam A. Effectiveness of Mindfulness-Based Cognitive Therapy (MBCT) in Reducing Aggression of Individuals at the Juvenile Correction and Rehabilitation Center. Int J High Risk Behav Addict. Dec. 2013;2(3):126-31. X-5. [pmid: 24971290].
544 Miles A. Changes in the attitudes to authority of patients with behaviour disorders in a therapeutic community. Br J Psychiatry. Sep. 1969;115(526):1049-57. X-11. [pmid: 5386994].
545 Miller NV, Haas SM, Waschbusch DA, et al. Behavior therapy and callous-unemotional traits: effects of a pilot study examining modified behavioral contingencies on child behavior. Behav Ther. Sep. 2014;45(5):606-18. X-4, X-5, X-6. [pmid: 25022772].
546 Millichap JG. Drugs in the management of learning and behavior disorders in school children. IMJ Ill Med J. Apr. 1974;145(4):322-3. X-11. [pmid: 4151138].
547 Mlele TJ, Wiley YV. 43. Br J Psychiatry. Sep. 1986;149:373-6. X-11. [pmid: 3779305].
548 Money J, Wiedeking C, Walker P, et al. 47,XYY and 46,XY males with antisocial and/or sex-offending behavior: antiandrogen therapy plus counseling. Psychoneuroendocrinology. 1975;1(2):165-76. X-11. [pmid: 1234655].
549 Mordock JD. Treatment issues for the disruptive child. Diagnosis and interventions require flexibility. Behav Healthc Tomorrow. Dec. 1999;8(6):41-2. 4. 6. X-10. [pmid: 10747584].
550 Moretti MM, Obsuth I. Effectiveness of an attachment-focused manualized intervention for parents of teens at risk for aggressive behaviour: The Connect Program. J Adolesc. Dec. 2009;32(6):1347-57. X-6. [pmid: 19766302].
551 Morgan M. Conduct disorders. Nursing (Lond). Apr. 1981;1(24):1036-7. X-11. [pmid: 6965125].
552 Morris E, Le Huray C, Skagerberg E, et al. Families changing families: The protective function of multi-family therapy for children in education. Clin Child Psychol Psychiatry. 2013. Jul. 9. X-4. X-5. [pmid: 23838692].
553 Morris E, Le Huray C, Skagerberg E, et al. Families changing families: the protective function of multi-family therapy for children in education. Clin Child Psychol Psychiatry. Oct. 2014;19(4):617-32. X-4. [pmid: 23838692].
554 Morrison JR, Minkoff K. Explosive personality as a sequel to the hyperactive-child syndrome. Compr Psychiatry. Jul-Aug. 1975;16(4):343-8. X-11. [pmid: 1157478].
555 Mottram L, Berger-Gross P. An intervention to reduce disruptive behaviours in children with brain injury. Pediatr Rehabil. Apr-Jun. 2004;7(2):133-43. X-4. [pmid: 15204584].
556 Mukhopadhyay P, Chakrabartii M. Token economy and cognitive modification in the treatment of study behaviour problem in children: A comparative study. Indian Journal of Clinical Psychology. 1996;23(2):142-5. X-10.
557 Muntz R, Hutchings J, Edwards RT, et al. Economic evaluation of treatments for children with severe behavioural problems. J Ment Health Policy Econ. Dec. 2004;7(4):177-89. X-7. [pmid: 15701933].
558 Muratori P, Polidori L, Lambruschi F, et al. Un modello di trattamento in setting di gruppo per i disturbi da comportamento dirompente in età evolutiva: Il «Pisa-Coping Power Program». Psicologia Clinica dello Sviluppo. 2013;17(3):411-28. X-10, X-11.
559 Murphy CJ, Siv AM. A one year study of mode deactivation therapy: Adolescent residential patients with conduct and personality disorders. International Journal of Behavioral Consultation and Therapy. 2011;7(1):33-40. X-5, X-6, X-8.
560 Myeroff R, Mertlich G, Gross J. Comparative effectiveness of holding therapy with aggressive children. Child Psychiatry Hum Dev. Summer. 1999;29(4):303-13. X-4. [pmid: 10422354].
561 Nada PJ. Heart rate variability in the assessment and biofeedback training of common mental health problems in children. Med Arh. 2009;63(5):244-8. X-2, X-6, X-7, X-8. [pmid: 20380120].
562 Najdowski AC, Wallace MD, Ellsworth CL, et al. Functional analyses and treatment of precursor behavior. J Appl Behav Anal. Spring. 2008;41(1):97-105. X-2. [pmid: 18468282].
563 Nantel-Vivier A, Pihl RO, Young SN, et al. Serotonergic contribution to boys' behavioral regulation. PLoS One. 2011;6(6):e20304. X-2, X-7. [pmid: 21673801].
564 Niccols A. Immediate and short-term outcomes of the ‘COPEing with Toddler Behaviour’ parent group. J Child Psychol Psychiatry. May. 2009;50(5):617-26. X-4. [pmid: 19076262].
565 Nicolson R, Craven-Thuss B, Smith J. A prospective, open-label trial of galantamine in autistic disorder. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):621-9. X-4. [pmid: 17069550].
566 Nihira K, Yusin A, Sinay R. Perception of parental behavior by adolescents in crisis. Psychol Rep. Dec. 1975;37(3 Pt 1):787-93. X-11. [pmid: 1197556].
567 Nilsen W. Fostering futures: a preventive intervention program for school-age children in foster care. Clin Child Psychol Psychiatry. Jan. 2007;12(1):45-63. X-4a. [pmid: 17378079].
568 Nitkowski D, Petermann F, Buttner P, et al. Behavior modification of aggressive children in child welfare: evaluation of a combined intervention program. Behav Modif. Jul. 2009;33(4):474-92. X-5. [pmid: 19571325].
569 Nitkowski D, Petermann F, Büttner P, et al. Behavior modification of aggressive children in child welfare: Evaluation of a combined intervention program. Behavior Modification. 2009;33(4):474-92. X-5. [pmid: 19571325].
570 Nix RL, Bierman KL, McMahon RJ. How attendance and quality of participation affect treatment response to parent management training. J Consult Clin Psychol. Jun. 2009;77(3):429-38. X-6. [pmid: 19485585].
571 Nixon RDV, Sweeney L, Erickson DB, et al. Parent-child interaction therapy: A comparison of standard and abbreviated treatments for oppositional defiant preschoolers. Journal of Consulting and Clinical Psychology. 2003;71(2):251-60. X-9. [pmid: 12699020].
572 Nixon RDV, Sweeney L, Erickson DB, et al. Parent-Child Interaction Therapy: One- and Two-Year Follow-Up of Standard and Abbreviated Treatments for Oppositional Preschoolers. Journal of Abnormal Child Psychology. 2004;32(3):263-71. X-9. [pmid: 15228175].
573 Nock MK, Kazdin AE. Randomized controlled trial of a brief intervention for increasing participation in parent management training. J Consult Clin Psychol. Oct. 2005;73(5):872-9. X-2, X-6, X-7, X-8. [pmid: 16287387].
574 Novaes CM, Ponde MP, Freire AC. Control of psychomotor agitation and aggressive behavior in patients with autistic disorder: a retrospective chart review. Arq Neuropsiquiatr. Sep. 2008;66(3B):646-51. X-2, X-4, X-6, X-7, X-8. [pmid: 18949256].
575 Nyhan WL. The Lesch-Nyhan syndrome. Dev Med Child Neurol. Jun. 1978;20(3):376-80. X-11. [pmid: 307504].
576 Nylander I. The development of antisocial behaviour in children. Acta Paedopsychiatr. Jun. 1981;47(2):71-80. X-11. [pmid: 7027730].
577 Obsuth I, Moretti MM, Holland R, et al. Conduct disorder: new directions in promoting effective parenting and strengthening parent-adolescent relationships. J Can Acad Child Adolesc Psychiatry. Feb. 2006;15(1):6-15. X-6, X-8. [pmid: 18392190].
578 O'Callaghan P, Branham L, Shannon C, et al. A pilot study of a family focused, psychosocial intervention with war-exposed youth at risk of attack and abduction in north-eastern Democratic Republic of Congo. Child Abuse Negl. Jul. 2014;38(7):1197-207. X-4. [pmid: 24636358].
579 O'Callaghan PM, Allen KD, Powell S, et al. The efficacy of noncontingent escape for decreasing children's disruptive behavior during restorative dental treatment. J Appl Behav Anal. Summer. 2006;39(2):161-71. X-4. [pmid: 16813038].
580 O'Connor TG, Matias C, Futh A, et al. Social learning theory parenting intervention promotes attachment-based caregiving in young children: randomized clinical trial. J Clin Child Adolesc Psychol. 2013;42(3):358-70. X-3, X-5, X-7, X-8. [pmid: 23020146].
581 Oettinger L Jr. Meratran; preliminary report of a new drug for the treatment of behavior disorders in children. Dis Nerv Syst. Oct. 1955;16(10):299-302. X-11. [pmid: 13261892].
582 Ogden T, Amlund Hagen K. What works for whom? Gender differences in intake characteristics and treatment outcomes following Multisystemic Therapy. J Adolesc. Dec. 2009;32(6):1425-35. X-7a. [pmid: 19619894].
583 Ogden T, Hagen KA. Multisystemic Treatment of Serious Behaviour Problems in Youth: Sustainability of Effectiveness Two Years after Intake. Child and Adolescent Mental Health. 2006;11(3):142-9. X-4.
584 Ogden T, Halliday-Boykins CA. Multisystemic treatment of antisocial adolescents in Norway: Replication of clinical outcomes outside of the US. Child and Adolescent Mental Health. 2004;9(2):77-83. X-4.
585 Olds DL, Holmberg JR, Donelan-McCall N, et al. Effects of Home Visits by Paraprofessionals and by Nurses on Children: Follow-up of a Randomized Trial at Ages 6 and 9 Years. JAMA Pediatr. 2013. Dec. 2. X-4, X-6, X-8. [pmid: 24296904].
586 O'Leary KD, Kent RN. A behavioral consultation program for parents and teachers of children with conduct problems. Proc Annu Meet Am Psychopathol Assoc. 1976;(64):89-95. X-11. [pmid: 946689].
587 O'Neal CR, Brotman LM, Huang KY, et al. Understanding relations among early family environment, cortisol response, and child aggression via a prevention experiment. Child Dev. Jan-Feb. 2010;81(1):290-305. X-4, X-8. [pmid: 20331668].
588 O'Neill D, McGilloway S, Donnelly M, et al. A cost-effectiveness analysis of the Incredible Years parenting programme in reducing childhood health inequalities. Eur J Health Econ. Feb. 2013;14(1):85-94. X-7. [pmid: 21853340].
589 O'Neill H, Woodward R. Evaluation of the Parenting Wisely CD-ROM parent-training programme: An Irish replication. Irish Journal of Psychology. 2002;23(1-2):62-72. X-4, X-5, X-6.
590 Oord SV, Ponsioen AJ, Geurts HM, et al. A Pilot Study of the Efficacy of a Computerized Executive Functioning Remediation Training With Game Elements for Children With ADHD in an Outpatient Setting: Outcome on Parent- and Teacher-Rated Executive Functioning and ADHD Behavior. J Atten Disord. 2012. Aug. 9. X-4. [pmid: 22879577].
591 Oosterlaan J, Sergeant JA. Effects of reward and response cost on response inhibition in AD/HD, disruptive, anxious, and normal children. J Abnorm Child Psychol. Jun. 1998;26(3):161-74. X-4, X-6, X-7, X-8. [pmid: 9650623].
592 Ordway MR, Sadler LS, Dixon J, et al. Lasting Effects of an Interdisciplinary Home Visiting Program on Child Behavior: Preliminary Follow-Up Results of a Randomized Trial. J Pediatr Nurs. 2013. May. 15. X-4, X-5. [pmid: 23685264].
593 Orimoto TE, Mueller CW, Hayashi K, et al. Community-based treatment for youth with co- and multimorbid disruptive behavior disorders. Administration and Policy in Mental Health and Mental Health Services Research. 2014;41(2):262-75. X-2, X-6. [pmid: 23334466].
594 Orrell-Valente JK, Pinderhughes EE, Valente E Jr., et al. If it's offered, will they come? Influences on parents' participation in a community-based conduct problems prevention program. Am J Community Psychol. Dec. 1999;27(6):753-83. X-2, X-4, X-5, X-6. [pmid: 10723534].
595 Oruche UM, Gerkensmeyer JE, Carpenter JS, et al. Predicting outcomes among adolescents with disruptive disorders being treated in a system of care program. Journal of the American Psychiatric Nurses Association. 2013;19(6):335-44. X-6. [pmid: 23942090].
596 Osborn SG, West DJ. Do young delinquents really reform?. J Adolesc. Jun. 1980;3(2):99-114. X-11. [pmid: 7381077].
597 Ostberg M, Rydell AM. An efficacy study of a combined parent and teacher management training programme for children with ADHD. Nord J Psychiatry. Apr. 2012;66(2):123-30. X-7a. [pmid: 22150634].
598 Owens JS, Murphy CE, Richerson L, et al. Science to practice in underserved communities: the effectiveness of school mental health programming. J Clin Child Adolesc Psychol. Apr. 2008;37(2):434-47. X-5, X-8. [pmid: 18470779].
599 Palermo MT, Di Luigi M, Dal Forno G, et al. Externalizing and oppositional behaviors and karate-do: the way of crime prevention. A pilot study. Int J Offender Ther Comp Criminol. Dec. 2006;50(6):654-60. X-2, X-8. [pmid: 17068190].
600 Pandina GJ, Bilder R, Harvey PD, et al. Risperidone and cognitive function in children with disruptive behavior disorders. Biological Psychiatry. 2007;62(3):226-34. X-4. [pmid: 17210137].
601 Pantin H, Prado G, Lopez B, et al. A randomized controlled trial of Familias Unidas for Hispanic adolescents with behavior problems. Psychosom Med. Nov. 2009;71(9):987-95. X-4. [pmid: 19834053].
602 Paprocki J, Versiani M. A double-blind comparison between loxapine and haloperidol by parenteral route in acute schizophrenia. Curr Ther Res Clin Exp. Jan. 1977;21(1):80-100. X-11. [pmid: 12922].
603 Parent V, Guay M-C, Lageix P, et al. Cognitive remediation impacts on children with conduct disorder. Annual Review of CyberTherapy and Telemedicine. 2007;5:85-91. X-1, X-5, X-6.
604 Parish-Plass J, Lufi D. Combining physical activity with a behavioral approach in the treatment of young boys with behavior disorders. Small Group Research. 1997;28(3):357-69. X-2, X-7.
605 Patterson GR. Interventions for boys with conduct problems: multiple settings, treatments, and criteria. J Consult Clin Psychol. Aug. 1974;42(4):471-81. X-11. [pmid: 4847255].
606 Patterson GR, Forgatch MS, Degarmo DS. Cascading effects following intervention. Dev Psychopathol. Nov. 2010;22(4):949-70. X-1, X-7, X-8. [pmid: 20883592].
607 Patterson GR, Reid JB. Intervention for families of aggressive boys: a replication study. Behav Res Ther. Nov. 1973;11(4):383-94. X-11. [pmid: 4777636].
608 Patterson J, Barlow J, Mockford C, et al. Improving mental health through parenting programmes: block randomised controlled trial. Arch Dis Child. Dec. 2002;87(6):472-7. X-4. [pmid: 12456542].
609 Pelosi AA, Friedman H. The activity period in group psychotherapy. Psychiatr Q. 1974;48(2):223-9. X-11. [pmid: 4438476].
610 Pepler D, Walsh M, Yuile A, et al. Bridging the gender gap: interventions with aggressive girls and their parents. Prev Sci. Sep. 2010;11(3):229-38. X-4. [pmid: 20107897].
611 Petermann F. Situation-oriented assessment and reduction of aggressive behavior. Int J Rehabil Res. 1980;3(4):561-4. X-11. [pmid: 7203761].
612 Petermann U, Nitkowski D, Polchow D, et al. Therapiestudie: Langfristige effekte des trainings mit aggressiven kindern. Kindheit und Entwicklung. 2007;16(3):143-51. X-6, X-8, X-12.
613 Petermann U, Petermann F, Büttner P, et al. Effektivität kinderverhaltenstherapeutischer maßnahmen in der jugendhilfe: Das training mit aggressiven kindern. Verhaltenstherapie. 2008;18(2):101-8. X-10, X-12.
614 Pfeffer CR, Plutchik R, Mizruchi MS, et al. Assaultive behavior in child psychiatric inpatients, outpatients, and nonpatients. J Am Acad Child Adolesc Psychiatry. Mar. 1987;26(2):256-61. X-11. [pmid: 3584028].
615 Phillips BN. Problem behavior in the elementary school. Child Dev. Sep. 1968;39(3):895-903. X-11. [pmid: 5687334].
616 Phillips J, Morgan S, Cawthorne K, et al. Pilot evaluation of parent-child interaction therapy delivered in an Australian community early childhood clinic setting. Aust N Z J Psychiatry. Aug. 2008;42(8):712-9. X-6. [pmid: 18622779].
617 Platt JE, Campbell M, Grega DM, et al. Cognitive effects of haloperidol and lithium in aggressive conduct-disorder children. Psychopharmacol Bull. Winter. 1984;20(1):93-7. X-11. [pmid: 6718655].
618 Plueck J, Eichelberger I, Hautmann C, et al. Effectiveness of a Teacher-Based Indicated Prevention Program for Preschool Children with Externalizing Problem Behavior. Prev Sci. 2014. Apr. 22. X-6, X-8. [pmid: 24752568].
619 Pogge DL, Young K, Insalaco B, et al. Use of atypical antipsychotic medications in adolescent psychiatric inpatients: a comparison with inpatients who did not receive antipsychotic medications during their stay. Int J Clin Pract. Jun. 2007;61(6):896-902. X-2, X-4, X-5, X-6. [pmid: 17504351].
620 Polanczyk G, Faraone SV, Bau CH, et al. The impact of individual and methodological factors in the variability of response to methylphenidate in ADHD pharmacogenetic studies from four different continents. Am J Med Genet B Neuropsychiatr Genet. Dec. 5. 2008;147B(8):1419-24. X-1, X-4, X-5. [pmid: 18802923].
621 Pond DA. Behavior disorders of the adolescent. Student mental health. Trans Med Soc Lond. 1970;86:116-21. X-11. [pmid: 5494689].
622 Presnall N, Webster-Stratton CH, Constantino JN. Parent training: equivalent improvement in externalizing behavior for children with and without familial risk. J Am Acad Child Adolesc Psychiatry. Aug. 2014;53(8):879-87. 87.e1. 2. X-2a. [pmid: 25062595].
623 Price JM, Roesch S, Walsh NE. Effectiveness of the KEEP Foster Parent Intervention during an Implementation Trial. Child Youth Serv Rev. Dec. 2012;34(12):2487-94. X-4. [pmid: 23359633].
624 Price JM, Roesch S, Walsh NE, et al. Effects of the KEEP Foster Parent Intervention on Child and Sibling Behavior Problems and Parental Stress During a Randomized Implementation Trial. Prev Sci. 2014. Nov. 25. X-4. [pmid: 25418812].
625 Prinz RJ, Miller GE. Family-based treatment for childhood antisocial behavior: experimental influences on dropout and engagement. J Consult Clin Psychol. Jun. 1994;62(3):645-50. X-7, X-8. [pmid: 8063993].
626 Pritchard D, Hoerger M, Mace FC, et al. Clinical translation of animal models of treatment relapse. Journal of the Experimental Analysis of Behavior. 2014;101(3):442-9. X-4, X-6. [pmid: 24700533].
627 Prows CA, Nick TG, Saldana SN, et al. Drug-metabolizing enzyme genotypes and aggressive behavior treatment response in hospitalized pediatric psychiatric patients. J Child Adolesc Psychopharmacol. Aug. 2009;19(4):385-94. X-2, X-4, X-5, X-6, X-7. [pmid: 19702490].
628 Puig-Antich J. Major depression and conduct disorder in prepuberty. J Am Acad Child Psychiatry. Mar. 1982;21(2):118-28. X-11. [pmid: 7069078].
629 Quinn D. The conduct-disordered child-a psychiatric nursing approach. Nurs Times. Mar. 24. 1977;73(12):426-7. X-11. [pmid: 854429].
630 Raine A, Portnoy J, Liu J, et al. Reduction in behavior problems with omega-3 supplementation in children aged 8-16 years: a randomized, double-blind, placebo-controlled, stratified, parallel-group trial. J Child Psychol Psychiatry. 2014. Aug. 22. X-2. [pmid: 25146492].
631 Rawson HE. Residential short-term camping for children with behavior problems: a behavior-modification approach. Child Welfare. Oct. 1973;52(8):511-20. X-11. [pmid: 4780764].
632 Realmuto GM, August GJ, Egan EA. Testing the goodness-of-fit of a multifaceted preventive intervention for children at risk for conduct disorder. Can J Psychiatry. Nov. 2004;49(11):743-52. X-6, X-7. [pmid: 15633852].
633 Reid JB, Eddy JM, Fetrow RA, et al. Description and immediate impacts of a preventive intervention for conduct problems. Am J Community Psychol. Aug. 1999;27(4):483-517. X-5. [pmid: 10573832].
634 Reid MJ, Webster-Stratton C, Baydar N. Halting the development of conduct problems in head start children: the effects of parent training. J Clin Child Adolesc Psychol. Jun. 2004;33(2):279-91. X-4, X-5, X-6, X-7, X-8. [pmid: 15136193].
635 Reisinger JJ. Unprogrammed learning of differential attention by fathers of oppositional children. J Behav Ther Exp Psychiatry. Sep. 1982;13(3):203-8. X-11. [pmid: 7142410].
636 Renshaw DC. Understanding the hyperactive child. IMJ Ill Med J. Apr. 1976;149(4):351-4. X-11. [pmid: 5361].
637 Rey JM, Denshire E, Wever C, et al. Three-year outcome of disruptive adolescents treated in a day program. Eur Child Adolesc Psychiatry. Mar. 1998;7(1):42-8. X-6. [pmid: 9563813].
638 Richman DM, Berg WK, Wacker DP, et al. Using pretreatment and posttreatment assessments to enhance and evaluate existing treatment packages. J Appl Behav Anal. Winter. 1997;30(4):709-12. X-4, X-6, X-7. [pmid: 9433796].
639 Richman DM, Wacker DP, Cooper-Brown LJ, et al. Stimulus characteristics within directives: effects on accuracy of task completion. J Appl Behav Anal. Fall. 2001;34(3):289-312. X-2, X-6. [pmid: 11678525].
640 Rifkin A, Karajgi B, Dicker R, et al. Lithium treatment of conduct disorders in adolescents. Am J Psychiatry. Apr. 1997;154(4):554-5. X-5. [pmid: 9090346].
641 Riggs PD. Clinical approach to treatment of ADHD in adolescents with substance use disorders and conduct disorder. J Am Acad Child Adolesc Psychiatry. Mar. 1998;37(3):331-2. X-1. [pmid: 9519639].
642 Riggs PD, Hall SK, Mikulich-Gilbertson SK, et al. A randomized controlled trial of pemoline for attention-deficit/hyperactivity disorder in substance-abusing adolescents. J Am Acad Child Adolesc Psychiatry. Apr. 2004;43(4):420-9. X-4, X-6. [pmid: 15187802].
643 Riggs PD, Leon SL, Mikulich SK, et al. An open trial of bupropion for ADHD in adolescents with substance use disorders and conduct disorder. J Am Acad Child Adolesc Psychiatry. Dec. 1998;37(12):1271-8. X-4, X-6. [pmid: 9847499].
644 Riggs PD, Mikulich-Gilbertson SK, Davies RD, et al. A randomized controlled trial of fluoxetine and cognitive behavioral therapy in adolescents with major depression, behavior problems, and substance use disorders. Arch Pediatr Adolesc Med. Nov. 2007;161(11):1026-34. X-4. [pmid: 17984403].
645 Rimm DC, Hill GA, Brown NN, et al. Group-assertive training in treatment of expression of inappropriate anger. Psychol Rep. Jun. 1974;34(3):791-8. X-11. [pmid: 4846914].
646 Robbins MS, Szapocznik J, Horigian VE, et al. Brief strategic family therapy for adolescent drug abusers: a multi-site effectiveness study. Contemp Clin Trials. May. 2009;30(3):269-78. X-4. [pmid: 19470315].
647 Roberts D. An evaluation of a community-based basic parenting programme: a two-year follow-up. Community Pract. Feb. 2012;85(2):27-31. X-2, X-4, X-6, X-7, X-8. [pmid: 22439447].
648 Robinson BA, Winiarski DA, Brennan PA, et al. Social Context, Parental Monitoring, and Multisystemic Therapy Outcomes. Psychotherapy (Chic). 2014. Nov. 3. X-6. [pmid: 25365153].
649 Rodman FR. SETTING LIMITS FOR AGGRESSIVE CHILDREN. Ment Hosp. Nov. 1964;15:606. X-11. [pmid: 14228744].
650 Rodriguez GM, Bagner DM, Graziano PA. Parent Training for Children Born Premature: A Pilot Study Examining the Moderating Role of Emotion Regulation. Child Psychiatry Hum Dev. 2013. May. 17. X-4. [pmid: 23681677].
651 Rodriguez GM, Bagner DM, Graziano PA. Parent training for children born premature: a pilot study examining the moderating role of emotion regulation. Child Psychiatry Hum Dev. Apr. 2014;45(2):143-52. X-4. [pmid: 23681677].
652 Roke Y, Buitelaar JK, Boot AM, et al. Risk of hyperprolactinemia and sexual side effects in males 10-20 years old diagnosed with autism spectrum disorders or disruptive behavior disorder and treated with risperidone. J Child Adolesc Psychopharmacol. Dec. 2012;22(6):432-9. X-2, X-6. [pmid: 23234586].
653 Roke Y, van Harten PN, Buitelaar JK, et al. Antipsychotic-induced hyperprolactinemia and testosterone levels in boys. Horm Res Paediatr. 2012;77(4):235-40. X-2, X-6, X-7. [pmid: 22538969].
654 Roke Y, van Harten PN, Buitelaar JK, et al. Bone mineral density in male adolescents with autism spectrum disorders and disruptive behavior disorder with or without antipsychotic treatment. Eur J Endocrinol. Dec. 2012;167(6):855-63. X-4. [pmid: 23011870].
655 Rollin SA, Potts I, Kaiser-Ulrey C, et al. Middle school internships for at-risk youth: a proven intervention. Ethn Dis. Summer. 2003;13(3 Suppl 3):S3-99-101. X-5, X-6. [pmid: 14552464].
656 Romano E, Thornhill S, Lacourse E. An 8-year follow-up study of profiles and predictors of methylphenidate use in a nationwide sample of boys. J Pediatr. Nov. 2009;155(5):721-7. X-2. [pmid: 19643442].
657 Ronan KR, Kendall PC. Non-self-controlled adolescents: applications of cognitive-behavioral therapy. Adolesc Psychiatry. 1990;17:479-505. X-11. [pmid: 2240433].
658 Roscoe EM, Kindle AE, Pence ST. Functional analysis and treatment of aggression maintained by preferred conversational topics. J Appl Behav Anal. Winter. 2010;43(4):723-7. X-2, X-4, X-6, X-7, X-8. [pmid: 21541156].
659 Rose J, Loftus M, Flint B, et al. Factors associated with the efficacy of a group intervention for anger in people with intellectual disabilities. Br J Clin Psychol. Sep. 2005;44(Pt 3):305-17. X-4. [pmid: 16238879].
660 Rosenbaum JB. Gender-specific problems in the treatment of young women. Am J Psychoanal. Fall. 1977;37(3):215-21. X-11. [pmid: 596477].
661 Rosenberg RM, Mueller BC. Preschool antisocial children. Psychodynamic considerations and implications for treatment. J Am Acad Child Psychiatry. Jul. 1968;7(3):421-41. X-11. [pmid: 5666078].
662 Rosenthal L. Some dynamics of resistance and therapeutic management in adolescent group therapy. Psychoanal Rev. Fall. 1971;58(3):353-66. X-11. [pmid: 5150683].
663 Rowland MD, Halliday-Boykins CA, Henggeler SW, et al. A Randomized Trial of Multisystemic Therapy With Hawaii's Felix Class Youths. Journal of Emotional and Behavioral Disorders. 2005;13(1):13-23. X-4.
664 Ruby E, Sher L. Prevention of suicidal behavior in adolescents with post-traumatic stress disorder. Int J Adolesc Med Health. 2013;25(3):283-93. X-1, X-2, X-4, X-5, X-6, X-7, X-8. [pmid: 23843573].
665 Ryan SR, Stanger C, Thostenson J, et al. The impact of disruptive behavior disorder on substance use treatment outcome in adolescents. J Subst Abuse Treat. May-Jun. 2013;44(5):506-14. X-8. [pmid: 23228436].
666 Sachdeva S, Goldman G, Mustata G, et al. Naturalistic outcomes of evidence-based therapies for borderline personality disorder at a university clinic: a quasi-randomized trial. J Am Psychoanal Assoc. Jun. 2013;61(3):578-84. X-3, X-4. [pmid: 23720029].
667 Safer DJ. Establishing boundary lines for families of children with behavior disorders. Psychiatr Q Suppl. 1968;42(Pt 1):86-97. X-11. [pmid: 4190009].
668 Salmon K, Dadds MR, Allen J, et al. Can emotional language skills be taught during parent training for conduct problem children?. Child Psychiatry Hum Dev. Dec. 2009;40(4):485-98. X-7. [pmid: 19373551].
669 Salmon K, Dittman C, Sanders M, et al. Does adding an emotion component enhance the Triple P-Positive Parenting Program?. J Fam Psychol. Apr. 2014;28(2):244-52. X-4. [pmid: 24588606].
670 Salzer S, Cropp C, Jaeger U, et al. Psychodynamic therapy for adolescents suffering from co-morbid disorders of conduct and emotions in an in-patient setting: A randomized controlled trial. Psychological Medicine. 2014;44(10):2213-22. X-5. [pmid: 24229481].
671 Salzman C, Green AI, Rodriguez-Villa F, et al. Benzodiazepines combined with neuroleptics for management of severe disruptive behavior. Psychosomatics. Jan. 1986;27(1 Suppl):17-22. X-11. [pmid: 3952250].
672 Sanchez LE, Armenteros JL, Small AM, et al. Placebo response in aggressive children with conduct disorder. Psychopharmacol Bull. 1994;30(2):209-13. X-2, X-5, X-6, X-7, X-8. [pmid: 7831457].
673 Sanders LM, Schaechter J, Serwint JR. Conduct disorder. Pediatr Rev. Nov. 2007;28(11):433-4. discussion 4. X-1, X-2, X-5, X-6, X-7. [pmid: 17974708].
674 Sanders MR, Christensen AP. A comparison of the effects of child management and planned activities training in five parenting environments. J Abnorm Child Psychol. Mar. 1985;13(1):101-17. X-11. [pmid: 3973246].
675 Sanders MR, Dittman CK, Farruggia SP, et al. A comparison of online versus workbook delivery of a self-help positive parenting program. J Prim Prev. Jun. 2014;35(3):125-33. X-5. [pmid: 24500106].
676 Sanders MR, Montgomery DT, Brechman-Toussaint ML. The mass media and the prevention of child behavior problems: the evaluation of a television series to promote positive outcomes for parents and their children. J Child Psychol Psychiatry. Oct. 2000;41(7):939-48. X-2, X-8. [pmid: 11079436].
677 Sanders MR, Plant K. Programming for generalization to high and low risk parenting situations in families with oppositional developmentally disabled preschoolers. Behav Modif. Jul. 1989;13(3):283-305. X-11. [pmid: 2764862].
678 Santinello M, Cristini F, Vieno A, et al. “Volunteering by chance” to promote civic responsibility and civic engagement: does it work?. J Prev Interv Community. Jan. 2012;40(1):64-79. X-4, X-5. [pmid: 22242782].
679 Santos RG, Chartier MJ, Whalen JC, et al. Effectiveness of school-based violence prevention for children and youth: a research report. Healthc Q. 2011. Apr. 14. Spec No: 80-91. X-4, X-5. [pmid: 24956430].
680 Sarne Y, Mandel J, Goncalves MH, et al. Imipramine binding to blood platelets and aggressive behavior in offenders, schizophrenics and normal volunteers. Neuropsychobiology. 1995;31(3):120-4. X-2, X-3, X-4, X-5. [pmid: 7609859].
681 Satterfield JH, Satterfield BT, Cantwell DP. Three-year multimodality treatment study of 100 hyperactive boys. J Pediatr. Apr. 1981;98(4):650-5. X-11. [pmid: 7205499].
682 Saxena K, Silverman MA, Chang K, et al. Baseline predictors of response to divalproex in conduct disorder. J Clin Psychiatry. Dec. 2005;66(12):1541-8. X-4, X-5. [pmid: 16401155].
683 Scahill L. How do I decide whether or not to use medication for my child with autism? Should I try behavior therapy first?. J Autism Dev Disord. Jul. 2008;38(6):1197-8. X-1, X-5. [pmid: 18463973].
684 Scahill L, Sukhodolsky DG, Bearss K, et al. Randomized trial of parent management training in children with tic disorders and disruptive behavior. J Child Neurol. Aug. 2006;21(8):650-6. X-4, X-6. [pmid: 16970865].
685 Scarboro ME, Forehand R. Effects of two types of response-contingent time-out on compliance and oppositional behavior of children. J Exp Child Psychol. Apr. 1975;19(2):252-64. X-11. [pmid: 1151283].
686 Schaeffer CM, Borduin CM. Long-term follow-up to a randomized clinical trial of multisystemic therapy with serious and violent juvenile offenders. J Consult Clin Psychol. Jun. 2005;73(3):445-53. X-4. [pmid: 15982142].
687 Scharer KM. Helping disturbed children change their passive-aggressive behavior through milieu therapy. ANA Publ. 1979;(NP-59):275-92. X-11. [pmid: 259410].
688 Scharfstein DO, Manski CF, Anthony JC. On the construction of bounds in prospective studies with missing ordinal outcomes: application to the good behavior game trial. Biometrics. Mar. 2004;60(1):154-64. X-2, X-4, X-5, X-6, X-8. [pmid: 15032785].
689 Schechter DS, Willheim E. When parenting becomes unthinkable: intervening with traumatized parents and their toddlers. J Am Acad Child Adolesc Psychiatry. Mar. 2009;48(3):249-53. X-1, X-2, X-3, X-4, X-5, X-6. [pmid: 19242290].
690 Scheeringa MS, Weems CF, Cohen JA, et al. Trauma-focused cognitive-behavioral therapy for posttraumatic stress disorder in three-through six year-old children: a randomized clinical trial. J Child Psychol Psychiatry. Aug. 2011;52(8):853-60. X-4. [pmid: 21155776].
691 Scheres A, Oosterlaan J, Sergeant JA. Response inhibition in children with DSM-IV subtypes of AD/HD and related disruptive disorders: the role of reward. Child Neuropsychol. Sep. 2001;7(3):172-89. X-2, X-6, X-7, X-8. [pmid: 12187474].
692 Schmidt MH, Mocks P, Lay B, et al. Does oligoantigenic diet influence hyperactive/conduct-disordered children--a controlled trial. Eur Child Adolesc Psychiatry. Jun. 1997;6(2):88-95. X-2, X-5. [pmid: 9257090].
693 Schmidt MH, Möcks P, Lay B, et al. Does oligoantigenic diet influence hyperactive/conduct-disordered children—a controlled trial. European Child & Adolescent Psychiatry. 1997;6(2):88-95. X-2, X-5, X-6. [pmid: 9257090].
694 Schoenwald SK, Chapman JE, Sheidow AJ, et al. Long-term youth criminal outcomes in MST transport: the impact of therapist adherence and organizational climate and structure. J Clin Child Adolesc Psychol. Jan. 2009;38(1):91-105. X-4, X-7. [pmid: 19130360].
695 Schoenwald SK, Garland AF, Southam-Gerow MA, et al. Adherence Measurement in Treatments for Disruptive Behavior Disorders: Pursuing Clear Vision through Varied Lenses. Clin Psychol (New York). Dec. 1. 2011;18(4):331-41. X-1, X-2, X-4, X-5, X-6, X-8. [pmid: 22563149].
696 Scholer SJ, Reich SM, Boshers RB, et al. A brief program improves counseling of mothers with children who have persistent aggression. J Interpers Violence. Apr. 2012;27(6):991-1004. X-2, X-3, X-4. [pmid: 22204948].
697 Schuppert HM, Giesen-Bloo J, van Gemert TG, et al. Effectiveness of an emotion regulation group training for adolescents--a randomized controlled pilot study. Clin Psychol Psychother. Nov-Dec. 2009;16(6):467-78. X-4, X-7, X-8. [pmid: 19630069].
698 Schuppert HM, Timmerman ME, Bloo J, et al. Emotion regulation training for adolescents with borderline personality disorder traits: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Dec. 2012;51(12):1314-23 e2. X-4, X-7, X-8. [pmid: 23200288].
699 Schvehla TJ, Mandoki MW, Sumner GS. Clonidine therapy for comorbid attention deficit hyperactivity disorder and conduct disorder: preliminary findings in a children's inpatient unit. South Med J. Jul. 1994;87(7):692-5. X-5, X-6. [pmid: 8023201].
700 Scott S. Deciding whether interventions for antisocial behaviour work: principles of outcome assessment, and practice in a multicentre trial. Eur Child Adolesc Psychiatry. Suppl 1. 2001;10:I59-70. X-1, X-7. [pmid: 11794557].
701 Scott S, Briskman J, O'Connor TG. Early prevention of antisocial personality: long-term follow-up of two randomized controlled trials comparing indicated and selective approaches. Am J Psychiatry. Jun. 2014;171(6):649-57. X-2a. [pmid: 24626738].
702 Segal D, Chen PY, Gordon DA, et al. Development and evaluation of a parenting intervention program: Integration of scientific and practical approaches. International Journal of Human-Computer Interaction. 2003;15(3):453-67. X-4.
703 Serra-Pinheiro MA, Mattos P, Souza I, et al. The effect of methylphenidate on oppositional defiant disorder comorbid with attention deficit/hyperactivity disorder. Arq Neuropsiquiatr. Jun. 2004;62(2B):399-402. X-6. [pmid: 15273834].
704 Shabry F, Wolk JA. Granulocytopenia in children after phenothiazine therapy. Am J Psychiatry. Mar. 1980;137(3):374-5. X-11. [pmid: 6101935].
705 Shaffer A, Lindhiem O, Kolko DJ, et al. Bidirectional relations between parenting practices and child externalizing behavior: a cross-lagged panel analysis in the context of a psychosocial treatment and 3-year follow-up. J Abnorm Child Psychol. Feb. 2013;41(2):199-210. X-6, X-8. [pmid: 22821450].
706 Shagass C, Bittle RM. Therapeutic effects of LSD: a follow-up study. J Nerv Ment Dis. Jun. 1967;144(6):471-8. X-11. [pmid: 4860930].
707 Shamoo AE, Tauer CA. Ethically questionable research with children: the fenfluramine study. Account Res. Jul-Dec. 2002;9(3-4):143-66. X-1, X-2, X-4, X-5. [pmid: 12816124].
708 Shapiro A. Problems of behaviour disorder and delinquency in adolescents and its treatment. J Bras Psiquiatr. 1968;17(1):7-23. X-11. [pmid: 5760627].
709 Shapiro JP, Welker CJ, Jacobson BJ. A naturalistic study of psychotherapeutic methods and client in-therapy functioning in a child community setting. J Clin Child Psychol. Dec. 1997;26(4):385-96. X-6. [pmid: 9418177].
710 Shaw DS, Dishion TJ, Supplee L, et al. Randomized trial of a family-centered approach to the prevention of early conduct problems: 2-year effects of the family check-up in early childhood. J Consult Clin Psychol. Feb. 2006;74(1):1-9. X-4. [pmid: 16551138].
711 Shechtman Z. The relation of client behavior and therapist helping skills to reduced aggression of boys in individual and group treatment. Int J Group Psychother. Oct. 2004;54(4):435-54. X-4, X-5. [pmid: 15388400].
712 Shechtman Z, Leichtentritt J. The association of process with outcomes in child group therapy. Psychother Res. Jan. 2010;20(1):8-21. X-4, X-5, X-6, X-7. [pmid: 19634048].
713 Shelton TL, Barkley RA, Crosswait C, et al. Multimethod psychoeducational intervention for preschool children with disruptive behavior: two-year post-treatment follow-up. J Abnorm Child Psychol. Jun. 2000;28(3):253-66. X-5. [pmid: 10885683].
714 Shenk CE, Dorn LD, Kolko DJ, et al. Predicting treatment response for oppositional defiant and conduct disorder using pre-treatment adrenal and gonadal hormones. Journal of Child and Family Studies. 2012;21(6):973-81. X-8.
715 Sherburne S, Utley B, McConnell S, et al. Decreasing violent or aggressive theme play among preschool children with behavior disorders. Except Child. Oct. 1988;55(2):166-72. X-11. [pmid: 3191930].
716 Sheridan SM, Ryoo JH, Garbacz SA, et al. The efficacy of conjoint behavioral consultation on parents and children in the home setting: Results of a randomized controlled trial. J Sch Psychol. Dec. 2013;51(6):717-33. X-5. [pmid: 24295145].
717 Shipley D. Safety net. Ment Health Today. Jul-Aug. 2014:12-3. X-1. [pmid: 25195232].
718 Shytle RD, Silver AA, Sheehan KH, et al. Neuronal nicotinic receptor inhibition for treating mood disorders: Preliminary controlled evidence with mecamylamine. Depression and Anxiety. 2002;16(3):89-92. X-2, X-4. [pmid: 12415531].
719 Siassi I. Lithium treatment of impulsive behavior in children. J Clin Psychiatry. Dec. 1982;43(12):482-4. X-11. [pmid: 6819289].
720 Sidora-Arcoleo K, Anson E, Lorber M, et al. Differential effects of a nurse home-visiting intervention on physically aggressive behavior in children. J Pediatr Nurs. Feb. 2010;25(1):35-45. X-4, X-8. [pmid: 20117675].
721 Sieving RE, McMorris BJ, Secor-Turner M, et al. Prime Time: 18-Month Violence Outcomes of a Clinic-Linked Intervention. Prev Sci. 2013. Apr. 2. X-4. [pmid: 23543359].
722 Signorovitch J, Erder MH, Xie J, et al. Comparative effectiveness research using matching-adjusted indirect comparison: an application to treatment with guanfacine extended release or atomoxetine in children with attention-deficit/hyperactivity disorder and comorbid oppositional defiant disorder. Pharmacoepidemiol Drug Saf. May. Suppl 2. 2012;21:130-7. X-1, X-4. [pmid: 22552988].
723 Sinzig J, Döpfner M, Lehmkuhl G. Long-acting methylphenidate has an effect on aggressive behavior in children with attention-deficit/hyperactivity disorder. Journal of Child and Adolescent Psychopharmacology. 2007;17(4):421-32. X-4. [pmid: 17822338].
724 Sinzig J, Dopfner M, Lehmkuhl G, et al. Long-acting methylphenidate has an effect on aggressive behavior in children with attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. Aug. 2007;17(4):421-32. X-4. [pmid: 17822338].
725 Slavkin ML. What every clinician needs to know about juvenile firesetters. Psychiatr Serv. Oct. 2002;53(10):1237-8. X-1, X-2. [pmid: 12364667].
726 Smith C. Mental health of children and young people in hospital. Paediatr Nurs. Jun. 2009;21(5):28-31. X-1, X-2, X-4, X-5, X-6, X-7. [pmid: 19552248].
727 Smith JD, Dishion TJ, Shaw DS, et al. Negative Relational Schemas Predict the Trajectory of Coercive Dynamics During Early Childhood. J Abnorm Child Psychol. 2014. Sep. 11. X-2, X-4. [pmid: 25208813].
728 Smith JD, Knoble NB, Zerr AA, et al. Family check-up effects across diverse ethnic groups: reducing early-adolescence antisocial behavior by reducing family conflict. J Clin Child Adolesc Psychol. 2014;43(3):400-14. X-4. [pmid: 24731120].
729 Smith TE, Sells SP, Rodman J, et al. Reducing adolescent substance abuse and delinquency: Pilot research of a family-oriented psychoeducation curriculum. Journal of Child & Adolescent Substance Abuse. 2006;15(4):105-15. X-6.
730 Smolkowski K, Biglan A, Barrera M, et al. Schools and homes in partnership (SHIP): long-term effects of a preventive intervention focused on social behavior and reading skill in early elementary school. Prev Sci. Jun. 2005;6(2):113-25. X-5, X-7. [pmid: 15889626].
731 Snyder J, McEachern A, Schrepferman L, et al. Contribution of peer deviancy training to the early development of conduct problems: mediators and moderators. Behav Ther. Sep. 2010;41(3):317-28. X-2, X-4, X-5, X-6, X-7, X-8. [pmid: 20569781].
732 Snyder R, Turgay A, Aman M, et al. Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage IQs. J Am Acad Child Adolesc Psychiatry. Sep. 2002;41(9):1026-36. X-4. [pmid: 12218423].
733 Soleimani S, Sharif F, Mani A, et al. The Effect of Conflict Resolution Training on Children's Behavioral Problems in Shiraz, Southern Iran: A Randomized Controlled Trial. Int J Community Based Nurs Midwifery. Jul. 2014;2(3):185-95. X-4. [pmid: 25349861].
734 Solholm R, Kjobli J, Christiansen T. Early initiatives for children at risk-development of a program for the prevention and treatment of behavior problems in primary services. Prev Sci. Dec. 2013;14(6):535-44. X-1, X-2, X-5, X-6. [pmid: 23404660].
735 Solomon M, Ono M, Timmer S, et al. The effectiveness of parent-child interaction therapy for families of children on the autism spectrum. J Autism Dev Disord. Oct. 2008;38(9):1767-76. X-4. [pmid: 18401693].
736 Solovey De Milechnin G. Conduct problems in children and hypnosis. Dis Nerv Syst. Aug. 1955;16(8):249-53. X-11. [pmid: 13241327].
737 Somogyi I, Vetro A, Szentistvanyi I, et al. Lithium treatment of aggressive children and the EEG. Acta Paediatr Hung. 1988;29(3-4):365-72. X-11. [pmid: 3151984].
738 Spada S, Bomba M, Donati C, et al. Risperidone in età pediatrica: Tollerabilità ed efficacia nei soggetti con disturbo da comportamento dirompente. Giornale di Neuropsichiatria dell'Età Evolutiva. 2011;31(2):149-53. X-10, X-12.
739 Spence D. Bad medicine: medicated minors. BMJ. 2010;341:c3907. X-1. [pmid: 20659982].
740 Spijkers W, Jansen DE, Reijneveld SA. Effectiveness of Primary Care Triple P on child psychosocial problems in preventive child healthcare: a randomized controlled trial. BMC Med. Nov. 11. 2013;11(1):240. X-4, X-8. [pmid: 24207163].
741 Spoth RL, Redmond C, Shin C. Reducing adolescents' aggressive and hostile behaviors: randomized trial effects of a brief family intervention 4 years past baseline. Arch Pediatr Adolesc Med. Dec. 2000;154(12):1248-57. X-5, X-7. [pmid: 11115311].
742 Spuij M, Prinzie P, Dekovic M, et al. The effectiveness of Grief-Help, a cognitive behavioural treatment for prolonged grief in children: study protocol for a randomised controlled trial. Trials. Nov. 20. 2013;14(1):395. X-4, X-7, X-8. [pmid: 24252587].
743 Stadler C, Grasmann D, Fegert JM, et al. Heart rate and treatment effect in children with disruptive behavior disorders. Child Psychiatry Hum Dev. Sep. 2008;39(3):299-309. X-2, X-6. [pmid: 18058222].
744 Staller JA. Psychopharmacologic treatment of aggressive preschoolers: a chart review. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 30. 2007;31(1):131-5. X-2, X-6, X-8. [pmid: 17007977].
745 Stanger C, Noel V. A social skills and parental training intervention for disruptive boys reduces substance use behaviours in adolescence. Evid Based Ment Health. 2013. Dec. 12. X-1. [pmid: 24336694].
746 Stein DB. Outpatient behavioral management of aggressiveness in adolescents: A response cost paradigm. Aggressive Behavior. 1999;25(5):321-30. X-6, X-7.
747 Stein DB, Smith ED. The “REST” program: a new treatment system for the oppositional defiant adolescent. Adolescence. Winter. 1990;25(100):891-904. X-11. [pmid: 2275444].
748 Steinberg GG, Troshinsky C, Steinberg HR. Dextroamphetamine-responsive behavior disorder in school children. Am J Psychiatry. Aug. 1971;128(2):174-9. X-11. [pmid: 4939589].
749 Sternbach O. Arrested ego development and its treatment in conduct disorders and neuroses of childhood. Nerv Child. Jul. 1947;6(3):306-17. X-11. [pmid: 20254531].
750 Stevens L, Zhang W, Peck L, et al. EFA supplementation in children with inattention, hyperactivity, and other disruptive behaviors. Lipids. Oct. 2003;38(10):1007-21. X-8. [pmid: 14669965].
751 Stocks JD, Taneja BK, Baroldi P, et al. A phase 2a randomized, parallel group, dose-ranging study of molindone in children with attention-deficit/hyperactivity disorder and persistent, serious conduct problems. J Child Adolesc Psychopharmacol. Apr. 2012;22(2):102-11. X-6. [pmid: 22372512].
752 Strayhorn JM, Weidman CS. Reduction of attention deficit and internalizing symptoms in preschoolers through parent-child interaction training. J Am Acad Child Adolesc Psychiatry. Nov. 1989;28(6):888-96. X-11. [pmid: 2808259].
753 Stroh G. The function of in-service training in the management of disturbed children. J Child Psychol Psychiatry. Dec. 1968;9(3):189-201. X-11. [pmid: 5730947].
754 Stubblefield RL. Adolescent behaviour disorders. Evaluation and treatment. Tex State J Med. Apr. 1962;58:284-7. X-11. [pmid: 13917945].
755 Sukhodolsky DG, Gorman BS, Scahill L, et al. Exposure and response prevention with or without parent management training for children with obsessive-compulsive disorder complicated by disruptive behavior: a multiple-baseline across-responses design study. J Anxiety Disord. Apr. 2013;27(3):298-305. X-2a, X-7a. [pmid: 23602943].
756 Sukhodolsky DG, Vitulano LA, Carroll DH, et al. Randomized trial of anger control training for adolescents with Tourette's syndrome and disruptive behavior. J Am Acad Child Adolesc Psychiatry. Apr. 2009;48(4):413-21. X-4, X-6, X-8. [pmid: 19242384].
757 Sundell K, Hansson K, Löfholm CA, et al. The transportability of multisystemic therapy to Sweden: Short-term results from a randomized trial of conduct-disordered youths. Journal of Family Psychology. 2008;22(4):550-60. X-9. [pmid: 18729669].
758 Suveg C, Hudson JL, Brewer G, et al. Cognitive-behavioral therapy for anxiety-disordered youth: secondary outcomes from a randomized clinical trial evaluating child and family modalities. J Anxiety Disord. Apr. 2009;23(3):341-9. X-4. [pmid: 19216048].
759 Svanborg P, Thernlund G, Gustafsson PA, et al. Atomoxetine improves patient and family coping in attention deficit/hyperactivity disorder: a randomized, double-blind, placebo-controlled study in Swedish children and adolescents. Eur Child Adolesc Psychiatry. Dec. 2009;18(12):725-35. X-4. [pmid: 19466476].
760 Svendsen BB, Willadsen J. THE USE OF HALOPERIDOL (SERENASE (R)) IN CHLORPROTIXEN RESISTANT PATIENTS. Acta Psychiatr Scand. Suppl169. 1963;39:351-5. X-11. [pmid: 14078687].
761 Swanson JM, Kraemer HC, Hinshaw SP, et al. Clinical relevance of the primary findings of the MTA: success rates based on severity of ADHD and ODD symptoms at the end of treatment. J Am Acad Child Adolesc Psychiatry. Feb. 2001;40(2):168-79. X-4. [pmid: 11211365].
762 Swanson JW, Swartz MS, Van Dorn RA, et al. Comparison of antipsychotic medication effects on reducing violence in people with schizophrenia. Br J Psychiatry. Jul. 2008;193(1):37-43. X-3, X-4. [pmid: 18700216].
763 Swart GT, Siman E, Stewart SL. The use of Pro Re Nata or Statim medications for behavioral control: a summary of experience at a tertiary care children's mental health center. J Child Adolesc Psychopharmacol. Feb. 2011;21(1):67-77. X-2, X-4, X-5. [pmid: 21288118].
764 Swart J, Apsche J. Mindfulness, mode deactivation, and family therapy: A winning combination for treating adolescents with complex trauma and behavioral problems. International Journal of Behavioral Consultation and Therapy. 2014;9(2):9-14. X-5.
765 Tamm L, Trello-Rishel K, Riggs P, et al. Predictors of treatment response in adolescents with comorbid substance use disorder and attention-deficit/hyperactivity disorder. J Subst Abuse Treat. Feb. 2013;44(2):224-30. X-4, X-7, X-8. [pmid: 22889694].
766 Tanner VL, Holliman WB. Effectiveness of assertiveness training in modifying aggressive behaviors of young children. Psychol Rep. Feb. 1988;62(1):39-46. X-11. [pmid: 3363075].
767 Tavormina JB, Henggeler SW, Gayton WF. Age trends in parental assessments of the behavior problems of their retarded children. Ment Retard. Feb. 1976;14(1):38-9. X-11. [pmid: 1250150].
768 Taylor E, Schachar R, Thorley G, et al. Which boys respond to stimulant medication? A controlled trial of methylphenidate in boys with disruptive behaviour. Psychol Med. Feb. 1987;17(1):121-43. X-11. [pmid: 3554290].
769 Teixeira EH, Celeri EV, Jacintho ACA, et al. Clozapine in severe conduct disorder. Journal of Child and Adolescent Psychopharmacology. 2013;23(1):44-8. X-6. [pmid: 23347126].
770 Ter-Stepanian M, Grizenko N, Zappitelli M, et al. Clinical response to methylphenidate in children diagnosed with attention-deficit hyperactivity disorder and comorbid psychiatric disorders. Can J Psychiatry. May. 2010;55(5):305-12. X-4, X-7. [pmid: 20482957].
771 Theise R, Huang KY, Kamboukos D, et al. Moderators of intervention effects on parenting practices in a randomized controlled trial in early childhood. J Clin Child Adolesc Psychol. 2014;43(3):501-9. X-2, X-4, X-7. [pmid: 24063291].
772 Theodore LA, Bray MA, Kehle TJ, et al. Randomization of group contingencies and reinforcers to reduce classroom disruptive behavior. Journal of School Psychology. 2001;39(3):267-77. X-5.
773 Thomas CR. Evidence-based practice for conduct disorder symptoms. J Am Acad Child Adolesc Psychiatry. Jan. 2006;45(1):109-14. X-1, X-2, X-5, X-6, X-7, X-8. [pmid: 16327588].
774 Thorell LB. The Community Parent Education Program (COPE): treatment effects in a clinical and a community-based sample. Clin Child Psychol Psychiatry. Jul. 2009;14(3):373-87. X-7a. [pmid: 19515754].
775 Tiernan K, Foster SL, Cunningham PB, et al. Predicting Early Positive Change in Multisystemic Therapy With Youth Exhibiting Antisocial Behaviors. Psychotherapy (Chic). 2014. May. 26. X-4, X-6. [pmid: 24866967].
776 Timmer SG, Ware LM, Urquiza AJ, et al. The effectiveness of parent-child interaction therapy for victims of interparental violence. Violence Vict. 2010;25(4):486-503. X-6. [pmid: 20712147].
777 Timmons-Mitchell J, Bender MB, Kishna MA, et al. An independent effectiveness trial of multisystemic therapy with juvenile justice youth. J Clin Child Adolesc Psychol. Jun. 2006;35(2):227-36. X-4. [pmid: 16597218].
778 Tolan PH, Gorman-Smith D, Henry D, et al. The benefits of booster interventions: evidence from a family-focused prevention program. Prev Sci. Dec. 2009;10(4):287-97. X-4, X-8. [pmid: 19513845].
779 Tremblay RE, McCord J, Boileau H, et al. Can disruptive boys be helped to become competent?. Psychiatry. May. 1991;54(2):148-61. X-11. [pmid: 1852848].
780 Troost PW, Althaus M, Lahuis BE, et al. Neuropsychological effects of risperidone in children with pervasive developmental disorders: a blinded discontinuation study. J Child Adolesc Psychopharmacol. Oct. 2006;16(5):561-73. X-4. [pmid: 17069545].
781 Turgay A, Binder C, Snyder R, et al. Long-term safety and efficacy of risperidone for the treatment of disruptive behavior disorders in children with subaverage IQs. Pediatrics. Sep. 2002;110(3):e34. X-4. [pmid: 12205284].
782 Uliaszek AA, Wilson S, Mayberry M, et al. A pilot intervention of multifamily dialectical behavior group therapy in a treatment-seeking adolescent population: Effects on teens and their family members. The Family Journal. 2014;22(2):206-15. X-4, X-6.
783 van Bokhoven I, Matthys W, van Goozen SHM, et al. Adolescent outcome of disruptive behaviour disorder in children who had been treated in in-patient and day-treatment settings. European Child & Adolescent Psychiatry. 2006;15(2):79-87. X-5, X-6, X-7. [pmid: 16463012].
784 van de Wiel NM, van Goozen SH, Matthys W, et al. Cortisol and treatment effect in children with disruptive behavior disorders: a preliminary study. J Am Acad Child Adolesc Psychiatry. Aug. 2004;43(8):1011-8. X-2, X-6. [pmid: 15266196].
785 Van De Wiel NMH, Matthys W, Cohen-Kettenis P, et al. Application of the Utrecht Coping Power Program and Care as Usual to Children With Disruptive Behavior Disorders in Outpatient Clinics: A Comparative Study of Cost and Course of Treatment. Behavior Therapy. 2003;34(4):421-36. X-6, X-7.
786 van den Hoofdakker BJ, Nauta MH, van der Veen-Mulders L, et al. Behavioral parent training as an adjunct to routine care in children with attention-deficit/hyperactivity disorder: moderators of treatment response. J Pediatr Psychol. Apr. 2010;35(3):317-26. X-4. [pmid: 19633060].
787 van Krevelen DA, Maresca A, Schreurs-Dijkrtra M. Evaluation of Tegretol in the treatment of behavior disorders in children. Methodology and results. Acta Paedopsychiatr. Dec. 1970;37(7):222-34. X-11. [pmid: 4927118].
788 van Loon LM, Granic I, Engels RC. The Role of Maternal Depression on Treatment Outcome for Children with Externalizing Behavior Problems. J Psychopathol Behav Assess. Jun. 2011;33(2):178-86. X-6. [pmid: 21765595].
789 van Oorsouw WM, Israel ML, von Heyn RE, et al. Side effects of contingent shock treatment. Res Dev Disabil. Nov-Dec. 2008;29(6):513-23. X-2, X-5, X-8. [pmid: 17945467].
790 van Praag HM, Dols LC, Schut T. Biochemical versus psychopathological action profile of neuroleptics: a comparative study of chlorpromazine and oxypertine in acute psychotic disorders. Compr Psychiatry. May-Jun. 1975;16(3):255-63. X-11. [pmid: 237735].
791 Van Ryzin MJ, Dishion TJ. The impact of a family-centered intervention on the ecology of adolescent antisocial behavior: modeling developmental sequelae and trajectories during adolescence. Dev Psychopathol. Aug. 2012;24(3):1139-55. X-4. [pmid: 22781876].
792 Vance JE. Aggressive youth: healing biology with relationship. Ann N Y Acad Sci. Jan. 15. 1997;807:587-9. X-1. [pmid: 9071405].
793 Vancraeyveldt C, Verschueren K, Wouters S, et al. Improving Teacher-Child Relationship Quality and Teacher-Rated Behavioral Adjustment Amongst Externalizing Preschoolers: Effects of a Two-Component Intervention. J Abnorm Child Psychol. 2014. Jul. 16. X-5. [pmid: 25028283].
794 Vanschoonlandt F, Vanderfaeillie J, Van Holen F, et al. Development of an intervention for foster parents of young foster children with externalizing behavior: theoretical basis and program description. Clin Child Fam Psychol Rev. Dec. 2012;15(4):330-44. X-4. [pmid: 22983481].
795 Vassilopoulos SP, Brouzos A, Andreou E. A Multi-Session Attribution Modification Program for Children with Aggressive Behaviour: Changes in Attributions, Emotional Reaction Estimates, and Self-Reported Aggression. Behav Cogn Psychother. Apr. 2014;25:1-11. X-5. [pmid: 24762404].
796 Vetro A, Pallag P, Szentistvanyi LI, et al. Treatment of childhood aggressivity with lithium. Agressologie. Nov. 1981;22(E):27-30. X-11. [pmid: 7332046].
797 Villodas MT, McBurnett K, Kaiser N, et al. Additive Effects of Parent Adherence on Social and Behavioral Outcomes of a Collaborative School-Home Behavioral Intervention for ADHD. Child Psychiatry Hum Dev. 2013. Sep. 17. X-4, X-6, X-8. [pmid: 24043560].
798 Villodas MT, McBurnett K, Kaiser N, et al. Additive effects of parent adherence on social and behavioral outcomes of a collaborative school-home behavioral intervention for ADHD. Child Psychiatry Hum Dev. Jun. 2014;45(3):348-60. X-6, X-8. [pmid: 24043560].
799 Vimpani GV. Prescribing stimulants for disruptive behaviour disorders: sometimes against the best interests of the child?. J Paediatr Child Health. Feb. 1997;33(1):9-11. X-1, X-2. [pmid: 9069037].
800 Vitaro F, Barker ED, Brendgen M, et al. Pathways explaining the reduction of adult criminal behaviour by a randomized preventive intervention for disruptive kindergarten children. J Child Psychol Psychiatry. Jul. 2012;53(7):748-56. X-4. [pmid: 22211635].
801 Vitaro F, Brendgen M, Pagani L, et al. Disruptive behavior, peer association, and conduct disorder: testing the developmental links through early intervention. Dev Psychopathol. Spring. 1999;11(2):287-304. X-5, X-6. [pmid: 16506535].
802 Vitaro F, Tremblay RE. Impact of a prevention program on aggressive children's friendships and social adjustment. J Abnorm Child Psychol. Aug. 1994;22(4):457-75. X-4. [pmid: 7963078].
803 Votruba-Drzal E, Coley RL, Maldonado-Carreno C, et al. Child care and the development of behavior problems among economically disadvantaged children in middle childhood. Child Dev. Sep-Oct. 2010;81(5):1460-74. X-2, X-4, X-5, X-6, X-7, X-8. [pmid: 20840234].
804 Wachlarowicz M, Snyder J, Low S, et al. The moderating effects of parent antisocial characteristics on the effects of Parent Management Training-Oregon (PMTO). Prev Sci. Jun. 2012;13(3):229-40. X-5, X-7, X-8. [pmid: 22274595].
805 Waddell C, Lipman E, Offord D. Conduct disorder: practice parameters for assessment, treatment, and prevention. Can J Psychiatry. Oct. Suppl 2. 1999;44:35s-40s. X-1. [pmid: 10566117].
806 Wade SL, Stancin T, Kirkwood M, et al. Counselor-assisted problem solving (CAPS) improves behavioral outcomes in older adolescents with complicated mild to severe TBI. J Head Trauma Rehabil. May-Jun. 2014;29(3):198-207. X-4. [pmid: 23640543].
807 Wahler RG, Fox JJ. Solitary toy play and time out: a family treatment package for children with aggressive and oppositional behavior. J Appl Behav Anal. Spring. 1980;13(1):23-39. X-11. [pmid: 7364699].
808 Walsh WJ, Glab LB, Haakenson ML. Reduced violent behavior following biochemical therapy. Physiol Behav. Oct. 15. 2004;82(5):835-9. X-3, X-6. [pmid: 15451647].
809 Ware LM, Novotny ES, Coyne L. A therapeutic nursery evaluation study. Bull Menninger Clin. Fall. 2001;65(4):522-48. X-5, X-6. [pmid: 11761495].
810 Warner J. Scapegoat in the family. Spec Educ. Sep. 1972;61(3):19-20. X-11. [pmid: 5071551].
811 Warren K, Moberg DP, McDonald L. FAST and the arms race: the interaction of group aggression and the families and schools together program in the aggressive and delinquent behaviors of inner-city elementary school students. J Prim Prev. Jan. 2006;27(1):27-45. X-4, X-5. [pmid: 16421656].
812 Waschbusch DA, Carrey NJ, Willoughby MT, et al. Effects of methylphenidate and behavior modification on the social and academic behavior of children with disruptive behavior disorders: the moderating role of callous/unemotional traits. J Clin Child Adolesc Psychol. Oct-Dec. 2007;36(4):629-44. X-4. [pmid: 18088220].
813 Watt BD, Hoyland M, Best D, et al. Treatment participation among children with conduct problems and the role of telephone reminders. Journal of Child and Family Studies. 2007;16(4):522-30. X-2, X-4, X-6, X-7, X-8.
814 Waxman D. Hypnosis in the psychotherapy of neurotic illness. Br J Med Psychol. Dec. 1975;48(4):339-48. X-11. [pmid: 1225350].
815 Weaver CM, Shaw DS, Crossan JL, et al. Parent-Child Conflict and Early Childhood Adjustment in Two-Parent Low-Income Families: Parallel Developmental Processes. Child Psychiatry Hum Dev. 2014. Mar. 8. X-4. [pmid: 24610382].
816 Webster-Stratton C. Randomized trial of two parent-training programs for families with conduct-disordered children. J Consult Clin Psychol. Aug. 1984;52(4):666-78. X-11. [pmid: 6470293].
817 Webster-Stratton C. Early-onset conduct problems: does gender make a difference?. J Consult Clin Psychol. Jun. 1996;64(3):540-51. X-6. [pmid: 8698948].
818 Webster-Stratton C. Preventing conduct problems in Head Start children: strengthening parenting competencies. J Consult Clin Psychol. Oct. 1998;66(5):715-30. X-5. [pmid: 9803690].
819 Webster-Stratton C, Reid J, Hammond M. Social skills and problem-solving training for children with early-onset conduct problems: who benefits?. J Child Psychol Psychiatry. Oct. 2001;42(7):943-52. X-2a, X-7a. [pmid: 11693589].
820 Webster-Stratton C, Reid MJ, Hammond M. Preventing conduct problems, promoting social competence: a parent and teacher training partnership in head start. J Clin Child Psychol. Sep. 2001;30(3):283-302. X-4, X-5, X-6. [pmid: 11501247].
821 Weis R, Wilson NL, Whitemarsh SM. Evaluation of a voluntary, military-style residential treatment program for adolescents with academic and conduct problems. J Clin Child Adolesc Psychol. Dec. 2005;34(4):692-705. X-5. [pmid: 16232066].
822 Weiss G, Werry J, Minde K, et al. Studies on the hyperactive child. V. The effects of dextroamphetamine and chlorpromazine on behaviour and intellectual functioning. J Child Psychol Psychiatry. Dec. 1968;9(3):145-56. X-11. [pmid: 4893343].
823 Weiss M, Panagiotopoulos C, Giles L, et al. A naturalistic study of predictors and risks of atypical antipsychotic use in an attention-deficit/hyperactivity disorder clinic. J Child Adolesc Psychopharmacol. Oct. 2009;19(5):575-82. X-2, X-4. [pmid: 19877982].
824 Weissman MM, Pilowsky DJ, Wickramaratne PJ, et al. Remissions in Maternal Depression and Child Psychopathology: A STAR*D-Child Report. JAMA: Journal of the American Medical Association. 2006;295(12):1389-98. X-4. [pmid: 16551710].
825 Weisz JR, Chorpita BF, Palinkas LA, et al. Testing standard and modular designs for psychotherapy treating depression, anxiety, and conduct problems in youth: a randomized effectiveness trial. Arch Gen Psychiatry. Mar. 2012;69(3):274-82. X-7. [pmid: 22065252].
826 Weisz JR, Suwanlert S, Chaiyasit W, et al. Thai and American perspectives on over- and undercontrolled child behavior problems: exploring the threshold model among parents, teachers, and psychologists. J Consult Clin Psychol. Aug. 1988;56(4):601-9. X-11. [pmid: 3198820].
827 Werba BE, Eyberg SM, Boggs SR, et al. Predicting outcome in parent-child interaction therapy: success and attrition. Behav Modif. Sep. 2006;30(5):618-46. X-2, X-7. [pmid: 16894233].
828 Werry JS, Aman MG. Methylphenidate and haloperidol in children. Effects on attention, memory, and activity. Arch Gen Psychiatry. Jun. 1975;32(6):790-5. X-11. [pmid: 1093506].
829 Westrupp E, Northam E, Lee K, et al. Reducing and preventing internalizing and externalizing behavior problems in children with type 1 diabetes: a randomized controlled trial of the Triple P-Positive Parenting Program. Pediatr Diabetes. 2014. Aug. 29. X-4. [pmid: 25168676].
830 Whalley LJ, Robinson TJ, McIsaac M, et al. Psychiatric referrals from Scottish children's hearings: a comparative study. J Child Psychol Psychiatry. Jul. 1978;19(3):269-78. X-11. [pmid: 681469].
831 Whitfield GW. Validating school social work: An evaluation of a cognitive-behavioral approach to reduce school violence. Research on Social Work Practice. 1999;9(4):399-426. X-2a.
832 Whitmore EA, Mikulich SK, Ehlers KM, et al. One-year outcome of adolescent females referred for conduct disorder and substance abuse/dependence. Drug Alcohol Depend. May. 1. 2000;59(2):131-41. X-6. [pmid: 10891626].
833 Wildman BG, Langkamp DL. Impact of location and availability of behavioral health services for children. J Clin Psychol Med Settings. Dec. 2012;19(4):393-400. X-2, X-3, X-6, X-7, X-8. [pmid: 23053830].
834 Wilens TE, Spencer TJ, Swanson JM, et al. Combining methylphenidate and clonidine: a clinically sound medication option. J Am Acad Child Adolesc Psychiatry. May. 1999;38(5):614-9. discussion 9-22. X-1. [pmid: 10230195].
835 Williamson AA, Dierkhising CB, Guerra NG. Brief report: piloting the Positive Life Changes (PLC) program for at-risk adolescents. J Adolesc. Jun. 2013;36(3):623-8. X-4, X-5, X-6, X-8. [pmid: 23582978].
836 Williford AP, Shelton TL. Using mental health consultation to decrease disruptive behaviors in preschoolers: adapting an empirically-supported intervention. J Child Psychol Psychiatry. Feb. 2008;49(2):191-200. X-4. [pmid: 18211278].
837 Willock B. From acting out to interactive play. Int J Psychoanal. 1990;71(Pt 2):321-34. X-11. [pmid: 2365551].
838 Winsberg BG, Bialer I, Kupietz S, et al. Effects of imipramine and dextroamphetamine on behavior of neuropsychiatrically impaired children. Am J Psychiatry. May. 1972;128(11):1425-31. X-11. [pmid: 4553490].
839 Winsberg BG, Press M, Bialer I, et al. Dextroamphetamine and methylphenidate in the treatment of hyperactive-aggressive children. Pediatrics. Feb. 1974;53(2):236-41. X-11. [pmid: 4590730].
840 Winsberg BG, Yepes LE, Bialer I. Pharmacologic management of children with hyperactive/aggressive/inattentive behavior disorders. Suggestions for the pediatrician. Clin Pediatr (Phila). May. 1976;15(5):471-7. X-11. [pmid: 4253].
841 Wodarski JS. Prevention of adolescent reoccurring violence and alcohol abuse: a multiple site evaluation. J Evid Based Soc Work. Jul. 2010;7(4):280-301. X-7. [pmid: 20799128].
842 Wodarski JS, Pedi SJ. The empirical evaluation of the effects of different group treatment strategies against a controlled treatment strategy on behavior exhibited by antisocial children, behaviors of the therapist, and two self-rating scales that measure antisocial behavior. J Clin Psychol. Apr. 1978;34(2):471-81. X-11. [pmid: 681526].
843 Wood RJ, Wood AR, Mullins DT. Back to school: recommendations to assist mentally ill, post-incarcerated youth return to school. J Sch Health. Sep. 2008;78(9):514-7. X-1, X-2. [pmid: 18786044].
844 Woods DW, Piacentini JC, Scahill L, et al. Behavior therapy for tics in children: Acute and long-term effects on psychiatric and psychosocial functioning. Journal of Child Neurology. 2011;26(7):858-65. X-4. [pmid: 21555779].
845 Xeniditis K, Russell A, Murphy D. Management of people with challenging behaviour. Advances in Psychiatric Treatment. 2001;7(2):109-16. X-1, X-2, X-3, X-4, X-5, X-6.
846 Yeager DS, Trzesniewski KH, Dweck CS. An implicit theories of personality intervention reduces adolescent aggression in response to victimization and exclusion. Child Dev. May-Jun. 2013;84(3):970-88. X-4, X-5, X-7, X-8. [pmid: 23106262].
847 Yepes LE, Balka EB, Winsberg BG, et al. Amitriptyline and methylphenidate treatment of behaviorally disordered children. J Child Psychol Psychiatry. Jan. 1977;18(1):39-52. X-11. [pmid: 320219].
848 Yu JW, Buka SL, McCormick MC, et al. Behavioral problems and the effects of early intervention on eight-year-old children with learning disabilities. Matern Child Health J. Jul. 2006;10(4):329-38. X-2, X-4, X-6, X-8. [pmid: 16474990].
849 Zafra-Cabeza A, Rivera DE, Collins LM, et al. A Risk-based Model Predictive Control Approach to Adaptive Interventions in Behavioral Health. IEEE Trans Control Syst Technol. Jul. 1. 2011;19(4):891-901. X-1, X-2. [pmid: 21643450].
850 Zapletalek M, Hametova M, Rydlova E. Isofloxythepin in restless oligophrenic children. Act Nerv Super (Praha). Dec. 1989;31(4):265. X-11. [pmid: 2576920].
851 Zarcone JR, Lindauer SE, Morse PS, et al. Effects of risperidone on destructive behavior of persons with developmental disabilities: III. Functional analysis. Am J Ment Retard. Jul. 2004;109(4):310-21. X-3, X-4, X-6, X-7, X-8. [pmid: 15176916].
852 Zimmerman FT, Burgemeister BB. Action of methyl-phenidylacetate (ritalin) and reserpine in behavior disorders in children and adults. Am J Psychiatry. Oct. 1958;115(4):323-8. X-11. [pmid: 13583220].
853 Zubrick SR, Ward KA, Silburn SR, et al. Prevention of child behavior problems through universal implementation of a group behavioral family intervention. Prev Sci. Dec. 2005;6(4):287-304. X-4, X-5. [pmid: 16160760].