# Applicability Tables

Table G-1 Applicability of evidence for psychosocial interventions

Domain | Description of applicability of evidence
Population | The population studied included children from ages 1.5 - 18 years, inclusive, and 72% male. The inclusion criteria varied from strict diagnostic criteria for a disruptive behavior disorder (typically ODD) to more vague assessments of disruptive behaviors typically operationalized as above a clinical cutoff on a well-validated parent-report measure.
Intervention | Psychosocial interventions for disruptive behaviors included interventions with a child, parent, or family component (single component interventions) and multicomponent interventions that included more than one of those individual components. Within each of these broad categories, individual interventions were heterogeneous.
Comparators | The studies compared active treatment to treatment as usual or to a wait list control group.
Outcomes | Parent report of child disruptive behaviors was by far the most commonly reported outcomes. The CBCL externalizing subscale, ECBI Intensity subscale, ECBI Problem subscale, and SDQ were the most commonly used parent-reported measures. Child self-report, teacher report, and direct observations of child disruptive behaviors were reported. Measures of functional outcomes were far less common.
Setting | The vast majority of studies was in the outpatient setting and generally carried out at academic medical centers in the United States. Several studies were conducted at specialty centers including a psychiatric day treatment program and domestic violence shelter.

Table G-2 Applicability of evidence for antipsychotic medications

Domain | Description of applicability of evidence
Population | The population studied included children ages 6-17, inclusive, and 83% male. The inclusion criteria varied from strict diagnostic criteria of ODD and CD to more vague assessments of aggressive behavior “severe enough to warrant pharmacotherapy.” One study 1 studied aggression in patients with ADHD exclusively.
Intervention | The intervention medications, Aripiprazole, Quetiapine, Risperidone, and Ziprasidone are not FDA approved for treatment of disruptive behavior in children, but are used routinely in clinical practice in the US.
Comparators | Only one of the studies (5102) studied two medications head-to-head. The other studies compared the active medication to placebo.
Outcomes | The most common measures were the OAS and CGI. The OAS specifically addresses aggressive behavior symptoms and the CGI addresses improvement of symptoms compared to baseline.
Setting | The studies were all in the outpatient setting and generally carried out at academic medical centers in the US, with one (5102) at a community outpatient clinic.

Notes: Abbreviations: ADHD – Attention Deficit Hyperactivity Disorder; CD – Conduct Disorder; CGI – Clinical Global Impression; OAS – Ongoing Abuse Screen; ODD – Oppositional Defiant Disorder

Table G-3 Applicability of evidence for antiepileptic medications

Domain | Description of applicability of evidence
Population | The population studied included children from ages 6 to 18 years, inclusive, and 90% male.
Intervention | The intervention, valproic acid, is not FDA approved for disruptive behaviors in children, but is used in clinical practice in the US.
Comparators | Valproic acid compared to placebo or to low dose valproic acid.
Outcomes | The most common measures were the OAS and CGI. The OAS specifically addresses aggressive behavior symptoms and the CGI addresses improvement of symptoms compared to baseline.
Setting | The largest of the three studies (n=58) analyzed patients from a correctional facility, which indicates a higher acuity of disruptive behaviors. The other studies were conducted in outpatient clinics.

Table G-4 Applicability of evidence for nonstimulant medications

Domain | Description of applicability of evidence
Population | The population studied included school-aged children and adolescents, ages 6-17 years, and mostly male (69%-92%). Inclusion criteria included specifically children with ADHD and co-morbid ODD based on strict diagnostic criteria of ODD/CD.
Intervention | The intervention medications include the selective norepinephrine reuptake inhibitor atomoxetine and Guanfacine extended release, a selective central alpha2A-adrenergic receptor agonist; both of which are approved for the treatment of ADHD, but are not FDA approved for treatment of disruptive behavior in children.
Comparators | All studies compared the active medication to placebo. One study (665) had three arms that compared fast to slow titration of atomoxetine with target dose in both arms of 1.2mg/kg/d.
Outcomes | Primary outcomes were the change from baseline in the Swanson, Nolan, and Pelham Rating Scale-Revised (SNAP-IV) ODD subscore, or the oppositional subscale of the Conners Parent Rating Scale-Revised: Long Form (CPRS-R: L) measured at 8-9 weeks of treatment.
Setting | The studies were all in the outpatient setting at centers in the US, Germany, and Italy.

Table G-5 Applicability of evidence for ADHD stimulant medications

Domain | Description of applicability of evidence
Population | The population studied included school-aged children and adolescents, 6-17 years; and mostly male (69-90%). Patient population had ODD symptoms based on strict diagnostic criteria; and majority had co-morbid ADHD (66% to 79%)
Intervention | The intervention medications included methylphenidate and mixed amphetamine salts extended release (MAS XR); both of which are approved for treatment of ADHD; but are not FDA approved for disruptive behaviors in children.
Comparators | All studies compared the active medication to placebo. One study (1650) compared four different doses of MAS XR (10 mg, 20 mg, 30 mg, and 40 mg/d) to placebo.
Outcomes | Primary outcomes were the ODD subscore of the SNAP-IV and parent and teacher ratings of CD symptoms based on the Conners Teacher Rating Scale, and subscales of the Quay revised behavior problem checklist, measured after 4-5 weeks of treatment.
Setting | The two studies were conducted in the outpatient setting at centers in the US.