# Summary of Existing Systematic Reviews

Table F-1 Existing reviews of psychosocial interventions for DBD

Author, Year | Focus Area | Inclusion Criteria | Outcome(s) | # Studies Included | Key Findings
Dretzke, J., et al. (2009)1 | Group based parent training programs | - Children with a conduct problems; - Aged younger than 18 years | - Child behavior using a standardized measure | 57 RCTs | - Parent and independent reports were significantly better for intervention groups; - Insufficient evidence for relative effectiveness of different approaches to delivering parenting programs.
Littell, J. H., et al. (2005)2 | Multisystemic Therapy (MST) | - Literature from 1985 to January 2003; - Children with social, emotional, and/or behavioral problems; - Aged 10 to 17 years | - Crime and delinquency; - Child behavior and psychosocial outcomes | 8 studies | - ITT analysis found no significant differences between MST and usual services in arrests or convictions; - Inconclusive evidence of the effectiveness of MST compared with other interventions with youth
Comer, J.S., et al. (2013)3 | Psychosocial treatment | - RCTs; - Children with DBD; - Aged younger than 8 years at baseline | - Pooled analyses; - General externalizing symptoms; - Overall disruptive behavior symptoms | 36 controlled trials 3,042 children | - Largest effect sizes associated with behavioral treatment, older and male youth.; - Effects largest for general externalizing problems and weakest for impulsivity and hyperactivity.
McCart, M. R., et al. (2006)4 | Behavioral parent-training (BPT) and cognitive-behavioral therapy (CBT) | - Youth with antisocial behavior problems | - Youth demographic variables were examined as potential moderators of the effectiveness | 76 studies Of these, 71 were included in analyses: 30 BPT studies and 41 CBT studies | - Child age moderated outcome; - BPT had a stronger effect for preschool and school-aged youth and CBT had a stronger effect for adolescents
Dretzke, J., et al. (2005)5 | Parent training programs | - Children with conduct disorder; - Aged younger than 18 years | - Clinical effectiveness; - Cost-effectiveness | 37 RCTs | - Six included studies were assessed as good or adequate quality; - Many (n=31) of the studies that met the review inclusion and exclusion criteria were assessed as being of poor methodological quality.
Fossum, S., et al. (2008)6 | Psychotherapy | - 1987-2008 | - Aggressive behaviors | 65 studies (4,971 patients) ; Of these 33 studies compared a psychosocial intervention with an untreated comparison group | - Effect sizes were larger in studies of behavioral interventions compared to studies of family therapeutic interventions.
Ozabaci, N. (2011)7 | Cognitive behavioural therapy (CBT) | - Children and adolescents demonstrating high levels of violence; - 1997-2009 | - Aggressive behavior | 6 studies | - CBT reduced violence
Eyberg, S. M., et al. (2008)8 update of Brestan and Eyberg, 1998 | Psychosocial treatments | - Literature from 1996 to 2007; - Child and adolescent disruptive behavior, including oppositional defiant disorder and conduct disorder | - Child and adolescent disruptive behavior | 16 EBTs identified (up from 12 in the earlier report) | - Studies were evaluated using criteria for EBTs developed by the task force on promotion and dissemination of psychological procedures
Bradley, M. C. and D. Mandell (2005)9 | Interventions for ODD | - Children diagnosed with ODD | - Outcomes in 6 domains | 7 studies | - Greatest effects on child behavior when interventions targeted parents; - Smaller effects if only children were targeted
Johnson, M.H., et al., (2013)10 | Behavioral interventions implemented in the community | - Children or adolescents with problem behaviors or at elevated risk | - Changes in externalizing behavior; - Inattention symptoms; - Social and organization skills | 12 RCTs (4 family-centered behavioral intervention studies; 3 school-based behavioral intervention studies; and 5 integrated behavioral intervention studies) | - Rated level of evidence as high for behavioral management
Michelson, D., et al. (2013)11 | Parent management training (PMT) including IY and Triple P and others | - RCTs; - Studies of children consistent with guidelines on recommended target population for PMT | - Disruptive behavior problems (using a standardized outcome measure); - Child disruptive behavior across different settings | 28 RCTs 2239 participants | - Significant overall advantage for PMT compared with waitlist control conditions.; - No significant differences in effect size estimates according to setting; - Six studies assessed as low or moderate risk of bias
Shelleby , E.C., et al. (2014)12 | Individual or group parent training | - Children with conduct problems; - Studies that examined moderators of parenting intervention effectiveness | - Moderators of effectiveness including baseline level of problem behavior, sociodemographic and family process risks | 6 studies assessing baseline child behavior as a moderator 13 studies examining the mediating effect of sociodemographic and family process risks | - Majority of studies on sociodemographic and family process risks found nonsignificant association with differential intervention effectiveness; - Studies of child baseline behavior suggest that increased problem behaviors at baseline are associated with increased benefit from interventions.
Piquero, A. R., et al. (2009)13 | Parent training or support | - RCT; - Children under 5 years | - Antisocial behavior; - Delinquency; - Parent, teacher, direct observation of child problem behavior | 55 studies | - early family/parent training was effective for antisocial behavior and delinquency,
Maughan, D. R., et al. (2005)14 | Behavioral Parent Training (BPT) | - 1966-2001; - Children ages 3 to 16 years; - Controlled studies, pre-post studies, and single subject design | - Externalizing behavior | 79 studies | - CBT was beneficial in all studies designs; - Parent reported outcomes may inflate effectiveness
Lundahl, B. W., et al. (2006)15 | Parent training programs | - For studies of children with ADHD, had to include a outcome for DBD separate from ADHD; - Controlled studies reporting means and SDs, pre and post treatment for intervention and control groups | - Child disruptive behavior; - Parent behavior; - Parental perception | 63 studies (69 behavioral experimental groups and 14 nonbehavioral experimental groups) | - Parent training was least effective for economically disadvantaged families; - Individually delivered parent training compared to group delivery was more effective for low SES families
Thomas, R. and M. J. Zimmer-Gembeck (2007)16 | Parent-Child Interaction Therapy and Triple P-Positive Parenting Program | - Children ages 3 to 12 years | | 24 studies | - Positive effects of both interventions, but effects varied depending on intervention length, components, and source of outcome data.
Sanders, M. R., et al. (2014)17 | Triple P-Positive Parenting Program | - 1979-2013; - RCTs, non-RCTs, and uncontrolled studies | - Child behavior; - Parenting practice; - Parenting satisfaction | 116 studies 101 studies (16,099 families) analyzed quantitatively | - Study approach, study power, Triple P level, and baseline severity of child problems produced moderated the intervention effects
Reyno, S. M. and P. J. McGrath (2006)18 | Parenting training | - 1980-2004; - Prevention and treatment studies | - Child disruptive behavior; - Child, parent and family variables that predict treatment outcome and dropout | 31 studies | - Maternal mental health and SES were predictors of treatment response
Nowak, C. and N. Heinrichs (2008)19 | Triple P Positive Parenting Program | - 1970-2007 | - Parenting skill, child problem behavior or parent-child wellbeing using a validated scale | 55 studies (11, 797 families) | - larger effects found on parent report as compared to observational measures; - Greater intervention effects associated with intensive formats and initially more distressed families.
Leijten, P., et al. (2013)20 | Parent training | - Before 1/31/2010; - Children aged 12 and younger | - Child disruptive behavior reported as mean and SD on a standardized measure; - SES and baseline DBD severity as predictors of intervention effectiveness | 75 studies | - SES interaction with baseline severity; - Samples of disadvantaged families with lower baseline severity benefitted less from parent management training than non-disadvantaged families with lower baseline severity DBD. SES did not predict effect sizes for patients with severe DBD at baseline
Kaminski, J. W., et al. (2008)21 | Parent training | - 1990-2002; - Unclear if nonrandomized studies were included; - Children aged 7 and younger | - Parenting measures; - Child measures; - Parent-child interaction | 77 studies including 45 RCTs | - Increasing positive parent-child interactions and emotional communication skills, teaching parents to use time out and parenting consistency, and parental practice of new skills with their children during parent training sessions were associated with larger effects.
Forehand, R., et al. (2014)22 | Behavioral Parent Training | - Children ages 2 to 18 years; - Intervention and prevention; - RCTs | - Parenting behavior; - Child externalizing behavior | 16 studies (3 intervention and 13 prevention studies)

## References for Appendix F

1 Dretzke J, Davenport C, Frew E, et al. The clinical effectiveness of different parenting programmes for children with conduct problems: a systematic review of randomised controlled trials. Child Adolesc Psychiatry Ment Health. 2009;3(1):7. [pmid: 19261188].
2 Littell JH, Campbell M, Green S, et al. Multisystemic Therapy for social, emotional, and behavioral problems in youth aged 10-17. Cochrane Database of Systematic Reviews. 2005;(4).
3 Comer JS, Chow C, Chan PT, et al. Psychosocial treatment efficacy for disruptive behavior problems in very young children: a meta-analytic examination. J Am Acad Child Adolesc Psychiatry. Jan. 2013;52(1):26-36. [pmid: 23265631].
4 McCart MR, Priester PE, Davies WH, et al. Differential effectiveness of behavioral parent-training and cognitive-behavioral therapy for antisocial youth: a meta-analysis. J Abnorm Child Psychol. Aug. 2006;34(4):527-43. [pmid: 16838122].
5 Dretzke J, Frew E, Davenport C, et al. The effectiveness and cost-effectiveness of parent training/education programmes for the treatment of conduct disorder, including oppositional defiant disorder, in children. Health Technol Assess. Dec. ix. 2005;9(50):iii-x. 1. 233. [pmid: 16336845].
6 Fossum S, Handegard BH, Martinussen M, et al. Psychosocial interventions for disruptive and aggressive behaviour in children and adolescents: a meta-analysis. Eur Child Adolesc Psychiatry. Oct. 2008;17(7):438-51. [pmid: 18427863].
7 Ozabaci N. Cognitive behavioural therapy for violent behaviour in children and adolescents: A meta-analysis. Children and Youth Services. 2011;33(10):1989-93.
8 Eyberg SM, Nelson MM, Boggs SR. Evidence-based psychosocial treatments for children and adolescents with disruptive behavior. Journal of Clinical Child and Adolescent Psychology. 2008;37(1):215-37. [pmid: 18444059].
9 Bradley MC, Mandell D. Oppositional defiant disorder: A systematic review of evidence of intervention effectiveness. Journal of Experimental Criminology. 2005;1(3):343-65.
10 Johnson MH, George P, Armstrong MI, et al. Behavioral Management for Children and Adolescents: Assessing the Evidence. Psychiatr Serv. 2013. Dec. 17. [pmid: 24343339].
11 Michelson D, Davenport C, Dretzke J, et al. Do evidence-based interventions work when tested in the “real world?” a systematic review and meta-analysis of parent management training for the treatment of child disruptive behavior. Clin Child Fam Psychol Rev. Mar. 2013;16(1):18-34. [pmid: 23420407].
12 Shelleby EC, Shaw DS. Outcomes of Parenting Interventions for Child Conduct Problems: A Review of Differential Effectiveness. Child Psychiatry Hum Dev. 2014. Jan. 4. [pmid: 24390592].
13 Piquero AR, Farrington DP, Welsh BC, Tremblay R, Jennings WG. Effects of early family/parent training programs on antisocial behavior and delinquency. Journal of Experimental Criminology. 2009;5:83-120.
14 Maughan DR, Christiansen E, Jenson WR, Olympia D, Clark E. Behavioral parent training as a treatment for externalizing behaviors and disruptive behavior disorders: A meta-analysis. School Psychology Review. 2005;34:267-86.
15 Lundahl BW, Risser HJ, Lovejoy MC. A meta-analysis of parent training: Moderators and follow-up effects. Clinical Psychology Review. 2006;26:86-104. [pmid: 16280191].
16 Thomas R, Zimmer-Gembeck MJ. Behavioral outcomes of Parent-Child Interaction Therapy and Triple P-Positive Parenting Program: a review and meta-analysis. J Abnorm Child Psychol. Jun. 2007;35(3):475-95. [pmid: 17333363].
17 Sanders MR, Kirby JN, Tellegen CL, et al. The Triple P-Positive Parenting Program: a systematic review and meta-analysis of a multi-level system of parenting support. Clinical Psychology Review. Jun. 2014;34(4):337-57. [pmid: 24842549].
18 Reyno SM, McGrath PJ. Predictors of parent training efficacy for child externalizing behavior problems--a meta-analytic review. J Child Psychol Psychiatry. Jan. 2006;47(1):99-111. [pmid: 16405646].
19 Nowak C, Heinrichs N. A comprehensive meta-analysis of Triple P-Positive Parenting Program using hierarchical linear modeling: effectiveness and moderating variables. Clin Child Fam Psychol Rev. Sep. 2008;11(3):114-44. [pmid: 18509758].
20 Leijten P, Raaijmakers MA, de Castro BO, et al. Does socioeconomic status matter? A meta-analysis on parent training effectiveness for disruptive child behavior. J Clin Child Adolesc Psychol. 2013;42(3):384-92. [pmid: 23461526].
21 Kaminski JW, Valle LA, Filene JH, et al. A meta-analytic review of components associated with parent training program effectiveness. J Abnorm Child Psychol. May. 2008;36(4):567-89. [pmid: 18205039].
22 Forehand R, Lafko N, Parent J, et al. Is parenting the mediator of change in behavioral parent training for externalizing problems of youth?. Clinical Psychology Review. Dec. 2014;34(8):608-19. [pmid: 25455625].