# Outcome Measures Used in the Meta-Analysis of Intervention Effects

The Bayesian multivariate, mixed treatment (network) meta-analysis used data from a subset of RCTs identified as addressing KQ1 that measured parent-reported child disruptive behavior using one of the following outcome measures: 1) ECBI Intensity subscale; 2) ECBI Problem subscale; 3) CBCL externalizing subscale reported as a T-score. These three measures were the most prevalent in the literature.

The Eyberg Child Behavior Inventory (ECBI)1,2 is an inventory used in the assessment of disruptive behaviors in children ages 2 through 16 that occur in the home and in school. The ECBI is completed by parents and assesses behaviors on two scales: an Intensity Scale, which indicates how often the behaviors occur, and a Problem Scale, which identifies the specific behaviors that are cause problems for the parent. The Intensity Scale uses a frequency of occurrence rating: from Never (1) to Always (7). The sum of the Intensity Scale item ratings ranges from 36 to 252. The Problem Scale consists of a “Yes” or “No” problem identification rating for each item. The count of the “Yes” responses yields a problem score with a range from 0 to 36. The clinical cutoffs are 127 and 11 on the Intensity and Problem scales, respectively.

The Child Behavior Checklist (CBCL)3 is part of the Achenbach System of Empirically Based Assessments (ASEBA). The target population for the CBCL is children between the ages of 6 and 18. The pre-2001 version was intended for children ages 4 to 18 years. A version of the CBCL is also available for children ages 1 ½ to 5 years of age. The CBCL obtains reports from parents, other close relatives, and/or guardians regarding children's competencies and behavioral/emotional problems. Parents provide information for 20 competence items covering their child's activities, social relations, and school performance. The CBCL/6-18 has 118 items that describe specific behavioral and emotional problems, plus two open-ended items for reporting additional problems. Parents rate their child for how true each item is now or within the past 6 months using the following scale: 0 = not true (as far as you know); 1 = somewhat or sometimes true; 2 = very true or often true. Responses to items are aggregated to generate a total score, externalizing subscale score, internalizing subscale score, empirically based syndrome scales, and/or DSM-oriented scales.

## References for Appendix E

1 Eyberg SM, Sutter J, Pincus D. Eyberg Child Behavior Inventory and Sutter-Eyberg Student Behavior Inventory-Revised. Psychological Assessment Resources, Inc., 16204 N. Florida Avenue, Lutz, FL 33549-8119; Telephone: 800-331-8378; FAX: 800-727-9329; E-mail: custsupp@parinc.com; Web: www.parinc.com.
2 Eyberg S. Parent and teacher behavior inventories for the assessment of conduct problem behaviors in children. Innovations in clinical practice: A source book. 1992;11:261-70.
3 Achenbach TM. Child Behavior Checklist. ASEBA Research Center for Children, Youth, and Families, 1 South Prospect Street, Burlington, VT 05401-3456; Telephone: 802-264-6432; FAX: 802-264-6433; E-mail: mail@ASEBA.org; Web: www.ASEBA.org.