# Meta-Analytic Methods

We developed a meta-analysis to address Key Question 1, which concerns the comparative effectiveness of psychosocial interventions for improving psychosocial outcomes for children treated for disruptive behaviors. We employed a Bayesian multivariate, mixed treatment (network) meta-analytic methods1-3 to use both direct and indirect evidence for comparing a large suite of treatments.

Of the 16 instruments used to measure treatment outcomes, we included studies that employed one or more of the four most prevalent instruments: 1) Eyberg Child Behavior Inventory (ECBI), Intensity Subscale; 2) ECBI, Problem Scale; 3) Child Behavior Checklist (CBCL), Externalizing (T-score); 4) CBCL, Externalizing (raw score). Studies were included in the meta-analysis if they reported baseline and end-of-treatment (EOT) means and standard deviations from one of the four metrics listed above. In total, 28 studies were used to fit the model. The baseline was subtracted from the EOT mean and used as the response measure.

Equation 1 Response measure equals end of treatment mean minus the baseline mean

Response measure equals end of treatment mean minus the baseline mean d_i_ = y_i_^( e o t )^ – y_i_^( b l )^

The response expected values m were modeled jointly as a multivariate normal likelihood, with any unmeasured outcomes treated as missing data; this allowed for the covariance among measures to be accounted for and estimated.

Equation 2 Expected value response modeled jointly as multivariate normal distribution

Expected value response modeled jointly as multivariate normal distribution ( m_1_ m_2_ m_3_ m_4_ )_i_ ~ MVN ( μ , Σ )

To accommodate the large suite of interventions employed by the constituent studies, we classified each intervention according to the treatment components that comprised them. Specifically, the treatment arms of each study were classified as one of the following types: 1) child-only treatment; 2) parent-only treatment; or 3) multicomponent treatment. Thus, a given treatment arm was specified by a vector of indicator variables.

Equation 3 Treatment arm, X, specified by a vector of indicator variables, child-only, parent-only, and multicomponent

Treatment arm, X, specified by a vector of indicator variables, child-only, parent-only, and multicomponent X_i_ = [ x_c_ x_p_ x_f_ ]_i_

Those not identified by any of these three classes were considered either control or treatment-as-usual arms, encoded by a zero vector. Recognizing that these treatment categories are broad, encompassing a range of specific interventions, each component was modeled as a random effect.

Equation 4 Child-only treatment category modeled as a Gaussian random effect

Child-only treatment category modeled as a Gaussian random effect β_J_^( c )^ ~ N ( μ_β_^( c )^ , τ_β_^( c )^ )

Equation 5 Parent-only treatment category modeled as a Gaussian random effect

Parent-only treatment category modeled as a Gaussian random effect β_J_^( p )^ ~ N ( μ_β_^( p )^ , τ_β_^( p )^ )

Equation 6 Multicomponent treatment category modeled as a Gaussian random effect

Multicomponent treatment category modeled as a Gaussian random effect β_J_^( f )^ ~ N ( μ_β_^( f )^ , τ_β_^( f )^ )

This allowed for variation in treatment effect within each class, due to factors not explicitly modeled here. All measurement instruments shared the same study arm treatment effect in our model, but the effect was scaled by the standard deviation of the outcome variable.

The age of subjects in each study arm was included in the model as a categorical covariate, broadly grouped into pre-kindergarten, school age, or teenage categories. The school age child was used as the baseline value because it was the most prevalent among studies. The age covariate was combined additively with the intervention component effects and control/treatment-as-usual means to model the observed treatment differences relative to baseline. Though we considered age-by-treatment interactions, there was not enough balance among the age and treatment combinations to include them in the final model. We also considered including the study age distribution as a covariate, but this was ultimately left out of the final model based on poor deviance information criterion (DIC) scores.

Outcome means, treatment effects, and the age covariate were combined to calculate expected response (treatment difference) in an additive linear model.

Equation 7 Expected responses calculated from additive linear model of outcome mean, treatment effect, and age covariate

Expected responses calculated from additive linear model of outcome mean, treatment effect, and age covariate θ_i_ = m_j(i)k_ + X_i_β + αx_age_

The likelihood of the observed differences was specified as a Gaussian distribution, with the observed standard error of the treatment effect (the sum of the baseline and EOT standard deviations) as the standard deviation of the estimates.

Equation 8 Likelihood of observed differences, specified as a Gaussian distribution, and standard deviation of estimate derived from the standard error of the treatment effect

Likelihood of observed differences, specified as a Gaussian distribution, and standard deviation of estimate derived from the standard error of the treatment effect d_i_∼N (θ_i_, σ^2^)

All unknown parameters were given weakly-informative prior distributions and estimated using Markov chain Monte Carlo4 methods via the PyMC 2.3 software package.5 The model was run for 200,000 iterations, with the first 150,000 samples conservatively discarded as burn-in, leaving 50,000 for inference.

## References for Appendix D

1 Lu G, Ades AE. Combination of direct and indirect evidence in mixed treatment comparisons. Stat Med. Oct. 30. 2004;23(20):3105-24. [pmid: 15449338].
2 Lumley T. Network meta-analysis for indirect treatment comparisons. Stat Med. Aug. 30. 2002;21(16):2313-24. [pmid: 12210616].
3 Wei Y, Higgins JP. Bayesian multivariate meta-analysis with multiple outcomes. Stat Med. Jul. 30. 2013;32(17):2911-34. [pmid: 23386217].
4 Brooks S, Gelman A, Jones G, et al. Handbook of Markov Chain Monte Carlo. CRC Press. 2011.
5 Patil A, Huard D, Fonnesbeck CJ. PyMC: Bayesian Stochastic Modelling in Python. J Stat Softw. Jul. 2010;35(4):1-81. [pmid: 21603108].