# Risk of Bias Assessment Forms and Summaries

Cochrane Risk of Bias Assessment Tool

Ref ID:____________ Reviewer ___ ___ ___
Domain | Description | High Risk of Bias | Low Risk of Bias | Unclear Risk of Bias | Reviewer Assessment | Reviewer Comments
Selection bias Random sequence generation | Described the method used to generate the allocation sequence in sufficient detail to allow an assessment of whether it should produce comparable groups | Selection bias (biased allocation to interventions) due to inadequate generation of a randomized sequence | Random sequence generation method should produce comparable groups | Not described in sufficient detail | High Low Unclear
Selection bias Allocation concealment | Described the method used to conceal the allocation sequence in sufficient detail to determine whether intervention allocations could have been foreseen before or during enrollment | Selection bias (biased allocation to interventions) due to inadequate concealment of allocations prior to assignment | Intervention allocations likely could not have been foreseen in before or during enrollment | Not described in sufficient detail | High Low Unclear
Reporting bias Selective reporting | Stated how the possibility of selective outcome reporting was examined by the authors and what was found | Reporting bias due to selective outcome reporting | Selective outcome reporting bias not detected | Insufficient information to permit judgment† | High Low Unclear
Other bias Other sources of bias | Any important concerns about bias not addressed above^*^ | Bias due to problems not covered elsewhere in the table | No other bias detected | There may be a risk of bias, but there is either insufficient information to assess whether an important risk of bias exists or insufficient rationale or evidence that an identified problem will introduce bias | High Low Unclear
Performance bias Blinding (participants and personnel) | Described all measures used, if any, to blind study participants and personnel from knowledge of which intervention a participant received. Provided any information relating to whether the intended blinding was effective. | Performance bias due to knowledge of the allocated interventions by participants and personnel during the study. | Blinding was likely effective. | Not described in sufficient detail | High Low Unclear
Detection bias Blinding (outcome assessment) | Described all measures used, if any, to blind outcome assessors from knowledge of which intervention a participant received. Provided any information relating to whether the intended blinding was effective. | Detection bias due to knowledge of the allocated interventions by outcome assessors. | Blinding was likely effective. | Not described in sufficient detail | High Low Unclear
Attrition bias Incomplete outcome data | Described the completeness of outcome data for each main outcome, including attrition and exclusions from the analysis. Stated whether attrition and exclusions were reported, the numbers in each intervention group (compared with total randomized participants), reasons for attrition/exclusions where reported. | Attrition bias due to amount, nature or handling of incomplete outcome data. | Handling of incomplete outcome data was complete and unlikely to have produced bias | Insufficient reporting of attrition/exclusions to permit judgment (e.g., number randomized not stated, no reasons for missing data provided) | High Low Unclear

* If particular questions/entries were pre-specified in the study's protocol, responses should be provided for each question/entry.

Criteria for Judging Risk of Bias Using the Cochrane Risk of Bias Assessment Tool^*^

Bias | Judgment | Criteria
RANDOM SEQUENCE GENERATION Selection bias (biased allocation to interventions) due to inadequate generation of a randomised sequence. | ‘Low risk’ of bias. | The investigators describe a random component in the sequence generation process such as:; - Referring to a random number table;; - Using a computer random number generator;; - Coin tossing;; - Shuffling cards or envelopes;; - Throwing dice;; - Drawing of lots;; - Minimization*.; *Minimization may be implemented without a random element, and this is considered to be equivalent to being random.
RANDOM SEQUENCE GENERATION Selection bias (biased allocation to interventions) due to inadequate generation of a randomised sequence. | ‘High risk’ of bias. | The investigators describe a non-random component in the sequence generation process. Usually, the description would involve some systematic, non-random approach, for example:; - Sequence generated by odd or even date of birth;; - Sequence generated by some rule based on date (or day) of admission;; - Sequence generated by some rule based on hospital or clinic record number.; Other non-random approaches happen much less frequently than the systematic approaches mentioned above and tend to be obvious. They usually involve judgement or some method of non-random categorization of participants, for example:; - Allocation by judgement of the clinician;; - Allocation by preference of the participant;; - Allocation based on the results of a laboratory test or a series of tests;; - Allocation by availability of the intervention.
RANDOM SEQUENCE GENERATION Selection bias (biased allocation to interventions) due to inadequate generation of a randomised sequence. | ‘Unclear risk’ of bias. | Insufficient information about the sequence generation process to permit judgement of ‘Low risk’ or ‘High risk’.
ALLOCATION CONCEALMENT Selection bias (biased allocation to interventions) due to inadequate concealment of allocations prior to assignment. | ‘Low risk’ of bias. | Participants and investigators enrolling participants could not foresee assignment because one of the following, or an equivalent method, was used to conceal allocation:; - Central allocation (including telephone, web-based and pharmacy-controlled randomization);; - Sequentially numbered drug containers of identical appearance;; - Sequentially numbered, opaque, sealed envelopes.
ALLOCATION CONCEALMENT Selection bias (biased allocation to interventions) due to inadequate concealment of allocations prior to assignment. | ‘High risk’ of bias. | Participants or investigators enrolling participants could possibly foresee assignments and thus introduce selection bias, such as allocation based on:; - Using an open random allocation schedule (e.g. a list of random numbers);; - Assignment envelopes were used without appropriate safeguards (e.g. if envelopes were unsealed or non­opaque or not sequentially numbered);; - Alternation or rotation;; - Date of birth;; - Case record number;; - Any other explicitly unconcealed procedure.
ALLOCATION CONCEALMENT Selection bias (biased allocation to interventions) due to inadequate concealment of allocations prior to assignment. | ‘Unclear risk’ of bias. | Insufficient information to permit judgement of ‘Low risk’ or ‘High risk’. This is usually the case if the method of concealment is not described or not described in sufficient detail to allow a definite judgement – for example if the use of assignment envelopes is described, but it remains unclear whether envelopes were sequentially numbered, opaque and sealed.
SELECTIVE REPORTING Reporting bias due to selective outcome reporting. | ‘Low risk’ of bias. | Any of the following:; - The study protocol is available and all of the study's pre-specified (primary and secondary) outcomes that are of interest in the review have been reported in the pre-specified way;; - The study protocol is not available but it is clear that the published reports include all expected outcomes, including those that were pre-specified (convincing text of this nature may be uncommon).
SELECTIVE REPORTING Reporting bias due to selective outcome reporting. | ‘High risk’ of bias. | Any one of the following:; - Not all of the study's pre-specified primary outcomes have been reported;; - One or more primary outcomes is reported using measurements, analysis methods or subsets of the data (e.g. subscales) that were not pre-specified;; - One or more reported primary outcomes were not pre-specified (unless clear justification for their reporting is provided, such as an unexpected adverse effect);; - One or more outcomes of interest in the review are reported incompletely so that they cannot be entered in a meta-analysis;; - The study report fails to include results for a key outcome that would be expected to have been reported for such a study.
SELECTIVE REPORTING Reporting bias due to selective outcome reporting. | ‘Unclear risk’ of bias. | Insufficient information to permit judgement of ‘Low risk’ or ‘High risk’. It is likely that the majority of studies will fall into this category.
OTHER BIAS Bias due to problems not covered elsewhere in the table. | ‘Low risk’ of bias. | The study appears to be free of other sources of bias.
OTHER BIAS Bias due to problems not covered elsewhere in the table. | ‘High risk’ of bias. | There is at least one important risk of bias. For example, the study:; - Had a potential source of bias related to the specific study design used; or; - Has been claimed to have been fraudulent; or; - Had some other problem.
OTHER BIAS Bias due to problems not covered elsewhere in the table. | ‘Unclear risk’ of bias. | There may be a risk of bias, but there is either:; - Insufficient information to assess whether an important risk of bias exists; or; - Insufficient rationale or evidence that an identified problem will introduce bias.
BLINDING OF PARTICIPANTS AND PERSONNEL Performance bias due to knowledge of the allocated interventions by participants and personnel during the study. | ‘Low risk’ of bias. | Any one of the following:; - No blinding or incomplete blinding, but the review authors judge that the outcome is not likely to be influenced by lack of blinding;; - Blinding of participants and key study personnel ensured, and unlikely that the blinding could have been broken.
BLINDING OF PARTICIPANTS AND PERSONNEL Performance bias due to knowledge of the allocated interventions by participants and personnel during the study. | ‘High risk’ of bias. | Any one of the following:; - No blinding or incomplete blinding, and the outcome is likely to be influenced by lack of blinding;; - Blinding of key study participants and personnel attempted, but likely that the blinding could have been broken, and the outcome is likely to be influenced by lack of blinding.
BLINDING OF PARTICIPANTS AND PERSONNEL Performance bias due to knowledge of the allocated interventions by participants and personnel during the study. | ‘Unclear risk’ of bias. | Any one of the following:; - Insufficient information to permit judgment of ‘Low risk’ or ‘High risk’;; - The study did not address this outcome.
BLINDING OF OUTCOME ASSESSMENT Detection bias due to knowledge of the allocated interventions by outcome assessors. | ‘Low risk’ of bias. | Any one of the following:; - No blinding of outcome assessment, but the review authors judge that the outcome measurement is not likely to be influenced by lack of blinding;; - Blinding of outcome assessment ensured, and unlikely that the blinding could have been broken.
BLINDING OF OUTCOME ASSESSMENT Detection bias due to knowledge of the allocated interventions by outcome assessors. | ‘High risk’ of bias. | Any one of the following:; - No blinding of outcome assessment, and the outcome measurement is likely to be influenced by lack of blinding;; - Blinding of outcome assessment, but likely that the blinding could have been broken and the outcome measurement is likely to be influenced by lack of blinding.
BLINDING OF OUTCOME ASSESSMENT Detection bias due to knowledge of the allocated interventions by outcome assessors. | ‘Unclear risk’ of bias. | Any one of the following:; - Insufficient information to permit judgment of ‘Low risk’ or ‘High risk’;; - The study did not address this outcome.
INCOMPLETE OUTCOME DATA Attrition bias due to amount, nature, or handling of incomplete outcome data. | ‘Low risk’ of bias. | Any one of the following:; - No missing outcome data;; - Reasons for missing outcome data unlikely to be related to true outcome (for survival data, censoring unlikely to be introducing bias);; - Missing outcome data balanced in numbers across intervention groups, with similar reasons for missing data across groups;; - For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk not enough to have a clinically relevant impact on the intervention effect estimate;; - For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes not enough to have a clinically relevant impact on observed effect size;; - Missing data have been imputed using appropriate methods.
INCOMPLETE OUTCOME DATA Attrition bias due to amount, nature, or handling of incomplete outcome data. | ‘High risk’ of bias. | Any one of the following:; - Reason for missing outcome data likely to be related to true outcome, with either imbalance in numbers or reasons for missing data across intervention groups;; - For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk enough to induce clinically relevant bias in intervention effect estimate;; - For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes enough to induce clinically relevant bias in observed effect size;; - ‘As-treated’ analysis done with substantial departure of the intervention received from that assigned at randomization;; - Potentially inappropriate application of simple imputation.
INCOMPLETE OUTCOME DATA Attrition bias due to amount, nature, or handling of incomplete outcome data. | ‘Unclear risk’ of bias. | Any one of the following:; - Insufficient reporting of attrition/exclusions to permit judgement of ‘Low risk’ or ‘High risk’ (e.g. number randomized not stated, no reasons for missing data provided);; - The study did not address this outcome.

* Adapted from the Cochrane Collaboration

RTI Bank Risk of Bias Assessment Form

Ref ID:____________ Reviewer ___ ___ ___
| | No | Yes | Comments
Questions to Assess the Risk of Bias
Q1 | Do the inclusion/exclusion criteria vary across the comparison groups of the study?
Q2 | Does the strategy for recruiting participants into the study differ across groups?
Q3 | Is the selection of the comparison group inappropriate, after taking into account feasibility and ethical considerations?
Q4 | Was the outcome assessor not blinded to the intervention or exposure status of participants?
Q5 | Were valid and reliable measures, implemented consistently across all study participants used to assess inclusion/exclusion criteria, intervention/exposure outcomes, participant health benefits and harms, and confounding?
Q6 | Was the length of followup different across study groups?
Q7 | In cases of high loss to followup (or differential loss to followup), was the impact assessed (e.g., through sensitivity analysis or other adjustment method)?
Questions to Assess Confounding
Q8 | Any attempt to balance the allocation between the groups or match groups (e.g., through stratification, matching, propensity scores)?
Q9 | Were the important confounding variables taken into account in the design and/or analysis (e.g., through matching, stratification, interaction terms, multivariate analysis, or other statistical adjustment such as instrumental variables)?
Questions to Assess Precision
Q10 | Are the statistical methods used to assess the primary benefit outcomes inadequate?
Q11 | Are the statistical methods used to assess the main harm or adverse event outcomes inadequate?

Based on cohort questions from: Viswanathan M, Berkman ND, Dryden DM, et al. Assessing Risk of Bias and Confounding in Observational Studies of Interventions or Exposures: Further Development of the RTI Item Bank [Internet]. Rockville (MD). Agency for Healthcare Research and Quality (US). 2013. Aug. Available from: http://www.ncbi.nlm.nih.gov/books/NBK154461/.

Risk of Bias Assessment Form: Harms Reporting

Reviewer: __________ Ref ID: __________
Question | Yes | No | Comments
Were the harms predefined using standardized or precise definitions? (McHarms)
Are all pre-specified harms reported? (RTI case series)
Did the author(s) use STANDARD scale(s) or checklist(s) for harms collection? (McHarms)
Are the statistical methods used to assess the main harm or adverse event outcomes adequate? (RTI cohort)

Quality Assessment Form (AMSTAR): Systematic Reviews

1. Was a priori design provided? | □ Yes □ No □ Can't answer □ Not applicable
2. Was there duplicate study selection and data extraction? | □ Yes □ No □ Can't answer □ Not applicable
3. Was a comprehensive literature search performed? | □ Yes □ No □ Can't answer □ Not applicable
4. Was the status of publication (i.e. grey literature) used as an inclusion criterion? | □ Yes □ No □ Can't answer □ Not applicable
5. Was a list of studies (included and excluded) provided? | □ Yes □ No □ Can't answer □ Not applicable
6. Were the characteristics of the included studies provided? | □ Yes □ No □ Can't answer □ Not applicable
7. Was the scientific quality of the included studies assessed and documented? | □ Yes □ No □ Can't answer □ Not applicable
8. Was the scientific quality of the included studies used appropriately in formulating conclusions? | □ Yes □ No □ Can't answer □ Not applicable
9. Were the methods used to combine the findings of studies appropriate? | □ Yes □ No □ Can't answer □ Not applicable
10. Was the likelihood of publication bias assessed? | □ Yes □ No □ Can't answer □ Not applicable
11. Was the conflict of interest included? | □ Yes □ No □ Can't answer □ Not applicable

Adapted from: Shea BJ, et al. BMC Medical Research Methodology. 2007.

## Assessment of Overall Risk of Bias for Individual Studies

There are three categories for describing the overall risk of bias for assessed studies: low risk of bias; moderate risk of bias; and high risk of bias.

### Cochrane Risk of Bias Assessment Tool

Use for risk of bias assessments for randomized controlled trials (RCTs).

The tool includes seven items in six domains:

- Selection Bias (2 items)
- Reporting bias (1 item)
- Other bias (1 item)
- Performance bias (1 item)
- Detection bias (1 item)
- Attrition bias (1 item)

The overall risk of bias for an RCT is calculated from individual domain assessments:

- Low: “low” for all domains.
- Moderate: “unclear” for one or more domains and no known important limitation that could invalidate its results.
- High: “high” for one or more domains.

### RTI Bank Risk of Bias Assessment Form

Use for risk of bias assessments for cohort/non-randomized controlled studies.

The form includes eleven items in three domains:

- Risk of Bias (7 items)
- Confounding (2 items)
- Precision (2 items)

The overall risk of bias for a cohort/non-randomized controlled study is calculated from individual domain assessments:

- Low: all “positive”
- Moderate: two or fewer “negative”
- High: more than two “negative”

Table C-1 Risk of bias assessment summary for KQ1 RCTs

Citation | AgeCat | Random Sequence Generation | Allocation Conceal | Selective Reporting | Other Bias | Outcome(s) | Blinding (pts, personnel) | Blinding (outcome assess) | Incomplete Outcome Data | Low | High | Unclear | Overall Score
Perrin et al., 2013^1^ | PRE-K | L | U | L | U | ECBI | H | H | L | 3 | 2 | 2 | Moderate
Jones, et al., 2013^2^ | PRE-K | U | U | L | L | ECBI problem, ECBI intensity | U | U | H | 2 | 1 | 4 | High
Somech et al., 2012^3^ | PRE-K | L | U | U | L | ECBI Intensity | U | U | L | 3 | 0 | 4 | Moderate
Cummings et al., 2008^4^ | PRE-K | L | L | U | H | CBCL,ECBI | H | H | H | 2 | 4 | 1 | High
Lavigne, et al., 2008^5^ | PRE-K | U | U | U | H | ECBI, CBCL | U | U | U | 0 | 1 | 6 | High
Hutchings et al., 2007^6^ | PRE-K | L | L | L | L | ECBI | H | L | L | 6 | 1 | 0 | Moderate
Markie-Dadds, et al., 2006^7^ | PRE-K | U | U | U | U | ECBI Intensity, ECBI Problem, PDR | U | U | L | 1 | 0 | 6 | Moderate
McGilloway, et al., 2012^8^ | PRE-K | L | L | U | H | ECBI | L | L | L | 5 | 1 | 1 | Low
Markie-Dadds, et al., 2006^9^ | PRE-K | L | U | U | U | ECBI Intensity, ECBI Problem, PDR | H | H | H | 1 | 3 | 3 | Moderate
Sanders et al., 2000^10^ | PRE-K | U | U | U | L | ECBI, PDR, PS, PSOC, ADAS, PPC, PASS | H | H | H | 1 | 3 | 3 | Moderate
Connell, et al., 1997^11^ | PRE-K | L | U | U | U | ECBI (intensity), ECBI (problem), PDRC | H | U | L | 2 | 1 | 4 | High
Sanders, et al., 2012^12^ | PRE-K | L | u | U | H | ECBI intensity, ECBI problem, SDQ | H | U | L | 2 | 2 | 3 | High
Jouriles, et al., 2001^13^ | PRE-K | U | U | U | H | CBCL, direct observation | U | U | U | 0 | 1 | 6 | High
Bagner, et al., 2010^14^ | PRE-K | L | U | U | L | CBCL (externalizing), CBCL (aggression), ECBI (intensity), ECBI (problem) | H | H | H | 2 | 3 | 2 | High
McCabe, et al., 2009^15^ | PRE-K | L | U | U | L | ECBI, CBCL, ARSMA-II | L | L | L | 5 | 0 | 2 | Low
Schuhmann et al., 1998^16^ | PRE-K | L | L | U | L | DPICS | U | L | H | 4 | 1 | 2 | Moderate
Eyberg et al., 1995^17^ | PRE-K | U | U | U | L | ECBI intensity, ECBI problem | H | U | H | 1 | 2 | 4 | High
Nixon, et al., 2003^18^ | PRE-K | U | U | U | L | ECBI Intensity, DPICS | U | H | L | 2 | 1 | 4 | Moderate
Sells, et al., 2011^19^ | PRE-K | U | U | U | U | | H | H | L | 1 | 2 | 4 | Moderate
Sanders, et al., 2000^20^ | PRE-K | U | U | U | U | | H | H | U | 0 | 2 | 5 | High
Havighurst, et al., 2013^21^ | PRE-K | L | L | U | L | | H | H | U | 3 | 2 | 2 | Moderate
Nixon, et al., 2001^22^ | PRE-K | U | U | U | U | | H | H | U | 0 | 2 | 5 | High
van Manen et al., 2004^23^ | SCHOOL | U | L | U | U | CBCL, TOPS, TRA, SCRS, SCST | U | U | H | 1 | 1 | 5 | Moderate
Kjobli, et al., 2012^24^ | SCHOOL | L | U | U | U | ECBI, CBCL | H | H | L | 2 | 2 | 3 | High
Axberg, et al., 2012^25^ | SCHOOL | U | U | U | H | ECBI | H | H | L | 1 | 3 | 3 | High
McGrath, et al., 2011^26^ | SCHOOL | L | L | L | L | K-SADS | U | L | L | 6 | 0 | 1 | Low
Kling, et al., 2010^27^ | SCHOOL | U | U | U | L | PDR, ECB1, ECBIP | U | U | L | 2 | 0 | 5 | Moderate
Ogden et al., 2008^28^ | SCHOOL | L | L | U | L | CBCL, SSRS, PDR | U | U | L | 4 | 0 | 3 | Moderate
Gardner, et al., 2006^29^ | SCHOOL | L | L | U | U | ECBI | U | U | L | 3 | 0 | 4 | Moderate
Webster-Stratton et al., 1994^30^ | SCHOOL | U | U | U | L | CBCL, ECBI, DPICS | U | U | U | 1 | 0 | 6 | Moderate
Hutchings, et al., 2002^31^ | SCHOOL | U | U | U | U | ECBI | U | U | L | 1 | 0 | 6 | Moderate
Scott et al., 2010^32^ | SCHOOL | L | L | L | U | PACS, ECBI | L | L | L | 6 | 0 | 1 | Low
Larsson, et al., 2009^33^ | SCHOOL | U | U | U | L | ECBI, CBCL, KSADS-PL | U | U | L | 2 | 0 | 5 | Moderate
van de Wiel et al., 2007^34^ | SCHOOL | U | U | U | U | CBCL, CBCL,TRF | U | U | L | 1 | 0 | 6 | Moderate
Drugli, et al., 2006^35^ | SCHOOL | U | U | U | H | ECBI, CBCL, KSANS | H | H | L | 1 | 3 | 3 | Moderate
Webster-Stratton et al., 2004^36^ | SCHOOL | U | U | U | L | ECBI, CBCL | U | U | U | 1 | 0 | 6 | Moderate
Cabiya et al., 2008^37^ | SCHOOL | U | U | U | H | BSBI, CDI | U | L | H | 1 | 2 | 4 | High
Webster-Stratton et al., 1997^38^ | SCHOOL | U | U | U | L | CBCL,EBCI Intensity, PDR | U | U | L | 2 | 0 | 5 | Moderate
Boylan, et al., 2013^39^ | SCHOOL | U | U | U | U | ChIPS, P-ChIPS, CDRS-R, MRS, MSI | U | L | L | 2 | 0 | 5 | Moderate
Augimeri et al., 2007^40^ | SCHOOL | U | U | U | H | CBCL | U | U | L | 1 | 1 | 5 | Moderate
Kolko, et al., 2001^41^ | SCHOOL | L | U | U | L | FHS, CP w, fire, CFI, SUFA | U | U | L | 3 | 0 | 4 | Moderate
Kolko, et al., 2010^42^ | SCHOOL | L | U | U | L | PSC-17; SDQ | U | H | L | 3 | 1 | 3 | Moderate
Kolko, et al., 2009^43^ | SCHOOL | L | U | U | L | KSADS, TRE, CBCL | U | U | L | 3 | 0 | 4 | Moderate
Greene, et al., 2004^44^ | SCHOOL | U | U | U | U | PCRI, PSI.ODBRS, C6I, KSADS-E | U | U | L | 1 | 0 | 6 | Moderate
Jouriles, et al., 2009^45^ | SCHOOL | L | H | U | L | CBCL-EXT, ECBI | H | H | U | 2 | 3 | 2 | High
Barrett, et al., 2000^46^ | SCHOOL | U | U | U | U | | H | H | U | 0 | 2 | 5 | High
Brestan, et al., 1997^47^ | SCHOOL | U | U | U | L | | H | H | L | 2 | 2 | 3 | Moderate
Rohde et al., 2004^48^ | TEEN | L | L | H | H | Conduct Disorder, BDI-II, HDRS, CBCL, CGAS, SAS-R | L | L | U | 4 | 2 | 1 | High
Weiss et al., 2013^49^ | TEEN | U | U | U | L | CBCL | U | U | L | 2 | 0 | 5 | Moderate
Butler, et al., 2011^50^ | TEEN | L | L | U | L | arrest records | U | L | L | 5 | 0 | 2 | Low
Asscher et al., 2013^51^ | TEEN | L | U | L | U | CBCL - parents + YSR | U | H | L | 3 | 1 | 3 | High
Borduin et al., 1995^52^ | TEEN | L | U | U | U | symptom checklist, RPBX, FACES II | U | U | H | 1 | 1 | 5 | Moderate
Sundell et al., 2008^53^ | TEEN | L | L | L | L | CBCL | U | U | L | 5 | 0 | 2 | Low
Shechtman, et al., 2006^54^ | TEEN | U | U | U | U | CBCL, CCNES | U | U | L | 1 | 0 | 6 | Moderate
Santisteban et al., 2003^55^ | TEEN | U | U | U | L | RBPC | U | U | H | 1 | 1 | 5 | High
Nickel, et al., 2006^56^ | TEEN | L | L | L | L | ARBS, STAXI, SF-36 | L | L | L | 7 | 0 | 0 | Low
Nickel, et al., 2005^57^ | TEEN | L | L | L | L | ARBS, STAXI | L | L | L | 7 | 0 | 0 | Low
Nickel, et al., 2006^58^ | TEEN | L | L | U | U | Salivary, STAXI | U | L | L | 4 | 0 | 3 | Moderate
Azrin, et al., 2001^59^ | TEEN | H | U | U | L | | H | L | H | 2 | 3 | 2 | High

Table C-2 Risk of bias assessment summary for KQ1 cohort/nonrandomized controlled studies

Author, Year | Inclusion/exclusion criteria across groups | Recruitment strategy across groups | Selection of the comparison group | Outcome assessor blinding | Valid & reliable measures across study participants | Length of followup different across groups | Assessment of impact of high loss to followup | Balancing allocation between groups/matching groups | Accounting for confounding factors | Adequacy of statistical methods to assess primary outcomes | Adequacy of statistical methods to assess harms or adverse events outcomes | Rating
van der Put et al., 2013^60^ | + | + | - | - | - | - | NA | - | - | + | NA | Poor
Koegl et al., 2008^61^ | + | - | + | - | + | + | - | + | + | + | NA | Poor
Posthumus et al., 2012^62^ | + | + | + | - | + | + | NA | + | + | + | NA | Fair
Lipman et al., 2008^63^ | + | + | + | - | + | + | - | - | + | + | NA | Poor
Costin et al., 2004^64^ | + | + | + | - | + | + | - | - | - | - | NA | Poor
Coughlin 2009^65^ | + | + | + | - | + | + | - | - | - | + | NA | Poor
Shapiro et al., 2012^66^ | + | + | + | - | + | - | + | - | + | + | NA | Poor
Foster et al, 2007^67^ | + | + | + | - | + | - | - | NA | - | + | NA | Poor
Masi et al., 2014^68^ | + | + | + | - | + | + | NA | + | + | + | NA | Fair

Table C-3 Risk of bias assessment summary for KQ2 RCTs

Citation (Family) | Drug | Random Sequence Generation | Allocation Conceal | Selective Reporting | Other Bias | Outcome(s) | Blinding (pts/personnel) | Blinding (outcome assess) | Incomplete Outcome Data | Low | High | Unclear | Overall Score
Dittmann et al., 2011^69^ | Atomoxetine | L | L | U | L | ECBI, SNAP | U | U | H | 3 | 1 | 3 | Moderate
Connor et al., 2010^70^ | Guanfacine | L | L | L | L | CPRS | U | U | L | 5 | 0 | 2 | Moderate
Saxena et al., 2010^71^ | Divalproex | H | U | L | H | CGI; OAS | H | H | H | 1 | 5 | 1 | High
Blader et al., 2009^72^ | Divalproex | L | U | L | U | OAS | U | H | L | 3 | 2 | 2 | Moderate
Dell'Agnello et al., 2009^73^ | Atomoxetine | U | U | L | L | SWAR-IV, CGI-S, CPRS-S | U | U | L | 3 | 0 | 4 | High
Connor et al., 2008^74^ | Quetiapine | U | U | L | U | CGI-S; OAS; CPRS-CP | L | L | L | 4 | 1 | 2 | Moderate
Armenteros et al., 2007^75^ | Risperidone | U | U | L | U | CAS; CGI | L | L | L | 4 | 1 | 2 | Moderate
Spencer et al., 2006^76^ | Amphetamine | U | U | L | L | SNAP | U | U | L | 3 | 0 | 4 | High
Reyes et al., 2006^77^ | Risperidone | U | U | L | U | CGI; CGAS | U | U | H | 1 | 2 | 4 | High
Steiner et al., 2003^78^ | Divalproex | U | U | L | U | CGI | U | L | L | 3 | 1 | 3 | Moderate
Donovan et al., 2000^79^ | Divalproex | U | U | L | L | OAS | L | L | L | 3 | 0 | 4 | Moderate
Findling et al., 2000^80^ | Risperidone | L | L | L | U | CBCL; CPRS | L | L | L | 6 | 0 | 1 | Low
Klein et al., 1997^81^ | Methylphenidate | H | H | L | U | CTRS; IOWA | H | H | L | 2 | 4 | 1 | High

Table C-4 Risk of bias assessment summary for KQ2 cohort/nonrandomized controlled studies

Author, Year | Inclusion/exclusion criteria across groups | Recruitment strategy across groups | Selection of the comparison group | Outcome assessor blinding | Valid & reliable measures across study participants | Length of followup different across groups | Assessment of impact of high loss to followup | Balancing allocation between groups/matching groups | Accounting for confounding factors | Adequacy of statistical methods to assess primary outcomes | Adequacy of statistical methods to assess harms or adverse events outcomes | Rating
Bastiaens et al., 2009^82^ | + | + | + | - | + | + | + | - | - | - | - | Poor

Table C-5 Risk of bias assessment summary for KQ5 studies reporting harms

Author, Year | Were the harms predefined using standardized or precise definitions? | Were all pre-specified harms reported? | Did the author(s) use STANDARD scale(s) or checklist(s) for harms collection? | Were the statistical methods used to assess the main harm adequate? | Rating
Dittmann et al., 2011^69^ | + | Unsure | - | - | Poor
Dell'Agnello et al., 2009^73^ | - | Unsure | - | + | Poor
Connor et al., 2010^70^ | + | Unsure | Unsure | + | Poor
Bastiaens et al., 2009^82^ | - | Unsure | + | + | Poor
Connor et al., 2008^74^ | + | + | + | + | Good
Spencer et al., 2006^76^ and Connor et al., 2005^83^ | - | Unsure | Unsure | + | Poor
Steiner et al., 2003^78^ | - | Unsure | Unsure | - | Poor
Donovan et al., 2000^79^ | - | Unsure | Unsure | + | Poor
Blader et al., 2009^72^ | + | Unsure | + | + | Fair
Ercan et al., 2003^84^ | + | + | - | + | Fair
Armenteros et al., 2007^75^ | + | + | + | + | Good
Penzner et al., 2009^85^ | + | + | + | + | Good
Reyes et al., 2006^77^ and Pandina et al., 2009^86^ | - | Unsure | + | + | Fair
Findling et al., 2000^80^ | + | + | + | + | Good
Klein et al., 1997^81^ | - | Unsure | - | - | Poor

Table C-6 Summary of quality assessment for KQ5 existing reviews reporting harms

Author, Year | A priori design | Duplicate study selection/extraction | Comprehensive literature search | Status of publication as exclusion criterion | Included and excluded studies provided | Characteristics of included studies provided | Quality assessed | Quality used appropriately | Synthesis methods appropriate | Publication bias assessed | Conflict of interest stated | Rating
Loy et al., 2012^87^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | NA | Yes | Good
Seida et al., 2012^88^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Pringsheim et al., 2011^89^ | Yes | Yes | No | Yes | No | yes | Yes | Yes | Yes | No | Yes | Good

## References for Appendix C

1 Perrin EC, Sheldrick RC, McMenamy JM, et al. Improving Parenting Skills for Families of Young Children in Pediatric Settings: A Randomized Clinical Trial. JAMA Pediatr. 2013. Nov. 4. [pmid: 24190691].
2 Jones DJ, Forehand R, Cuellar J, et al. Technology-Enhanced Program for Child Disruptive Behavior Disorders: Development and Pilot Randomized Control Trial. J Clin Child Adolesc Psychol. 2013. Aug. 7. [pmid: 23924046].
3 Somech LY, Elizur Y. Promoting self-regulation and cooperation in pre-kindergarten children with conduct problems: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Apr. 2012;51(4):412-22. [pmid: 22449647].
4 Cummings JG, Wittenberg JV. Supportive expressive therapy--Parent child version: An exploratory study. Psychotherapy (Chic). Jun. 2008;45(2):148-64. [pmid: 22122414].
5 Lavigne JV, Lebailly SA, Gouze KR, et al. Treating oppositional defiant disorder in primary care: a comparison of three models. J Pediatr Psychol. Jun. 2008;33(5):449-61. [pmid: 17956932].
6 Hutchings J, Gardner F, Bywater T, et al. Parenting intervention in Sure Start services for children at risk of developing conduct disorder: pragmatic randomised controlled trial. BMJ. Mar. 31. 2007;334(7595):678. [pmid: 17350966].
7 Markie-Dadds C, Sanders MR. A Controlled Evaluation of an Enhanced Self-Directed Behavioural Family Intervention for Parents of Children With Conduct Problems in Rural and Remote Areas. Behaviour Change. 2006;23(1):55-72.
8 McGilloway S, Mhaille GN, Bywater T, et al. A parenting intervention for childhood behavioral problems: A randomized controlled trial in disadvantaged community-based settings. J Consult Clin Psychol. 2012;80(1):116-27. [pmid: 22148879].
9 Markie-Dadds C, Sanders MR. Self-Directed Triple P (Positive Parenting Program) for Mothers with Children at-Risk of Developing Conduct Problems. Behav Cogn Psychother. 2006;34(3):259-75.
10 Sanders MR, Markie-Dadds C, Tully LA, et al. The triple P-positive parenting program: a comparison of enhanced, standard, and self-directed behavioral family intervention for parents of children with early onset conduct problems. J Consult Clin Psychol. Aug. 2000;68(4):624-40. [pmid: 10965638].
11 Connell S, Sanders MR, Markie-Dadds C. Self-directed behavioral family intervention for parents of oppositional children in rural and remote areas. Behav Modif. Oct. 1997;21(4):379-408. [pmid: 9337598].
12 Sanders MR, Baker S, Turner KM. A randomized controlled trial evaluating the efficacy of Triple P Online with parents of children with early-onset conduct problems. Behav Res Ther. Nov. 2012;50(11):675-84. [pmid: 22982082].
13 Jouriles EN, McDonald R, Spiller L, et al. Reducing conduct problems among children of battered women. J Consult Clin Psychol. Oct. 2001;69(5):774-85. [pmid: 11680554].
14 Bagner DM, Sheinkopf SJ, Vohr BR, et al. Parenting intervention for externalizing behavior problems in children born premature: an initial examination. J Dev Behav Pediatr. Apr. 2010;31(3):209-16. [pmid: 20375736].
15 McCabe K, Yeh M. Parent-child interaction therapy for Mexican Americans: a randomized clinical trial. J Clin Child Adolesc Psychol. Sep. 2009;38(5):753-9. [pmid: 20183659].
16 Schuhmann EM, Foote RC, Eyberg SM, et al. Efficacy of parent-child interaction therapy: interim report of a randomized trial with short-term maintenance. J Clin Child Psychol. Mar. 1998;27(1):34-45. [pmid: 9561935].
17 Eyberg SM, Boggs SR, Algina J. Parent-child interaction therapy: a psychosocial model for the treatment of young children with conduct problem behavior and their families. Psychopharmacol Bull. 1995;31(1):83-91. [pmid: 7675994].
18 Nixon RD, Sweeney L, Erickson DB, et al. Parent-child interaction therapy: a comparison of standard and abbreviated treatments for oppositional defiant preschoolers. J Consult Clin Psychol. Apr. 2003;71(2):251-60. [pmid: 12699020].
19 Sells SP, Early KW, Smith TE. Reducing Adolescent Oppositional and Conduct Disorders: An Experimental Design Using the Parenting with Love and Limits® Model. Professional Issues in Criminal Justice. 2011;6(3).
20 Sanders MR, McFarland M. Treatment of depressed mothers with disruptive children: A controlled evaluation of cognitive behavioral family intervention. Behav Ther. Winter. 2000;31(1):89-112.
21 Havighurst SS, Wilson KR, Harley AE, et al. “Tuning into Kids”: reducing young children's behavior problems using an emotion coaching parenting program. Child Psychiatry Hum Dev. Apr. 2013;44(2):247-64. [pmid: 22820873].
22 Nixon RDV. Changes in hyperactivity and temperament in behaviourally disturbed preschoolers after parent-child interaction therapy (PCIT). Behaviour Change. 2001;18(3):168-76.
23 van Manen TG, Prins PJ, Emmelkamp PM. Reducing aggressive behavior in boys with a social cognitive group treatment: results of a randomized, controlled trial. J Am Acad Child Adolesc Psychiatry. Dec. 2004;43(12):1478-87. [pmid: 15564817].
24 Kjobli J, Ogden T. A randomized effectiveness trial of brief parent training in primary care settings. Prev Sci. Dec. 2012;13(6):616-26. [pmid: 22956303].
25 Axberg U, Broberg AG. Evaluation of “the incredible years” in Sweden: the transferability of an American parent-training program to Sweden. Scand J Psychol. Jun. 2012;53(3):224-32. [pmid: 22621727].
26 McGrath PJ, Lingley-Pottie P, Thurston C, et al. Telephone-based mental health interventions for child disruptive behavior or anxiety disorders: randomized trials and overall analysis. J Am Acad Child Adolesc Psychiatry. Nov. 2011;50(11):1162-72. [pmid: 22024004].
27 Kling A, Forster M, Sundell K, et al. A randomized controlled effectiveness trial of parent management training with varying degrees of therapist support. Behav Ther. Dec. 2010;41(4):530-42. [pmid: 21035616].
28 Ogden T, Hagen KA. Treatment effectiveness of Parent Management Training in Norway: a randomized controlled trial of children with conduct problems. J Consult Clin Psychol. Aug. 2008;76(4):607-21. [pmid: 18665689].
29 Gardner F, Burton J, Klimes I. Randomised controlled trial of a parenting intervention in the voluntary sector for reducing child conduct problems: outcomes and mechanisms of change. J Child Psychol Psychiatry. Nov. 2006;47(11):1123-32. [pmid: 17076751].
30 Webster-Stratton C. Advancing videotape parent training: a comparison study. J Consult Clin Psychol. Jun. 1994;62(3):583-93. [pmid: 8063985].
31 Hutchings J, Appleton P, Smith M, et al. Evaluation of two treatments for children with severe behaviour problems: Child behaviour and maternal mental health outcomes. Behav Cogn Psychother. Jul. 2002;30(3):279-95.
32 Scott S, Sylva K, Doolan M, et al. Randomised controlled trial of parent groups for child antisocial behaviour targeting multiple risk factors: the SPOKES project. J Child Psychol Psychiatry. Jan. 2010;51(1):48-57. [pmid: 19732250].
33 Larsson B, Fossum S, Clifford G, et al. Treatment of oppositional defiant and conduct problems in young Norwegian children : results of a randomized controlled trial. Eur Child Adolesc Psychiatry. Jan. 2009;18(1):42-52. [pmid: 18563473].
34 van de Wiel NM, Matthys W, Cohen-Kettenis PT, et al. The effectiveness of an experimental treatment when compared to care as usual depends on the type of care as usual. Behav Modif. May. 2007;31(3):298-312. [pmid: 17438344].
35 Drugli MB, Larsson B. Children aged 4-8 years treated with parent training and child therapy because of conduct problems: generalisation effects to day-care and school settings. Eur Child Adolesc Psychiatry. Oct. 2006;15(7):392-9. [pmid: 16614786].
36 Webster-Stratton C, Reid MJ, Hammond M. Treating children with early-onset conduct problems: intervention outcomes for parent, child, and teacher training. J Clin Child Adolesc Psychol. Mar. 2004;33(1):105-24. [pmid: 15028546].
37 Cabiya JJ, Padilla-Cotto L, González K, et al. Effectiveness of a cognitive-behavioral intervention for Puerto Rican children. Revista Interamericana de Psicología. 2008;42(2):195-202.
38 Webster-Stratton C, Hammond M. Treating children with early-onset conduct problems: a comparison of child and parent training interventions. J Consult Clin Psychol. Feb. 1997;65(1):93-109. [pmid: 9103739].
39 Boylan K, Macpherson HA, Fristad MA. Examination of disruptive behavior outcomes and moderation in a randomized psychotherapy trial for mood disorders. J Am Acad Child Adolesc Psychiatry. Jul. 2013;52(7):699-708. [pmid: 23800483].
40 Augimeri LK, Farrington DP, Koegl CJ, et al. The SNAPTM Under 12 Outreach Project: Effects of a community based program for children with conduct problems. J Child Fam Stud. 2007;16(6):799-807.
41 Kolko DJ. Efficacy of cognitive-behavioral treatment and fire safety education for children who set fires: initial and follow-up outcomes. J Child Psychol Psychiatry. Mar. 2001;42(3):359-69. [pmid: 11321205].
42 Kolko DJ, Campo JV, Kelleher K, et al. Improving access to care and clinical outcome for pediatric behavioral problems: a randomized trial of a nurse-administered intervention in primary care. J Dev Behav Pediatr. Jun. 2010;31(5):393-404. [pmid: 20495474].
43 Kolko DJ, Dorn LD, Bukstein OG, et al. Community vs. clinic-based modular treatment of children with early-onset ODD or CD: a clinical trial with 3-year follow-up. J Abnorm Child Psychol. Jul. 2009;37(5):591-609. [pmid: 19221871].
44 Greene RW, Ablon JS, Goring JC, et al. Effectiveness of collaborative problem solving in affectively dysregulated children with oppositional-defiant disorder: initial findings. J Consult Clin Psychol. Dec. 2004;72(6):1157-64. [pmid: 15612861].
45 Jouriles EN, McDonald R, Rosenfield D, et al. Reducing conduct problems among children exposed to intimate partner violence: a randomized clinical trial examining effects of Project Support. J Consult Clin Psychol. Aug. 2009;77(4):705-17. [pmid: 19634963].
46 Barrett P, Turner C, Rombouts S, et al. Reciprocal skills training in the treatment of externalising behaviour disorders in childhood: A preliminary investigation. Behaviour Change. 2000;17(4):221-34.
47 Brestan EV, Eyberg SM, Boggs SR, et al. Parent–child interaction therapy: Parents' perceptions of untreated siblings. Child Fam Behav Ther. 1997;19(3):13-28.
48 Rohde P, Clarke GN, Mace DE, et al. An efficacy/effectiveness study of cognitive-behavioral treatment for adolescents with comorbid major depression and conduct disorder. J Am Acad Child Adolesc Psychiatry. Jun. 2004;43(6):660-8. [pmid: 15167082].
49 Weiss B, Han S, Harris V, et al. An Independent Randomized Clinical Trial of Multisystemic Therapy With Non-Court-Referred Adolescents With Serious Conduct Problems. J Consult Clin Psychol. 2013. Aug. 12. [pmid: 23937347].
50 Butler S, Baruch G, Hickey N, et al. A randomized controlled trial of multisystemic therapy and a statutory therapeutic intervention for young offenders. J Am Acad Child Adolesc Psychiatry. Dec. 2011;50(12):1220-35 e2. [pmid: 22115143].
51 Asscher JJ, Deković M, Manders WA, et al. A randomized controlled trial of the effectiveness of multisystemic therapy in the Netherlands: Post-treatment changes and moderator effects. J Exp Criminol. 2013;9(2):169-87.
52 Borduin CM, Mann BJ, Cone LT, et al. Multisystemic treatment of serious juvenile offenders: long-term prevention of criminality and violence. J Consult Clin Psychol. Aug. 1995;63(4):569-78. [pmid: 7673534].
53 Sundell K, Hansson K, Lofholm CA, et al. The transportability of multisystemic therapy to Sweden: short-term results from a randomized trial of conduct-disordered youths. J Fam Psychol. Aug. 2008;22(4):550-60. [pmid: 18729669].
54 Shechtman Z, Birani-Nasaraladin D. Treating mothers of aggressive children: a research study. Int J Group Psychother. Jan. 2006;56(1):93-112. [pmid: 16555426].
55 Santisteban DA, Coatsworth JD, Perez-Vidal A, et al. Efficacy of brief strategic family therapy in modifying Hispanic adolescent behavior problems and substance use. J Fam Psychol. Mar. 2003;17(1):121-33. [pmid: 12666468].
56 Nickel M, Luley J, Krawczyk J, et al. Bullying girls - changes after brief strategic family therapy: a randomized, prospective, controlled trial with one-year follow-up. Psychother Psychosom. 2006;75(1):47-55. [pmid: 16361874].
57 Nickel MK, Krawczyk J, Nickel C, et al. Anger, interpersonal relationships, and health-related quality of life in bullying boys who are treated with outpatient family therapy: a randomized, prospective, controlled trial with 1 year of follow-up. Pediatrics. Aug. 2005;116(2):e247-54. [pmid: 16061577].
58 Nickel MK, Muehlbacher M, Kaplan P, et al. Influence of family therapy on bullying behaviour, cortisol secretion, anger, and quality of life in bullying male adolescents: A randomized, prospective, controlled study. Can J Psychiatry. May. 2006;51(6):355-62. [pmid: 16786816].
59 Azrin NH, Donohue B, Teichner GA, et al. A controlled evaluation and description of individual-cognitive problem solving and family-behavior therapies in dually-diagnosed conduct-disordered and substance-dependent youth. J Child Adolesc Subst Abuse. 2001;11(1):1-43.
60 van der Put CE, Asscher JJ, Stams GJ, et al. Recidivism after treatment in a forensic youth-psychiatric setting: the effect of treatment characteristics. Int J Offender Ther Comp Criminol. Sep. 2013;57(9):1120-39. [pmid: 22811475].
61 Koegl CJ, Farrington DP, Augimeri LK, et al. Evaluation of a targeted cognitive-behavioral program for children with conduct problems--the SNAP Under 12 Outreach Project: service intensity, age and gender effects on short- and long-term outcomes. Clin Child Psychol Psychiatry. Jul. 2008;13(3):419-34. [pmid: 18783124].
62 Posthumus JA, Raaijmakers MA, Maassen GH, et al. Sustained effects of incredible years as a preventive intervention in preschool children with conduct problems. J Abnorm Child Psychol. May. 2012;40(4):487-500. [pmid: 22006348].
63 Lipman EL, Kenny M, Sniderman C, et al. Evaluation of a community-based program for young boys at-risk of antisocial behaviour: results and issues. J Can Acad Child Adolesc Psychiatry. 2008;17(1):12-9. [pmid: 18392161].
64 Costin J, Lichte C, Hill-Smith A, et al. Parent group treatments for children with Oppositional Defiant Disorder. AeJAMH (Australian e-Journal for the Advancement of Mental Health). 2004;3(1).
65 Coughlin M, Sharry J, Fitzpatrick C, et al. A controlled clinical evaluation of the parents plus children's programme: a video-based programme for parents of children aged 6 to 11 with behavioural and developmental problems. Clin Child Psychol Psychiatry. Oct. 2009;14(4):541-58. [pmid: 19759073].
66 Shapiro JP, Youngstrom JK, Youngstrom EA, et al. Transporting a manualized treatment for children's disruptive behavior to a community clinic. Journal of Contemporary Psychotherapy. 2012;42(4):215-25.
67 Foster EM, Olchowski AE, Webster-Stratton CH. Is stacking intervention components cost-effective? An analysis of the Incredible Years program. J Am Acad Child Adolesc Psychiatry. Nov. 2007;46(11):1414-24. [pmid: 18049291].
68 Masi G, Milone A, Paciello M, et al. Efficacy of a multimodal treatment for disruptive behavior disorders in children and adolescents: focus on internalizing problems. Psychiatry Res. Nov. 30. 2014;219(3):617-24. [pmid: 25060833].
69 Dittmann RW, Schacht A, Helsberg K, et al. Atomoxetine versus placebo in children and adolescents with attention-deficit/hyperactivity disorder and comorbid oppositional defiant disorder: a double-blind, randomized, multicenter trial in Germany. J Child Adolesc Psychopharmacol. Apr. 2011;21(2):97-110. [pmid: 21488751].
70 Connor DF, Findling RL, Kollins SH, et al. Effects of guanfacine extended release on oppositional symptoms in children aged 6-12 years with attention-deficit hyperactivity disorder and oppositional symptoms: a randomized, double-blind, placebo-controlled trial. CNS Drugs. Sep. 2010;24(9):755-68. [pmid: 20806988].
71 Saxena K, Mora L, Torres E, et al. Divalproex sodium-ER in outpatients with disruptive behavior disorders: a three month open label study. Child Psychiatry Hum Dev. Jun. 2010;41(3):274-84. [pmid: 20043204].
72 Blader JC, Schooler NR, Jensen PS, et al. Adjunctive divalproex versus placebo for children with ADHD and aggression refractory to stimulant monotherapy. Am J Psychiatry. Dec. 2009;166(12):1392-401. [pmid: 19884222].
73 Dell'Agnello G, Maschietto D, Bravaccio C, et al. Atomoxetine hydrochloride in the treatment of children and adolescents with attention-deficit/hyperactivity disorder and comorbid oppositional defiant disorder: A placebo-controlled Italian study. Eur Neuropsychopharmacol. Nov. 2009;19(11):822-34. [pmid: 19716683].
74 Connor DF, McLaughlin TJ, Jeffers-Terry M. Randomized controlled pilot study of quetiapine in the treatment of adolescent conduct disorder. J Child Adolesc Psychopharmacol. Apr. 2008;18(2):140-56. [pmid: 18439112].
75 Armenteros JL, Lewis JE, Davalos M. Risperidone augmentation for treatment-resistant aggression in attention-deficit/hyperactivity disorder: a placebo-controlled pilot study. J Am Acad Child Adolesc Psychiatry. May. 2007;46(5):558-65. [pmid: 17450046].
76 Spencer TJ, Abikoff HB, Connor DF, et al. Efficacy and safety of mixed amphetamine salts extended release (adderall XR) in the management of oppositional defiant disorder with or without comorbid attention-deficit/hyperactivity disorder in school-aged children and adolescents: A 4-week, multicenter, randomized, double-blind, parallel-group, placebo-controlled, forced-dose-escalation study. Clin Ther. Mar. 2006;28(3):402-18. [pmid: 16750455].
77 Reyes M, Buitelaar J, Toren P, et al. A randomized, double-blind, placebo-controlled study of risperidone maintenance treatment in children and adolescents with disruptive behavior disorders. Am J Psychiatry. Mar. 2006;163(3):402-10. [pmid: 16513860].
78 Steiner H, Petersen ML, Saxena K, et al. Divalproex sodium for the treatment of conduct disorder: a randomized controlled clinical trial. J Clin Psychiatry. Oct. 2003;64(10):1183-91. [pmid: 14658966].
79 Donovan SJ, Stewart JW, Nunes EV, et al. Divalproex treatment for youth with explosive temper and mood lability: a double-blind, placebo-controlled crossover design. Am J Psychiatry. May. 2000;157(5):818-20. [pmid: 10784478].
80 Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry. Apr. 2000;39(4):509-16. [pmid: 10761354].
81 Klein RG, Abikoff H, Klass E, et al. Clinical efficacy of methylphenidate in conduct disorder with and without attention deficit hyperactivity disorder. Arch Gen Psychiatry. Dec. 1997;54(12):1073-80. [pmid: 9400342].
82 Bastiaens L. A non-randomized, open study with aripiprazole and ziprasidone for the treatment of aggressive behavior in youth in a community clinic. Community Ment Health J. Feb. 2009;45(1):73-7. [pmid: 18597173].
83 Connor DF, Spencer TJ. Short-term cardiovascular effects of mixed amphetamine salts extended release in children and adolescents with oppositional defiant disorder. CNS Spectr. Oct. 2005;10(10 Suppl 15):31-8. [pmid: 15618945].
84 Ercan ES, Kutlu A, Cikoglu S, et al. Risperidone in children and adolescents with conduct disorder: A single-center, open-label study. Current Therapeutic Research - Clinical and Experimental. 01. Jan. 2003;64(1):55-64. [pmid: 24944356].
85 Penzner JB, Dudas M, Saito E, et al. Lack of effect of stimulant combination with second-generation antipsychotics on weight gain, metabolic changes, prolactin levels, and sedation in youth with clinically relevant aggression or oppositionality. J Child Adolesc Psychopharmacol. Oct. 2009;19(5):563-73. [pmid: 19877981].
86 Pandina GJ, Zhu Y, Cornblatt B. Cognitive function with long-term risperidone in children and adolescents with disruptive behavior disorder. J Child Adolesc Psychopharmacol. Dec. 2009;19(6):749-56. [pmid: 20035593].
87 Loy JH, Merry SN, Hetrick SE, et al. Atypical antipsychotics for disruptive behaviour disorders in children and youths. Cochrane Database Syst Rev. 2012;9. CD008559. [pmid: 22972123].
88 Seida JC, Schouten JR, Mousavi SS, et al. First- and Second-Generation Antipsychotics for Children and Young Adults. Comparative Effectiveness Review. AHRQ Publication No: 11(12)-EHC077-EF. Rockville, MD. Agency for Healthcare Research and Quality. Feb. 2012;39. http://effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productID=835.
89 Pringsheim T, Lam D, Ching H, et al. Metabolic and neurological complications of second-generation antipsychotic use in children: a systematic review and meta-analysis of randomized controlled trials. Drug Saf. Aug. 1. 2011;34(8):651-68. [pmid: 21751826].