# Literature Screening Forms

Primary Literature Abstract Screening Form

Primary Literature Full-Text Screening Form

Existing Reviews Relevance Screening Form