# Search Strategies

Table A-1 MEDLINE search strategies updated (PubMed interface) December 11, 2013

Search terms | | Results
Psychosocial interventions
#1 | attention deficit and disruptive behavior disorders[mh:noexp] OR conduct disorder[mh] OR (mental disorders[mh] AND aggression[mh]) OR externalizing behavior^*^[tiab] OR externalizing behaviour^*^[tiab] OR oppositional defian^*^[tiab] OR conduct disorder^*^[tiab] OR disruptive behavior disorder^*^[tiab] OR antisocial personality disorder[mh] OR conduct problems[tiab] OR antisocial behavior^*^[tiab] | 23579
#2 | therapy[sh] OR therapeutics[mh] OR teaching[mh] OR psychotherapy[mh] OR treatment outcome[mh] OR “Adolescent Transitions Program”[tiab] OR “Anger control training”[tiab] OR “Assertive training”[tiab] OR “Behavioral parent training”[tiab] OR “Brief Strategic Family Therapy”[tiab] OR “Collaborative Problem Solving”[tiab] OR “Coping Power”[tiab] OR “Early Risers Skills for Success”[tiab] OR “Skills for Success Program”[tiab] OR “First Step to Success”[tiab] OR “Functional Family Therapy”[tiab] OR “Helping the Noncompliant Child”[tiab] OR “Incredible Years”[tiab] OR “Interpersonal skills training”[tiab] OR “Multidimensional Family Therapy”[tiab] OR “Multidimensional Treatment Foster Care”[tiab] OR “Multisystemic Therapy”[tiab] OR “Multi-systemic Therapy”[tiab] OR “Parent Management Training”[tiab] OR “Parent-Child Interaction Therapy”[tiab] OR “Positive Parenting Program”[tiab] OR “Problem Solving Skills Training”[tiab] OR “Positive Behavioral Support System”[tiab] OR “Promoting Alternative Thinking Strategies”[tiab] OR “Second Step”[tiab] OR “Self-Control training”[tiab] OR “Teacher-Child Interaction Training”[tiab] OR “Teacher Child Interaction Training”[tiab] | 6753849
#3 | eng[la] AND (child[mh] OR adolescent[mh]) | 1775464
#4 | newspaper article[pt] OR letter[pt] OR comment[pt] OR case reports[pt] OR review[pt] OR practice guideline[pt] OR news[pt] OR editorial[pt] OR historical article[pt] OR meta-analysis[pt] OR legal cases[pt] OR published erratum[pt] OR congresses[pt] OR jsubsetk | 4996769
#5 | (#1 AND #2 AND #3) NOT #4 | 3181
#6 | (oppositional defian^*^[tiab] OR conduct disorder^*^[tiab] OR disruptive behavior disorder^*^[tiab] OR disruptive behaviour disorder^*^[tiab] OR conduct problem^*^[tiab] OR antisocial behavior^*^[tiab] OR antisocial behavior^*^[tiab] OR ((externaliz^*^[tiab] OR aggressi^*^[tiab]) AND (behavior^*^[tiab] OR behaviour^*^))) NOT medline[sb] | 3745
#7 | (therapy[tiab] OR effectiveness[tiab] OR efficacy[tiab] OR outcome[tiab] OR treatment^*^[tiab] OR randomized[tiab] OR “Adolescent Transitions Program”[tiab] OR “Anger control training”[tiab] OR “Assertive training”[tiab] OR “Behavioral parent training”[tiab] OR “Brief Strategic Family Therapy”[tiab] OR “Collaborative Problem Solving”[tiab] OR “Coping Power”[tiab] OR “Early Risers Skills for Success”[tiab] OR “Skills for Success Program”[tiab] OR “First Step to Success”[tiab] OR “Functional Family Therapy”[tiab] OR “Helping the Noncompliant Child”[tiab] OR “Incredible Years”[tiab] OR “Interpersonal skills training”[tiab] OR “Multidimensional Family Therapy”[tiab] OR “Multidimensional Treatment Foster Care”[tiab] OR “Multisystemic Therapy”[tiab] OR “Multi-systemic Therapy”[tiab] OR “Parent Management Training”[tiab] OR “Parent-Child Interaction Therapy”[tiab] OR “Positive Parenting Program”[tiab] OR “Problem Solving Skills Training”[tiab] OR “Positive Behavioral Support System”[tiab] OR “Promoting Alternative Thinking Strategies”[tiab] OR “Second Step”[tiab] OR “Self-Control training”[tiab] OR “Teacher-Child Interaction Training”[tiab] OR “Teacher Child Interaction Training”[tiab]) NOT medline[sb] | 388791
#8 | (child^*^[tiab] OR youth^*^[tiab] OR adolescen^*^[tiab] OR teen^*^[tiab] OR preschool^*^[tiab] OR parent^*^[tiab] OR family[tiab] OR families[tiab] OR juvenile^*^[tiab] OR school-age^*^[tiab]) NOT medline[sb] | 149580
#9 | #6 AND #7 AND #8 | 564
#10 | #5 OR #9 (Medline and non-indexed results) | 3745
Pharmacologic interventions
#11 | attention deficit and disruptive behavior disorders[mh:noexp] OR conduct disorder[mh] OR (mental disorders[mh] AND aggression[mh]) OR externalizing behavior^*^[tiab] OR externalizing behaviour^*^[tiab] OR oppositional defian^*^[tiab] OR conduct disorder^*^[tiab] OR disruptive behavior disorder^*^[tiab] OR antisocial personality disorder[mh] OR conduct problems[tiab] OR antisocial behavior^*^[tiab] | 23579
#12 | “drug therapy” [Subheading] OR “Drug Therapy”[Mesh] OR “Antipsychotic Agents”[Mesh] OR “Antipsychotic Agents” [Pharmacological Action] OR “Adrenergic alpha-Agonists”[Mesh] OR “Adrenergic alpha-2 Receptor Agonists”[Mesh] OR “Anticonvulsants”[Mesh] OR “Anticonvulsants” [Pharmacological Action] OR “Serotonin Uptake Inhibitors”[Mesh] OR “Serotonin Uptake Inhibitors” [Pharmacological Action] OR “Central Nervous System Stimulants”[Mesh] | 2353195
#13 | eng[la] AND (child[mh] OR adolescent[mh]) | 1775464
#14 | newspaper article[pt] OR letter[pt] OR comment[pt] OR case reports[pt] OR review[pt] OR practice guideline[pt] OR news[pt] OR editorial[pt] OR historical article[pt] OR meta-analysis[pt] OR legal cases[pt] OR published erratum[pt] OR congresses[pt] OR jsubsetk | 4996769
#15 | (#11 AND #12 AND #13) NOT #14 | 685
Pharmacologic or psychosocial interventions
#16 | #15 OR #10 (all results) | 3781
#17 | #10 NOT #15 | 3096

Key: [mh] Medical Subject Heading; [tiab] title/abstract word; [pt] publication type; [sh] subheading;

* Note: numbers do not tally as some articles are excluded in more than one category

After duplicates were removed, this search contributed 1678 records to the existing 2407 in the database, for a total of 4085 records.

Table A-2 MEDLINE search strategies updated (PubMed interface) January 13, 2014

Search terms | | Results
#1 | “aggressive behavior”[tiab] OR “aggressive behaviors”[tiab] OR “aggressive behavior”[tiab] OR “aggressive behaviours”[tiab] OR “aggressive children”[tiab] OR “aggressive child”[tiab] OR “aggressive adolescent”[tiab] OR “aggressive adolescents”[tiab] OR “adolescent aggression”[tiab] OR “child aggression”[tiab] OR “antisocial behavior”[tiab] OR “antisocial behaviors”[tiab] OR “antisocial behaviour”[tiab] OR “antisocial behaviours”[tiab] OR “aggressive disruptive”[tiab] OR “Attention Deficit and Disruptive Behavior Disorders”[Mesh:NoExp] OR “behavior disorder”[tiab] OR “behavior disorders”[tiab] OR “behaviour disorder”[tiab] OR “behaviour disorders”[tiab] OR “conduct disorder”[tiab] OR “conduct disorders”[tiab] OR “Conduct Disorder”[mesh] OR “conduct problems”[tiab] OR “disruptive behavior”[tiab] OR “disruptive behaviour”[tiab] OR “disruptive behaviors”[tiab] OR “disruptive behaviours”[tiab] OR “externalizing disorder” OR “externalizing disorders” OR “externalizing behavior”[tiab] OR “externalizing behaviors”[tiab] OR “externalizing behaviour”[tiab] OR “externalizing behaviours”[tiab] OR “externalizing problem behavior”[tiab] OR “externalizing problem behaviors”[tiab] OR “externalizing problem behaviour”[tiab] OR “externalizing problem behaviours”[tiab] OR “oppositional defiant”[tiab] OR “oppositional defiance”[tiab] OR oppositionality[tiab] OR ((Aggression[Mesh] OR aggression[tiab] OR bullying[tiab] OR noncompliant[tiab] OR defiance[tiab] OR defiant[tiab] OR disruptive[tiab] OR oppositional[tiab] OR antisocial[tiab] OR “Psychomotor Agitation”[mesh]) AND (“Child Behavior”[mesh] OR “Adolescent Behavior”[mesh] OR behavior[tiab] OR behaviour[tiab] OR behaviors[tiab] OR behaviours[tiab] OR conduct[tiab])) | 36627
#2 | “anger management”[tiab] OR “anger control”[tiab] OR “behavior management”[tiab] OR “behaviour management”[tiab] OR “behavioral management”[tiab] OR “behavioural management”[tiab] OR “behavioral support”[tiab] OR “behavioural support”[tiab] OR “cognitive therapy”[tiab] OR “cognitive behavior therapy”[tiab] OR “cognitive behaviour therapy”[tiab] OR “CBT”[tiab] OR “cognitive behavioral therapy”[tiab] OR “cognitive behavioural therapy”[tiab] OR “conflict management”[tiab] OR counseling[tiab] OR “coping power”[tiab] OR “Counseling”[Mesh] OR “drug therapy”[tiab] OR “early intervention”[tiab] OR “family therapy”[tiab] OR “multisystemic therapy”[tiab] OR “multi-systemic therapy”[tiab] OR “multidimensional treatment”[tiab] OR “multidimensional therapy”[tiab] OR “nonpharmacologic therapy”[tiab] OR “nondrug therapy”[tiab] OR “non-drug therapy”[tiab] OR “parent training”[tiab] OR “parent engagement”[tiab] OR “parent management”[tiab] OR “parenting skills”[tiab] OR “parenting intervention”[tiab] OR “parenting interventions”[tiab] OR “family training”[tiab] OR “family education”[tiab] OR “family intervention”[tiab] OR “family interventions”[tiab] OR “pharmacologic therapy”[tiab] OR “pharmacologic treatment”[tiab] OR “Problem Solving”[Mesh] OR “problem solving”[tiab] OR “Psychology, Applied”[Mesh] OR psychoeducation[tiab] OR “psychosocial therapy”[tiab] OR “psychosocial intervention”[tiab] OR “psychosocial interventions”[tiab] OR “psychosocial approach”[tiab] OR “psychosocial approaches”[tiab] OR “psychosocial treatment”[tiab] OR “psychosocial support”[tiab] OR “Psychotherapy”[Mesh] OR psychotherap^*^[tiab] OR “skills training”[tiab] OR “symptom management”[tiab] OR teaching[tiab] OR “Therapeutics”[Mesh:NoExp] OR treatment[tiab] OR therapy[tiab] OR training[tiab] OR “Treatment Outcome”[Mesh] OR “Adrenergic alpha-2 Receptor Agonists” [Pharmacological Action] OR “Adrenergic alpha-2 Receptor Agonists”[Mesh] OR “alpha-2 agonist”[tiab] OR “alpha-2 agonists”[tiab] OR “Antidepressive Agents”[Mesh] OR “Antidepressive Agents” [Pharmacological Action] OR antidepressant[tiab] OR antidepressants[tiab] OR “Antipsychotic Agents”[Mesh] OR “Antipsychotic Agents” [Pharmacological Action] OR antipsychotics[tiab] OR antipsychotic[tiab] OR “mood stabilizer”[tiab] OR “mood stabilizing”[tiab] OR “mood stabilizers”[tiab] OR psychostimulant[tiab] OR psychostimulants[tiab] OR “Serotonin Uptake Inhibitors”[Mesh] OR “SSRI”[tiab] OR “SSRIs”[tiab] OR “selective serotonin reuptake inhibitors”[tiab] OR “Serotonin Uptake Inhibitors” [Pharmacological Action] OR stimulants[tiab] OR “Central Nervous System Stimulants”[Mesh] OR “Central Nervous System Stimulants” [Pharmacological Action] OR “Sympatholytics”[Mesh] OR “Sympatholytics” [Pharmacological Action] OR sympatholytic[tiab] OR sympatholytics[tiab] | 4613496
#3 | #1 AND #2 AND english[la] AND (child[mh] OR adolescent[mh] OR child^*^[tiab] OR teen^*^[tiab] OR adolescent^*^[tiab] OR adolescence[tiab] OR pediatric[tiab] OR paediatric^*^[tiab]) | 6076
#4 | newspaper article[pt] OR letter[pt] OR comment[pt] OR case reports[pt] OR review[pt] OR practice guideline[pt] OR news[pt] OR editorial[pt] OR historical article[pt] OR meta-analysis[pt] OR legal cases[pt] OR published erratum[pt] OR congresses[pt] OR jsubsetk | 5028324
#5 | #3 NOT #4 | 4695

Key: [mh] Medical Subject Heading; [tiab] title/abstract word; [pt] publication type; [sh] subheading;

* Note: numbers do not tally as some articles are excluded in more than one category

This search, less the duplicates, contributed 2716 citations for a total of 6801 records for initial screening

Table A-3 PsycINFO (via ProQuest interface) search results, November 26, 2013

Search terms | | Results
PsycInfo- psychosocial
#1 | SU.EXACT(“Conduct Disorder”) OR SU.EXACT(“Oppositional Defiant Disorder”) OR SU.EXACT(“Antisocial Personality Disorder”) OR (disruptive behavior disorder OR disruptive behavior disorders) | 11181
#2 | SU.EXACT.EXPLODE(“Treatment”) OR SU.EXACT.EXPLODE(“Medicinal Herbs and Plants”) OR SU.EXACT.EXPLODE(“Dietary Supplements”) OR SU.EXACT.EXPLODE(“Nutrition”) OR SU.EXACT.EXPLODE(“Vitamins”) OR SU.EXACT(“Drug Therapy”) OR SU.EXACT.EXPLODE(“Behavior Therapy”) | 573194
#3 | #1 and #2 | 2580
#4 | #3, limited children and adolescents | 1558
#5 | #3, limited to 2003-2013 publication date | 1323
#6 | #3 limited to peer reviewed, scholarly journals | 1719
#7 | #3 limited to research methodology (Empirical Study OR Quantitative Study OR Treatment Outcome/Clinical Trial OR Longitudinal Study OR Followup Study OR Retrospective Study OR Prospective Study OR Field Study) | 1200
#8 | #3 AND #4 AND #5 AND #6 AND #7 | 412
PsycInfo- pharmacologic
#9 | SU.EXACT(“Conduct Disorder”) OR SU.EXACT(“Oppositional Defiant Disorder”) OR SU.EXACT(“Antisocial Personality Disorder”) OR (disruptive behavior disorder OR disruptive behavior disorders) | 11181
#10 | (SU.EXACT.EXPLODE(“Adrenergic Blocking Drugs”) OR SU.EXACT.EXPLODE(“Adrenergic Drugs”)) OR (SU.EXACT.EXPLODE(“Anticonvulsive Drugs”) OR SU.EXACT.EXPLODE(“Antidepressant Drugs”)) OR (SU.EXACT.EXPLODE(“Drug Augmentation”) OR SU.EXACT.EXPLODE(“Drug Therapy”)) OR SU.EXACT.EXPLODE(“Neuroleptic Drugs”) OR antipsychotic | 142032
#11 | #9 AND #10 | 643
#12 | #11, limited to children and adolescents | 436
#13 | #11, limited to 2003-2013 | 384
#14 | #11, limited to peer reviewed, scholarly journals | 540
#15 | #11, limited to research methodology ((Empirical Study OR Quantitative Study OR Treatment Outcome/Clinical Trial OR Longitudinal Study OR Followup Study OR Retrospective Study OR Prospective Study OR Field Study) | 398
#16 | #11 AND #12 AND #13 AND #14 AND #15 | 170
PsycInfo- psychosocial and pharmacologic interventions
#17 | #8 OR #16 | 425

Table A-4 Embase search strategy (OvidSP interface, includes MEDLINE results), April 18, 2014

Search terms | | Search results
#1 | conduct disorder/ or behavior disorder/ or disruptive behavior/ or oppositional defiant disorder/ or aggression/ or intermittent explosive disorder/ or disruptive mood dysregulation disorder.mp | 80970
#2 | exp antidepressant agent/ or exp neuroleptic agent/ or exp serotonin uptake inhibitor/ or exp central stimulant agent/ or exp adrenergic receptor blocking agent/ or exp alpha 2 adrenergic receptor stimulating agent/ | 811935
#3 | #1 AND #2 | 13405
#4 | #3 NOT (review or conference paper or conference abstract or editorial or letter or note or short survey).pt. or case report/ or practice guideline/ or systematic review/ or meta analysis/ | 5115
#5 | #4 limit to (human and english language and exclude medline journals and yr=“1994 -Current” and (infant <to one year> or child <unspecified age> or preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years>)) | 70

Key: [mh] Medical Subject Heading; [la] language; [tiab] title/abstract word; [pt] publication type; [sh] subheading