# Abbreviations

AABC: Adolescent Antisocial Behavior Checklist
AACAP: American Academy of Child and Adolescent Psychiatry
AARS: Adolescent Anger Rating Scale
AAQ: Barratt Aggressive Acts Questionnaire
ABC: Aberrant Behavior Checklist
ABC-IS: Aberrant Behavior Checklist-Irritability Subscale
ABI: Adaptive Behavior Inventory
ADHD: Attention Deficit Hyperactivity Disorder
AGG: Aggression
AIAQ: Anger Irritability and Aggression Questionnaire
AIAQ: Anger Irritability and Assault Questionnaire
APS: Adolescent Psychopathology Scale
APSD: Antisocial Process Screening Device
AQ or AGQ: Aggression Questionnaire (Buss-Perry Aggression Questionnaire)
ARBS: Adolescent Risk Taking Behavior Scale
ART: Aggression Replacement Training
ATP: Adolescent Transitions Program
ATX: Atomoxetine
BASC: Behavior Assessment System for Children
BASC-2: Behavior Assessment System for Children, Second Edition
BASIC: Behavioral and Affective Skills in Coping
BDHI: Buss-Durkee Hostility Inventory
BPC: Brief Problem Checklist
BPI-01: Behavior Problem Inventory
BSFT: Brief Strategic Family Therapy
CAFAS: Child and Adolescent Functioning Scale
CANS-MH: Child and Adolescent Needs and Strength-Mental Health
CAS: Children's Aggression Scale
CAS-P: Children's Aggression Scale, Parent Rated
CAS-T: Children's Aggression Scale, Teacher Rated
CBCL: Child Behavior Checklist
CBRS: Conners Comprehensive Behavior Rating Scales
CBT: Cognitive-Behavioral Therapy
CBQ: Children's Behavior Questionnaire
CCNES: Coping with Children's Negative Emotions Scale
CD: Conduct Disorder
CERT: Center for Education and Research on Mental Health Therapeutics
CGAS: Children's Global Assessment Scale
CGI-C: Clinical Global Impressions, Change Scores
CGI-I: Clinical Global Impressions, Improvement Item
CGI-S: Clinical Global Impressions, Severity
CI: Confidence Interval
CNS: Central Nervous System
CON: Control
CPPRG: Conduct Problems Prevention Research Group
CPRS: Children's Psychiatric Rating Scale
CPRS: Conners Parent Rating Scale
CPRS-RS: Conners Parent Rating Scale, Revised
CPS: Collaborative Problem Solving
CrPTRC: Conners Parent and Teacher Rating Checklist, Revised Short Form
CRS: Conners Rating Scale
CSBS: Children's Social Behavior Scale
CSI-4: Children Symptom Inventory-4
CT: Child Training
CTRS: Conners Teacher Rating Scale
CWD-A: Adolescents Coping with Depression
CWL: Caregiver Wish List
DARE: Drug Abuse Resistance Education
DBD: Disruptive Behavior Disorder
DB-DOS: Disruptive Behavior Diagnostic Observation Scale
DBD-NOS: Disruptive Behavior Disorder-not otherwise specified
DBR: Direct Behavior Rating
DBS: Disruptive Behavior Scale
DISC: Diagnostic Interview Schedule for Children
DOF: Direct Observation Form
DPICS: Dyadic Parent-Child Interaction Coding System III
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, Fourth edition
ECBI: Eyberg Child Behavior Inventory
ECI-4: Early Childhood Inventory-4
EPS: Emergent Extrapyramidal Symptoms
FDA: Food and Drug Administration
FFT: Functional Family Therapy
FSE: Educational Fire Safety Intervention
FT: Family Training
G: Group
GCJS: Global Clinical Judgements Scale
HNC: Helping the Noncompliant Child
HSQ: Home Situations Questionnaire
HVF: Home Visit from a Firefighter
IAB: Interview for Antisocial Behavior
ICD: International Classification of Diseases
IIP-D: Inventory of Interpersonal Problems
INT: Intervention
ITT: Intention to treat
IY: Incredible Years
IY-CT: Incredible Years Child Training
IY-PT: Incredible Years Parent Training
IY-TT: Incredible Years Teacher Training
K-DBDS: Kiddie Disruptive Behavior Disorders Schedule
KQ: Key Question
KSADS: Schedule for Affective Disorders and Schizophrenia for School-Age Children
LHA: Life History of Aggression
LSM: Least Square Mean
MAS XR: Mixed Amphetamine Salts Extended Release
MDD: Major Depressive Disorder
MST: Multisystemic Therapy
MTFC: Multidimensional Treatment Foster Care
N: Number
NA: Not Applicable
NAMCS: National Ambulatory Medical Care Survey
NCBRF: Nisonger Child Behavior Rating Form
ND: No Data
NHAMCS: National Hospital Ambulatory Medical Care Survey
NMA: Network Meta-analysis
NR: Not Reported
NYTRS: New York Teacher Rating Scale for Disruptive and Antisocial Behavior
OAS: Overt Aggression Scale
ODD: Oppositional Defiant Disorder
PAI-A: Personality Assessment Inventory-Adolescent
PATHS: Promoting Alternative Thinking Strategies
PBSS: Positive Behavioral Support System
PCIT: Parent-Child Interaction Therapy
PDR: Parent Daily Report
P-GBI: General Behavior Inventory, Parent Vision
PICOTS: Population, Intervention, Comparator, Outcomes, Timing, Setting
PMT: Parent Management Training
PMT-O: Parent Management Training-Oregon
POS: Play Observation
PRA: Proactive and Reactive Aggression Scale
PS: Parenting Scale
PSC-17: Pediatric Symptom Checklist
PSI: Parenting Stress Index
PSI/SF: Parenting Stress Index Short Version
PSST: Problem-Solving Skills Training
PT: Parent Training
QOL: Quality of Life
QRBC: Quay Revised Behavior Checklist
QT: Interval between Q-wave and T-wave
QTcB: Heart-rate corrected QT interval
RAAPP: Rating of Aggression Against People and/or Property
RBPC: Revised Behavior Problem Checklist
RCOH: Retrospective cohort study
RCT: Randomized Controlled Trial
R-CTRS: Conners Teacher Rating Scale, Revised
RPQ: Reactive-Proactive Aggression Questionnaire
R-TRPA: Reactive and Proactive Rating Scale, Teacher Revised
SAMHSA: Substance Abuse and Mental Health Services Administration
SCIP: Social Cognitive Intervention Program
SCL-90: Symptom Checklist, 90-item
SD: Standard Deviation
SDQ: Strengths and Difficulties Questionnaire
SESBI: Sutter-Eyberg Student Behavior Inventory
SET-PC: Supportive Expressive Therapy-Parent Child
SGA: Second-generation Antipsychotics
SIP: Scientific Information Packets
SKAMP: Swanson Kotkin Atkins M-Flynn and Pelham Scale
SNAP-IV: Swanson Nolan and Pelham-IV
SNAP ORP: Stop Now and Plan Under 12 Outreach Project
SOE: Strength of Evidence
SRC: Scientific Resource Center
SRD: Self-report Delinquency Scale
SRDR: Systematic Review Data Repository
SSQ: School Situations Questionnaire
SSRI: Selective Serotonin Reuptake Inhibitors
SSS: Sensation Seeking Scale
SST: Social Skills Training
STAXI: State-Trait Anger and Expression of Anger Inventory
SUDD: Substance Use Disorder Diagnosis Schedule
TAU: Treatment As Usual
TCIT: Teacher-Child Interaction Training
T-MAY: Treatment of Maladaptive Aggression in Youth
TPA: Top Problems Assessment
TRAAY: Treatment Recommendations for the use of Antipsychotics for Aggressive Youth
TRF: Teacher Report Form
Triple P: Positive Parenting Program
VAQ: Vitiello Aggression Questionnaire
VAS-TO: Visual Analogue Scale of Target Outcome
VPA: Valproic Acid
WLC: Waitlist Control
YOT: Youth Offending Team
YSR: Youth Self Report
XR: Extended release